# REFERENCES

* Not cited in text

ACGIH. RDX. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH. American Conference of Governmental Industrial Hygienists. 2008:22.
Adinolfi M. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol. 1985;27(4):532-537. [pmid: 4029526].
Adlercreutz H. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl. 1995;103(7):103-112.
Agency for Toxic Substances and Disease Registry. Health assessment for Cornhusker Army Ammunition Plant Grand Island, Nebraska, Region 7. Atlanta, GA. Agency for Toxic Substances and Disease Registry. 1989a. PB90112202.
Agency for Toxic Substances and Disease Registry. Health assessment for Milan Army Ammunition Plant, Milan, Carrol and Gibson Counties, Tennessee, Region 4. Atlanta, GA. Agency for Toxic Substances and Disease Registry. 1989b. PB90142118.
Agency for Toxic Substances and Disease Registry. Health assesment for Savanna Army Depot, Savanna Carroll County, Illinois, Region 5. Atlanta, GA. Agency for Toxic Substances and Disease Registry. 1989c. PB90106014.
Agency for Toxic Substances and Disease Registry. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry, Division of Toxicology. Fed Regist. 1989d;54(174):37618-37634.
Agency for Toxic Substances and Disease Registry. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Subcommittee on Biomarkers of Organ Damage and Dysfunction. Atlanta, GA. Agency for Toxic Substances and Disease Registry. 1990.
AIHA. Emergency Response Planning Guidelines (ERPG). Fairfax, VA. American Industrial Hygiene Association. 2008. http://www.aiha.org/1documents/Committees/ERP-erpglevels.pdf. May 19, 2009.
Akhavan J. Explosives and propellants. Kirk-Othmer encyclopedia of chemical toxicology. John Wiley & Sons. 2004;Vol. 10:719-744. http://mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/expllind.a01/current/pdf. July 28, 2009.
Altman PL, Dittmer DS. Biological handbooks: Biology data book. 2nd ed. Bethesda, MD. Federation of American Societies for Experimental Biology. 1974;Vol. III:2041. 1987–2008.
Andersen ME, Krishnan K. Salem H, editor. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. Animal test alternatives: Refinement, reduction, replacement. New York, NY. Marcel Dekker, Inc. 1994:9-25.
Andersen ME, Clewell HJ, Gargas ML, et al. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol. 1987;87(2):185-205. [pmid: 3824380].
Arfsten DP, Davenport R, Schaeffer DJ. Reversion of bioluminescent bacteria (Mutatox) to their luminescent state upon exposure to organic compounds, munitions, and metal salts. Biomed Environ Sci. 1994;7:144-149. [pmid: 7946010].
Atkinson R. A structure-activity relationship for the estimation of rate constants for the gas-phase reactions of OH radicals with organic compounds. Int J Chem Kinet. 1987;19:799-828.
Balakrishnan VK, Halasz A, Hawari J. Alkaline hydrolysis of the cyclic nitramine explosives RDX, HMX and CL-20: New insights into degradation pathways obtained by the observation of novel intermediates. Environ Sci Technol. 2003;37:1838-1843. [pmid: 12775055].
Bannon DI, Dillman JF, Hable MA, et al. Global gene expression in rat brain and liver after oral exposure to the explosive hexahydro-1,3,5-trinitro-1,3,5-triazine (RDX). Chem Res Toxicol. 2009a;22(4):620-625. [pmid: 19239275].
Bannon DI, Johnson M, Williams L, et al. RDX and mIRNA expression in B6C3F1 mice. Environ Health Perspect. 2009b;117(3):A98-A99. [pmid: 19337499].
Barnes DG, Dourson M. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol. 1988;8(4):471-486. [pmid: 3222488].
*. Barsotti M, Crotti G. Epileptic attacks as manifestations of industrial intoxication caused by trimethylenetrinitroamine (T4). Med Lav. 1949;40:107-112.
Bart JC, Judd LL, Hoffman KE, et al. Application of a portable immunosensor to detect the explosives TNT and RDX in groundwater samples. Environ Sci Technol. 1997;31(5):1505-1511.
Bauer CF, Koza SM, Jenkins TF. Liquid chromatographic method for determination of explosive residues in soil: Collaborative study. J Assoc Off Anal Chem. 1990;73:541-552.
Belkin F, Bishop RW, Sheely MV. Analysis of explosives in water by capillary gas chromatography. J Chromatogr Sci. 1985;23:532-534.
Beller HR, Tiemeier K. Use of liquid chromatography/tandem mass spectrometry to detect distinctive indicators of in situ RDX transformation in contaminated groundwater. Environ Sci Technol. 2002;36:2060-2066. [pmid: 12026993].
Berberich DW, Yost RA, Fetterolf DD. Analysis of explosives by liquid chromatography/thermospray/mass spectrometry. J Forensic Sci. 1988;33:946-959.
Berger GS, editor. Epidemiology of endometriosis. Endometriosis: Advanced management and surgical techniques. New York, NY. Springer-Verlag. 1994:3-7.
Best EPH, Sprecher SL, Larson SL, et al. Environmental behavior of explosives in groundwater from the Milan Army Ammunition Plant in aquatic and wetland plant treatments. Removal, mass balances and fate in groundwater of TNT and RDX. Chemosphere. 1999;38(14):3383-3396. [pmid: 10390848].
Bhushan B, Trott S, Spain JC, et al. Biotransformation of hexahydro-1,3,5-trinitro-1,3,5-triazine (RDX) by a rabbit liver cytochrome P450: Insight into the mechanism of RDX biodegration by Rhodococcus sp strain DN22. Appl Environ Microbiol. 2003;69(3):1347-1351. [pmid: 12620815].
Bishop RW, Ayers TA, Rinehart DS. The use of a solid sorbent as a collection medium for TNT and RDX vapours. Am Ind Hyg Assoc J. 1981;42:586-589.
Bishop RW, Kennedy JL, Podolak GE, et al. A field evaluation of air sampling methods for TNT and RDX. Am Ind Hyg Assoc J. 1988;49:635-638. [pmid: 3213817].
Bohn MA, Schweppe R, Weisweiler W. Recovering of components from plastic bonded propellants. Waste Manag. 1997;17(2/3):175-185.
Boileau J, Fauquignon C, Hueber B, et al. Explosives. Ullman's encyclopedia of industrial chemistry. Weinheim. Wiley-VCH Verlag GmbH & Co. 2009. http://mrw.interscience.wiley.com/emrw/9783527306732/ueic/article/a10_143/current/pdf. July 27, 2009.
Bongiovanni R, Podolak GE, Clark LD, et al. Analysis of trace amounts of six selected poly-nitro compounds in soils. Am Ind Hyg Assoc J. 1984;45:222-226.
Bricka RM, Sharp W. Treatment of groundwater contaminated with low levels of military munitions. 47th Purdue Industrial Waster Conference Proceedings. Chelsea, MI. Lewis Publishers. 1992:199-204.
*. Brown RP, Delp MD, Lindstedt SL, et al. Physiological parameter values for physiologically based pharmacokinetic models. Toxicol Ind Health. 1997;13:407-484. [pmid: 9249929].
Budavari S, O'Neil MJ, editors. The Merck index. Rahway, NJ. Merck & Co. Inc. 1989:428.
Burdette LJ, Cook LL, Dyer RS. Convulsant properties of cyclotrimethylenetrinitramine (RDX): Spontaneous audiogenic, and amygdaloid kindled seizure activity. Toxicol Appl Pharmacol. 1988;92:436-444. [pmid: 3353989].
Burken JG, Schnoor JL. Predictive relationships for uptake of organic contaminants by hybrid poplar trees. Environ Sci Technol. 1998;32:3379-3385.
Burrows EP, Brueggemann EE. Reversed-phase gradient high-performance liquid chromatography of nitramine munitions and characterization of munitions process samples by gas chromatography-mass spectrometry. J Chromatogr. 1985;329:285-289.
Burrows WD, Chyrek RH, Noss CI, et al. LaGrega MD, Long DA, editors. Treatment for removal of munition chemicals from army industrial wastewaters. Toxic and hazardous wastes: Proceedings of the 16th Mid-Atlantic Industrial Waste Conference, Bucknell University, 1984. Lancaster, PA. Technomic Publishing Co., Inc. 1984:331-342.
Cataldo DA, Harvey SD, Fellows RJ. The environmental behavior and chemical fate of energetic compounds (TNT, RDX, tetryl) in soil and plant systems. 17th Annual Army Environmental R&D symposium and 3rd USACE innovative technology transfer workshop. Richland, WA. U.S. Department of Energy. 1993. DE93019614.
Clewell HJ, Andersen ME. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health. 1985;1(4):111-131. [pmid: 3843496].
CMR. Chemical profile: Hexamine. Chem Market Rep. 1980. July 28, 1980.
Crocker FH, Indest KJ, Fredrickson HL. Biodegradation of the cyclic nitramine explosives RDX, HMX, and CL-20. Appl Microbiol Biotechnol. 2006;73:274-290. [pmid: 17058075].
Crouse LC, Michie MW, Major MA, et al. Oral bioavailability of cyclotrimethylenetrinitramine (RDX) from contaminated site soils in rats. Int J Toxicol. 2008;27(4):317-322. [pmid: 18821395].
Crowson CA, Cullum HE, Hiley RW, et al. A survey of high explosives traces in public places. J Forensic Sci. 1996;41(6):980-989.
Cullum HE, McGavigan C, Uttley CZ, et al. A second survey of high explosives traces in public places. J Forensic Sci. 2004;49(4):684-690. [pmid: 15317181].
Dacre JC. Hazard evaluation of army compounds in the environment. Drug Metab Rev. 1994;26(4):649-662. [pmid: 7875059].
Davies JO, Roberts DM, Hittarage A, et al. Oral C-4 plastic explosives in humans-case series. Clin Toxicol. 2007;45:454-457.
DOD. DoD STTR program phase 1 selections for FY06. U.S. Department of Defense Resource Center. Small Business Innovation Research. 2009. http://dodsbir.net/selections/sttr1_06.htm. July 29, 2009.
Douglas TA, Walsh ME, McGrath CJ, et al. Investigating the fate of nitroaromatic (TNT) and nitramine (RDX and HMX) explosives in fractured and pristine soils. J Environ Qual. 2009;38:2285-2294. [pmid: 19875785].
Douse JMF. Trace analysis of explosives in hand-swab extracts using amberlite XAD-7, porous polymer beads, silica capillary-column gas chromatography with electron capture detection and thin-layer chromatography. J Chromatogr. 1982;234:415-425.
Ehrich M, Wu X, Werre SR, et al. Calcium signaling in neuronal cells exposed to the munitions compound cyclotrimethylenetrinitramine (RDX). Int J Toxicol. 2009;28:425-435. [pmid: 19652196].
Eisenreich SJ, Looney BB, Thornton JD. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol. 1981;15:30-38.
Eminger S, Vejrostova M. Photometric determination of microgram quantities of 1,3,5-trinitro-1,3,5-triazacyclohexane in air. Collect Czech Chem Commun. 1984;49:1464-1467.
Emmrich M, Kaiser M, Rueden H, et al. Determination of RDX, 2,4,6-trinitrotoluene and other nitroaromatic compounds by high-performance liquid chromatography with photoiodide-array detection. J Chromatogr. 1993;64(1):89-94.
EPA. Method 4051. Hexahydro-1,3,5-trinitro-1,3,5-triazine (rdx) in soil by immunoassay. Test methods for evaulating solid waste. SW-846. Washington, DC. U.S. Environmental Protection Agency. 1986. http://www.epa.gov/epawaste/hazard/testmethods/sw846/pdfs/4051.pdf. June 13, 2011.
EPA. Hazardous wastes from specific sources. U.S. Environmental Protection Agency. 1990a. Code of Federal Regulations. 40 CFR 261.32.
EPA. Interim methods for development of inhalation reference concentrations. Washington, DC. U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. 1990b. EPA600890066A.
EPA. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC. U.S. Environmental Protection Agency, Risk Assessment Forum. 1997. EPA630R96012.
EPA. National primary drinking water regulations. Washington, DC. Office of Ground Water and Drinking Water. U. S. Environmental Protection Agency. 2003. http://www.epa.gov/safewater/contaminants/index.html. May 19, 2009.
EPA. Drinking water standards and health advisories. Washington, DC. U.S. Environmental Protection Agency. 2006a. http://epa.gov/waterscience/criteria/drinking/. May 19, 2009.
EPA. National recommended water quality criteria. Washington, DC. Office of Water, Office of Science and Technology, U.S. Environmental Protection Agency. 2006b. http://www.epa.gov/waterscience/criteria/wqcriteria.html. May 11, 2009.
EPA. Letter from BAE Systems to the U.S. Environmental Protection Agency (USEPA) Office of Pollution Prevention and Toxics, TSCA--Submission of preliminary assessment information reporting for BAE Systems/Holston Army Ammunition Plant, Kingsport, Tennessee. 2006c. EPA Docket ID No. EPA-HQ-OPPT-2005-0014. November 9, 2006.
EPA. Method 8510. Colorimetric screening procedure for RDX and HMX in soil. Test methods for evaulating solid waste. SW-846. Washington, DC. U.S. Environmental Protection Agency. 2007. http://www.epa.gov/epawaste/hazard/testmethods/sw846/pdfs/8510.pdf. June 13, 2011.
*. EPA. Acute exposure guideline levels (AEGLs). Second AEGL chemical priority list. Washington, DC. Office of Pollution Prevention and Toxics, U.S. Environmental Protection Agency. 2008a. http://www.epa.gov/oppt/aegl/pubs/priority_2.htm. May 19, 2009.
EPA. Measurement and monitoring technologies for the 21st century [21m^2^]. 27th Quartely literature search. U.S. Environmental Protection Agency. 2008b. http://www.clu-in.org/programs/21m2/spotlight/. July 29, 2009.
EPA. Hazardous air pollutants. Clean Air Act. U.S. Environmental Protection Agency. 2009b. United States Code. 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. May 19, 2009.
EPA. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notifications. U.S. Environmental Protection Agency. 2009c. Code of Federal Regulations. 40 CFR 302.4. http://www.epa.gov/lawsregs/search/40cfr.html. May 20, 2009.
EPA. Superfund, emergency planning, and community right-to-know programs. toxic chemical release reporting. U.S. Environmental Protection Agency. 2009d. Code Of Federal Regulations 40 CFR 372.65. http://www.epa.gov/lawsregs/search/40cfr.html. May 11, 2009.
EPA. Toxic substances control act. Chemical lists and reporting periods. U.S. Environmental Protection Agency. 2009e. Code of Federal Regulations. 40 CFR 712.30.
EPA. Toxic substances control act. Health and safety data reporting. U.S. Environmental Protection Agency. 2009a. Code of Federal Regulations. 40 CFR 716.120.
EPA. List of lists. Consolidated list of chemicals subject to the Emergency Planning and Community Right-To-Know Act (EPCRA), Comprehensive Environmental Response, Compensation and Liability Act (CERCLA) and Section 112 ® of the Clean Air Act. Office of Solid Waste U.S. Environmental Protection Agency. 2010. EPA550B10001. http://www.epa.gov/osweroe1/docs/chem/list_of_lists_05_07_10.pdf. June 30, 2011.
FDA. Everything added to food in the United States (EAFUS). Washington, DC. U.S. Food and Drug Administration. 2008. http://vm.cfsan.fda.gov/~dms/eafus.html. May 19, 2009.
FEDRIP. RDX. Federal Research in Progress database. Springfield, VA. National Technical Information Service. 2009.
Fine DH, Yu WC, Goff EU, et al. Picogram analyses of explosive residues using the thermal energy analyzer (TEA). J Forensic Sci. 1984;29:732-746.
Fomon SJ. Falkner F, editor. Body composition of the infant: Part I: The male reference infant. Human development. Philadelphia, PA. WB Saunders. 1966:239-246.
Fomon SJ, Haschke F, Ziegler EE, et al. Body composition of reference children from birth to age 10 years. Am J Clin Nutr. Suppl 5. 1982;35:1169-1175. [pmid: 7081099].
Ford-Green J, Isayev O, Gorb L, et al. Evalaution of natural and nitramine binding energies to 3-D models of the S1S2 domains in the N-methyl-D-aspartate receptor. J Mol Model. 2011. [Epub ahead of Print].
Funk SB, Roberts DJ, Crawford DL, et al. Initial-phase optimization for bioremediation of munition compound-contaminated soils. Appl Environ Microbiol. 1993;59:2171-2177. [pmid: 8357251].
George SE, Huggins-Clark G, Brooks LR. Use of a Salmonella microsuspension bioassay to detect the mutagenicity of munitions compounds at low concentrations. Mutat Res. 2001;490:45-56. [pmid: 11152971].
Gibbs TR, Popolato A, editors. LASL explosive property data. Berkeley, CA. University of California Press. 1980:141-143.
Giwercman A, Carlsen E, Keiding N, et al. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl. 1993;101(2):65-71.
Godejohann M, Preiss A, Levsen K, et al. Determination of polar organic pollutants in aqueous samples of former ammunition sites in Lower Saxony by means of HPLC/photodiode array detection (HPLC/PDA) and proton nuclear magnetic resonance spectroscopy (^1^H-NMR). Acta Hydrochim Hydrobiol. 1998;26(6):330-337.
Goldberg DJ, Green ST, Nathwani D, et al. RDX intoxication causing seizures and a widespread petechial rash mimicking meningococcaemia. J R Soc Med. 1992;85:181. [pmid: 1556729].
Grant CL, Jenkins TF, Myers KF, et al. Holding-time estimates for soils containing explosives residues: Comparison of fortification vs. field-contamination. Environ Toxicol Chem. 1995;14(11):1865-1874.
Griest WH, Guzman C, Dekker M. Packed-column supercritical fluid chromatographic separation of highly explosive compounds. J Chromatogr. 1989;467:423-429.
Griest WH, Stewart AJ, Tyndall, et al. Chemical and toxicological testing of composted explosives-contaminated soil. Environ Toxicol Chem. 1993;12:1105-1116.
Griest WH, Tyndall RL, Stewart AJ, et al. Chemical characterization and toxicological testing of windrow compost from explosives-contaminated sediments. Environ Toxicol Chem. 1995;14(1):51-59.
Gunderson CA, Kostuk JM, Gibbs MH, et al. Multispecies toxicity assessment of compost produced in bioremediation of an explosives-contaminated sediment. Environ Toxicol Chem. 1997;16(12):2529-2537.
Guo L, Xu H, Chen Y, et al. Distribution and metabolism of 3H-RDX in mice. Zhonghua Lao Dong Wei Sheng Zhi Ye Bing Za Zhi. 1985;3(6):335-339.
Gust KA, Pirooznia M, Quinn MJ, et al. Neurotoxicogenomic investigations to assess mechanisms of action of the munitions constituents RDX and 2,6-DNT in Northern bobwhite (Colinus virginianus). Toxicol Sci. 2009;110(1):168-180. [pmid: 19417177].
Guzelian PS, Henry CJ, Olin SS, editors. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC. International Life Sciences Institute Press. 1992.
Haas R, Schreiber I, Von Loew E, et al. Conception for the investigation of contaminated munition plants: 2. Investigation of former RDX-plants and filling stations. Fresenius J Anal Chem. 1990;338:41-45.
Hable M, Stern C, Asowata C, et al. The determination of nitroaromatics and nitramines in ground and drinking water by wide-bore capillary gas chromatography. J Chromatogr Sci. 1991;29:131-135. [pmid: 1874908].
Harrell-Bruder B, Hutchins KL. Seizures caused by ingestion of composition C-4. Ann Emerg Med. 1995;26:746-748. [pmid: 7492047].
Harvey SD, Fellows RJ, Cataldo DA, et al. Environmental chemistry: Fate of the explosive hexahydro-1,3,5-triazine (RDX) in soil and bioaccumulation in bush bean hydroponic plants. Environ Toxicol Chem. 1991;10:845-855.
Harvey SD, Galloway H, Krupsha A. Trace analysis of military high explosives (2,4,6-trinitrotoluene and hexahydro-1,3,5-trinitro-1,3,5-triazine) in agricultural crops. J Chromatogr A. 1997;775(1–2):117-124.
Hathaway JA, Buck CR. Absence of health hazards associated with RDX manufacture and use. J Occup Med. 1977;19:269-272. [pmid: 323432].
Hawari J, Halasz A, Sheremata T, et al. Characterization of metabolires during biodegradation of hexahydro-1,3,5-trinitro-1,3,5-triazine (RDX) with municipal anaerobic sludge. Appl Environ Microbiol. 2000;66:2652-2657. [pmid: 10831452].
HazDat. RDX. Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA. Agency for Toxic Substances and Disease Registry. 2007.
Heilmann HM, Wiesmann U, Stenstrom MK. Kinetics of the alkaline hydrolysis of high explosives RDX and HMX in aqueous solution and adsorbed to activated carbon. Environ Sci Technol. 1996;30:1485-1492.
Hoel DG, Davis DL, Miller AB, et al. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst. 1992;84(5):313-320. [pmid: 1738181].
Hoffsommer JC, Rosen JM. Analysis of explosives in sea water. Bull Env Contam Toxicol. 1972;7:177-181.
Hoffsommer JC, Rosen JM. Hydrolysis of explosives in sea water. Bull Env Contam Toxicol. 1973;10:78-79. [pmid: 4749300].
Hollander AI, Colbach EM. Composition C-4 induced seizures: A report of five cases. Milit Med. 1969;134:1529-1530.
HSDB. Cyclonite. Hazardous Substances Data Bank. National Library of Medicine. 2009. http://toxnet.nlm.nih.gov. July 29, 2009.
Hundal LS, Singh J, Bier EL, et al. Removal of TNT and RDX from water and soil using iron metal. Environ Pollut. 1997;97(1–2):55-64. [pmid: 15093378].
IARC. Agents Reviewed by the IARC Monographs. Lyon, France. International Agency for Research on Cancer. 2009;Volumes 1–99. http://monographs.iarc.fr/ENG/Classification/index.php. May 19, 2009.
IRIS. RDX. Integrated Risk Information System. Washington, DC. U.S. Environmental Protection Agency. 2009. http://www.epa.gov/ncea/iris/subst/0313.htm. July 13, 2009.
Jenkins TF, Grant CL. Comparison of extraction techniques for munitions residues in soil. Anal Chem. 1987;59:1326-1331.
Jenkins TF, Leggett DC, Grant CL, et al. Reversed-phase high-performance liquid chromatographic determination of nitroorganics in munitions wastewater. Anal Chem. 1986;58:170-175.
Jenkins TF, Walsh ME, Schumacher PW, et al. Liquid chromatographic method for determination of extractable nitroaromatic and nitramine residues in soil. J Assoc Off Anal Chem. 1989;72:890-899.
JHC/U.S. Army. Toxicology study No. 87-XE-059F-06. Biomarkers of RDX exposure in breath of swine. Laurel, MD. John Hopkins University Applied Physics Laboratory. U.S. Army Center for Health Promotion and Preventive Medicine. 2006.
Jian C, Seitz WR. Membrane for in situ optical detection of organic nitro compounds based on fluorescence quenching. Anal Chim Acta. 1990;237:265-271.
Johanson CE. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res. 1980;190(1):3-16. [pmid: 6769537].
Kaplan AS, Berghout CF, Peczenik A. Human intoxication from RDX. Arch Environ Health. 1965;10:877-883. [pmid: 14313521].
Kasuske L, Schofer JM, Hasegawa K. Two marines with generalized seizure activity. J Emerg Nurs. 2009;35(6):542-543. [pmid: 19914481].
Ketel WB, Hughes JR. Toxic encephalopathy with seizures secondary to ingestion of an explosive material composition C-4: A clinical and electroencephalographic study. Neurology. 1972;22:871-876. [pmid: 4673417].
Komori M, Nishio K, Kitada M, et al. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry. 1990;29(18):4430-4433. [pmid: 2350547].
Krishnan K, Andersen ME. Hayes AW, editor. Physiologically based pharmacokinetic modeling in toxicology. Principles and methods of toxicology. 3rd ed. New York, NY. Raven Press, Ltd. 1994:149-188.
Krishnan K, Andersen ME, Clewell HJ, et al. Yang RSH, editor. Physiologically based pharmacokinetic modeling of chemical mixtures. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA. Academic Press. 1994:399-437.
Krishnan K, Crouse LCB, Bazar MA, et al. Physiologically based pharmacokinetic modeling of cyclotrimethylenetrinitramine in male rats. J Appl Toxicol. 2009;29(7):629-637. [pmid: 19629953].
Krull IS, Ding XD, Selavka C, et al. Explosives and other nitro compounds determined by liquid chromatography with photolysis-electrochemical detection. Methodological surveys in biochemistry and analysis. 1984:365-366.
Küçükardalǐ Y, Acar HV, Ozkan S, et al. Accidental oral poisoning caused by RDX (cyclonite):A report of 5 cases. J Intensive Care Med. 2003;18(1):42-46. [pmid: 15189666].
Lachance B, Robicoux PY, Hawari J, et al. Cytotoxic and genotoxic effects of energetic compounds on bacterial and mammalian cells in vitro. Mutat Res. 1999;444:25-39. [pmid: 10477337].
Lafleur AL, Morriseau BD. Identification of explosives at trace levels by high-performance liquid chromatography with a nitrosyl-specific detector. Anal Chem. 1980;52:1313-1318.
Larson SL, Weiss CA, Escalon BL, et al. Increased extraction efficiency of acetonitrile/water mixtures for explosives determination in plant tissues. Chemosphere. 1999b;38(9):2153-2162.
Leeder JS, Kearns GL. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am. 1997;44(1):55-77. [pmid: 9057784].
Leung HW. Ballentyne B, Marrs T, Turner P, editors. Physiologically-based pharmacokinetic modelling. General and applied toxicology. New York, NY. Stockton Press. 1993;Vol. 1:153-164.
Levine BS, Furedi EM, Gordon DE, et al. Thirteen-week toxicity study of hexahydro-1,3,5-trinitro-1,3,5-triazine (RDX) in Fischer 344 rats. Toxicol Lett. 1981;8:241-245. [pmid: 7196606].
Levine BS, Furedi EM, Gordon DE, et al. Toxic interactions of the munitions compounds TNT and RDX in F344 rats. Fundam Appl Toxicol. 1990;15:373-380. [pmid: 2227162].
Levsen K, MuBmann P, Berger-PreiB E, et al. Analysis of nitroaromatics and nitramines in ammunition waste water and in aqueous samples from former ammunition plants and other military sites. Acta Hydrochim Hydrobiol. 1993;21:153-166.
Lewis RJ. Sax's dangerous properties of industrial materials. 10 ed. New York, NY. John Wiley & Sons, Inc. 2000:1050-1051.
Lewis RJ, editor. Hawley's condensed chemical dictionary. 15th ed. New York, NY. John Wiley & Sons, Inc. 2007:361.
*. Lipscomb JC, Poet TS. In vitro measurements of metabolism for application in pharmacokinetic modeling. Pharmacol Ther. 2008;118:82-103. [pmid: 18374419].
Livingston AL. Forage plant estrogens. J Toxicol Environ Health. 1978;4(2–3):301-324. [pmid: 351201].
Lloyd JBF. High-performance liquid chromatography of organic explosives components with electrochemical detection at a pendent-mercury-drop electrode. J Chromatogr. 1983;257:227-236.
Lyman WJ, Reehl WF, Rosenblatt DH. Handbook of chemical property estimation methods: Environmental behavior of organic compounds. New York, NY. McGraw-Hill Book Company. 1982.
Lyter AH. A high performance liquid chromatographic (HPLC) study of seven common explosive materials. J Forensic Sci. 1983;28:446-450.
Ma B, Li H. Neurobehavioral effects of hexogen. Gongye Weisheng Yu Zhiyebing. 1993;19(1):20-23. (Chinese).
Major MA, Reddy G. Metabolite profiling of [14C]hexahydro-1,3,5-trinitro-1,3,5-triazine (RDX) in Yucatan miniature pigs. J Toxicol Environ Health A. 2007;70:1191-1202. [pmid: 17573633].
Maryland University. The acute and chronic biochemical and behavioral effects of cyclotrimethylenetriamine. Baltimore, MD. Maryland University Baltimore School of Pharmacy. 1975. ADA024415.
Maskarinec MP, Manning DL, Harvey RW. Determination of munitions components in water by resin adsorption and high-performance liquid chromatography-electrochemical detection. J Chromatogr. 1984;302:51-63.
Mayr U, Butsch A, Schneider S. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology. 1992;74(2–3):135-149. [pmid: 1387742].
McCormick NG, Cornell JH, Kaplan AM. Biodegradation of hexahydro-1,3,5-trinitro-1,3,5triazine. Appl Environ Microbiol. 1981;42:817-823. [pmid: 16345884].
McDonough JH, Shih T. Neuropharmacological mechanisms of nerve agent-induced seizure and neuropathology. Neurosci Biobehav Rev. 1997;21(5):559-579. [pmid: 9353792].
McKone TE, Layton DW. Screening the potential risks of toxic substances using a multimedia compartment model: Estimation of human exposure. Regul Toxicol Pharmacol. 1986;6:359-380. [pmid: 3809615].
McLuckey SA, Glish GL, Carter JA. The analysis of explosives by tandem mass spectrometry. J Forensic Sci. 1985;30:773-788.
Merrill SL. Ingestion of an explosive material, composition C-4: A report of two cases. U.S. ARV Med Bull. 1968;3:5-11.
Meyer SA, Marchand AJ, Hight JL, et al. Up-and-down procedure (UDP) determinations of acute oral toxicity of nitroso degradation products of hyxahydro-1,3,5-trinitro-1,3,5-triazine (RDX). J Appl Toxicol. 2005;25(5):427-434. [pmid: 16092083].
Morselli PL, Franco-Morselli R, Bossi L. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin. 1980;5(6):485-527.
NAS/NRC. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC. National Academy of Sciences, National Research Council, National Academy Press. 1989:15-35.
NIOSH. RDX. CAS 121-82-4. Estimated numbers of employees potentially exposed to specific agents by 2-digit Standard Industrial Classification (SIC). National Occupational Exposure Survey conducted from 1981–1983. Centers for Disease Control. National Institute for Occupational Safety and Health. 1990. http://www.cdc.gov/noes/. January 30, 2010.
NIOSH. Recommendations for occupational safety and health. Compendium of policy documents and statements. Cincinnati, OH. U.S. Department of Health and Human Services, National Institute of Occupational Safety and Health. 1992.
NIOSH. RDX. NIOSH pocket guide to chemical hazards. Atlanta, GA. National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. 2005. http://www.cdc.gov/niosh/npg/npgd0169.html. July 13, 2009.
NRC. National Research Council. Pesticides in the diets of infants and children. Washington, DC. National Academy Press. 1993.
NREPC. New or modified sources emitting toxic air pollutants. Proposed regulations. Frankfort, KY. Department for Environmental Protection, Natural Resources and Environmental Protection Cabinet. 1986. 401 KAR 63:022.
NTP. Report on carcinogens. 11th edition. Research Triangle Park, NC. U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. 2005. server.niehs.nih.gov/ntp/roc/toc11.html. May 11, 2009.
O'Neil MJ, Heckelman PE, Koch CB, et al., editors. Merck index. 14th ed. Whitehouse Station, NJ. Merck Research Laboratories. 2006:458-459.
OSHA. Air contaminants - 58:35338-35351. Occupational Safety and Health Administration. 1993. Code of Federal Regulations. 29 CFR 1910.1000, Final Rule. http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=federal_register&p_id=13306. July 13, 2009.
OSHA. Sampling and analytical methods: Cyclonite (RDX), PV2135. Occupational Safety and Health Administration. 2008. http://www.osha.go/dts/sltc/methods/partial/pv2135/pv2135.html. July 13, 2009.
Osmon JL, Klausmeier RE. The microbial degradation of explosives. Dev Ind Microbiol. 1973;14:247-252.
Owen GM, Brozek J. Falkner F, editor. Influence of age, sex and nutrition on body composition during childhood and adolescence. Human development. Philadelphia, PA. WB Saunders. 1966:222-238.
Özhan G, Topuz S, Alpertunga B. Determination of cyclonite (RDX) in human plasma by high performance liquid chromatagraphy. Farmaco. 2003;58:445-448. [pmid: 12767384].
Pan X, San Francisco MJ, Lee C, et al. Examination of the mutagenicity of RDX and its N-nitroso metabolites using the Salmonella reverse mutation assay. Mutat Res. 2007;629:64-69. [pmid: 17360228].
Parker GA, Reddy G, Major MA. Reevaluation of a twenty-four-month chronic toxicity/carcinogenicity study of hexahydro-1,3,5-trinitro-1,3,5-triazine (RDX) in the B6C3F1 hybrid mouse. Int J Toxicol. 2006;25(5):373-378. [pmid: 16940009].
Pennington JC, Brannon JM. Environmental fate of explosives. Thermochim Acta. 2002;384:163-172.
PHYSPROP. 1,3,5,- Trinitrohexahydro-1,3,5-triazine. Physical Properties Database. SRC, Inc. 2009. http://www.syrres.com/what-we-do/product.aspx?id=133. July 30, 2009.
Reddy G, Allen NA, Major MM. Absorption of ^14^C-cyclotrimethylenetrinitramine (RDX) from soils through excised human skin. Toxicol Mech Methods. 2008;18:575-579. [pmid: 20020856].
Reddy G, Eisenhut K, Morrison SA, et al. Toxicokinetics of 14C RDX (cyclotrimethylene-trinitramine) in rats after intratracheal administration [Abstract]. Toxicologist. 1989;9:83.
Reddy G, Erexson GL, Cifone MA, et al. Genotoxicity assessment of hexahydro-1,3,5-trinitro-1,3,5-triazine (RDX). Int J Toxicol. 2005a;24:427-434. [pmid: 16393935].
Reifenrath WG, Kammen HO, Palmer WG, et al. Percutaneous absorption of explosives and related compounds: An empirical model of bioavailability of organic nitro compounds from soil. Toxicol Appl Pharmacol. 2002;182:160-168. [pmid: 12140179].
Richard JJ, Junk GA. Determination of munitions in water using macroreticular resins. Anal Chem. 1986;58:723-725.
Rockwood GA, Armstrong KR, Baskin SI. Species comparison of methemoglobin reductase. Exp Biol Med (Maywood). 2003;228(1):79-83. [pmid: 12524477].
Roth M, Murphy JM Jr. Correlation of oxygen demand and total organic carbon tests on wastewaters from ammunition plants. Proceedings of the 32nd Industrial Waste Conference. Ann Arbor, MI. Ann Arbor Science. 1978:674-688.
RTECS. RDX. Registry of Toxic Effects on Chemical Substances. National Institute of Occupational Safety and Health. MDL Information Systems, Inc. 2009. July 30, 2009.
Sax NI, Lewis RJ. Dangerous properties of industrial materials. 7th ed. New York, NY. Van Nostrand Reinhold. 1989. 3391.
Schneider NR, Bradley SL, Anderson ME. Toxicology of cyclotrimethylenetrinitramine: Distribution and metabolism in the rat and the miniature swine. Toxicol Appl Pharmacol. 1977;39:531-541. [pmid: 854927].
Schneider NR, Bradley SL, Anderson ME. The distribution and metabolism of cyclotrimethylenetrinitramine (RDX) in the rat after subchronic administration. Toxicol Appl Pharmacol. 1978;46:163-171. [pmid: 725941].
Selim HM, Xue SK, Iskandar IK. Transport of 2,4,6-trinitrotoluene and hexahydro-1,3,5-trinitro-1,3,5-triazine in soils. Soil Sci. 1995;160(5):328-339.
Setchell BP, Waites GMH. Creep RO, Astwood EB, Geiger SR, editors. The blood-testis barrier. Handbook of physiology: Endocrinology V. Washington, DC. American Physiological Society. 1975:143-172.
Simini M, Checkai RT. Uptake of RDX and TNT in crop plants irrigated with contaminated water [Abstract]. Phytopathology. Suppl 11. 1996;85:S86.
Simini M, Wentsel RS, Checkai RT, et al. Evaluation of soil toxicity at Joliet Army Ammunition Plant. Environ Toxicol Chem. 1995;14(4):623-630.
Smith JE, Beutler E. Methemoglobin formation and reduction in man and various animal species. 1966;210(2):347-350.
Smith JN, Liu J, Espino MA, et al. Age dependent acute oral toxicity of hexahydro-1,3,5-trinitro-1,3,5-triazine (RDX) and two anaerobic N-nitroso metabolites in deer mice (Peromyscus maniculatus). Chemosphere. 2007;67:2267-2273. [pmid: 17275885].
Spalding RF, Fulton JW. Groundwater munition residues and nitrate near Grand Island, Nebraska, USA. J Contam Hydrol. 1988;2:139-153.
SRI. 2009 Directory of chemical producers. Menlo Park, CA. Access Intelligence, LLC. 2009. SRI Consulting, 511.
Steuckart C, Berger-Preiss E, Levsen K. Determination of explosives and their biodegradation products in contaminated soil and water from former ammunition plants by automated multiple development high-performance thin-layer chromatography. Anal Chem. 1994;66(15):2570-2577.
St. John GA, McReynolds JH, Blucher WG, et al. Determination of the concentration of explosives in air by isotope dilution analysis. Forensic Sci. 1975;6:53-66. [pmid: 814074].
Stokinger HE. Clayton GD, Clayton FE, editors. Aliphatic nitro compounds, nitrates, nitrites. Patty's industrial hygiene and toxicology. 3rd revised ed. New York, NY. John Wiley & Sons. 4196. 1982;Vol. 2C:4141-4197.
Stone WJ, Paletta TL, Heiman EM, et al. Toxic effects following ingestion of C-4 plastic explosive. Arch Intern Med. 1969;124:726-730. [pmid: 5353482].
Strobel RA, Tontarski RE. Organic solvent extracts of explosive debris: Clean-up procedures using bonded phase sorbents. Proceedings of the International Symposium on the Analysis and Detection of Explosives, FBI Academy, Quantico, VA, March 29 –31, 1983. Washington, DC. U.S. Department of Justice, Federal Bureau of Investigation. 1983:67-70.
Sunahara GI, Dodard S, Sarrazin M, et al. Ecotoxicological characterization of energetic substances using a soil extraction procedure. Ecotoxicol Environ Saf. 1999;43(2):138-148. [pmid: 10375416].
Sunderman FW. Hazards to the health of individuals working with RDX(B). OSRD Report No. 4147. National Defense Research Committee of the Office of Scientific Research and Development. 1944.
Swann RL, Laskowski DA, McCall PJ. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Res Rev. 1983;85:17-28.
Sweeney LM, Gut CP, Okolica MR, et al. Assessing the non-cancer risk for RDX (hexahydro-1,3,5-trinitro-1,3,5-triazine) using physiologically-based pharmacokinetic (PBPK) modeling. Reg Toxicol Pharmacol. 2012;62:107-114.
Tanner SD, Davidson WR, Fulford JE. The instantaneous detection of explosives by tandem mass spectrometry. Proceedings of the International Symposium on the Analysis and Detection of Explosives, FBI Academy, Quantico, VA, March 29–31, 1983. Washington, DC. U.S. Department of Justice, Federal Bureau of Investigation. 1983:409-417.
Testud F, Glanclaude JM, Descotes J. Acute hexogen poisoning after occupational exposure. J Toxicol Clin Toxicol. 1996a;34(1):109-111. [pmid: 8632501].
Testud F, Glanclaude JM, Imperatori J, et al. Acute hexogen poisoning after occupational exposure: Report of two cases. Arch Mal Prof Med Trav Secur Soc. 1996b;57(5):342-346.
Thomas K, Colborn T. Colborn T, Clement C, editors. Organochlorine endocrine disruptors in human tissue. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ. Princeton Scientific Publishing. 1992:365-394.
Timchalk C, Nolan RJ, Mendrala AL, et al. A physiologically based pharmacokinetic and pharmacodynamic (PBPK/PD) model for the organophosphate insecticide chlorpyrifos in rats and humans. Toxicol Sci. 2002;66:34-53. [pmid: 11861971].
Turley CP, Brewster MA. Liquid-chromatographic analysis of cyclotrimethylenetrinitramine in biological fluids using solid-phase extraction. J Chromatogr Biomed Appl. 1987;421:430-433.
Twibell JD, Turner SL, Smalldon KW, et al. The persistence of military explosives on hands. J Forensic Sci. 1984;29:284-290.
U.S. Army. The toxicology of cyclotrimethylenetrinitramine (RDX) and cyclotetramethylene-tetranitramine (HMX) solutions in dimethylsulfoxide (DMSO), cyclohexanone, and acetone. Edgewood Arsenal technical report EB-TR-73040. Aberdeen Proving Ground, MD. U.S. Army. 1974. AD788010. (author: McNamara BP et al.).
U.S. Army. Development of industrial hygiene sampling and analytical methodology for evaluation of exposures to TNT and associated explosives. Washington, DC. U.S. Army Medical Research and Developmental Command. 1975. ADA008399. (author: Saltzman BE et al.).
*. U.S. Army. Adverse health effects of selected explosives (TNT, RDX). Report no. USAEHH32-049-75/76. Aberdeen Proving Ground, MD. U.S. Army Environmental Hygiene Agency. 1976. ADB010943. (author: Buck CR and Wilson SE).
*. U.S. Army. Laboratory evaluation of the toxicity of cyclotrimethylene trinitramine (RDX) to aquatic organisms. Frederick, MD. U.S. Army Medical Research and Development Command, Fort Detrick. 1977a. ADA061730. (author: Bentley RZ et al.).
U.S. Army. Mutagenicity of some munition wastewater chemicals and chlorine test reagents. Frederick, MD. U.S. Army Medical Research and Development Command, Fort Detrick. 1977b. ADA057680. (author: Simmon VF et al.).
*. U.S. Army. The hazard ranking and allocation methodology: Evaluation of TNT wastewaters for continuing research efforts. Technical report 7808. Frederick, MD. U.S. Army Medical Research and Development Command, Fort Detrick. 1978a. ADA061770. (author: Small MJ).
U.S. Army. Mammalian toxicological evaluation of TNT wastewaters. Volume II: Acute and subacute mammalian toxicity of TNT and the LAP mixture. Frederick, MD. U.S. Army Medical Research and Development Command. 1978b. ADA080957. (author: Dilley JV et al.).
U.S. Army. Specific air pollutants from munitions processing and their atmospheric behavior. Volume 2: RDX/HMX production. Frederick, MD. U.S. Army Medical Research and Development Command, Fort Detrick. 1978c. ADA060122. (author: Carpenter BH et al.).
U.S. Army. Environmental fate of RDX and TNT. Frederick, MD. U.S. Army Medical Research and Development Command. 1980a. TR 81-538. (author: Sikka HC et al.).
U.S. Army. Environmental fate studies on certain munition wastewater constituents: Phase II–Laboratory studies. Frederick, MD. U.S. Army Medical Research and Development Command. 1980c. ADA099256. (author: Spanggord et al.).
U.S. Army. Mammalian toxicological evaluation of RDX. Frederick, MD. U.S. Army Medical Research and Development Command, Fort Detrick. 1980b. ADA092531. (author: Cholakis et al.).
U.S. Army. Identification or development of chemical analysis methods for plants and animal tissues. Aberdeen Proving Ground, MD. U.S. Army Toxic and Hazardous Materials Agency. 1981a. ADA107346. (author: Lakings and Gan).
*. U.S. Army. Preliminary pollutant limit values for Alabama Army Ammunition Plant. Technical report 8105. Frederick, MD. U.S. Army Medical Research and Development Command. 1981b. ADA104203. (author: Rosenblatt and Small).
U.S. Army. Determination of the chronic mammalian toxicological effects of RDX: Twenty-four month chronic toxicity/carcinogenicity study of hexahydro-1,3,5-trinitro-1,3,5-triazine (RDX) in the Fischer 344 rat: Phase V. Frederick, MD. U.S. Army Medical Research and Development Command. 1983a;Vol. 1. ADA160774. (author: Levine BS et al.).
U.S. Army. Environmental fate studies on certain munitions wastewater constituents: Phase IV—Lagoon model studies. Frederick, MD. U.S. Army Medical Research and Development Command. 1983b. ADA138550. (author: Spanggord RJ et al.).
U.S. Army. HPLC analysis of SEX, HMX, TAX, RDX, and TNT in wastewater. Frederick, MD. Army Medical Research and Development Command. 1983c. AD127348. (author: Brueggemann EE).
U.S. Army. Database assessment of the health and environmental effects of munition production waste products. Frederick, MD. U.S. Army Medical Research and Development Command, Fort Detrick. 1984a. ADA145417. (author: Ryon MG et al.).
U.S. Army. Determination of the chronic mammalian toxicological effects of RDX: Acute dermal toxicity test of hexahydro-1,3,5-trinitro-1,3,5-triazine (RDX) in rabbits. Frederick, MD. U.S. Army Medical Research and Development Command. 1984b. ADA174710. (author: Furedi-Machacek EM et al.).
U.S. Army. Determination of the chronic mammalian toxicological effects of RDX: Twenty-four month chronic toxicity/carcinogenicity study of hexahydro-1,3,5-trinitro-1,3,5-triazine (RDX) in the B6C3F1 hybrid mouse: Phase VI. Frederick, MD. U.S. Army Medical Research and Development Command. 1984c;Vol. 1. ADA181766. (author: Lish PM et al.).
*. U.S. Army. Development of novel decontamination techniques for explosive contaminated facilities. U.S. Army Toxic and Hazardous Material Agency. 1984d. ADP004880. (author: Benecke HP et al.).
*. U.S. Army. Reverse phase HPLC method for analysis of TNT, RDX, HMX, and 2,4-DNT in munitions wastewater. CRREL report 84-29. Aberdeen Proving Ground, MD. U.S. Army Toxic and Hazardous Materials Agency. 1984e. Report no. DRXTH-TE-TR-84301. (author: Jenkins TF et al.).
U.S. Army. The anaerobic biotransformation of RDX, HMX, and their acetylated derivatives. Technical report NATICK/TR-85/007. Aberdeen Proving Ground, MD. U.S. Army Toxic and Hazardous Materials Agency. 1984f. ADA149464. (author: McCormick NG et al.).
U.S. Army. Degradation of pink water compounds in soil - TNT, RDX, HMX. Technical report NATICK/TR-85/046. Aberdeen Proving Ground, MD. U.S. Army Toxic and Hazardous Materials Agency. 1985a. ADA157954. (author: Greene B et al.).
U.S. Army. Neurotoxicology of cyclotrimethylenetrinitramine (RDX). Frederick, MD. U.S. Army Medical Research and Development Command, Fort Detrick. 1985b. ADA168266. (author: MacPhail RC et al.).
U.S. Army. Suitability of polyvinyl chloride pipe for monitoring, TNT, RDX, HMX, and DNT in groundwater. Aberdeen Proving Ground, MD. U.S. Army Toxic and Hazardous Materials Agency. 1985c. ADA1607332. (author: Parker LV et al.).
U.S. Army. Database assessment of pollution control in the military explosives and propellants production industry. Frederick, MD. U.S. Army Medical Research and Development Command. 1986a. (author: Pal BC and Ryon MG).
U.S. Army. Composting explosives/organics contaminated soils. Aberdeen Proving Ground, MD. U.S. Army Toxic and Hazardous Materials Agency. 1986b. ADA169994. (author: Doyle RC et al.).
U.S. Army. Demilitarization of conventional ordnance: Priorities for data-base assessments of environmental contaminants. Frederick, MD. U.S. Army Medical and Development Command. 1986c. ADA182922. (author: Layton DW, et al.).
U.S. Army. Teratological assessment of trinitro - RDX in rats. Aberdeen Proving Ground, MD. Department of the Army, U.S. Army Environmental Hygiene Agency. 1986d. ADA166249. (author: Angerhofer et al.).
U.S. Army. Water quality criteria for hexahydro-1,3,5-trinitro-1,3,5-triazine (RDX). Frederick, MD. U.S. Army Medical Research and Development Command. 1986e. (author: Etnier EL).
U.S. Army. Conventional weapons demilitarization: A health and environmental effects data base assessment: Explosives and their co-contaminants. Frederick, MD. U.S. Army Medical Research and Development Command. 1987a. ADA220588. (author: Layton D et al.).
U.S. Army. Development of an analytical method for explosive residues in soil. Aberdeen Proving Ground, MD. U.S. Army Toxic and Hazardous Materials Agency. 1987b. ADA183738. (author: Jenkins TF and Walsh ME).
U.S. Army. Treatment alternatives for explosive-laden spent carbons. Aberdeen Proving Ground, MD. U.S. Army Toxice and Hazardous Materials Agency. 1987c. ADA199506. (author: Balasco AA et al.).
U.S. Army. Residual explosives criteria for treatment of area P soil, Louisiana Army Ammunition Plant. Frederick, MD. U.S. Army Medical Research and Development Command. 1988. ADA197799. (author: Small MJ).
U.S. Army. Evaluation of four well casing materials for monitoring selected trace level organics in ground water. Aberdeen Proving Ground, MD. U.S. Army Toxic and Hazardous Materials Agency. 1989a. Crrel Report 89-18. ADA2165025. (author: Parker et al.).
*. U.S. Army. Validation of a sorbent tube/high performance liquid chromatographic procedure for the determination of eight explosives in water. Aberdeen Proving Ground, MD. U.S. Army Toxic and Hazardous Materials Agency. 1989b. ADA210777. (author: Valis RJ et al.).
U.S. Army. An evaluation of the environmental fate and behavior of munitions material (TNT, RDX) in soil and plant systems: Environmental fate and behavior of RDX. Frederick, MD. U.S. Army Biomedical Research and Development Laboratory. 1990a. PNL-7529. (author: Cataldo et al.).
*. U.S. Army. Environmental transformation products of nitroaromatics and nitramines: Literature review and recommendations for analytical method development. Special report 90-2. Aberdeen Proving Ground, MD. U.S. Army Toxic and Hazardous Materials Agency. 1990b. (author: Walsh ME).
U.S. Army. Improved salting out extraction-preconcentration determination of nitroaromatics and nitramines in water. U.S. Army Corps of Engineers, Cold Regions Research and Engineering Lab. 1991. Special Report 91-18. ADA245491. (author: Miyares PH and Jenkins TF).
U.S. Army. Relationship between the leachability characteristics of unique energetic compounds and soil properties. Frederick, MD. U.S. Army Medical Research and Development Command. 1993a. ADA267580. (author: Ainsworth CC et al.).
*. U.S. Army. Toxicity of selected munitions and munition-contaminated soil on the earthworm (Eisenia foetida). Fort Detrick, MD. U.S. Army Biomedical Research and Development Laboratory. 1993b. ERDEC-TR-037. ADA264408. (author: Phillips CT et al.).
U.S. Army. Toxicological study No. 6955-31-97-05-02, 14-day feeding study of hexahydro1,3,5,trinitro-1,3,5-triazine (RDX) in the white-footed mouse, Peromyscus leucopus, 2 June-23 July 1997. Aberdeen Proving Ground, MD. U.S. Army Center for Health Promotion and Preventive Medicine. 1999. (author: Ferguson JW Mccain WC).
+. U.S. Army. Toxicology study no. 85-XC-5131-03. Subchronic oral toxicity of RDX in rats. Aberdeen Proving Ground, MD. U.S. Army Center for Health Promotion and Preventive Medicine. 2006. (author: Crouse LCB et al.).
U.S. Army. Physiologically-based pharmacokinetic (PBPK) modeling of RDX in rats, miniature swine and humans. Draft report. U.S. Army Center for Health Promotion and Preventive Medicine. 2007a.
U.S. Army. Toxicology study No. 85-XC-064Y-07. RDX pilot for developmental. Aberdeen Proving Ground, MD. U.S. Army Center for Health Promotion and Preventive Medicine. 2007b. (author: Hess-Ruth A et al.).
U.S. Army. Toxicology study no. 87-XE-0982-09. In vitro study of hexahydro-1,3,5-trinitro-1,3,5-triazine (RDX) metabolism in human liver. Aberdeen Proving Ground, MD. U.S. Army Center for Health Promotion and Preventive Medicine. 2008. (author: Cao CJ et al.).
U.S. Army. Evaluation of the cytotoxic potential of RDX in primary human cell cultures as integrated discrete multiple organ co-cultures (IdMOC) and as individual primary cultures. Aberdeen Proving Ground, MD. U.S. Army Center for Health Promotion and Preventive Medicine. 2010. (author: Li AP).
U.S. Army. Army Environmental Database Restoration Module. 2011. http://aec.army.mil/usaec/reporting/aedb-r00.html. May 11, 2011.
U.S. Navy. Analysis of explosives in sea water and in ocean floor sediment and fauna. Silver Springs, MD. Naval Ordinance Laboratory. 1972. AD757778. (author: Hoffsommer et al.).
U.S. Navy. Microbial degradation of cyclonite (RDX). China Lake, CA. Naval Weapons Center. 1973. AD762751. (author: Soli G).
U.S. Navy. Subacute toxicity of RDX and TNT in dogs. Arlington, VA. Office of Naval Research. 1974a. ADA035717. (author: Hart ER).
U.S. Navy. Subacute toxicity of RDX and TNT in monkeys. Arlington, VA. Office of Naval Research. 1974b. AD044650. (author: Martin and Hart).
U.S. Navy. Two-year feeding study in rats. Arlington, VA. Office of Naval Research. 1976. ADA040161. (author: Hart ER).
U.S. Navy. Second five-year review of record of decision. Poulsbo, WA. Department of the Navy. Naval Facilities Engineering Command Northwest. 2005.
Verweij A, De Bruyn P, Choufoer C, et al. Liquid chromatographic, thermospray/negative ion, tandem mass spectrometic analysis (LC/TSP/MS/MS) of some exposives. Forensic Sci Int. 1993;60:7-13.
Vieira I, Sonnier M, Cresteil T. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem. 1996;238(2):476-483. [pmid: 8681961].
von Oettingen WF, Donahue DD, Yagoda H, et al. Toxicity and potential dangers of cyclotrimethylenetrinitramine (RDX). J Ind Hygiene Toxicol. 1949;31:21-31.
Vouros P, Petersen BA, Colwell L, et al. Analysis of explosives by high performance liquid chromatography and chemical ionization mass spectrometry. Anal Chem. 1977;49:1039-1044.
Walker JE, Kaplan DL. Biological degradation of explosives and chemical agents. Biodegradation. 1992;3:369-385.
West JR, Smith HW, Chasis H. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr. 1948;32:10-18. [pmid: 18920567].
WHO. Air quality guidelines. 2nd edition. Geneva, Switzerland. World Health Organization. 2000. http://www.euro.who.int/air/activities/20050223_4. May 11, 2009.
WHO. Guidelines for drinking-water quality. 3rd edition. Geneva, Switzerland. World Health Organization. 2006. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. May 11, 2009.
Whong WZ, Speciner ND, Edwards GS. Mutagenic activity of tetryl, a nitroaromatic explosive, in three microbial test systems. Toxicol Lett. 1980;5:11-17. [pmid: 6445609].
Widdowson EM, Dickerson JWT. Comar CL, Bronner F, editors. Chemical composition of the body. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York, NY. Academic Press. 1964:1-247.
Williams LR, Aroniadou-Anderjaska V, Qashu F, et al. RDX binds to the GABAA receptorconvulsant site and blocks GABAA receptor-mediated currents in the amygdale: A mechanisms ofr RDX-induced seizures. Environ Health Perspect. 2011;119:357-363. [pmid: 21362589].
Williams RT, Ziegenfuss PS, Sisk WE. Composting of explosives and propellent contaminated soils under thermophilic and mesophilic conditions. J Ind Microbiol. 1992;9:137-144.
Woody RC, Kearns GL, Brewster MA, et al. The neurotoxicity of cyclotrimethylenetrinitramine (RDX) in a child: A clinical and pharmacokinetic evaluation. Clin Toxicol. 1986;24:305-319.
Wujcik WJ, Lowe WL, Marks PJ, et al. Granular activated carbon pilot treatment studies for explosives removal from contaminated groundwater. Environ Prog. 1992;11:178-189.
Yalkowsky SH, He Y. Cyclonite. Handbook of aqueous solubility data. Boca Raton FL. CRC Press. 2003:63.
Yinon J, Laschever M. Direct-injection chemical ionization mass spectrometry of explosives in water. Eur J Mass Spectrom Biochem Med Environ Res. 1982;2:101-104.
Zhang B, Pan X. RDX induces aberrant expression of microRNAs in mouse brain and liver. Environ Health Perspect. 2009;117(2):231-240. [pmid: 19270793].
Ziegler EE, Edwards BB, Jensen RL, et al. Absorption and retention of lead by infants. Pediatr Res. 1978;12(1):29-34. [pmid: 643372].