# REGULATIONS, ADVISORIES, AND GUIDELINES

MRLs are substance specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

The international and national regulations, advisories, and guidelines regarding RDX in air, water, and other media are summarized in Table 8-1.

ATSDR has derived an acute-duration oral MRL of 0.2 mg/kg/day based on a NOAEL of 8.5 mg/kg/day for neurotoxicity in rats administered RDX via gavage 7 days/week for 14 days (U.S. Army 2006b). Using a PBPK model, an internal dose metric (peak brain concentration) was simulated and a HED of 6.4547 mg/kg/day was estimated. An uncertainty factor of 30 (3 for animal to human extrapolation with dosimetric adjustment and 10 for human variability) was applied to the NOAEL_HED_.

ATSDR has derived an intermediate-duration oral MRL of 0.1 mg/kg/day based on a BMDL_10_ for neurological effects in rats administered RDX via gavage 7 days/week for 90 days (U.S. Army 2006b). The BMDL_10_ was estimated using an internal dose metric to simulate peak brain concentration; a HED of the BMDL_10_ was estimated using a PBPK model. The BMDL_HED_ of 4.1308 mg/kg/day was divided by an uncertainty factor of 30 (3 for animal to human extrapolation with dosimetric adjustments and 10 for human variability).

ATSDR has derived a chronic-duration oral MRL of 0.1 mg/kg/day based on a NOAEL of 8 mg/kg/day for neurotoxicity in rats exposed to dietary RDX for 2 years (U.S. Army 1983a). Using a PBPK model, an internal dose metric (peak brain concentration) was simulated and a HED of 4.223 mg/kg/day was estimated. An uncertainty factor of 30 (3 for animal to human extrapolation with dosimetric adjustment and 10 for human variability) was applied to the NOAEL_HED_.

EPA (IRIS 2009) has derived an oral reference dose (RfD) of 0.003 mg/kg/day based on a NOAEL 0.3 mg/kg/day and LOAEL of 1.5 mg/kg/day for inflammation of the prostate in rats exposed to RDX in the diet for 2 years (U.S. Army 1983a). An uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 to protect against unusually susceptible individuals) was applied to the NOAEL.

Table 8-1

Regulations and Guidelines Applicable to RDX

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | No | IARC 2009
WHO | Air quality guidelines | No | WHO 2000
| Drinking water quality guidelines | No | WHO 2006
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA)^a^ | 0.5 mg/m^3^ | ACGIH 2008
| STEL (15-minute TWA) | No
| TLV-basis (critical effect) | Liver damage
AIHA | ERPG values | No | AIHA 2008
EPA | AEGL values | No | EPA 2008a
| Hazardous air pollutant | No | EPA 2009b 42 USC 7412
NIOSH | REL (10-hour TWA) | 1.5 mg/m^3^ | NIOSH 2005
| STEL (15-minute) | 3.0 mg/m^3^
| IDLH | Not determined
| Target organs | Eyes, skin, and central nervous system
OSHA | PEL (8-hour TWA) for general industry | Vacated^b^ | OSHA 1993 29 CFR 1910.1000, Final Rule
b. Water
EPA | Drinking water standards and health advisories | | EPA 2006a
| 1-day health advisory for a 10-kg child | 0.1 mg/L
| 10-day health advisory for a 10-kg child | 0.1 mg/L
| DWEL | 0.1 mg/L
| Lifetime | 0.03 mg/L
| 10^−4^ Cancer risk | 0.03 mg/L
| National primary drinking water standards | No | EPA 2003
| National recommended water quality criteria | No | EPA 2006b
c. Food
FDA | EAFUS | No^c^ | FDA 2008
d. Other
ACGIH | Carcinogenicity classification | A4^d^ | ACGIH 2008
EPA | Carcinogenicity classification | Group C^e^ | IRIS 2009
| RfC | No
| RfD | 3.0×10^−3^ mg/kg/day
| Oral slope factor | 1.1 mg/kg/day^−1^
| Superfund, emergency planning, and community right-to-know
| Designated CERCLA hazardous substance | No | EPA 2009c 40 CFR 302.4
| Effective date of toxic chemical release reporting | No | EPA 2009d 40 CFR 372.65
| TSCA chemical lists and reporting periods | | EPA 2009e 40 CFR 712.30
| Effective date | 09/29/2006
| Reporting date | 11/28/2006
| TSCA health and safety data reporting | | EPA 2009a
| Effective date | 09/29/2006 | 40 CFR 716.120
| Sunset date | 11/28/2006
NTP | Carcinogenicity classification | No | NTP 2005

a Skin: refers to the potential significant contribution to the overall exposure by the cutaneous route.

b On January 19, 1989, OSHA published its final rule on Air Contaminants, which amended 29 CFR 1910.1000 by lowering 212 of OSHA’s existing PELs for toxic substances and setting PELs for 164 toxic substances that had been previously unregulated. A PEL value of 1.5 mg/m^3^ was adopted for RDX in March 1989. However, on July 7, 1992, the Eleventh Circuit Court of Appeals issued a decision in AFL-CIO vs. OSHA that vacated these revised standards.

c The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

d A4: not classifiable as a human carcinogen.

e Group C: possible human carcinogen, based on hepatocellular adenomas and carcinomas in female B6C3F1 mice.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; GRAS = Generally Recognized As Safe; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; STEL = short-term expsoure limit; TLV = threshold limit values; TSCA = Toxic Substances Control Act; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization