# CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

RDX is a nitramine produced mainly for use in explosives (HSDB 2009). Information regarding the chemical identity of RDX is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

RDX is a white crystalline solid. Information regarding the physical and chemical properties of RDX is located in Table 4-2. Pure RDX is a highly explosive compound that can be initiated by impact, temperature, and friction (Akhavan 2004; Boileau et al. 2009; HSDB 2009). RDX is toxic by inhalation and dermal routes (Lewis 2007). Acrid fumes of nitrogen oxides may be released when heated to decomposition (HSDB 2009; Lewis 2000).

Table 4-1 Chemical Identity of RDX

Characteristic | Information | Reference
Chemical name | RDX | HSDB 2009
Synonym(s) | Cyclonite; hexogen; cyclotrimethylenetrinitramine; hexogen 5W;T4; hexahydro-1,3,5-trinitro-1,3,5-triazine; 1,3,5-triaza-1,3,5,-trinitrocyclohexane; 1,3,5-trinitrohexahydro-1,3,5-triazine; cyclotrimethylenenitramine; hexolite; S-triazine, hexahydro-1,3,5-trinitro-; 1,3,5-triazine, hexahydro-1,3,5-trinitro-; 1,3,5-triazine, perhydro, 1,3,5-trinitro-; trimethylenetrinitramine; sym-trimethylene trinitramine; 1,3,5-trinitrohexahydro-S-triazine; 1,3,5-trinitroperhydro-1,3,5-triazine; 1,3,5-trinitro-1,3,5-triazacyclohexane; trinitrotrimethylenetriamine | HSDB 2009
Registered trade name(s) | No data
Chemical formula | C_3_H_6_N_6_O_6_ | HSDB 2009
Chemical structure | | O’Neil et al. 2006
Identification numbers:
CAS registry | 121-82-4 | HSDB 2009
RTECS | XY9450000 | RTECS 2009
EPA hazardous waste | No data
OHM/TADS | No data
DOT/UN/NA/IMDG shipping | UN0072; UN0391; UN0483; IMO1.1; DOT Explosive 1.1D | HSDB 2009; Lewis 2000
HSDB | 2079 | HSDB 2009
NCI | No data

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of RDX

Property | Information | Reference
Molecular weight | 222.26 | Merck 1989
Color | White | Akhavan 2004
Physical state | Crystalline solid | Akhavan 2004
Melting point | 204–206 °C | Boileau et al. 2009; Merck 1989
Boiling point | Decomposes | U.S. Army 1991
| Decomposition temperature: 213 °C | Akhavan 2004
Density at 20 °C | 1.82 g/mL | Merck 1989
Odor | No data
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 20 °C | 38.4–38.9 mg/L; 60 mg/L | U.S. Army 1983b, 1991
Organic solvents | Slightly soluble in methanol, ether, ethyl acetate, glacial acetic acid | Merck 1989
Partition coefficients:
Log K_ow_ | 0.87 | HSDB 2009; PHYSPROP 2009
Log K_oc_ | 1.80^a^ | U.S. Army 1987a
Vapor pressure
At 20 °C | 1×10^−9^ mm Hg (Torr) | U.S. Army 1987a
At unidentified temperature | 0.05 Pa (3.8×10^−4^ mm Hg) | Boileau et al. 2009
Henry's law constant at 25 °C | 2.0×10^−11^ atm-m^3^/mol^b^ | PHYSPROP 2009
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | No data
Explosive limits | Explosion may be prompted by sudden shock, high temperature, or combination of both | HSDB 2009

a Calculated value

b Estimated value