# REFERENCES

* Not cited in text

Aaseth J, Alexander J, Norseth T. Uptake of ^51^Cr-chromate by human erythrocytes -A role of glutathione. Acta Pharmacol Toxicol. 1982;50:310-315.
Abranko L, Yang L, Sturgeon RE, et al. Solid phase microextraction for the determination of chromium in sea-water. J Anal At Spectrom. 2004;19(9):1098-1103.
Abu-Saba K, Flegal AR. Temporally variable freshwater sources of dissolved chromium to the San Francisco Bay estuary. Environ Sci Technol. 1997;31:3455-3460.
ACGIH. Chromium. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH. American Conference of Governmental Industrial Hygienists. 2007:20.
Acharya S, Mehta K, Krishnan S, et al. A subtoxic interactive toxicity study of ethanol and chromium in male Wistar rats. Alcohol. 2001;23(2):99-108. [pmid: 11331107].
Adachi S. Effect of chromium compounds on the respiratory system: Part 5. Long term inhalation of chromic acid mist in electroplating by C57BL female mice and recapitulation on our experimental studies. Jpn J Ind Health. 1987;29:17-33.
Adachi S, Yoshimura H, Katayama H, et al. Effects of chromium compounds on the respiratory system: Part 4. Long term inhalation of chromic acid mist in electroplating to ICR female mice. Jpn J Ind Health. 1986;28:283-287.
Adachi S, Yoshimura H, Miyayama R, et al. Effects of chromium compounds on the respiratory system: Part 1. An experimental study of inhalation of chromic acid mist in electroplating. Jpn J Ind Health. 1981;23:294-299.
Adekola FA, Eletta OAA. A study of heavy metal pollution of Asa River, Ilorin. Nigeria; trace metal modeling and geochemistry. Environ Monit Assess. 2007;125:157-163. [pmid: 17058013].
Adinolfi M. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol. 1985;27:532-537. [pmid: 4029526].
Adlercreutz H. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl. 1995;103(7):103-112.
Agency for Toxic Substances and Disease Registry. Decision guide for identifying substance-specific data needs related to toxicological profiles. Atlanta, GA. Agency for Toxic Substances and Disease Registry, Division of Toxicology. 1989.
Agency for Toxic Substances and Disease Registry. Health assessment for Cherokee County-Galena subsite National Priorities List (NPL) site, Galena, Cherokee County, Kansas, Region 7. Atlanta, GA. Agency for Toxic Substances and Disease Registry. 1990a. CERCLIS No. KSD980741862. PB90112053.
Agency for Toxic Substances and Disease Registry. Health assessment for Butterworth Landfill, Kent County, Michigan, Region 5. Atlanta, GA. Agency for Toxic Substances and Disease Registry. 1990b. CERCLIS No. MIDO62222997. PB90106899.
Agency for Toxic Substances and Disease Registry. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Subcommittee on Biomarkers of Organ Damage and Dysfunction. Atlanta, GA. Agency for Toxic Substances and Disease Registry. 1990.
Aguilar MV, Martinez-Para C, Gonzalez J. Effects of arsenic(V)-chromium(III) interaction on plasma glucose and cholesterol levels in growing rats. Ann Nutr Metab. 1997;41:189-195. [pmid: 9286469].
Aitio A, Jarvisalo J, Kiilunen M, et al. Urinary excretion of chromium as an indicator of exposure to trivalent chromium sulphate in leather tanning. Int Arch Occup Environ Health. 1984;54:241-249. [pmid: 6490183].
Aiyar J, Berkovits HJ, Floyd RA, et al. Reaction of chromium(VI) with glutathione or with hydrogen peroxide: Identification of reactive intermediates and their role in chromium(VI)-induced DNA damage. Environ Health Perspect. 1991;92:53-62. [pmid: 1657590].
Aiyar J, Borges K, Floyd RA, et al. Role of chromium(V), glutathione thiyl radical and hydroxyl radical intermediates in chromium(VI)-induced DNA damage. Toxicol Environ Chem. 1989;22:135-148.
*. Akatsuka K, Fairhall LT. The toxicology of chromium. J Ind Hyg. 1934;16:1-24.
Albert RE. Issues in the risk assessment of chromium. Environ Health Perspect. 1991;92:91-92. [pmid: 1935856].
Alderson M, Rattan N, Bidstrup L. Health of workmen in the chromate-producing industry in Britain. Br J Ind Med. 1981;38:117-124. [pmid: 7236535].
Al-Hamood MH, Elbetieha A, Bataineh H. Sexual maturation and fertility of male and female mice exposed prenatally and postnatally to trivalent and hexavalent chromium compounds. Reprod Fertil Dev. 1998;10:179-183. [pmid: 9801270].
Alimonti A, Petrucci F, Krachler M, et al. Reference values for chromium, nickel and vanadium in urine of youngsters from the urban area of Rome. J Environ Monit. 2000;2(4):351-354. [pmid: 11249791].
Al-Saleh I, Al-Doush I. Survey of trace elements in household and bottled drinking water samples collected in Riyadh, Saudi Arabia. Sci Total Environ. 1998;216:181-192. [pmid: 9646527].
Althuis MD, Jordan NE, Ludington EA, et al. Glucose and insulin responses to dietary chromium supplements: A meta-analysis. Am J Clin Nutr. 2002;76:148-155. [pmid: 12081828].
Altman PK, Dittmer DS. Biological handbooks: Biology data book. 2nd ed. Bethesda, MD. Federation of American Societies for Experimental Biology, 1987–2008. 1974;Vol. III:2041.
American Chrome and Chemicals. Chromic acid. Material safety data sheets. Corpus Christi, TX. American Chrome and Chemicals, Inc. 1989.
Amrani S, Rizki M, Creus A, et al. Genotoxic activity of different chromium compounds in larval cells of Drosphila melanogaster, as measured in the wing spot test. Environ Mol Mutagen. 1999;34:47-51. [pmid: 10462723].
Anand SS. Protective effects of vitamin B6 in chromium-induced oxidative stress in liver. J Appl Toxicol. 2005;25:440-443. [pmid: 15986493].
Andersen ME, Krishnan K. Salem H, editor. Relating in vitro to in vivo exposures with physiologically-based tissue dosimetry and tissue response models. Animal test alternatives. Aberdeen Proving Ground, MD. U.S. Army Chemical Research Development and Engineering Center. 1994.
Andersen ME, Clewell HJ, Gargas ML, et al. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol. 1987;87:185-205. [pmid: 3824380].
Anderson RA. Nutritional role of chromium. Sci Total Environ. 1981;17:13-29. [pmid: 7010598].
Anderson RA. Chromium metabolism and its role in disease processes in man. Clin Physiol Biochem. 1986;4:31-41. [pmid: 3514054].
Anderson RA. Mertz W, editor. Chromium. Trace elements in human and animal nutrition. 5th ed. San Diego, CA. Academic Press, Inc. 1987;Vol. 1:225-244.
Anderson RA. Chromium, glucose intolerance and diabetes. J Am Coll Nutr. 1998a;17(6):548-555. [pmid: 9853533].
Anderson RA. Effects of chromium on body composition and weight loss. Nutr Rev. 1998b;56(9):266-270. [pmid: 9763876].
Anderson RA. Chromium and insulin resistance. Nutr Res Rev. 2003;16(2):267-275. [pmid: 19087394].
Anderson RA, Bryden NA, Polansky MM. Lack of toxicity of chromium chloride and chromium picolinate in rats. J Am Coll Nutr. 1997b;16(3):273-279. [pmid: 9176835].
Anderson RA, Bryden NA, Patterson KY, et al. Breast milk chromium and its association with chromium intake, chromium excretion, and serum chromium. Clin Nutr. 1993;57:519-523.
Anderson RA, Bryden NA, Polansky MM, et al. Dietary chromium effects on tissue chromium concentrations and chromium absorption in rats. J Trace Elem Exp Med. 1996;9:11-25.
Anderson RA, Cheng N, Bryden NA, et al. Elevated intakes of supplemental chromium improve glucose and insulin variables in individuals with type 2 diabetes. Diabetes. 1997c;46:1786-1791. [pmid: 9356027].
Anderson RA, Polansky MM, Bryden NA, et al. Effects of chromium supplementation on urinary Cr excretion of human subjects and correlation of Cr excretion with selected clinical parameters. J Nutr. 1983;113:276-281. [pmid: 6822901].
*. Anwar RA, Langham RF, Hoppert CA, et al. Chronic toxicity studies: III. Chronic toxicity of cadmium and chromium in dogs. Arch Environ Health. 1961;3:456-460. [pmid: 13861841].
*. Appenroth D, Braunlich H. Age dependent differences in sodium dichromate nephrotoxicity in rats. Exp Pathol. 1988;33:179-185. [pmid: 3224679].
Appenroth D, Karge E, Kiessling G, et al. LLU-α, an endogenous metabolite of gamma-tocopherol, is more effective against metal nephrotoxicity in rats than γ-tocopherol. Toxicol Lett. 2001;122:255-265. [pmid: 11489360].
Arreola-Mendoza L, Reyes JL, Melendez E, et al. Apha-tocopherol protects against the renal damage caused by potassium dichromate. Toxicology. 2006;218:237-246. [pmid: 16343725].
Aruldhas MM, Subramanian S, Sekhar P, et al. Microcanalization in the epididymis to overcome ductal obstruction caused by chronic exposure to chromium -- a study in the mature bonnet monkey (Macaca radiata Geoffroy). Reproduction. 2004;128:127-137. [pmid: 15232070].
Aruldhas MM, Subramanian S, Sekhar P, et al. Chronic chromium exposure-induced changes in testicular histoarchitecture are associated with oxidative stress: Study in a non-human primate (Macaca radiata Geoffroy). Hum Reprod. 2005;20(10):2801-2813. [pmid: 15980013].
Aruldhas MM, Subramanian S, Sekhar P, et al. In vivo spermatotoxic effect of chromium as reflected in the epididymal epithelial principal cells, basal cells, and intraepithelial macrophages of a nonhuman primate (Macaca radiata Geoffroy). Fertil Steril. Suppl 3. 2006;86:1097-1105. [pmid: 16949592].
Asatiani N, Sapojnikova N, Abuladze M, et al. Effects of Cr(VI) long-term and low-dose action on mammalian antioxidant enzymes (an in vitro study). J Inorg Biochem. 2004;98:490-496. [pmid: 14987850].
Ashley K, Applegate GT, Marcy AD, et al. Evaluation of sequential extraction procedures for soluble and insoluble hexavalent chromium compounds in workplace air samples. J Environ Monit. 2009;11(2):318-325. [pmid: 19212588].
Ashley K, Howe AM, Demange M, et al. Sampling and analysis considerations for the determination of hexavalent chromium in workplace air. J Environ Monit. 2003;5(5):707-716. [pmid: 14587839].
ASTM. Designation: D6832-08. Standard test method for the determination of hexavalent chromium in workplace air by ion chromatography and spectrophotometric measurement using 1,5-diphenylcarbazide1. ASTM International. 2008. http://www.astm.org/Standards/D6832.htm. February 8, 2012.
Athavale P, Shum KW, Chen Y, et al. Occupational dermatitis related to chromium and cobalt: Experience of dermatologists (EPIDERM) and occupational physicians (OPRA) in the U.K. over an 11-year period (1993–2004). Br J Dermatol. 2007;157(3):518-522. [pmid: 17596174].
Avudainayagam S, Megharaj M, Owens G, et al. Chemistry of chromium in soils with emphasis on tannery waste sites. Rev Environ Contam Toxicol. 2003;178:53-91. [pmid: 12868781].
Axelsson G, Rylander R. Environmental chromium dust and lung cancer mortality. Environ Res. 1980;23:469-476. [pmid: 7202385].
Axelsson G, Rylander R, Schmidt A. Mortality and incidence of tumours among ferrochromium workers. Br J Ind Med. 1980;37:121-127. [pmid: 7426462].
Ayyamperumal T, Jonathan MP, Srinivasalu S, et al. Assessment of acid leachable trace metals in sediment cores from River Uppanar, Cuddalor, southeast coast of India. Environ Pollut. 2006;143:34-45. [pmid: 16412538].
Baetjer AM. Pulmonary carcinoma in chromate workers: II. Incidence and basis of hospital records. Int Arch Ind Hyg Occup Med. 1950b;2(5):505-516.
Baetjer AM, Damron C, Budacz V. The distribution and retention of chromium in men and animals. Arch Ind Health. 1959a;20:136-150.
Baetjer AM, Lowney JF, Steffee H, et al. Effect of chromium on incidence of lung tumors in mice and rats. Arch Ind Health. 1959b;20:124-135.
Bagchi D, Bagchi M, Stohs SJ. Chromium (VI)-induced oxidative stress, apoptotic cell death and modulation of p53 tumor suppressor gene. Mol Cell Biochem. 2001;222:149-158. [pmid: 11678597].
Bagchi D, Balmoori J, Bagchi M, et al. Comparative effect of TCDD, endrin, naphthalene and chromium (VI) on oxidative stress and tissue damage in the liver and brain tissues of mice. Toxicology. 2002a;175:73-82. [pmid: 12049837].
Baggett JM. Serrone D, editor. Chromium and the potentiative interaction with some other nephrotoxins. Proceedings of chromium symposium 1986: An update. Pittsburgh, PA. Industrial Health Foundation. 1986:59-78.
Bailey MM, Boohaker JG, Jernigan PL, et al. Effects of pre- and postnatal exposure to chromium picolinate or picolinic acid on neurological development in CD-1 mice. Biol Trace Elem Res. 2008b;124(1):70-82. [pmid: 18408898].
Bailey MM, Sturdivant J, Jernigan PL, et al. Comparison of the potential for developmental toxicity of prenatal exposure to two dietary chromium supplements, chromium picolinate and [Cr3O(O2CCH2CH3)(6(H2O)3]+, in mice. Birth Defects Res B Dev Reprod Toxicol. 2008a;83(1):27-31. [pmid: 18076115].
*. Baines AD. Cell renewal following dichromate induced renal tubular necrosis. Am J Pathol. 1965;47:851-876. [pmid: 4284755].
Balachandar V, Arun M, Mohana Devi S, et al. Evaluation of the genetic alterations in direct and indirect exposures of hexavalent chromium [Cr(VI)] in leather tanning industry workers North Arcot District, South India. Int Arch Occup Environ Health. 2010;83(7):791-801. [pmid: 20617332].
Balasoiu CF, Zagury GJ, Deschenes L. Partitioning and speciation of chromium, copper, and arsenic in CCA-contaminated soils: Influence of soil composition. Sci Total Environ. 2001;280(1–3):239-255. [pmid: 11763270].
Balato A, Balato N, Di Costanzo L, et al. Contact sensitization of older patients in an academic department in Naples, Italy. Dermatitis. 2008;19(4):209-212. [pmid: 18674456].
Banner W, Koch M, Capin M, et al. Experimental chelation therapy in chromium, lead, and boron intoxication with N-acetylcysteine and other compounds. Toxicol Appl Pharmacol. 1986;83:142-147. [pmid: 3952743].
Banu SK, Samuel JB, Arosh JA, et al. Lactational exposure to hexavalent chromium delays puberty by impairing ovarian development, steroidogenesis and pituitary hormone synthesis in developing Wistar rats. Toxicol Appl Pharmacol. 2008;232(2):180-189. [pmid: 18602937].
Baranowski J, Norska-Borowka I, Baranowska I. Determination of heavy metals in the bones and livers of deceased neonatal humans. Bull Environ Contam Toxicol. 2002;69:1-7. [pmid: 12053249].
Baranowska-Dutkiewicz B. Absorption of hexavalent chromium by skin in man. Arch Toxicol. 1981;47:47-50. [pmid: 7283739].
Barceloux DG. Chromium. Clin Toxicol. 1999;37(2):173-194.
Barešić M, Gornik I, Radonic R, et al. Survival after severe acute chromic acid poisoning complicated with renal and liver failure. Intern Med. 2009;48(9):711-715. [pmid: 19420819].
Barnes DG, Dourson M. Reference dose (RfD): Description and use in health risk assessment. Regul Toxicol Pharmacol. 1988;8:471-486. [pmid: 3222488].
Barnhart J. Chromium chemistry and implications for environmental fate and toxicity. J Soil Contam. 1997;6(6):561-568.
Barrie LA, Hoff RM. Five years of air chemistry observations in the Canadian Arctic. Atmos Environ. 1985;19(12):1995-2010.
Barrie LA, Lindberg SE, Chan WH, et al. On the concentration of trace metals in precipitation. Atmos Environ. 1987;21:1133-1135.
Bartlett R. Chromium cycling in soils and water: Links, gaps, and methods. Environ Health Perspect. 1991;92:17-24. [pmid: 1935847].
Bartlett RJ, Kimble JM. Behavior of chromium in soils: Trivalent forms. J Environ Qual. 1976;5:379-386.
Basketter D, Horev L, Slodovnik D, et al. Investigation of the threshold for allergic reactivity to chromium. Contact Dermatitis. 2001;44:70-74. [pmid: 11205406].
Bataineh H, Al-Hamood MH, Elbetieha A, et al. Effect of long-term ingestion of chromium compounds on aggression, sex behavior and fertility in adult male rat. Drug Chem Toxicol. 1997;20(3):133-149. [pmid: 9292274].
Bataineh H, Bataineh Z, Daradka H. Short-term exposure of female rats to industrial metal salts: Effect on implantation and pregnancy. Reprod Med Biol. 2007;6(3):179-183.
Beaumont JJ, Sedman RM, Reynolds SD, et al. Cancer mortality in a Chinese population exposed to hexavalent chromium in drinking water. Epidemiology. 2008;19(1):12-23. (Comment in: Epidemiology 19(1):1-2, Epidemiology 19(1):24-26). [pmid: 18091413].
Becker N. Cancer mortality among arc welders exposed to fumes containing chromium and nickel: Results of a third follow-up: 1989–1995. J Occup Environ Med. 1999;41(4):294-303. [pmid: 10224596].
Becker N, Claude J, Frentzel-Beyme R. Cancer risk of arc welders exposed to fumes containing chromium and nickel. Scand J Work Environ Health. 1985;11:75-82. [pmid: 4001902].
Bednar CM, Kies C. Inorganic contaminants in drinking water correlated with disease occurrence in Nebraska. Water Resour Bull. 1991;27(4):631-635.
*. Behari J, Chandra SV, Tandon SK. Comparative toxicity of trivalent and hexavalent chromium to rabbits: III. Biochemical and histological changes in testicular tissue. Acta Biol Med Ger. 1978;37:463-468. [pmid: 153692].
Behari JR, Tandon SK. Chelation in metal intoxication: VIII. Removal of chromium from organs of potassium chromate administered rats. Clin Toxicol. 1980;16(1):33-40. [pmid: 6771085].
Bell RW, Hipfner JC. Airborne hexavalent chromium in Southwestern Ontario. J Air Waste Manage Assoc. 1997;47:905-910.
Bennett BG. Exposure assessment for metals involved in carcinogenesis. IARC Sci Publ. 1986;71:115-128. [pmid: 3770849].
Bennicelli C, Camoirano A, Petruzzelli S, et al. High sensitivity of Salmonella TA102 in detecting hexavalent chromium mutagenicity and its reversal by liver and lung preparations. Mutat Res. 1983;122:1-5. [pmid: 6353220].
Benova D, Hadjidekova V, Hristova R, et al. Cytogenetic effects of hexavalent chromium in Bulgarian chromium platers. Mutat Res. 2002;514:29-38. [pmid: 11815242].
Bentley SA. Red cell survival studies reinterpreted. Clin Haematol. 1977;6(3):601-623. [pmid: 334424].
*. Berg NO, Berlin M, Bohgard M, et al. Bronchocarcinogenic properties of welding and thermal spraying fumes containing chromium in the rat. Am J Ind Med. 1987;11:39-54. [pmid: 3812497].
Berger GS. Berger GS, editor. Epidemiology of endometriosis. Endometriosis: Advanced management and surgical techniques. New York, NY. Springer-Verlag. 1994:3-7.
*. Berry JP, Hourdry J, Galle P, et al. Chromium concentration by proximal renal tubule cells: An ultrastructural microanalytical and cytochemical study. J Histochem Cytochem. 1978;26:651-657. [pmid: 690404].
Beveridge R, Pintos J, Parent ME, et al. Lung cancer risk associated with occupational exposure to nickel, chromium VI, cadmium in two population-based case-control studies in Montreal. Am J Ind Med. 2010;53(5):476-485. [pmid: 20187007].
Beyer WN, Cromartie EJ. A survey of Pb, Cu, Zn, Cd, Cr, As and Se in earthworms and soil from diverse sites. Environ Monit Assess. 1987;8:27-36.
Beyersmann D, Koster A. On the role of trivalent chromium in chromium genotoxicity. Toxicol Environ Chem. 1987;14:11-22.
*. Bick RL, Girardi TV, Lack WJ, et al. Hodgkin's disease in association with hexavalent chromium exposure. Int J Hematol. 1996;64(3–4):257-262. [pmid: 8923788].
Bidstrup P. Carcinoma of the lung in chromate workers. Br J Ind Med. 1951;8:302-305. [pmid: 14878968].
Bidstrup P, Case R. Carcinoma of the lung in workmen in the bichromates-producing industry in Great Britain. Br J Ind Med. 1956;13:260-264. [pmid: 13364155].
Blade LM, Yencken MS, Wallace ME, et al. Hexavalent chromium exposures and exposure-control technologies in American enterprise: Results of NIOSH field research study. J Occup Environ Hyg. 2007;4(8):596-618. [pmid: 17577750].
*. Blair J. Chrome ulcers. Report on twelve cases. J Am Med Assoc. 1928;90:1927-1928.
Blankenship LJ, Carlisle DL, Wise JP, et al. Induction of apoptotic cell death by particulate lead chromate: Differential effects of vitamins C and E on genotoxicity and survival. Toxicol Appl Pharmacol. 1997;146:270-280. [pmid: 9344895].
Blasiak J, Kowalik J. A comparison of the vitro genotoxicity of tri- and hexavalent chromium. Mutat Res. 2000;469(1):135-145. [pmid: 10946250].
Bock M, Schmidt A, Bruckner T, et al. Contact dermatitis and allergy: Occupational skin disease in the construction industry. Br J Dermatol. 2003;149(6):1165-1171. [pmid: 14674893].
Bonatti S, Meini M, Abbondandolo A. Genetic effects of potassium dichromate in Schizosaccharomyces pombe. Mutat Res. 1976;38:147-150. [pmid: 1272272].
Bonde JPE, Olsen JH, Hansen KS. Adverse pregnancy outcome and childhood malignancy with reference to paternal welding exposure. Scand J Work Environ Health. 1992;18:169-177. [pmid: 1615291].
Bonnefoy C, Menudier A, Moesch C, et al. Determination of chromium in whole blood by DRC-ICP-MS: Spectral and non-spectral interferences. Anal Bioanal Chem. 2005;383(2):167-173. [pmid: 16132130].
Borg H. Trace metals and water chemistry of forest lakes in northern Sweden. 198. Water Res. 1987;21(1):65-72.
Borneff I, Engelhardt K, Griem W, et al. Carcinogenic substances in water and soil. XXII. Mouse drinking study with 3,4-benzopyrene and potassium chromate. Arch Hyg. 1968;152:45-53.
Boscolo P, Di Gioacchino M, Bavazzano P, et al. Effects of chromium on lymphocyte subsets and immunoglobulins from normal population and exposed workers. Life Sci. 1997;60(16):1319-1325. [pmid: 9096252].
Bovet P, Lob M, Grandjean M. Spirometric alterations in workers in the chromium electroplating industry. Int Arch Occup Environ Health. 1977;40:25-32. [pmid: 914372].
Bragt PC, van Dura EA. Toxicokinetics of hexavalent chromium in the rat after intratracheal administration of chromates of different solubilities. Ann Occup Hyg. 1983;27(3):315-322. [pmid: 6638765].
Braver ER, Infante P, Chu K. An analysis of lung cancer risk from exposure to hexavalent chromium. Teratog Carcinog Mutagen. 1985;5:365-378. [pmid: 2867619].
Bridgewater LC, Manning FCR, Patierno SR. Base-specific arrest of in vitro DNA replication by carcinogenic chromium: Relationship to DNA interstrand crosslinking. Carcinogenesis. 1994a;15(11):2421-2427. [pmid: 7955085].
Bridgewater LC, Manning FCR, Patierno SR. Arrest of replication by mammalian DNA polymerase α and β caused by chromium-DNA lesions. Mol Carcinogen. 1998;23:201-206.
Bridgewater LC, Manning FCR, Woo ES, et al. DNA polymerase arrest by adducted trivalent chromium. Mol Carcinogen. 1994b;9:122-133.
Brieger H. The symptoms of acute chromate poisoning. Z Exper Path Therap. 1920;21:393-408. (German).
Briggs JA, Briggs RC. Characterization of chromium effects on a rat liver epithelial cell line and their relevance to in vitro transformation. Cancer Res. 1988;48:6484-6490. [pmid: 3180065].
Broadhurst CL, Schmidt WF, Reeves JB, et al. Characterization and structure by NMR and FTIR spectroscopy, and molecular modeling of chromium(III) picolinate and nicotinate complexes utilized for nutritional supplementation. J Inorg Biochem. 1997;66:119-130.
Bronzetti GL, Galli A. Influence of NTA on the chromium genotoxicity. Toxicol Environ Chem. 1989;23:101-104.
Bronzetti G, Galli A, Boccardo P, et al. Genotoxicity of chromium in vitro on yeast: Interaction with DNA. Toxicol Environ Chem. 1986;13:103-111.
Brune D, Nordberg G, Wester PO. Distribution of 23 elements in the kidney, liver, and lungs of workers from a smeltery and refinery in north Sweden exposed to a number of elements and of a control group. Sci Total Environ. 1980;16:13-35. [pmid: 7433969].
Bryant HE, Ying S, Helleday T. Homologous recombination is involved in repair of chromium-induced DNA damage in mammalian cells. Mutat Res. 2006;599:116-123. [pmid: 16564059].
Bryson WG, Goodall CM. Differential toxicity and clearance kinetics of chromium(III) or (VI) in mice. Carcinogenesis. 1983;4(12):1535-1539. [pmid: 6652867].
Buckell M, Harvey DG. An environmental study of the chromate industry. Br J Ind Med. 1951;8:298-301. [pmid: 14878967].
Bukowski JA, Goldstein MD, Korn LR, et al. Biological markers in chromium exposure assessment: Confounding variables. Arch Environ Health. 1991;46(4):230-236. [pmid: 2069432].
Bunker VW, Lawson MS, Delves HT, et al. The uptake and excretion of chromium by the elderly. Am J Clin Nutr. 1984;39:797-802. [pmid: 6711482].
Burrows D, editor. Adverse chromate reactions on the skin. Chromium: Metabolism and toxicity. Boca Raton, FL. CRC Press, Inc. 1983:137-163. In: Burrows D, ed.
Byrne CJ, DeLeon IR. Trace metal residues in biota and sediments from Lake Pontchartrain, Louisiana. Bull Environ Contam Toxicol. 1986;37:151-158. [pmid: 3719140].
Caglieri A, Goldoni M, Acampa O, et al. The effect of inhaled chromium on different exhaled breath condensate biomarkers among chrome-plating workers. Environ Health Perspect. 2006;114(4):542-546. [pmid: 16581543].
Calder LM. Chromium contamination of groundwater. Adv Env Sci Technol. 1988;20:215-229.
Campbell WW, Joseph LJ, Davey SL, et al. Effects of resistance training and chromium picolinate on body composition and skeletal muscle in older men. J Appl Physiol. 1999;86(1):29-39. [pmid: 9887110].
Camyre E, Wise SS, Milligan P, et al. Ku80 deficiency does not affect particulate chromate-induced chromosome damage and cytotoxicity in Chinese hamster ovary cells. Toxicol Sci. 2007;97(2):348-354. [pmid: 17361020].
Capellmann M, Bolt HM. Chromium (VI) reducing capacity of ascorbic acid and of human plasma in vitro. Arch Toxicol. 1992;66:45-50. [pmid: 1580793].
Capellmann M, Mikalsen A, Hindrum M, et al. Influence of reducing compounds on the formation of DNA-protein cross-links in HL-60 cells induced by hexavalent chromium. Carcinogenesis. 1995;16(5):1135-1139. [pmid: 7767976].
CARB. Procedure for the analysis of hexavalent chromium at ambient atmospheric levels by ion-chromatography. El Monte, CA. California Air Resources Board. 1990.
Carlisle DL, Pritchard DE, Singh J, et al. Apoptosis and P53 induction in human lung fibroblasts exposed to chromium (VI): Effect of ascorbate and tocopherol. Toxicol Sci. 2000;55:60-68. [pmid: 10788560].
Carlton GN. Hexavalent chromium exposures during full-aircraft corrosion control. Am Ind Hyg Assoc J. 2003;64:668-672.
Carøe C, Andersen KE, Thyssen JP, et al. Fluctuations in the prevalence of chromate allergy in Denmark and exposure to chrome-tanned leather. Contact Dermatitis. 2010;63(6):340-346. [pmid: 21039593].
*. Carter WW. The effect of chromium poisoning on the nose and throat: The report of a case. Med J Rec. 1929;130:125-127.
Cary EE. Lang S, editor. Chromium in air, soil and natural waters. Topics in environmental health 5: Biological and environmental aspects of chromium. New York, NY. Elsevier Biomedical Press. 1982:49-64.
Casadevall M, da Cruz Fresco P, Kortenkamp A. Chromium(VI)-mediated DNA damage: Oxidative pathways resulting in the formation of DNA breaks and abasic sites. Chem Biol Interact. 1999;123(2):117-132. [pmid: 10597905].
Case CP, Ellis L, Turner JC, et al. Development of a routine method for the determination of trace metals in whole blood by magnetic sector inductively coupled plasma mass spectrometry with particular relevance to patients with total hip and knee arthroplasty. Clin Chem. 2001;47(2):275-280. [pmid: 11159776].
Casey CE, Hambidge KM. Chromium in human milk from American mothers. Br J Nutr. 1984;52:73-77. [pmid: 6743643].
Cason JS. Report on three extensive industrial chemical burns. Br Med J. 1959;1:827-829. [pmid: 13629134].
Cavalleri A, Minoia C. Distribution in serum and erythrocytes and urinary elimination in workers exposed to chromium(VI) and chromium(III). G Ital Med Lav. 1985;7:35-38. [pmid: 4076713].
Cavalleri A, Minoia C, Richelmi P, et al. Determination of total and hexavalent chromium in bile after intravenous administration of potassium dichromate in rats. Environ Res. 1985;37:490-496. [pmid: 4017998].
CDPH. Chromiuim-6 in drinking water: Sampling results. California Department of Public Health. 2007. http://ww2.cdph.ca.gov/certlic/drinkingwater/pages/chromium6sampling.aspx. August 21, 2008.
Cemeli E, Carder J, Anderson D, et al. Antigenotoxic properties of selenium compounds on potassium dichromate and hydrogen peroxide. Teratog Carcinog Mutagen. Suppl. 2. 2003;23:53-67. [pmid: 14691980].
Chakov NE, Collins RA, Vincent JB. A re-investigation the electron spectra of chromium(III) picolinate complexes and high yield synthesis and characterization of Cr2(μ-OH)2(pic)4 5H2O (Hpic=picolinate acid). Polyhedron. 1999;18:2891-2897.
Chang F, Wang S, Huang Y, et al. Biomonitoring of chromium for residents of areas with a high density of electroplating factories. J Expo Sci Environ Epidemiol. 2006;16(2):138-146. [pmid: 16106258].
Chen CJ, Shih TS, Chang HY, et al. The total body burden of chromium associated with skin disease and smoking among cement workers. Sci Total Environ. 2008;391:76-81. [pmid: 18054992].
Chen F, Shi X. Intracellular signal transduction of cells in response to carcinogenic metals. Crit Rev Oncol Hematol. 2002;42(1):105-121. [pmid: 11923072].
Chen F, Ye J, Zhang X, et al. One-electron reduction of chromium(VI) by α-lipoic acid and related hydroxyl radical generation, dG hydroxylation and nuclear transcription factor-κB activation. Arch Biochem Biophys. 1997;338(2):165-172. [pmid: 9028868].
Chen JM, Hao OJ. Microbial chromium (VI) reduction. Crit Rev Environ Sci. 1998;28(3):219-251.
Chen NSC, Tsai A, Dyer I. Effect of chelating agents on chromium absorption in rats. J Nutr. 1973;103:1182-1186. [pmid: 4198212].
Cheng TY, Tseng YH, Sun CC, et al. Contact sensitization to metals in Taiwan. Contact Dermatitis. 2008;59(6):353-360. [pmid: 19076886].
Chiang CT, Chang TK, Hwang YH, et al. A critical exploration of blood and environmental chromium concentration among oral cancer patients in an oral cancer prevalent area of Taiwan. Environ Geochem Health. 2011;33(5):469-476. [pmid: 20978824].
Chiba M, Sera K, Hashizume M, et al. Element concentrations in hair of children living in environmentally degraded districts of the East Aral Sea region. J Radioanal Nucl Chem. 2004;259(1):149-152.
Chillrud SN, Epstein D, Ross JM, et al. Elevated airborne exposures of teenagers to manganese, chromium, and iron from steel dust and New York City's subways. Environ Sci Technol. 2004;38(3):732-737. [pmid: 14968857].
Chorvatovičová D, Kováčiková Z, Šandula J, et al. Protective effect of sulfoethylglucan against hexavalent chromium. Mutat Res. 1993;302:207-211. [pmid: 7688859].
Chou TC, Chang HY, Chen CJ, et al. Effect of hand dermatitis on the total body burden of chromium after ferrous sulfate application in cement among cement workers. Contact Dermatitis. 2008;59(3):151-156. [pmid: 18759895].
Chowdhury AR, Mitra C. Spermatogenic and steroidogenic impairment after chromium treatment in rats. Indian J Exp Biol. 1995;33:480-484. [pmid: 7590955].
Christenson WR, Davis ME, Berndt WO. The effect of combined treatment with potassium dichromate and maleic acid on renal function in the rat. Toxicol Lett. 1989;49:21-27. [pmid: 2815112].
Cikrt M, Bencko V. Biliary excretion and distribution of ^51^CR(III) and ^51^CR(VI) in rats. J Hyg Epidemiol Microbiol Immunol. 1979;23:241-246.
Clancy SP, Clarkson PM, DeCheke ME, et al. Effects of chromium picolinate supplementation on body composition, strength, and urinary chromium loss in football players. Int J Sports Nutr. 1994;4:142-153.
Clapp TC, Umbreit TH, Meeker RJ, et al. Bioavailability of lead and chromium from encapsulated pigment materials. Bull Environ Contam Toxicol. 1991;46:271-275. [pmid: 1850311].
Clewell HJ III, Andersen ME. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health. 1985;1:111-113. [pmid: 3843496].
Clochesy JM. Chromium ingestion: A case report. J Emerg Nurs. 1984;10:281-282. [pmid: 6392663].
CMR. Chemical profile: Chromic acid. Chem Mark Rep. 1988a:54. October 24, 1988.
CMR. Chemical profile: Sodium bichromate. Chem Mark Rep. 1988b. October 17, 1988.
Cocker J, Jones K, Morton J, et al. Biomonitoring at the UK Health and Safety Laboratory. Int J Hyg Environ Health. 2007;210(3–4):383-386. [pmid: 17321210].
Cohen D. How safe are metal-on-metal hip implants?. BMJ. 2012;344:e1410. www.bmj.com/content/344/bmj.e1410. May 30, 2012. 2012. [pmid: 22374741].
*. Cohen HA. Carrier specificity of tuberculin-type reaction to trivalent chromium. Arch Dermatol. 1966;93:34-40. [pmid: 5900698].
Cohen MD, Sisco M, Baker K, et al. Impact of coexposure to ozone on the carcinogenic potential of inhaled chromium. J Toxicol Environ Health A. 2003;66(1):39-55. [pmid: 12587290].
Cohen MD, Zelikoff JT, Chen LC, et al. Immunotoxicologic effects of inhaled chromium: Role of particle solubility and co-exposure to ozone. Toxicol Appl Pharmacol. 1998;152:30-40. [pmid: 9772197].
Cohen SR, David DM, Kramkowski RS. Clinical manifestations of chromic acid toxicity: Nasal lesions in electroplate workers. Cutis. 1974;13:558-568.
Cole P, Rodu B. Epidemiologic studies of chrome and cancer mortality: A series of meta analyses. Regul Toxicol Pharmacol. 2005;43:225-231. [pmid: 16099572].
Coleman RF, Herrington J, Scales JT. Concentration of wear products in hair, blood, and urine after total hip replacement. Br Med J. 1973;1:527-529. [pmid: 4692678].
Comber S, Gardner M. Chromium redox speciation in natural waters. J Environ Monit. 2003;5:410-413. [pmid: 12833983].
Coogan T, Motz J, Snyder C, et al. Differential DNA-protein crosslinking in lymphocytes and liver following chronic drinking water exposure of rats to potassium chromate. Toxicol Appl Pharmacol. 1991a;109:60-72. [pmid: 2038750].
Coogan TP, Squibb KS, Motz J, et al. Distribution of chromium within cells of the blood. Toxicol Appl Pharmacol. 1991b;108:157-166. [pmid: 2006503].
Corbett GE, Dodge DG, O'Flaherty EO, et al. In vitro reduction kinetics of hexavalent chromium in human blood. Environ Res. 1998;78:7-11. [pmid: 9630439].
Corbett GE, Finley BL, Paustenbach DJ, et al. Systemic uptake of chromium in human volunteers following dermal contact with hexavalent chromium (22 mg/L). J Expo Anal Environ Epidemiol. 1997;7(2):179-189. [pmid: 9185011].
Cornelis R. Application of neutron activation analysis for trace element determinations in biological materials. TrAC Trends Anal Chem. 1985;4(9):237-241.
Cornelis R, Heinzow B, Herber RF, et al. Sample collection guidelines for trace elements in blood and urine. IUPAC Commission of Toxicology. J Trace Elem Med Biol. 1996;10(2):103-127. [pmid: 8829133].
Coryell VH, Stearns DM. Molecular analysis of hprt mutations induced by chromium picolinate in CHO AA8 cells. Mutat Res. 2006;610:114-123. [pmid: 16877033].
Costa M. Potential hazards of hexavalent chromate in our drinking water. Toxicol Appl Pharmacol. 2003;188(1):1-5. [pmid: 12668116].
Costa M, Klein C. Response to comments by Post and Stern on article "Toxicity and carcinogenicity of chromium compounds in humans". Crit Rev Toxicol. 2006a;36(9):779. (Comment on: 36(2):155-163).
*. Costa M, Klein CB. Toxicity and carcinogenicity of chromium compounds in humans. Crit Rev Toxicol. 2006b;36(2):155-163. (Comment in: Crit Rev Toxicol 36(9):777-778, discussion 779). [pmid: 16736941].
Costa M, Zhitkovich A, Gargas M, et al. Interlaboratory validation of a new assay for DNA-protein crosslinks. Mutat Res. 1996;369:13-21. [pmid: 8700178].
Costa M, Zhitkovich A, Harris M, et al. DNA-protein cross-links produced by various chemicals, in cultured human lymphoma cells. J Toxicol Environ Health. 1997;50(5):433-449. [pmid: 9140463].
Crump C, Crump K, Hack E, et al. Dose-response and risk-assessment of airborne hexavalent chromium and lung cancer mortality. Risk Anal. 2003;23(6):1147-1163. [pmid: 14641890].
Cruz MJ, Costa R, Marquilles E, et al. Occupational asthma caused by chromium and nickel. Arch Bronconeumol. 2006;42(6):302-306. [pmid: 16827980].
Cupo DY, Wetterhahn KE. Binding of chromium to chromatin and DNA from liver and kidney of rats treated with sodium dichromate and chromium(III) chloride in vivo. Cancer Res. 1985;45:1146-1151. [pmid: 2578874].
Da Costa JC, Jones FX, Rosenberger RC. Tanner's ulcer: Chrome sores - chrome holes - acid bites. Ann Surg. 1916;63:155-166. [pmid: 17863487].
Dalager NA, Mason TJ, Fraumeni JF, et al. Cancer mortality among workers exposed to zinc chromate paints. J Occup Med. 1980;22(1):25-29. [pmid: 7354410].
Danielsson BRG, Hassoun E, Dencker L. Embryotoxicity of chromium: Distribution in pregnant mice and effects on embryonic cells in vitro. Arch Toxicol. 1982;51:233-245.
Dasch JM, Wolff GT. Trace inorganic species in precipitation and their potential use in source apportionment studies. Water Air Soil Pollut. 1989;43:401-412.
Davids HW, Lieber M. Underground waste contamination by chromium wastes. Water Sewage Works. 1951;98:528-534.
Davidson T, Kluz T, Burns F, et al. Exposure to chromium (VI) in the drinking water increases susceptibility to UV-induced skin tumors in hairless mice. Toxicol Appl Pharmacol. 2004;196:431-437. [pmid: 15094314].
Davies J. Lung cancer mortality of workers in chromate pigment manufacture: An epidemiological survey. J Oil Colour Chem Assoc. 1979;62:157-163.
Davies J. Lung cancer mortality among workers making lead chromate and zinc chromate pigments at three English factories. Br J Ind Med. 1984;41:158-169. [pmid: 6722042].
Davies J, Easton D, Bidstrup P. Mortality from respiratory cancer and other causes in United Kingdom chromate production workers. Br J Ind Med. 1991;48:299-313. [pmid: 2039742].
Davis CM, Vincent JB. Chromium oligopeptide activates insulin receptor tyrosine kinase activity. Biochemistry. 1997;36:4382-4385. [pmid: 9109644].
De Flora S. Metabolic deactivation of mutagens in the Salmonella-microsome test. Nature. 1978;271:455-456. [pmid: 342967].
De Flora S. Study of 106 organic and inorganic compounds in the Salmonella/microsome test. Carcinogenesis. 1981;2(4):283-298. [pmid: 7023727].
De Flora S. Threshold mechanisms and site specificity in chromium(VI) carcinogenesis. Carcinogenesis. 2000;21(4):533-541. [pmid: 10753182].
De Flora S, Wetterhahn KE. Mechanisms of chromium metabolism and genotoxicity. Life Chemistry Reports. 1989;7:169-244.
De Flora S, Badolati GS, Serra D, et al. Circadian reduction of chromium in the gastric environment. Mutat Res. 1987a;192:169-174. [pmid: 3683437].
De Flora S, Bagnasco M, Serra D, et al. Genotoxicity of chromium compounds. A review. Mutat Res. 1990;238:99-172. [pmid: 2407950].
De Flora S, Bennicelli C, Zanacchi P, et al. Metabolic activation and deactivation of mutagens by preparations of human lung parenchyma and bronchial tree. Mutat Res. 1984;139:9-14. [pmid: 6361547].
De Flora S, Camoirana A, Bagnasco M, et al. Estimates of the chromium(VI) reducing capacity in human body compartments as a mechanism for attenuating its potential toxicity and carcinogenicity. Carcinogenesis. 1997;18(3):531-537. [pmid: 9067553].
De Flora S, Iltcheva M, Balansky RM. Oral chromium(VI) does not affect the frequency of micronuclei in hematopoietic cells of adult mice and of transplacentally exposed fetuses. Mutat Res. 2006;610:38-47. [pmid: 16872865].
De Flora S, Petruzelli S, Camoirano A, et al. Pulmonary metabolism of mutagens and its relationship with lung cancer and smoking habits. Cancer Res. 1987b;47:4740-4745. [pmid: 3621172].
De Lucca RC, Dutrey PL, Villarino ME, et al. Effect of different doses of hexavalent chromium on mandibular growth and tooth eruption in juvenile Wistar rats. Exp Toxicol Pathol. 2009;61(4):347-352. [pmid: 19042111].
Deng C, Lee HH, Xian H, et al. Chromosomal aberrations and sister chromatid exchanges of peripheral blood lymphocytes in Chinese electroplating workers: Effect of nickel and chromium. J Trace Elem Exper Med. 1988;1:57-62.
Depault F, Cojocaru M, Fortin F, et al. Genotoxic effects of chromium(VI) and cadmium(II) in human blood lymphocytes using the electron microscopy in situ end-labeling (EM-ISEL) assay. Toxicol In Vitro. 2006;20:513-518. [pmid: 16278061].
Derelanko NJ, Rinehart WE, Hilaski RJ, et al. Thirteen-week subchronic rat inhalation toxicity study with a recovery phase of trivalent chromium compounds, chronic oxide, and basic chromium sulfate. Toxicol Sci. 1999;52(2):278-288. [pmid: 10630581].
Dever M, Hausler DW, Smith JE. Comparison between radioactive isotope chromium-51 and stable isotope chromium-50 labels for the determination of red blood cell survival. J Anal Atom Spectrom. 1989;4:361-363.
Devi KD, Rozati R, Saleha Banu B, et al. In vivo genotoxic effect of potassium dichromate in mice leukocytes using comet assay. Food Chem Toxicol. 2001;39(8):859-865. [pmid: 11434993].
Diaz-Mayans J, Laborda R, Nunez A. Hexavalent chromium effects on motor activity and some metabolic aspects of Wistar albino rats. Comp Biochem Physiol. 1986;83C(1):191-195.
D'Ilio S, Violante N, Majorani C, et al. Dynamic reaction cell ICP-MS for determination of total As, Cr, Se and V in complex matrices: Still a challenge? A review. Anal Chim Acta. 2011;698(1–2):6-13. [pmid: 21645653].
Ding M, Shi X. Molecular mechanisms of Cr(VI)-induced carcinogenesis. Mol Cell Biochem. 2002;234/235:293-300. [pmid: 12162446].
DiPaolo JA, Casto BC. Quantitative studies of in vitro morphological transformation of Syrian hamster cells by inorganic metal salts. Cancer Res. 1979;39:1008-1013. [pmid: 427740].
DiSilvestro RA, Dy E. Comparison of acute absorption of commercially available chromium supplements. J Trace Elem Med Biol. 2007;21(2):120-124. [pmid: 17499152].
DOC. Standard reference material 1569. Brewers yeast. National Bureau of Standards Certificate of Analysis. U.S. Department of Commerce. 1976c. http://ts.nist.gov/MeasurementServices/ReferenceMaterials/ARCHIVED_CERTIFICATES/1569.pdf. April 23, 2008.
DOC. Standard reference material 1570. Trace elements in spinach. National Bureau of Standards Certificate of Analysis. U.S. Department of Commerce. 1976b. http://ts.nist.gov/MeasurementServices/ReferenceMaterials/ARCHIVED_CERTIFICATES/1570.pdf April 23, 2008.
DOC. Standard reference material 1573. Tomato leaves. National Bureau of Standards Certificate of Analysis. U.S. Department of Commerce. 1976a. http://ts.nist.gov/MeasurementServices/ReferenceMaterials/ARCHIVED_CERTIFICATES/1573.pdf. April 23, 2008.
DOC. Standard reference material 1571. Orchard leaves. National Bureau of Standards Certificate of Analysis. U.S. Department of Commerce. 1977a. http://ts.nist.gov/MeasurementServices/ReferenceMaterials/ARCHIVED_CERTIFICATES/1571.pdf. April 23, 2008.
DOC. Standard reference material 1577. Bovine liver. National Bureau of Standards Certificate of Analysis. U.S. Department of Commerce. 1977b. http://ts.nist.gov/MeasurementServices/ReferenceMaterials/ARCHIVED_CERTIFICATES/1577.pdf. April 23, 2008.
DOC. Standard reference material 1577a. Bovine liver. National Bureau of Standards Certificate of Analysis. U.S. Department of Commerce. 1982. http://ts.nist.gov/MeasurementServices/ReferenceMaterials/ARCHIVED_CERTIFICATES/1577a.pdf. April 22, 2008.
DOC. Standard reference material 1566. Oyster tissue. National Bureau of Standards Certificate of Analysis. U.S. Department of Commerce. 1983. http://ts.nist.gov/MeasurementServices/ReferenceMaterials/ARCHIVED_CERTIFICATES/1566.pdf. April 23, 2008.
DOC. Standard reference material 909. Human serum. National Bureau of Standards Certificate of Analysis. U.S. Department of Commerce. 1985. http://ts.nist.gov/MeasurementServices/ReferenceMaterials/ARCHIVED_CERTIFICATES/909.pdf. April 23, 2008.
DOC. Standard reference material 1566a. Oyster tissue. National Bureau of Standards Certificate of Analysis. U.S. Department of Commerce. 1989. http://ts.nist.gov/MeasurementServices/ReferenceMaterials/ARCHIVED_CERTIFICATES/1566a.pdf. April 23, 2008.
DOC. Standard reference material 1575. Pine needles. National Bureau of Standards Certificate of Analysis. U.S. Department of Commerce. 1993a. http://ts.nist.gov/MeasurementServices/ReferenceMaterials/ARCHIVED_CERTIFICATES/1575.pdf. April 23, 2008.
DOC. Standard reference material 909a. Human serum. National Bureau of Standards Certificate of Analysis. U.S. Department of Commerce. 1993b. http://ts.nist.gov/MeasurementServices/ReferenceMaterials/ARCHIVED_CERTIFICATES/909a.pdf. April 23, 2008.
DOC. Standard reference material 2670. Toxic metals in freeze-dried urine. National Bureau of Standards Certificate of Analysis. U.S. Department of Commerce. 1993c. http://ts.nist.gov/MeasurementServices/ReferenceMaterials/ARCHIVED_CERTIFICATES/2670.pdf. May 22, 2008.
DOC. Standard reference material 1570a. Trace elements in spinach leaves. National Bureau of Standards Certificate of Analysis. U.S. Department of Commerce. 1996. http://ts.nist.gov/MeasurementServices/ReferenceMaterials/ARCHIVED_CERTIFICATES/1570a%20July%2015,%201996.pdf. April 23, 2008.
DOC. Standard reference material 909b. Human serum. National Bureau of Standards Certificate of Analysis. U.S. Department of Commerce. 2003. http://ts.nist.gov/MeasurementServices/ReferenceMaterials/ARCHIVED_CERTIFICATES/909b.pdf. April 23, 2008.
DOC. NIST releases two new SRMs for monitoring human exposure to environmental toxins. U.S. Department of Commerce. The National Institute of Standards and Technology. 2012. http://www.nist.gov/mml/analytical/toxins.cfm. May 29, 2012.
*. DOD. The oral toxicity of hexavalent chromium. Washington, DC. U.S. Department of Defense. 1947. AD722266.
Doisy RJ, Streeten DPH, Souma ML, et al. Mertz W, Cornatzer WE. Metabolism of 51chromium in human subjects- normal, elderly, and diabetic subjects. Newer trace elements in nutrition. New York, NY. Marcel Dekker, Inc. 1971:155-168.
Donaldson DL, Smith CC, Yunice AA. Renal excretion of chromium-51 chloride in the dog. Am J Physiol. 1984;246(6):F870-F878. [pmid: 6742133].
Donaldson RM, Barreras RF. Intestinal absorption of trace quantities of chromium. J Lab Clin Med. 1966;68:484-493. [pmid: 5922758].
Douglas GR, Bell RDL, Grant CE, et al. Effect of lead chromate on chromosome aberration, sister-chromatid exchange and DNA damage in mammalian cells in vitro. Mutat Res. 1980;77:157-163. [pmid: 7374664].
Dube P. Determination of chromium in human urine by graphite furnace atomic absorption spectrometry with Zeeman-effect background correction. Analyst. 1988;113:917-921. [pmid: 3218767].
*. Dvizhkov PP, Fedorova VI. [Blastomogenic properties of chromium oxide]. Vopr Onkol. 1967;13:57-62. (Russian). [pmid: 4876551].
*. Eaton D, Stacey N, Wong K, et al. Dose-response effects of various metal ions on the rat liver metallothionein, glutathione, heme oxygenase, and cytochrome P-450. Toxicol Appl Pharmacol. 1980;55:393-402. [pmid: 6893504].
Eckel WP, Jacob TA. Ambient levels of 24 dissolved metals in U.S. surface and ground waters. Prepr Pap Natl Meet Am Chem Soc Div Environ Chem. 1988;28:371-372.
Edel J, Sabbioni E. Pathways of Cr (III) and Cr (VI) in the rat after intratracheal administration. Hum Toxicol. 1985;4(4):409-416. [pmid: 4018821].
Edme JL, Shirali P, Mereau M, et al. Assessment of biological chromium among stainless steel and mild steel workers in relation to welding processes. Int Arch Occup Environ Health. 1997;70:237-242. [pmid: 9342623].
Edmundson WF. Chrome ulcers of the skin and nasal septum and their relation to patch testing. J Invest Dermatol. 1951;17:17-19. [pmid: 14850777].
EEH. An epidemiological study of lead chromate plants: Final report. Berkeley, CA. Equitable Environmental Health, Inc. 1976.
EEH. Mortality in employees of three plants which produced chromate pigments. Berkeley, CA. Equitable Environmental Health, Inc. 1983.
Eisenberg M, Topping JJ. Trace metal residues in finfish from Maryland waters. 1978–1979. J Environ Sci Health. 1986;21(1):87-102.
Elbetieha A, Al-Hamood MH. Long-term exposure of male and female mice to trivalent and hexavalent chromium compounds: Effect on fertility. Toxicology. 1997;116:39-47. [pmid: 9020505].
El-Demerdash FM, Yousef MI, Elaswad FAM. Biochemical study on the protective role of folic acid in rabbits treated with chromium (VI). J Environ Sci Health B. 2006;41(5):731-746. [pmid: 16785179].
Elias Z, Mur J-M, Pierre F, et al. Chromosome aberrations in peripheral blood lymphocytes of welders and characterization of their exposure by biological samples analysis. J Occup Med. 1989a;31(5):477-483. [pmid: 2715858].
Elias Z, Poirot O, Pezerat H, et al. Cytotoxic and neoplastic transforming effects of industrial hexavalent chromium pigments in Syrian hamster embryo cells. Carcinogenesis. 1989b;10(11):2043-2052. [pmid: 2680145].
Ellis EN, Brouhard BH, Lynch RE, et al. Effects of haemodialysis and dimercaprol in acute dichromate poisoning. J Toxicol Clin Toxicol. 1982;19(3):249-258. [pmid: 7131611].
Elsaieed EM, Nada SA. Teratogenicity of hexavalent chromium in rats and the beneficial role of ginseng. Bull Environ Contam Toxicol. 2002;68:361-368. [pmid: 11993810].
Engebrigtsen JK. Some investigations on hypersensitiveness to bichromate in cement workers. Acta Derm Venereol. 1952;32:462-468. [pmid: 12985108].
Engel H, Calnan C. Chromate dermatitis from paint. Br J Ind Med. 1963;20:192-198. [pmid: 14046155].
Engelhardt S, Moser-Veillon PB, Mangels AR, et al. Atkinson SA, Hanson LA, Chandra RK, editors. Appearance of an oral dose of chromium (53Cr) in breast milk?. Breast feeding, nutrition, infection and infant growth in developed and emerging countries. St. John's, Canada. ARTS Biomedical Publishers and Distributors. 1990:485-487.
Enterline PE. Respiratory cancer among chromate workers. J Occup Med. 1974;16(8):523-526. [pmid: 4843401].
EPA. Water-related environmental fate of 129 priority pollutants: Vol. I: Introduction and technical background, metals and inorganics, pesticides and PCBs. Washington, DC. U.S. Environmental Protection Agency, 10-1 to 10-10. 1979. EPA440579029a.
EPA. Ambient water quality criteria for chromium. Washington, DC. Office of Water Regulations and Standards, Criteria and Standards Division, U.S. Environmental Protection Agency. 1980. EPA440580035.
EPA. Chromium. Method 218.2 (atomic absorption, furnace technique). Methods for chemical analysis of water and wastes. Cincinnati, OH. U.S. Environmental Protection Agency. 1983a. EPA600479020.
EPA. Chromium. Method 218.4 (atomic absorption, chelation-extraction). Methods for chemical analysis of water and wastes. Cincinnati, OH. U.S. Environmental Protection Agency. 1983b. EPA600479020.
EPA. Health assessment document for chromium. Research Triangle Park, NC. Environmental Assessment and Criteria Office, U.S. Environmental Protection Agency. 1984a. EPA600883014F.
EPA. Locating and estimating air emissions from sources of chromium. Research Triangle Park, NC. Office of Air Quality Planning and Standards, U.S. Environmental Protection Agency. 1984b. 85106474.
EPA. Environmental profiles and hazard indices for constituents of municipal sludge: Chromium. Washington, DC. Office of Health and Environmental Assessment, U.S. Environmental Protection Agency. 1985a.
*. EPA. National primary drinking water regulations; synthetic organic chemicals, inorganic chemicals and microorganism; proposed rule. U.S. Environmental Protection Agency: Fed Regist. 1985b;50:46966.
EPA. Chromium (atomic absorption, furnace technique): Method: 7191. Test methods for evaluating solid waste. Vol. 1A: Laboratory manual physical/chemical methods 3rd ed. SW-846. Washington, DC. Office of Solid Waste and Emergency Response, U.S. Environmental Protection Agency. 1986a.
EPA. Chromium (atomic absorption, direct aspiration): Method: 7190. Test methods for evaluating solid waste. Vol. 1A: Laboratory manual physical/chemical methods 3rd ed. Washington, DC. Office of Solid Waste and Emergency Response, U.S. Environmental Protection Agency. 1986b. SW-846.
EPA. Chromium, hexavalent (coprecipitation): Method: 7195. Test methods for evaluating solid waste. Vol. 1A: Laboratory manual physical/chemical methods 3rd ed. Washington, DC. Office of Solid Waste and Emergency Response, U.S. Environmental Protection Agency. 1986c. SW-846.
EPA. Chromium, hexavalent (chelation/extraction): Method: 7197. Test methods for evaluating solid waste. Vol. 1A: Laboratory manual physical/chemical methods 3rd ed. Washington, DC. Office of Solid Waste and Emergency Response, U.S. Environmental Protection Agency. 1986d. SW-846.
EPA. Chromium, hexavalent (differential pulse polarography): Method: 7198. Test methods for evaluating solid waste. Vol. 1A: Laboratory manual physical/chemical methods 3rd ed. Washington, DC. Office of Solid Waste and Emergency Response, U.S. Environmental Protection Agency. 1986e. SW-846.
*. EPA. Extremely hazardous substances list and threshold planning quantities; emergency planning and release notification requirements. U.S. Environmental Protection Agency. 1987a;52:13378-13410. Fed Regist.
EPA. Quality criteria for water 1986. Washington, DC. Office of Water Regulations and Standards, U.S. Environmental Protection Agency. 1987b. EPA440586001.
EPA. Analysis of the Clean Water Act effluent guidelines pollutants. Summary of the chemical regulated by industrial points source categories 40 CFR Parts 400–475. Draft. U.S. Environmental Protection Agency. 1988a.
EPA. Mining waste exclusion. U.S. Environmental Protection Agency. 1988b;53:41288-41300. Fed Regist.
EPA. Fate of chromium(III) in chlorinated water. Cincinnati, OH. Office of Research and Development, U.S. Environmental Protection Agency. 1988c. PB88130992.
EPA. Recommendations for and documentation of biological values for use in risk assessment. Cincinnati, OH. U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office, Office of Health and Environmental Assessment. 1988d. PB8817874.
EPA. Interim methods for development of inhalation reference concentrations. Washington, DC. U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. 1990a. EPA600890066A.
EPA. Noncarcinogenic effects of chromium: Update to health assessment document. Research Triangle Park, NC. Environmental Criteria and Assessment Office, Office of Health and Environmental Assessment, U.S. Environmental Protection Agency. 1990b. EPA600887048F.
*. EPA. Test methods for evaluating solid waste. Vol. 1A: Laboratory manual physical/chemical methods 3rd ed. Washington, DC. Office of Solid Waste and Emergency Response, U.S. Environmental Protection Agency. 1994a. SW-846.
EPA. EPA ground water issue. Natural attenuation of hexavalent chromium in groundwater and soils. Washington, DC. U.S. Environmental Protection Agency. 1994b. EPA540594505.
EPA. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC. U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. 1994c. EPA600890066F.
EPA. Emergency planning and community -right-to-know act. Title III (SARA). U.S. Environmental Protection Agency. 1995.
EPA. Method 7199: Determination of hexavalent chromium in drinking water, groundwater, and industrial wastewater effluents by ion chromatography. Test methods for evaluating solid waste. 3rd ed. Washington, DC. U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response. 1996a. SW-846.
EPA. Method 6010B: Inductively coupled plasma-atomic emission spectrometry. Test methods for evaluating solid waste. 3rd ed. Washington, DC. U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response. 1996b. SW-846.
EPA. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC. U.S. Environmental Protection Agency, Risk Assessment Forum. 1997. EPA630R96012.
*. EPA. Designation of hazardous substances. Washington, DC. U.S. Environmental Protection Agency. 1998a. Code of Federal Regulations. 40 CFR 302.4.
*. EPA. Clean water effluent guidelines. Washington, DC. U.S. Environmental Protection Agency. 1998b. Code of Federal Regulations. 40 CFR 406.
EPA. Notice of availability of RCRA waste minimization PBT chemical list. U.S. Environmental Protection Agency. 1998c. Fed Regist 63: 60332, http://www.gpoaccess.gov/fr/index.html. May 05, 2008.
EPA. Benchmark dose technical guidance document. Washington, DC. U.S. Environmental Protection Agency. 2000. EPA630R00001.
EPA. National primary drinking water standards. Washington, DC. U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. 2003. EPA816F03016. http://www.epa.gov/safewater/mcl.html. March 07, 2006.
EPA. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. 2005. EPA260B05001.
EPA. 2006 Edition of the drinking water standards and health advisories. Washington, DC. Office of Water, U.S. Environmental Protection Agency. 2006a. EPA822R06013. http://www.epa.gov/waterscience/criteria/drinking/dwstandards.pdf. April 11, 2007.
EPA. National recommended water quality criteria. Washington, DC. U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. 2006b. http://www.epa.gov/waterscience/criteria/nrwqc-2006.pdf. January 08, 2008.
EPA. Acute exposure guideline levels (AEGLs). Washington, DC. Office of Pollution Prevention and Toxics, U.S. Environmental Protection Agency. 2007a. http://www.epa.gov/oppt/aegl/pubs/compiled.pdf. April 24, 2008.
EPA. The Clean Air Act amendments of 1990 list of hazardous air pollutants. Clean Air Act. U.S. Environmental Protection Agency. 2007b. United States Code. 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. April 24, 2008.
EPA. Acute exposure guideline levels (AEGLs). Second AEGL chemical priority list. U.S. Environmental Protection Agency. 2008a. http://www.epa.gov/oppt/aegl/pubs/priority_2.htm. April 24, 2008.
EPA. Designation of hazardous substances. U.S. Environmental Protection Agency. 2008b. Code of Federal Regulations. 40 CFR 116.4 http://www.epa.gov/lawsregs/search/40cfr.html. April 24, 2008.
EPA. Determination of reportable quantities. U.S. Environmental Protection Agency. 2008c. Code of Federal Regulations. 40 CFR 117.3. http://www.epa.gov/lawsregs/search/40cfr.html. April 24, 2008.
EPA. Groundwater monitoring list. U.S. Environmental Protection Agency. 2008d. Code of Federal Regulations. 40 CFR 264, Appendix IX. http://www.epa.gov/lawsregs/search/40cfr.html. May 05, 2008.
EPA. Inert ingredients permitted for use in nonfood use pesticide products. U.S. Environmental Protection Agency. 2008e. http://www.epa.gov/opprd001/inerts/lists.html. April 24, 2008.
EPA. Master testing list. Washington, DC. Office of Pollution Prevention and Toxics, U.S. Environmental Protection Agency. 2008f. http://www.epa.gov/opptintr/chemtest/pubs/mtl.htm. April 24, 2008.
EPA. The list of extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. 2008g. Code of Federal Regulations. 40 CFR 355, Appendix A. http://www.epa.gov/lawsregs/search/40cfr.html. April 24, 2008.
EPA. Toxic chemical release reporting. Chemicals and chemical categories to which this part applies. U.S. Environmental Protection Agency. 2008h. Code of Federal Regulations. 40 CFR 372.65. http://www.epa.gov/lawsregs/search/40cfr.html. April 24, 2008.
EPA. Toxic pollutants. U.S. Environmental Protection Agency. 2008i. Code of Federal Regulations. 40 CFR 401.15. http://www.epa.gov/lawsregs/search/40cfr.html. April 24, 2008.
EPA. Designation of hazardous substances. U.S. Environmental Protection Agency. 2008j. Code of Federal Regulations. 40 CFR 302.4. http://www.epa.gov/lawsregs/search/40cfr.html.
EPA. Method 218.7: Determination of hexavalent chromium in drinking water by ion chromatography with post-column derivatization and UV-visable spectroscopic detection. U.S. Environmental Protection Agency. 2011. EPA815R11005. http://water.epa.gov/scitech/drinkingwater/labcert/upload/EPA_Method_218-7.pdf. June 12, 2012.
EPA. Chromium in drinking water. U.S. Environmental Protection Agency. 2012. http://water.epa.gov/drink/info/chromium/index.cfm#one. May 29, 2012.
Erickson BE. EPA addresses chromium (VI) in drinking water. C&EN. 2011;89(1):16.
Ertam I, Turkmen M, Alper S. Patch-test results of an academic department in Izmir, Turkey. Dermatitis. 2008;19(4):213-215. [pmid: 18674457].
Eun HC, Marks R. Dose-response relationships for topically applied antigens. Br J Dermatol. 1990;122:491-499. [pmid: 2186775].
*. Evan AP, Dail WG. The effects of sodium chromate on the proximal tubules of the rat kidney: Fine structural damage and lysozymuria. Lab Invest. 1974;30(6):704-715. [pmid: 4365167].
Evans GW. The effect of chromium picolinate on insulin controlled parameters in humans. Int J Biosocial Med Res. 1989;11(2):163-180.
Fagliano JA, Savrin J, Udasin I, et al. Community exposure and medical screening near chromium waste sites in New Jersey. Regul Toxicol Pharmacol. 1997;26:S13-S22. [pmid: 9380833].
Fahrni C. Biological applications of x-ray fluorescence microscopy: Exploring the subcellular topography and speciation of transition metals. Curr Opin Chem Biol. 2007;11:121-127. [pmid: 17353139].
Falerios M, Schild K, Sheehan P, et al. Airborne concentrations of trivalent and hexavalent chromium from contaminated soils at unpaved and partially paved commercial/industrial sites. J Air Waste Manage Assoc. 1992;42:40-48.
FDA. Beverages. Bottled water. U.S. Food and Drug Administration. 2007a. Code of Federal Regulations. 21 CFR 165.110. http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfcfr/CFRSearch.cfm. April 24, 2008.
FDA. Indirect food additives: Adhesives and components of coatings. U.S. Food and Drug Administration. 2007b. Code of Federal Regulations. 21 CFR 175.105. http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfcfr/CFRSearch.cfm. April 24, 2008.
FDA. Nutrition labeling of food. U.S. Food and Drug Administration. 2007c. Code of Federal Regulations. 21 CFR 101.9. http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfcfr/CFRSearch.cfm. May 20, 2008.
FDA. EAFUS: A food additive database. U.S. Food and Drug Administration. 2008. http://vm.cfsan.fda.gov/~dms/eafus.html. April 24, 2008.
Febel H, Szegedi B, Huszar S. Absorption of inorganic, trivalent and hexavalent chromium following oral and intrajejunal doses in rats. Acta Vet Hung. 2001;49(2):203-209. [pmid: 11402649].
FEDRIP. Chromium. Federal Research in Progress database. Springfield, VA. National Technical Information Service. 2008.
Fernandez-Nieto M, Quirce S, Carnes J, et al. Occupational asthma due to chromium and nickel salts. Int Arch Occup Environ Health. 2006;79:483-486. [pmid: 16402272].
Finley B, Fehling K, Falerios M, et al. Field validation for sampling and analysis of airborne hexavalent chromium. Appl Occup Environ Hyg. 1993;8(3):191-200.
Finley BL, Paustenbach DJ. Using applied research to reduce uncertainty in health risk assessment: Five case studies involving human exposure to chromium in soil and groundwater. J Soil Contam. 1997;6(6):650-705.
Finley BL, Kerger BD, Dodge DG, et al. Assessment of airborne hexavalent chromium in the home following use of contaminated tapwater. J Expo Anal Environ Epidemiol. 1996a;6(2):229-245. [pmid: 8792299].
Finley BL, Kerger BD, Katona MW, et al. Human ingestion of chromium (VI) in drinking water: Pharmacokinetics of following repeated exposure. Toxicol Appl Pharmacol. 1997;142:151-159. [pmid: 9007044].
Finley BL, Scott PK, Norton RL, et al. Urinary chromium concentrations in humans following ingestion of safe doses of hexavalent and trivalent chromium: Implications for biomonitoring. J Toxicol Environ Health. 1996b;48:479-499. [pmid: 8751836].
Fishbein L. Sources, transport and alterations of metal compounds: An overviewIArsenic, beryllium, cadmium, chromium and nickel. Environ Health Perspect. 1981;40:43-64. [pmid: 7023934].
Fishbein L. Overview of analysis of carcinogenic and/or mutagenic metals in biological and environmental samples: I. Arsenic, beryllium, cadmium, chromium and selenium. Int J Environ Anal Chem. 1984;17:113-170. [pmid: 6378814].
Flores A, Perez JM. Cytotoxicity, apoptosis, and in vitro DNA damage induced by potassium chromate. Toxicol Appl Pharmacol. 1999;161:75-81. [pmid: 10558925].
Foa V, Riboldi L, Patroni M, et al. Effects derived from long-term low-level chromium exposure in ferro-alloy metallurgy. Study of absorption and renal function in workers. Sci Total Environ. 1988;71:389-400. [pmid: 3406708].
Fomon SJ. Falkner F, editor. Body composition of the infant. Part I: The male reference infant. Human development. Philadelphia, PA. WB Saunders. 1966:239-246.
Fomon SJ, Haschke F, Ziegler EE, et al. Body composition of reference children from birth to age 10 years. Am J Clin Nutr. 1982;35:1169-1175. [pmid: 7081099].
Fornace AJ, Seres DS, Lechner JF, et al. DNA-protein cross-linking by chromium salts. Chem Biol Interact. 1981;36:345-354. [pmid: 7285240].
Franchini I, Mutti A. Selected toxicological aspects of chromium(VI) compounds. Sci Total Environ. 1988;71:379-387. [pmid: 3406707].
Franchini I, Magnani F, Mutti A. Mortality experience among chromeplating workers. Scand J Work Environ Health. 1983;9:247-252. [pmid: 6612265].
*. Franchini I, Mutti A, Cavatorta A, et al. Nephrotoxicity of chromium. Contrib Nephrol. 1978;10:98-110. [pmid: 668382].
Fregert S. Occupational dermatitis in a 10-year material. Contact Dermatitis. 1975;1:96-107. [pmid: 233894].
Fregert S, Rorsman H. Allergy to trivalent chromium. Arch Dermatol. 1964;90:4-6. [pmid: 14149722].
Fregert S, Rorsman H. Allergic reactions to trivalent chromium compounds. Arch Dermatol. 1966;93:711-713. [pmid: 5932159].
*. Fregert S, Hjorth N, Magnusson B, et al. Epidemiology of contact dermatitis. Trans St John's Hosp Dermatol Soc. 1969;55:17-35. [pmid: 5804349].
Frentzel-Beyme R. Lung cancer mortality of workers employed in chromate pigment factories. J Cancer Res Clin Oncol. 1983;105:183-188. [pmid: 6826639].
Fristedt B, Lindqvist B, Schutz A, et al. Survival in a case of acute oral chromic acid poisoning with acute renal failure treated by haemodialysis. Acta Med Scand. 1965;177:153-159. [pmid: 14279496].
Fryzek JP, Mumma MT, McLaughlin JK, et al. Cancer mortality in relation to environmental chromium exposure. J Occup Environ Med. 2001;43(7):635-640. [pmid: 11464395].
Fujii T, Sakamoto Y, Fukumori N, et al. [Primary eye irritation tests using a chromium dross extract]. Annual Report of the Tokyo Metropolitan Research Laboratory of Public Health. 1976;27:124-128. (Japanese).
Fukunaga M, Kurachi Y, Mizuguchi Y. Action of some metal ions on yeast chromosomes. Chem Pharm Bull. 1982;30(8):3017-3019. [pmid: 6754115].
Furst A, Schlauder M, Sasmore DP. Tumorigenic activity of lead chromate. Cancer Res. 1976;36:1779-1783. [pmid: 1268834].
Gad SC, Powers WJ, Dunn BJ, et al. Serrone DM, editor. Acute toxicity of four chromate salts. Chromium symposium 1986: An update. Pittsburgh, PA. Industrial Health Foundation Inc. 1986:43-58.
*. Gale TF. Embryotoxic effects of chromium trioxide in hamsters. Environ Res. 1978;16:101-109. [pmid: 679908].
*. Gale TF. The embryotoxic response to maternal chromium trioxide exposure in different strains of hamsters. Environ Res. 1982;29:196-203. [pmid: 7140706].
*. Gale TF, Bunch JD III. The effect of the time of administration of chromium trioxide on the embryotoxic response in hamsters. Teratology. 1979;19:81-86. [pmid: 451937].
Gambelunghe A, Piccinini R, Abbritti G, et al. Chromium VI-induced apoptosis in a human bronchial epithelial cell line (BEAS-2B) and a lymphoblastic leukemia cell line (MOLT-4). J Occup Environ Med. 2006;48(3):319-325. [pmid: 16531837].
Gambelunghe A, Piccinini R, Ambrogi M, et al. Primary DNA damage in chrome-plating workers. Toxicology. 2003;188:187-195. [pmid: 12767690].
Gao M, Levy LS, Braithwaite RA, et al. Monitoring of total chromium in rat fluids and lymphocytes following intratracheal administration of soluble trivalent or hexavalent chromium compounds. Hum Exp Toxicol. 1993;12:377-382. [pmid: 7902114].
Gao M, Levy LS, Faux SP, et al. Use of molecular epidemiological techniques in a pilot study on workers exposed to chromium. Occup Environ Med. 1994;51:663-668. [pmid: 8000490].
Gao N, Jiang BH, Leonard SS, et al. p38 Signaling-mediated hypoxia-inducible factor 1alpha and vascular endothelial growth factor induction by Cr(VI) in DU145 human prostate carcinoma cells. J Biol Chem. 2002;277(47):45041-45048. [pmid: 12213806].
Garcia E, Cabrera C, Lorenzo ML, et al. Estimation of chromium bioavailability from the diet by an in vitro method. Food Addit Contam. 2001;18(7):601-606. [pmid: 11469315].
Garcia J, Jennette K. Electron-transport cytochrome P-450 system is involved in the microsomal metabolism of the carcinogen chromate. J Inorganic Biochem. 1981;14:281-295.
Gargas ML, Norton RL, Paustenbach DJ, et al. Urinary excretion of chromium by humans following ingestion of chromium picolinate: Implications for biomonitoring. Drug Metab Dispos. 1994;22(4):522-529. [pmid: 7956725].
Gasiorowski K, Szyba K, Wozniak D, et al. Inhibition of potassium dichromate mutagenicity by todralazine. Mutagenesis. 1997;12(6):411-415. [pmid: 9412993].
Gasiorowski K, Szyba K, Wozniak D, et al. Genotoxicity of CR(VI) can be markedly lowered by complexation of the chromate anion. BioMetals. 1998;11:175-181.
Gass JK, Todd PM. Multiple manifestations of chromate contact allergy. Contact Dermatitis. 2007;56(5):290-291. [pmid: 17441858].
Gatto NM, Kelsh MA, Mai DH, et al. Occupational exposure to hexavalent chromium and cancers of the gastrointestinal tract: A meta-analysis. Cancer Epidemiol. 2010;34(4):388-399. [pmid: 20430714].
Gava C, Costa R, Zordan M, et al. Induction of gene mutations in Salmonella and Drosophila by soluble Cr(VI) compounds: Synergistic effects of nitrilotriacetic acid. Toxicol Environ Chem. 1989a;22:27-38.
Gava C, Perazzolo M, Zentilin L, et al. Genotoxic potentiality and DNA-binding properties of acetylacetone, maltol, and their aluminum(III) and chromium(III) neutral complexes. Toxicol Environ Chem. 1989b;22:149-157.
Gerhardsson L, Brune D, Nordberg GF, et al. Multielemental assay of tissues of deceased smelter workers and controls. Sci Total Environ. 1988;74:97-110. [pmid: 3222699].
Gianello G, Masci O, Carelli G, et al. Occupational exposure to chromium—An assessment of environmental pollution levels and biological monitoring of exposed workers. Ind Health. 1998;36:74-77. [pmid: 9473863].
Gibb HJ, Lees PSJ, Pinsky PF, et al. Clinical findings of irritation among chromium chemical production workers. Am J Ind Med. 2000a;38:127-131. [pmid: 10893505].
Gibb HJ, Lees PSJ, Pinsky PF, et al. Lung cancer among workers in chromium chemical production. Am J Ind Med. 2000b;38:115-126. [pmid: 10893504].
Giwercman A, Carlsen E, Keiding N, et al. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl. 1993;101(2):65-71.
Glaser U, Hochrainer D, Kloppel H, et al. Low level chromium(VI) inhalation effects on alveolar macrophages and immune functions in Wistar rats. Arch Toxicol. 1985;57:250-256. [pmid: 3879166].
Glaser U, Hochrainer D, Kloppel H, et al. Carcinogenicity of sodium dichromate and chromium(VI/III) oxide aerosols inhaled by male Wistar rats. Toxicology. 1986;42:219-232. [pmid: 3798470].
Glaser U, Hochrainer D, Oldiges H. Investigations of the lung carcinogenic potentials of sodium dichromate and Cr VI/III oxide aerosols in Wistar rats. Environ Hyg. 1988;1:111-116.
Glaser U, Hochrainer D, Steinhoff D. Investigation of irritating properties of inhaled CrVI with possible influence on its carcinogenic action. Environ Hyg. 1990;2:235-245.
Goitre M, Bedello PG, Cane D. Chromium dermatitis and oral administration of the metal. Contact Dermatitis. 1982;8:208-209. [pmid: 6212187].
Goldbohm RA, Tielemans ELJP, Heederik D, et al. Risk estimation for carcinogens based on epidemiological data: A structured approach, illustrated by an example on chromium. Regul Toxicol Pharmacol. 2006;44:294-310. [pmid: 16497421].
Goldman M, Karotkin RH. Acute potassium bichromate poisoning. Am J Med Sci. 1935;189:400-403.
Goldsby RA, Kindt TJ, Osborne BA, et al. Hypersensitive reactions. Immunology. 5th ed. New York, NY. W.H. Freeman and Company. 2003:361-386.
Gomes E. Incidence of chromium-induced lesions among electroplating workers in Brazil. Ind Med. 1972;41(12):21-25.
Gomez-Arroyo S, Altamirano M, Villalobos-Pietrini R. Sister chromatid exchanges induced by some chromium compounds in human lymphocytes in vitro. Mutat Res. 1981;90:425-431. [pmid: 7335108].
Gonzalez AR, Ndung'U K, Flegal AR. Natural occurrence of hexavalent chromium in the aromas red sands aquifer, California. Environ Sci Technol. 2005;39:5505-5511. [pmid: 16124280].
Gonzalez-Vergara E, De Gonzalez BC, Hegenauer J, et al. Chromium coordination compounds of pyridoxal and nicotinic acid: Synthesis, absorption and metabolism. Isr J Chem. 1981;21:18-22.
Gorman NgM, Stjernberg E, Koehoorn M, et al. Exposure to pesticides and metal contaminants of fertilizer among tree planters. Ann Occup Hyg. 2011;55(7):752-763. [pmid: 21673126].
Gormican A. Inorganic elements in foods used in hospital menus. J Am Diet Assoc. 1970;56:397-403. [pmid: 5439980].
Grant KE, Chandler RM, Castle AL, et al. Chromium and exercise training: Effect on obese women. Med Sci Sports Exer. 1997;29:992-998.
Gray SJ, Sterling K. The tagging of red cells and plasma proteins with radioactive chromium. J Clin Invest. 1950;29:1604-1613. [pmid: 14794790].
Greenberg RR, Zeisler R. A radiochemical procedure for ultratrace determination of chromium in biological materials. J Radioanal Nucl Chem. 1988;124(1):5-20.
Gregus Z, Klaassen CD. Disposition of metals in rats: A comparative study of fecal, urinary, and biliary excretion and tissue distribution of eighteen metals. Toxicol Appl Pharmacol. 1986;85:24-38. [pmid: 3726885].
Greig RA, Jones J. Nondestructive neutron activation analysis of marine organisms collected from ocean dump sites of the middle eastern United States. Arch Environ Contam Toxicol. 1976;4(4):420-434. [pmid: 999333].
Griepink B, Tolg G. Sample digestion for the determination of elemental traces in matrices of environmental concern. Pure Appl Chem. 1989;61(6):1139-1146.
*. Gromadzinska J, Wasowicz W, Sklodowska M, et al. The influence of atmospheric chromium on selenium content and glutathione peroxidase activity in blood of tannery workers. Environ Health Perspect. 1996;104(12):1312-1316. [pmid: 9118872].
Gross PR, Katz SA, Samitz MH. Sensitization of guinea pigs to chromium salts. J Invest Dermatol. 1968;50(5):424-427. [pmid: 5653240].
Gruber JE, Jennette KW. Metabolism of the carcinogen chromate by rat liver microsomes. Biochem Biophys Res Commun. 1978;82(2):700-706. [pmid: 27196].
Guerrero MML, Alonso EV, Pavon JMC, et al. On-line preconcentration using chelating and ion-exchange minicolumns for the speciation of chromium(III) and chromium(VI) and their quantitative determination in natural waters by inductively coupled plasma mass spectrometry. J Anal At Spectrom. 2012;27(4):682-688.
Guillemin MP, Berode M. A study of the difference in chromium exposure in workers in two types of electroplating process. Ann Occup Hyg. 1978;21:105-112. [pmid: 697263].
*. Gumbleton M, Nicholls PJ. Dose-response and time-response biochemical and histological study of potassium dichromate-induced nephrotoxicity in the rat. Food Chem Toxicol. 1988;26(1):37-44. [pmid: 2894338].
Gunaratnam M, Grant MH. Chromium(VI)-induced damage to the cytoskeleton and cell death in isolated hepatocytes. Biochem Soc Trans. 2002;30(4):748-750. [pmid: 12196185].
Gunaratnam M, Grant MH. Damage to F-actin and cell death induced by chromium VI and nickel in primary monolayer cultures of rat hepatocytes. Toxicol In Vitro. 2004;18:245-253. [pmid: 15046770].
Guzelian PS, Henry CJ, Olin SS. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC. International Life Sciences Institute Press. 1992.
Gylseth B, Gundersen N, Lang S. Evaluation of chromium exposure based on a simplified method for urinary chromium determination. Scand J Work Environ Health. 1977;3:28-31. [pmid: 847428].
Ha L, Ceryak S, Patierno SR. Chromium (VI) activates ataxia telangiectasia mutated (ATM) protein. Requirement of ATM for both apoptosis and recovery from terminal growth arrest. J Biol Chem. 2003;278(20):17885-17894. [pmid: 12637545].
Ha L, Ceryak S, Patierno SR. Generation of S phase-dependent DNA double-strand breaks by Cr(VI) exposure: Involvement of ATM in Cr(VI) induction of gamma-H2AX. Carcinogenesis. 2004;25(11):2265-2274. [pmid: 15284180].
Haberman PJ, Baggett JM, Berndt WO. The effect of chromate on citrinin-induced renal dysfunction in the rat. Toxicol Lett. 1987;38:83-90. [pmid: 3629635].
Haddad LM, Shannon MW, Winchester JF, editors. Chromium. Clinical management of poisoning and drug overdose. 3rd ed. Philadelphia, PA. W.B. Sanders Company. 1998:794-795.
Haguenoer JM, Dubois G, Frimat P, et al. [Mortality due to broncho-pulmonary cancer in a factory producing pigments based on lead and zinc chromates]. Prevention of occupational cancer - International Symposium, Occupational Safety and Health Series 46. Geneva, Switzerland. International Labour Office. 1981:168-176. (French).
Halasova E, Matakova T, Musak L, et al. Chromosomal damage and polymorphisms of DNA repair genes XRCC1 and XRCC3 in workers exposed to chromium. Neuro Endocrinol Lett. 2008;29(5):658-662. [pmid: 18987609].
Hallmark MA, Reynolds TH, DeSouza CA, et al. Effects of chromium on resistance training on muscle strength and body composition. Med Sci Sports Exerc. 1996;28:139-144. [pmid: 8775366].
Hamamy HA, Al-Hakkak ZS, Hussain AF. Chromosome aberrations in workers in a tannery in Iraq. Mutat Res. 1987;189:395-398. [pmid: 3683434].
Hansen MB, Johansen JD, Menne T. Chromium allergy: Significance of both Cr(III) and Cr(VI). Contact Dermatitis. 2003;49(4):206-212. [pmid: 14996070].
Hansen MB, Menne T, Johansen JD. Cr(III) and Cr(VI) in leather and elicitation of eczema. Contact Dermatitis. 2006a;54(5):278-282. [pmid: 16689813].
Hansen MB, Menne T, Johansen JD. Cr(III) reactivity and foot dermatitis in Cr(VI) positive patients. Contact Dermatitis. 2006b;54(3):140-144. [pmid: 16524436].
Hanslian L, Navratil J, Jurak J, et al. [Damage to the upper respiratory tract by a chromic acid aerosol]. Pracovni Lekarstvi. 1967;19:294-298. (Czechoslovakian).
Hara T, Hoshuyama T, Takahashi K, et al. Cancer risk among Japanese chromium platers, 1976–2003. Scand J Work Environ Health. 2010;36(3):216-221. [pmid: 20024521].
Harnly JM, Patterson KY, Veillon C, et al. Comparison of electrothermal atomic absorption spectrometry and atomic emission spectrometry for determination of chromium in urine. Anal Chem. 1983;55:1417-1419. [pmid: 6614496].
Hartford WH. Grayson M, editor. Chromium compounds. Kirk-Othmer encyclopedia of chemical technology. 3rd ed. New York, NY. John Wiley and Sons. 1979;Vol. 6:82-120.
Harzdorf C, Janser G. The determination of chromium(VI) in waste water and industrial effluents by differential pulse polarography. Anal Chim Acta. 1984;165:201-207.
Hasan A. A case report: Ammonium dichromate poisoning. Biomed Res. 2007;18(1):35-37.
Hasten DL, Rome EP, Franks BD, et al. Effects of chromium picolinate on beginning weight training students. Int J Sport Nutr. 1992;2:343-350. [pmid: 1299504].
Haworth S, Lawlor T, Mortelmans K, et al. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen Suppl. 1983;1:3-142.
Hayes RB, Lilienfeld AM, Snell LM. Mortality in chromium chemical production workers: A prospective study. Int J Epidemiol. 1979;8(4):365-374. [pmid: 541160].
Hayes RB, Sheffet A, Spirtas R. Cancer mortality among a cohort of chromium pigment workers. Am J Ind Med. 1989;16:127-133. [pmid: 2773944].
HazDat. Chromium. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA. Agency for Toxic Substances and Disease Registry. 2007. http://www.atsdr.cdc.gov/hazdat.html. May 02, 2008.
He X, Lin GX, Chen MG, et al. Protection against chromium (VI)-induced oxidative stress and apoptosis by Nrf2. Recruiting Nrf2 into the nucleus and disrupting the nuclear Nrf2/Keap1 association. Toxicol Sci. 2007;98(1):298-309. [pmid: 17420218].
Hegewald J, Uter W, Kranke B, et al. Patch test results with metals and meteorological conditions. Int Arch Allergy Immunol. 2008;147(3):235-240. [pmid: 18594154].
Hemminki K, Vainio H. Human exposure to potentially carcinogenic compounds. IARC Scientific Publ No. 1984;59:37-45.
Henderson RF, Rebar AH, Pickrell JA, et al. Early damage indicators in the lung. III. Biochemical and cytological response of the lung to inhaled metal salts. Toxicol Appl Pharmacol. 1979;50:123-136. [pmid: 494293].
Henshaw JM, Heithmar EM, Hinners TA. Inductively coupled plasma mass spectrometric determination of trace elements in surface waters subject to acidic deposition. Anal Chem. 1989;61:335-342.
*. Hernberg S, Westerholm P, Schultz-Larsen K, et al. Nasal and sinonasal cancer: Connection with occupational exposures in Denmark, Finland and Sweden. Scand J Work Environ Health. 1983;9:315-326. [pmid: 6635610].
Higgins TE, Halloran AR, Petura JC. Traditional and innovative treatment methods for Cr(VI) in soil. J Soil Contam. 1997;6(6):767-797.
Hill WJ, Ferguson WS. Statistical analysis of epidemiological data from a chromium chemical manufacturing plant. J Occup Med. 1979;21:103-106. [pmid: 430272].
Hjollund NHI, Bonde JPE, Hansen KS. Male-mediated risk of spontaneous abortion with reference to stainless steel welding. Scand J Work Environ Health. 1995;21:272-276. [pmid: 8553001].
Hoel DG, Davis DL, Miller AB, et al. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst. 1992;84(5):313-320. [pmid: 1738181].
Hojo Y, Satomi Y. In vivo nephrotoxicity induced in mice by chromium(VI): Involvement of glutathione and chromium(V). Biol Trace Elem Res. 1991;31:21-31. [pmid: 1724173].
Hojo Y, Nishiguchi K, Kawazoe S, et al. Comparison of susceptibility of liver and kidney to lipid peroxidation induction Cr(IV), Cr(V) and Cr(VI) compounds. J Health Sci. 1999;45(6):329-332.
Hojo Y, Nishiguchi K, Kawazoe S, et al. Enhancement of lipid peroxidation by chromium(IV) and chromium(V) is remarkable compared to that by chromium(VI) and is effectively suppressed by scavengers of reactive oxygen species. J Health Sci. 2000;46(2):75-80.
Holmes AL, Wise SS, Sandwick SJ, et al. The clastogenic effects of chronic exposure to particulate and soluble Cr(VI) in human lung cells. Mutat Res. 2006;610(1–2):8-13. [pmid: 16870495].
*. Hopkins LL. Distribution in the rat of physiological amounts of injected Cr^51^(III) with time. Am J Physiol. 1965;209:731-735. [pmid: 5891664].
*. Hopkins LL, Schwarz K. Chromium(III) binding to serum proteins, specifically siderophilin. Biochim Biophys Acta. 1964;90:484-491. [pmid: 14237857].
Hornig D. Distribution of ascorbic acid, metabolites and analogues in man and animals. Ann N Y Acad Sci. 1975;258:103-118. [pmid: 1106295].
Horowitz SB, Finley BL. Using human sweat to extract chromium from chromite ore processing residue: Applications to setting health-based cleanup levels. J Toxicol Environ Health. 1993;40:585-599. [pmid: 8277520].
HSDB. Chromium and chromium compounds. Hazardous Substances Data Bank. National Library of Medicine. 2012. http://toxnet.nlm.nih.gov/cgi-bin/sis/htmlgen?HSDB. May 30, 2012.
Hueper WC. Experimental studies in metal carcinogenesis. VII. Tissue reactions to parenterally introduced powdered metallic chromium and chromite ore. J Natl Cancer Inst. 1955;16:447-469. [pmid: 13263914].
Hueper WC. Experimental studies in metal carcinogenesis. Arch Ind Health. 1958;18:284-291.
Hueper WC, Payne WW. Experimental cancers in rats produced by chromium compounds and their significance to industry and public health. Ind Hyg J. 1959;20:274-280.
Hueper WC, Payne WW. Experimental studies in metal carcinogenesis. X. Cancerigenic effects of chromite ore roast deposited in muscle tissue and pleural cavity of rats. Arch Environ Health. 1962;5:51-68.
*. Hunter WC, Roberts JM. Experimental study of the effects of potassium bichromate on the monkey's kidney. Am J Pathol. 1932;9:133-147. [pmid: 19970054].
Hurlbut CS, editor. Dana's manual of mineralogy. 18th ed. New York, NY. John Wiley and Sons, Inc. 1971:346-347.
Husgafvel-Pursiainen K, Kalliomaki PL, Sorsa M. A chromosome study among stainless steel workers. J Occup Med. 1982;24:762-766. [pmid: 7143122].
Huvinen M, Makitie A, Jarventaus H, et al. Nasal cell micronuclei, cytology and clinical symptoms in stainless steel workers exposed to chromium. Mutagenesis. 2002b;17(5):425-429. [pmid: 12202631].
Huvinen M, Uitti J, Oksa P, et al. Respiratory health effects of long-term exposure to different chromium species in stainless steel production. Occup Med (Lond). 2002a;52(4):203-212. [pmid: 12091586].
Huvinen M, Uitti J, Zitting A, et al. Respiratory health of workers exposed to low levels of chromium in stainless steel production. Occup Environ Med. 1996;53:741-747. [pmid: 9038797].
Hyland JL, Snoots TR, Balthis WL. Sediment quality of estuaries in the southeastern U.S. Environ Monit Assess. 1998;51:331-343.
Hyodo K, Suzuki S, Furuya N, et al. An analysis of chromium, copper, and zinc in organs of a chromate worker. Int Arch Occup Environ Health. 1980;46:141-150. [pmid: 7399722].
IARC. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. Some metals and metallic compounds: Volume 23. Lyons, France. World Health Organization. 1980:205-323.
IARC. O'Neill IK, Schuller P, Fishbein L, editors. Selected methods of analysis: Some metals. Lyon, France. International Agency for Research on Cancer, World Health Organization. 1986a;Vol. 8:433-440. IARC Scientific Publications No. 71. 141-158; 291-317.
*. IARC. Sources of exposure and biological effects of chromium. International Agency for Research on Cancer. 1986b;(71):63-77. IARC Sci Publ.
IARC. IARC monographs on the evaluation of carcinogenic risks to humans. Chromium, nickel and welding. Lyons, France. International Agency for Research on Cancer, World Health Organization. 1990;Vol. 49:49-256.
IARC. Chromium, nickel and welding. Summary of data reported and evaluation. International Agency for Research on Cancer. World Health Organization. 1997;Vol 49. http://monographs.iarc.fr/ENG/Monographs/vol49/volume49.pdf May 02, 2008.
IARC. Agents reviewed by the IARC monographs: Volumes 1–99. Lyon, France. International Agency for Research on Cancer. 2008. http://monographs.iarc.fr/ENG/Classification/index.php. April 24, 2008.
Iarmarcovai G, Sari-Minodier I, Chaspoul F, et al. Risk assessment of welders using analysis of eight metals y ICP-MS in blood and urine and DNA damage evaluation by the comet and micronucleus assays; influence of XRCC1 and XRCC3 polymorphisms. Mutagenesis. 2005;20(6):425-432. [pmid: 16234265].
ICRP. Human respiratory tract model for radiological protection. Pergamon Press, Oxford. International Commission on Radiological Protection. 1994. ICRP publication 66.
ICSH. Recommended method for radioisotope red-cell survival studies. Br J Haematol. 1980;45(4):659-666. [pmid: 7426443].
Iijima S, Matsumoto N, Lu C. Transfer of chromic chloride to embryonic mice and changes in the embryonic mouse neuroepithelium. Toxicology. 1983;26:257-265. [pmid: 6857698].
IMC. Chromium. Industrial Minerals Corporation. 2007. http://www.industrialmineralscorp.com.au/index.php. May 21, 2008.
IOM. Chromium. Dietary reference intakes for vitamin A, vitamin K, arsenic, boron, chromium, copper, iodine, iron, manganese, molybdenum, nickel, silicon, vanadium, and zinc (2000). A Report of the Panel on Micronutrients, subcommittees on upper reference levels of nutrients and of interpretation and uses of dietary reference intakes, and the standing committee on the scientific evaluation of dietary reference intakes. Washington, DC. Food and Nutrition Board. Institute of Medicine. National Academy Press. 2001:197-223.
IPCS. Chromium hydroxide sulfate. ICSC: 1309. International chemical safety cards International Programme on Chemical Safety and the Commission of the European Communities. 2004. http://www.inchem.org/documents/icsc/icsc/eics1309.htm, May 30, 2012.
IRIS. Chromium. Integrated Risk Information System. Washington, DC. U.S. Environmental Protection Agency. 2008. http://www.epa.gov/iris/subst/index.html. May 14, 2008.
Iserson KV, Banner W, Froede RC, et al. Failure of dialysis therapy in potassium dichromate poisoning. J Emerg Med. 1983;1:143-149. [pmid: 6680130].
Ishikawa Y, Nakagawa K, Satoh Y, et al. Characteristics of chromate workers' cancers, chromium lung deposition and precancerous bronchial lesions: An autopsy study. Br J Cancer. 1994a;70(1):160-166. [pmid: 8018529].
Ishikawa Y, Nakagawa K, Satoh Y, et al. "Hot spots" of chromium accumulation at bifurcations of chromate workers' bronchi. Cancer Res. 1994b;54(9):2342-2346. [pmid: 8162579].
ISO. Workplace air-Determination of hexavalent chromium in airborne particulate matter-Method by ion chromatography and spectrophotometric measurement using diphenyl carbazide. International Organization for Standardization. 2005. http://www.iso.org/iso/iso_catalogue/catalogue_tc/catalogue_detail.htm?csnumber=30432. May 29, 2012.
Itoh S, Shimada H. Micronucleus induction by chromium and selenium, and suppression by metallothionein inducer. Mutat Res. 1996;367:233-236. [pmid: 8628330].
Itoh S, Shimada H. Clastogenicity and mutagenicity of hexavalent chromium in lacZ transgenic mice. Toxicol Lett. 1997;91:229-233. [pmid: 9217243].
Itoh S, Shimada H. Bone marrow and liver mutagenesis in lacZ transgenic mice treated with hexavalent chromium. Mutat Res. 1998;412:63-67. [pmid: 9508365].
Ivankovic S, Preussmann R. Absence of toxic and carcinogenic effects after administration of high doses of chromic oxide pigment in subacute and long-term feeding experiments in rats. Food Cosmet Toxicol. 1975;13:347-351. [pmid: 1158322].
Iyengar V, Woittiez J. Trace elements in human clinical specimens: Evaluation of literature data to identify reference values. Clin Chem. 1988;34(3):474-481. [pmid: 3280162].
Izzotti A, Bagnasco M, Camoirano A, et al. DNA fragmentation, DNA-protein crosslinks, 32P postlabeled nucleotide modifications, and 8-hydroxy-2'-deoxyguanosine in the lung but not in the liver of rats receiving intratracheal instillations of chromium(VI). Chemoprevention by oral N-acetylcysteine. Mutat Res. 1998;400:233-244. [pmid: 9685658].
Jacquamet L, Sun Y, Hatfield J, et al. Characterization of chromodulin by x-ray absorption and electron paramagnetic resonance spectroscopies and magnetic susceptibility measurements. J Am Chem Soc. 2003;125:774-780. [pmid: 12526678].
James BR, Petura JC, Vitale RJ, et al. Oxidation-reduction chemistry of chromium: Relevance to the regulation and remediation of chromate-contaminated soils. J Soil Contam. 1997;6(6):569-580.
Jansen LH, Berrens L. Sensitization and partial desensitization of guinea pigs to trivalent and hexavalent chromium. Dermatologica. 1968;137:65-73. [pmid: 5668250].
Jardine PM, Fendorf SE, Mayes MA, et al. Fate and transport of hexavalent chromium in undisturbed heterogeneous soil. Environ Sci Technol. 1999;33(17):2939-2944.
Jeejeebhoy KN. The role of chromium in nutrition and therapeutics and as a potential toxin. Nutr Rev. 1999;57(11):329-335. [pmid: 10628183].
Jeejeebhoy KN, Chu RC, Marliss EB, et al. Chromium deficiency, glucose intolerance, and neuropathy reversed by chromium supplementation in a patient receiving long-term total parenteral nutrition. Am J Clin Nutr. 1977;30:531-538. [pmid: 192066].
Jennette KW. Microsomal reduction of the carcinogen chromate produced chromium(V). J Am Chem Soc. 1982;104:874-875.
Jervis RE, Landsberger S, Aufreiter S, et al. Trace elements in wet atmospheric deposition: Application and comparison of PIXE, INAA, and graphite-furnace AAS techniques. Int J Environ Anal Chem. 1983;15:89-106.
Johanson CE. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res. 1980;190:3-16. [pmid: 6769537].
Johansson A, Robertson B, Curstedt, et al. Rabbit lung after inhalation of hexa- and trivalent chromium. Environ Res. 1986a;41:110-119. [pmid: 3757963].
Johansson A, Wiernik A, Jarstrand C, et al. Rabbit alveolar macrophages after inhalation of hexa- and trivalent chromium. Environ Res. 1986b;39:372-385. [pmid: 3956464].
Johnson J, Schewel L, Graedel TE. The contemporary anthropogenic chromium cycle. Environ Sci Technol. 2006;40:7060-7069. [pmid: 17154017].
Junaid M, Murthy RC, Saxena DK. Embryo- and fetotoxicity of chromium in pregestationally exposed mice. Bull Environ Contam Toxicol. 1996a;57:327-334. [pmid: 8661917].
Junaid M, Murthy RC, Saxena DK. Embryotoxicity of orally administered chromium in mice: Exposure during the period of organogenesis. Toxicol Lett. 1996b;84:143-148. [pmid: 8600613].
Kaaber K, Veien NK. The significance of chromate ingestion in patients allergic to chromate. Acta Derm Venereol. 1977;57:321-323. [pmid: 70924].
Kaats GR, Wise JA, Blum K, et al. The short-term therapeutic efficacy of beating obesity with a plan of improved nutrition and moderate calorie restriction. Curr Ther Res. 1992;51:261-274.
Kalahasthi R, Rao RHR, Krishna murthy RB, et al. Effect of chromium (VI) exposure on serum amylase activity in chromium plating workers. Environ Sci Indian J. 2007;2(1):1-6.
*. Kalliomaki PL, Aitio A, Hyvarinen HK, et al. Stern RM, editor. Lung clearance, transportation, and excretion of metals in rats after intratracheal instillation of activated welding fumes. International conference on health hazards and biological effects of welding fumes and gases, International Congress Series Vol. 676. New York, NY. Excepta Medica, Elsevier Science Publ. Co. 1986:345-348.
Kanematsu N, Hara M, Kada T. REC assay and mutagenicity studies on metal compounds. Mutat Res. 1980;77:109-116. [pmid: 6769036].
Kanojia RK, Junaid M, Murthy RC. Chromium induced teratogenicity in female rat. Toxicol Lett. 1996;89:207-213. [pmid: 9001589].
Kanojia RK, Junaid M, Murthy RC. Embryo and fetotoxicity of hexavalent chromium: A long-term study. Toxicol Lett. 1998;95:165-172. [pmid: 9704818].
Kaplan I, Zeligman I. Occupational dermatitis of railroad workers. Arch Dermatol. 1962;85:135-142.
Kargacin B, Squibb KS, Cosentino S, et al. Comparison of the uptake and distribution of chromate in rats and mice. Biol Trace Elem Res. 1993;36:307-318.
Katiyar S, Awasthi SK, Srivastava JK. Effect of chromium on the level of IL-12 and IFN-gamma in occupationally exposed workers. Sci Total Environ. 2009;407(6):1868-1874. [pmid: 19144391].
Kaufman DB, DiNicola W, McIntosh R. Acute potassium dichromate poisoning: Treated by peritoneal dialysis. Am J Dis Child. 1970;119:374-376. [pmid: 5434600].
Kaya B, Creus A, Velazquez A, et al. Genotoxicity is modulated by ascorbic acid studies using the wing spot test in Drosophila. Mutat Res. 2002;520:93-101. [pmid: 12297148].
Kelly WF, Ackrill P, Day JP, et al. Cutaneous absorption of trivalent chromium: Tissue levels and treatment by exchange transfusion. Br J Ind Med. 1982;39:397-400. [pmid: 7138799].
Kemsley J. Testing and treating for chromium. C&EN. 2011;89(14):34-35.
Kerger BD, Butler WJ, Paustenbach DJ, et al. Cancer mortality in Chinese populations surrounding an alloy plant with chromium smelting operations. J Toxicol Environ Health A. 2009;72(5):329-344. [pmid: 19184749].
Kerger BD, Finley BL, Corbett GE, et al. Ingestion of chromium(VI) in drinking water by human volunteers: Absorption, distribution, and excretion of single and repeated doses. J Toxicol Environ Health. 1997;50:67-95. [pmid: 9015133].
Kerger BD, Paustenbach DJ, Corbett GE, et al. Absorption and elimination of trivalent and hexavalent chromium in humans following ingestion of a bolus dose in drinking water. Toxicol Appl Pharmacol. 1996a;141:145-158. [pmid: 8917687].
Kerger BD, Richter RO, Chute SM, et al. Refined exposure assessment for ingestion of tapwater contaminated with hexavalent chromium: Consideration of exogenous and endogenous reducing agents. J Expo Anal Environ Epidemiol. 1996b;6(2):163-179. [pmid: 8792295].
Keskinen H, Kalliomaki P, Alanko K. Occupational asthma due to stainless steel welding fumes. Clin Allergy. 1980;10:151-159. [pmid: 7389069].
Kiilunen M, Järvisalo J, Mäkitie O, et al. Analysis, storage stability and reference values for urinary chromium and nickel. Int Arch Occup Environ Health. 1987;59:43-56. [pmid: 3793243].
Kiilunen M, Kivisto H, Ala-Laurila P, et al. Exceptional pharmacokinetics of trivalent chromium during occupational exposure to chromium lignosulfonate dust. Scand J Work Environ Health. 1983;9:265-271. [pmid: 6612268].
Kilburn KH, Warshaw R, Boylen CT, et al. Cross-shift and chronic effects of stainless-steel welding related to internal dosimetry of chromium and nickel. Am J Ind Med. 1990;17:607-615. [pmid: 2337084].
Kim G, Yurkow EJ. Chromium induces a persistent activation of mitogen-activated protein kinases by a redox-sensitive mechanism in H4 rat hepatoma cells. Cancer Res. 1996;56:2045-2051. [pmid: 8616849].
Kim HY, Lee SB, Jang BS. Subchronic inhalation toxicity of soluble hexavalent chromium trioxide in rats. Arch Toxicol. 2004;78:363-368. [pmid: 15205887].
Kimberly MM, Paschal DC. Screening for selected toxic elements in urine by sequential-scanning inductively-coupled plasma atomic emission spectrometry. Anal Chim Acta. 1985;174:203-210.
Kimbrough DE, Cohen Y, Winer AM, et al. A critical assessment of chromium in the environment. Crit Rev Environ Sci. 1999;29(1):1-46.
King LD. Retention of metals by several soils of the southeastern United States. J Environ Qual. 1988;17(2):239-246.
Kirpnick-Sobol Z, Reliene R, Schiestl RH. Carcinogenic Cr(VI) and the nutritional supplement Cr(III) induce DNA deletions in yeast and mice. Cancer Res. 2006;66(7):3480-3484. [pmid: 16585171].
Kitamura F, Yokoyama K, Araki S, et al. Increase of olfactory threshold in plating factory workers exposed to chromium in Korea. Ind Health. 2003;41(3):279-285. [pmid: 12916760].
Klein LA, Lang M, Nash N, et al. Sources of metals in New York City wastewater. J Water Pollut Control Fed. 1974;46(12):2653-2662. [pmid: 4436915].
Kleiner AM, Stolbun BM, Likhacheva YI, et al. [Indices of the functional status of the myocardium and hemodynamics in chronic occupational poisoning with chromium compounds.]. Gig Tr Prof Zabol. 1970;14:7-10. (Russian). [pmid: 5515459].
Kleinfeld M, Rosso A. Ulcerations of the nasal septum due to inhalation of chromic acid mist. Ind Med Surg. 1965;24:242-243. [pmid: 14279052].
Kollmeier H, Seemann J, Rothe G, et al. Age, sex, and region adjusted concentrations of chromium and nickel in lung tissue. Br J Ind Med. 1990;47:682-687. [pmid: 2223660].
Komori K, Toda K, Ohtake H. Effects of oxygen stress on chromate reduction in Enterobacter cloacae strain HO1. J Ferment Bioeng. 1990a;69(1):67-69.
Komori M, Nishio K, Kitada M, et al. Fetus-specific expression of a form of cytochrome P-450 in human liver. Biochemistry. 1990b;29:4430-4433. [pmid: 2350547].
Korallus U. Serrone DM, editor. Biological activity of chromium(VI) - against chromium(III) compounds: New aspects of biological monitoring. Chromium symposium 1986: An update. Pittsburgh, PA. Industrial Health Foundation Inc. 1986a:210-230.
Korallus U. Chromium compounds: Occupational health, toxicological and biological monitoring aspects. Toxicol Environ Chem. 1986b;12:47-59.
Korallus U, Ehrlicher H, Wustefeld E. [Trivalent chromium compounds. Results of a study in occupational medicine. Part 2. Disease status analysis.]. Arb Soz Prev. 1974b;9:76-79. (German).
Korallus U, Harzdorf C, Lewalter J. Experimental bases for ascorbic acid therapy of poisoning by hexavalent chromium compounds. Int Arch Occup Environ Health. 1984;53:247-256. [pmid: 6706420].
Korallus U, Ehrlicher H, Wustefeld E, et al. [Trivalent chromium compounds - results of a study in occupational medicine.]. Arb Soz Prev. 1974a;9:51-54. (German).
Korallus U, Lange H, Neiss A, et al. Relationships between hygienic measures and the bronchial carcinoma mortality in the chromate producing industry. Arb Soz Prev. 1982;17:159-167.
Kornhauser C, Wrobel K, Wrobel K, et al. Possible adverse effect of chromium in occupational exposure of tannery workers. Ind Health. 2002;40(2):207-213. [pmid: 12064563].
*. Kortenkamp A, Casadevall M, Faux SP, et al. A role for molecular oxygen in the formation of DNA damage during the reduction of the carcinogen chromium(VI) by glutathione. Arch Biochem Biophys. 1996a;329(2):199-207. [pmid: 8638952].
Kortenkamp A, Casadevall M, Fresco PDC. The reductive conversion of the carcinogen chromium(VI) and its role in the formation of DNA lesions. Ann Clin Lab Sci. 1996b;26(2):160-175. [pmid: 8852426].
Koshi K. Effects of fume particles from stainless steel welding on sister chromatid exchanges and chromosome aberrations in cultured Chinese hamster cells. Ind Health. 1979;17:39-49.
Koshi K, Iwasaki K. Solubility of low-solubility chromates and their clastogenic activity in cultured cells. Ind Health. 1983;21:57-65. [pmid: 6684105].
Koshi K, Yagami T, Nakanishi Y. Cytogenetic analysis of peripheral blood lymphocytes from stainless steel welders. Ind Health. 1984;22:305-318. [pmid: 6526704].
Kowalski LA, Tsang SS, Davison AJ. Arsenic and chromium enhance transformation of bovine papillomavirus DNA-transfected C3H/10T1/2 cells. Cancer Lett. 1996;103:65-69. [pmid: 8616810].
Krishnan K, Andersen ME. Hayes W, editor. Physiologically-based pharmacokinetic modeling in toxicology. Principles and methods of toxicology. 3rd edition. New York, NY. Raven Press, Ltd. 1994:149-188.
Krishnan K, Andersen ME, Clewell HJ, et al. Yang RSA, editor. Physiologically-based pharmacokinetic modeling of chemical mixtures. Toxicology of chemical mixtures. New York, NY. Academic Press. 1994:399-437.
Krull IS, Panaro KW, Gershman LL. Trace analysis and speciation for Cr(VI) and Cr(III) via HPLC-direct current plasma emission spectroscopy (HPLC-DCP). J Chromatogr Sci. 1983;21:460-472.
Kumar A, Rana SVS. Lipid accumulation in chromium-poisoned rats. Int J Tissue React. 1982;4(4):291-295. [pmid: 7169300].
Kumar A, Rana SVS. Enzymological effects of hexavalent chromium in the rat kidney. Int J Tissue React. 1984;6(2):135-139. [pmid: 6329979].
Kumar A, Rana SVS, Prakash R. Dysenzymuria induced by hexavalent chromium. Int J Tissue React. 1985;7(4):333-338. [pmid: 2999022].
Kumar S, Sathwara NG, Gautam AK, et al. Semen quality of industrial workers occupationally exposed to chromium. J Occup Health. 2005;47(5):424-430. [pmid: 16230836].
Kumpulainen J. Vercruysse A, editor. Chromium. Techniques and instrumentation in analytical chemistry. Vol. 4. Evaluation of analytical methods in biological systems. Part B: Hazardous metals in human toxicology. Amsterdam, The Netherlands. Elsevier Science Publishers. 1984:253-277.
Kumpulainen JT, Wolf WR, Veillon C, et al. Determination of chromium in selected United States diets. J Agric Food Chem. 1979;27(3):490-494. [pmid: 447922].
Kuo HW, Wu ML. Effects of chromic acid exposure on immunological parameters among electroplating workers. Int Arch Occup Environ Health. 2002;75(3):186-190. [pmid: 11954986].
Kuo HW, Lai JS, Lin TI. Nasal septum lesions and lung function in workers exposed to chromic acid in electroplating factories. Int Arch Occup Environ Health. 1997a;70:272-276. [pmid: 9342628].
*. Kuo HW, Lai JS, Lin TI. Concentration and size distribution of airborne hexavalent chromium in electroplating factories. Am Ind Hyg Assoc J. 1997b;58:29-32. [pmid: 9018834].
Kuykendall JR, Kerger BD, Jarvi EJ, et al. Measurement of DNA-protein cross-links in human leukocytes following acute ingestion of chromium in drinking water. Carcinogenesis. 1996;17(9):1971-1977. [pmid: 8824522].
*. Laborda R, Diaz-Mayans J, Nunez A. Nephrotoxic and hepatotoxic effects of chromium compound in rats. Bull Environ Contam Toxicol. 1986;36:332-336. [pmid: 3955242].
Lai JS, Kuo HW, Liao FC, et al. Sister chromatid exchange induced by chromium compounds in human lymphocytes. Int Arch Occup Environ Health. 1998;71:550-5532. [pmid: 9860164].
Landsberger S, Jervis RE, Kajrys G, et al. Characterization of trace elemental pollutants in urban snow using proton induced X-ray emission and instrumental neutron activation analysis. Int J Environ Anal Chem. 1983;16:95-130.
Langård S. A survey of respiratory symptoms and lung function in ferrochromium and ferrosilicon workers. Int Arch Occup Environ Health. 1980;46:1-9. [pmid: 7380569].
Langård S, Norseth T. A cohort study of bronchial carcinomas in workers producing chromate pigments. Br J Ind Med. 1975;32:62-65. [pmid: 164880].
Langård S, Vigander T. Occurrence of lung cancer in workers in producing chromium pigments. Br J Ind Med. 1983;40:71-74. [pmid: 6824603].
Langård S, Andersen A, Gylseth B. Incidence of cancer among ferrochromium and ferrosilicon workers. Br J Ind Med. 1980;37:114-120. [pmid: 7426461].
Langård S, Andersen A, Ravnestad J. Incidence of cancer among ferrochromium and ferrosilicon workers: An extended observation period. Br J Ind Med. 1990;47:14-19. [pmid: 2310703].
Langård S, Gundersen N, Tsalev DL, et al. Whole blood chromium level and chromium excretion in the rat after zinc chromate inhalation. Acta Pharmacol Toxicol. 1978;42:142-149.
Laskin S, Kuschner M, Drew RT. Hanna MG, Nettesheim P, Gilbert JR, editors. Studies in pulmonary carcinogenesis. Inhalation carcinogenesis. U.S. Atomic Energy Commission symposium series no. 18. Oak Ridge, TN. Division of Technical Information Extension, U.S. Atomic Energy Commission. 1970:321-351.
LaVelle JM. Chromium(VI) comutagenesis: Characterization of the interaction of K_2_CrO_4_ with azide. Environ Mutagen. 1986a;87:717-725. [pmid: 3533528].
LaVelle JM. Potassium chromate potentiates frameshift mutagenesis in Ecoli and S. Styphimurium. Mutat Res. 1986b;171:1-10. [pmid: 3523229].
Le Curieux F, Marzin D, Erb F. Genotoxic activity of three carcinogens in peripheral blood erythrocytes of the newt Pleurodeles waltl. Mutat Res. 1992;283:157-160. [pmid: 1383782].
Lee HS, Goh CL. Occupational dermatosis among chrome platers. Contact Dermatitis. 1988;18:89-93. [pmid: 2966707].
Lee KP, Ulrich CE, Geil RG, et al. Inhalation toxicity of chromium dioxide dust to rats after two years exposure. Sci Total Environ. 1989;86:83-108. [pmid: 2602942].
Lee NA, Reasner CA. Beneficial effect of chromium supplementation on serum triglyceride levels in NIDDM. Diabetes Care. 1994;17(12):1449-1452. [pmid: 7882815].
Leeder JS, Kearns GL. Pharmacogenetics in pediatrics: Implications for practice. Pediat Clin North Am. 1997;44:55-77.
Leikin JB, Paloucek FP, editors. Leikin and Paloucek's poisoning and toxicology handbook. 3rd ed. Hudson, OH. Lexi-Comp, Inc. 2002:372-379.
Leroyer C, Dewitte JD, Bassanets A, et al. Occupational asthma due to chromium. Respiration. 1998;65:403-405. [pmid: 9782225].
Letterer E. [Examination of a chromium-silicotic lung.] Arch Gewerbepatnol Gewerbe Hyg 9 498–508. [Abstract]. J Ind Hyg Toxicol. 1939;21:215-216. (German).
Leung H. Ballantine B, Marro T, Turner T, editors. Physiologically-based pharmacokinetic modeling. General and applied toxicology. New York, NY. Stockton Press. 1993;Vol. I:153-164.
Levin HM, Brunner MJ, Rattner H. Lithographer's dermatitis. J Am Med Assoc. 1959;169:566-569. [pmid: 13620505].
Levina A, Lay PA. Mechanistic studies of relevance to the biological activities of chromium. Coord Chem Rev. 2005;249(3–4):281-298.
Levine RA, Streeten DHP, Doisy RJ, et al. Effects of oral chromium supplementation on the glucose tolerance of elderly human subjects. Metabolism. 1968;17:114-125. [pmid: 5641744].
Levis AG, Majone F. Cytotoxic and clastogenic effects of soluble chromium compounds on mammalian cell cultures. Br J Cancer. 1979;40:523-533. [pmid: 497104].
Levy LS, Martin PA, Bidstrup PL. Investigation of the potential carcinogenicity of a range of chromium containing materials on rat lung. Br J Ind Med. 1986;43:243-256. [pmid: 3964573].
Lewalter J, Korallus U, Harzdorf C, et al. Chromium bond detection in isolated erythrocytes: A new principle of biological monitoring of exposure to hexavalent chromium. Int Arch Occup Environ Health. 1985;55:305-318. [pmid: 4008055].
Li H, Chen Q, Li S, et al. Effect of Cr(VI) exposure on sperm quality: Human and animal studies. Ann Occup Hyg. 2001;45(7):505-511. [pmid: 11583652].
Li Y, Xu X, Liu J, et al. The hazard of chromium exposure to neonates in Guiyu of China. Sci Total Environ. 2008;403(1–3):99-104. [pmid: 18603282].
Li Chen T, Lacerte C, Wise SS, et al. Comparative cytotoxicity and genotoxicity of particulate and soluble hexavalent chromium in human and sperm whale (Physeter macrocephalus) skin cells. Comp Biochem Physiol C Toxicol Pharmacol. 2012;155(1):143-150. [pmid: 21466859].
Li Chen T, Wise SS, Holmes A, et al. Cytotoxicity and genotoxicity of hexavalent chromium in human and North Atlantic right whale (Eubalaena glacialis) lung cells. Comp Biochem Physiol C Toxicol Pharmacol. 2009;150(4):487-494. [pmid: 19632355].
Lide DR. Lide DR, editor. Chromium. CRC handbook of chemistry and physics. 79th ed. Boca Raton, FL. CRC Press. 1998:4-8.
Liden S, Lundberg E. Penetration of chromium in intact human skin in vivo. J Invest Dermatol. 1979;72:42-45. [pmid: 762448].
Lieber M, Perlmutter NM, Frauenthal HL. Cadmium and hexavalent chromium in Nassau County groundwater. J Am Water Works Assoc. 1964;56:739-747.
Lieberman H. Chrome ulcerations of the nose and throat. New Engl J Med. 1941;225:132-133.
Lim TH, Sargent T, Kusubov N. Kinetics of trace element chromium(III) in the human body. Am J Physiol. 1983;244(4):445-454.
Lin CC, Wu ML, Yang CC, et al. Acute severe chromium poisoning after dermal exposure to hexavalent chromium. J Chin Med Assoc. 2009;72(4):219-221. [pmid: 19372081].
Lin KY, Chang BV, Wang Y-S. Mobility of copper, zinc and chromium with municipal solid waste leachate in soils. Proc Natl Sci Counc Repub China B. 1996;20(1):19-25.
Lin X, Zhuang Z, Costa M. Analysis of residual amino acid-DNA crosslinks induced in intact cells by nickel and chromium compounds. Carcinogenesis. 1992;3(10):1763-1768. [pmid: 1423835].
Lindberg E, Hedenstierna G. Chrome plating: Symptoms, findings in the upper airways, and effects on lung function. Arch Environ Health. 1983;38:367-374. [pmid: 6667038].
Lindberg E, Vesterberg O. Monitoring exposure to chromic acid in chromeplating by measuring chromium in urine. Scand J Work Environ Health. 1983a;9:333-340. [pmid: 6605579].
Lindberg E, Vesterberg O. Urinary excretion of proteins in chromeplaters, exchromeplaters and referents. Scand J Work Environ Health. 1983b;9:505-510. [pmid: 6369528].
Linos A, Petralias A, Christophi CA, et al. Oral ingestion of hexavalent chromium through drinking water and cancer mortality in an industrial area of Greece--an ecological study. Environ Health. 2011;10:50. http://www.ehjournal.net/content/pdf/1476-069X-10-50.pdf. October 20, 2011. [pmid: 21609468].
Little MC, Gawkrodger DJ, Macneil S. Chromium- and nickel-induced cytotoxicity in normal and transformed human keratinocytes: An investigation of pharmacological approaches to the prevention of Cr(VI)-induced cytotoxicity. Br J Dermatol. 1996;134:199-207. [pmid: 8746330].
Littorin M, Welinder H, Hultberg B. Kidney function in stainless steel welders. Int Arch Occup Environ Health. 1984;53:279-282. [pmid: 6706422].
Littorin M, Hogstedt B, Stromback B, et al. No cytogenetic effects in lymphocytes of stainless steel welders. Scand J Work Environ Health. 1983;9:259-264. [pmid: 6612267].
Liu JK, Morris JS. Relative chromium response as an indicator of chromium status. Am J Clin Nutr. 1978;31:972-976. [pmid: 665555].
Liu KJ, Shi X. In vivo reduction of chromium (VI) and its related free radical generation. Mol Cell Biochem. 2001;222:41-47. [pmid: 11678610].
Liu CS, Kuo HW, Lai JS, et al. Urinary N-acetyl-B-glucosaminidase as an indicator of renal dysfunction in electroplating workers. Int Arch Occup Environ Health. 1998;71:348-352. [pmid: 9749974].
Liu KJ, Shi X, Dalal NS. Synthesis of Cr(IV)-GSH, its identification and its free hydroxyl radical generation: A model compound for Cr(VI) carcinogenicity. Biochem Biophys Res Commun. 1997b;235:54-58. [pmid: 9196034].
Liu KJ, Jiang J, Swartz HM, et al. Low-frequency EPR detection of chromium(V) formation by chromium(VI) reduction in whole live mice. Arch Biochem Biophys. 1994;313(2):248-252. [pmid: 8080269].
Liu KJ, Mäder K, Shi X, et al. Reduction of carcinogenic chromium(VI) on the skin of living rats. MRM. 1997a;38:524-526.
Liu KJ, Shi X, Jiang JJ, et al. Chromate-induced chromium(V) formation in live mice and its control by cellular antioxidants: An L-band electron paramagnetic resonance study. Arch Biochem Biophys. 1995;323(1):33-39. [pmid: 7487070].
Livingston AL. Forage plant estrogens. J Toxicol Environ Health. 1978;4:301-324. [pmid: 351201].
Llagostera M, Garrido S, Guerrero R, et al. Induction of SOS genes of Escherichia coli by chromium compounds. Environ Mutagen. 1986;8:571-577. [pmid: 3525136].
Lo FB, Arai DK. Determination by atomic spectrometry of chromium on air sampling filters in the presence of iron. Am Ind Hyg Assoc J. 1988;49(5):207-212.
Lockman LE. Case report: Allergic contact dermatitis and new-onset asthma. Can Fam Physician. 2002;48:1907-1909. [pmid: 12520790].
Loubieres Y, de Lassence A, Bernier M, et al. Acute, fatal, oral chromic acid poisoning. J Toxicol Clin Toxicol. 1999;37(3):333-336. [pmid: 10384798].
Lovrincevic I, Leung FY, Alfieri MAH, et al. Can elevated chromium induce somatopsychic responses?. Biol Trace Elem Res. 1996;55:163-171. [pmid: 8971363].
Loyaux-Lawniczak S, Lecomte P, Ehrhardt J. Behavior of hexavalent chromium in a polluted groundwater: Redox Processes and immobilization in soils. Environ Sci Technol. 2001;35:1350-1357. [pmid: 11348066].
Lucas JB, Kramkowski RS. Health hazard evaluation determination report number 74-87-221. Cincinnati, OH. U.S. Department of Health, Education, and Welfare, Center for Disease Control, National Institute for Occupational Safety and Health. 1975.
Luippold RS, Mundt KA, Austin RP, et al. Lung cancer mortality among chromate production workers. Occup Environ Med. 2003;60(6):451-457. [pmid: 12771398].
Lukanova A, Toniolo P, Zhitkovich A, et al. Occupational exposure to Cr(VI): Comparison between chromium levels in lymphocytes, erythrocytes, and urine. Int Arch Occup Environ Health. 1996;69:39-44. [pmid: 9017433].
Lukaski HC, Bolonchuk WW, Siders WA, et al. Chromium supplementation and resistance training: Effects on body composition, strength, and trace element status of men. Am J Clin Nutr. 1996;63:954-965. [pmid: 8644693].
Luo H, Lu Y, Shi X, et al. Chromium(IV)-mediated Fenton-like reaction causes DNA damage: Implication to genotoxicity of chromate. Ann Clin Lab Sci. 1996;26(2):185-191. [pmid: 8852428].
Machle W, Gregorius F. Cancer of the respiratory system in the United States chromate-producing industry. Public Health Rep. 1948;63:114-127.
MacKenzie RD, Byerrum RU, Decker CF, et al. Chronic toxicity studies: II. Hexavalent and trivalent chromium administered in drinking water to rats. Arch Ind Health. 1958;18:232-234.
MacRae WD, Whiting RF, Stich HF. Sister chromatid exchanges induced in cultured mammalian cells by chromate. Chem Biol Interact. 1979;26:281-286. [pmid: 509691].
Maiti B, Desai SR. High-performance liquid chromatographic separation of beryllium, cobalt, nickel and chromium as the β-isopropyltropolone complexes and its application to the determination of chromium in air samples. Analyst. 1986;111:809-811.
Majone F, Levis AG. Chromosomal aberrations and sister-chromatid exchanges in Chinese hamster cells treated in vitro with hexavalent chromium compounds. Mutat Res. 1979;67:231-238. [pmid: 481449].
Major RH. Studies on a case of chromic acid nephritis. Johns Hopkins Hosp Bull. 1922;33:56-61.
Mali JW, Malten K, Van Neer FCJ. Allergy to chromium. Arch Dermatol. 1966;93:41-44. [pmid: 5900699].
Mali JWH, Van Kooten WJ, VanNeer FCJ. Some aspects of the behavior of chromium compounds in the skin. J Invest Dermatol. 1963;41:111-122. [pmid: 14062640].
Malinski T, Fish J, Matusiewicz H. Determining ultratrace metal concentrations by inductively coupled plasma emission spectrometry. Am Water Works Assoc J. 1988;80:81-85.
Malm O, Pfeiffer WC, Fiszman M, et al. Transport and availability of heavy metals in the Paraiba Do Sul-Guandu river system, Rio de Janiero State, Brazil. Sci Total Environ. 1988;75:201-209.
Malsch PA, Proctor DM, Finley BL. Estimation of chromium inhalation reference concentration using the benchmark dose method: A case study. Regul Toxicol Pharmacol. 1994;20:58-82. [pmid: 7838992].
Mancuso TF. Occupational cancer and other health hazards in a chromate plant: A medical appraisal: II. Clinical and toxicologic aspects. Ind Med Surg. 1951;20:393-407. [pmid: 14860912].
Mancuso TF. Hutchinson TC, editor. Consideration of chromium as an industrial carcinogen. Proceedings of the international conference on heavy metals in the environment. Toronto, Canada. Toronto Institute for Environmental Studies. 1975:343-356.
Mancuso TF. Chromium as an industrial carcinogen: Part I. Am J Ind Med. 1997a;31:129-139. [pmid: 9028428].
Mancuso TF. Chromium as an industrial carcinogen: Part II. Chromium in human tissues. Am J Ind Med. 1997b;31:140-147. [pmid: 9028429].
Mancuso TF, Hueper WC. Occupational cancer and other health hazards in a chromate plant: A medical appraisal: I. Lung cancers in chromate workers. Ind Med Surg. 1951;20:358-363. [pmid: 14850165].
Manning FCR, Xu J, Patierno SR. Transcriptional inhibition by carcinogenic chromate: Relationship to DNA damage. Mol Carcinog. 1992;6:270-279. [pmid: 1283064].
Manygoats KR, Yazzie M, Stearns DM. Ultrastructural damage in chromium picolinate-treated cells: A TEM study. J Biol Inorg Chem. 2002;7:791-798. [pmid: 12203015].
Manzo L, Di Nucci A, Edel J, et al. Biliary and gastrointestinal excretion of chromium after administration of Cr-III and Cr-VI in rats. Res Commun Chem Pathol Pharmacol. 1983;42(1):113-125. [pmid: 6648036].
Mao Y, Zang L, Shi X. Generation of free radicals by Cr(IV) from lipid hydroperoxides and its inhibition by chelators. Biochem Mol Biol Int. 1995;36(2):327-337. [pmid: 7663436].
Martin WR, Fuller RE. Suspected chromium picolinate-induced rhabdomyolysis. Pharmacotherapy. 1998;18(4):860-862. [pmid: 9692662].
Maruyama Y. The health effect of mice given oral administration of trivalent and hexavalent chromium over a long-term. Acta Scholae Medicinalis Universitatis in Gifu. 1982;31:24-46.
*. Mason RW, Edwards IR. Acute toxicity of combinations of sodium dichromate, sodium arsenate and copper sulphate in the rat. Comp Biochem Physiol 93C. 1989:121-125.
Mathur AK. Effects of dermal application of chromium and linear alkylbenzene sulphonate alone and in combination in guinea pigs. Toxicol Int. 2005;12(1):9-12.
*. Mathur AK, Chandra SV, Tandon SK. Comparative toxicity of trivalent and hexavalent chromium to rabbits: II. Morphological changes in some organs. Toxicology. 1977;8:53-61. [pmid: 929618].
Matsui S. Evaluation of a Bacillus subtilis rec-assay for the detection of mutagens which may occur in water environments. Water Res. 1980;14:1613-1619.
Matsumoto N, Iijima S, Katsunuma H. Placental transfer of chromic chloride and its teratogenic potential in embryonic mice. J Toxicol Sci. 1976;2(2):1-13.
Mattagajasingh SN, Misra HP. Mechanisms of the carcinogenic chromium(VI)-induced DNA-protein cross-linking and their characterization in cultured intact human cells. J Biol Chem. 1996;271(52):33550-33560. [pmid: 8969221].
Mayr U, Butsch A, Schneider S. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology. 1992;74:135-149. [pmid: 1387742].
McAughey JJ, Samuel AM, Baxter PJ, et al. Biological monitoring of occupational exposure in the chromate pigment production industry. Sci Total Environ. 1988;71:317-322. [pmid: 3406704].
McShane WJ, Steven Pappas R, Paschal D. Analysis of total arsenic, total selenium and total chromium in urine by inductively coupled plasma-dynamic reaction cell-mass spectrometry. J Anal At Spectrom. 2007;22(6):630-635.
Medeiros MG, Rodrigues AS, Batoreu MC, et al. Elevated levels of DNA-protein crosslinks and micronuclei in peripheral lymphocytes of tannery workers exposed to trivalent chromium. Mutagenesis. 2003a;18(1):19-24. [pmid: 12473731].
Medeiros MG, Rodrigues AS, Batoreu MC, et al. Cebulska-Wasilewska A, Au WW, Sram RJ, editors. Biomarkers of chromium exposure and cytogenetic damage in leather tanning and welding industry workers. Human monitoring for genetic effects. Washington, DC. IOS Press. 2003b:132-141.
Meranger JC, Subramanian KS, Chalifoux C. A national survey for cadmium, chromium, copper, lead, zinc, calcium and magnesium in Canadian drinking water supplies. Environ Sci Technol. 1979;13(6):707-711.
Merian E. Introduction on environmental chemistry and global cycles of chromium, nickel, cobalt, beryllium, arsenic, cadmium and selenium, and their derivatives. Toxicol Environ Chem. 1984;8:9-38.
Merkur'eva RV, Koganova ZI, Gabdullina MK, et al. [Comparison of metabolic reactions in the bodies of experimental animals exposed to hexavalent chromium with different paths of penetration]. Gig Sanit. 1982;8:75-76. (Russian). [pmid: 7129154].
*. Merritt K, Crowe TD, Brown SA. Elimination of nickel, cobalt, and chromium following repeated injections of high dose metal salts. J Biomed Mater Res. 1989;23:845-862. [pmid: 2777829].
Mertz W. Chromium occurrence and function in biological systems. Physiol Rev. 1969;49(2):163-239. [pmid: 4888391].
Mertz W, Roginski EE, Feldman FJ, et al. Dependence of chromium transfer into the rat embryo on the chemical form. J Nutr. 1969;99:363-367. [pmid: 5350992].
Messer J, Reynolds M, Stoddard L, et al. Causes of DNA single-strand breaks during reduction of chromate by glutathione in vitro and in cells. Free Radic Biol Med. 2006;40(11):1981-1992. [pmid: 16716899].
Meyers JB. Acute pulmonary complications following inhalation of chromic acid mist. Ann Ind Hyg Occup Med. 1950;2:742-747.
Michel R, Loer F, Nolte M, et al. Neutron activation analysis of human tissues, organs and body fluids to describe the interaction of orthopaedic implants made of cobalt-chromium alloy with the patients organisms. J Radioanal Nucl Chem. 1987;113(1):83-96.
Mignini F, Streccioni V, Baldo M, et al. Individual susceptibility to hexavalent chromium of workers of shoe, hide, and leather industries. Immunological pattern of HLA-B8,DR3-positive subjects. Prev Med. 2004;39(4):767-775.
Mignini F, Tomassoni D, Traini E, et al. Immunological pattern alteration in shoe, hide, and leather industry workers exposed to hexavalent chromium. Environ Toxicol. 2009;24(6):594-602. [pmid: 19051261].
Mikalsen A, Alexander J, Andersen RA, et al. Reduction of hexavalent chromium in a reconstituted system of cytochrome P-450 and cytochrome b_5_. Chem Biol Interact. 1989;71:213-221. [pmid: 2598298].
Mikalsen SO. Effects of heavy metal ions on intercellular communication in Syrian hamster embryo cells. Carcinogenesis. 1990;11(9):1621-1626. [pmid: 2401052].
Milford JB, Davidson CI. The sizes of particulate trace elements in the atmosphere — a review. J Air Pollut Control Assoc. 1985;35:1249-1260. [pmid: 3910700].
Milingou M, Tagka A, Armenaka M, et al. Patch tests in children: A review of 13 years of experience in comparison with previous data. Pediatr Dermatol. 2010;27(3):255-259. [pmid: 20609142].
Miller CA, Cohen MD, Costa M. Complexing of actin and other nuclear proteins to DNA by cisdiamminedichloroplatinum(II) and chromium compounds. Carcinogenesis. 1991;12(2):269-276. [pmid: 1995193].
Milosev I, Pisot V, Campbell P. Serum levels of cobalt and chromium in patients with Sikomet metal-metal total hip replacements. J Orthop Res. 2005;23(3):526-535. [pmid: 15885471].
Minoia C, Cavalleri A. Chromium in urine, serum and red blood cells in the biological monitoring of workers exposed to different chromium valency states. Sci Total Environ. 1988;71:323-327. [pmid: 3406705].
Mirsalis JC, Hamilton CM, O'Loughlin KG, et al. Chromium(VI) at plausible drinking water concentrations is not genotoxic in the in vivo bone marrow micronucleus or liver unscheduled DNA synthesis assays. Environ Mol Mutagen. 1996;28:60-63. [pmid: 8698048].
Mohamedshah FY, Moser-Veillon PB, Yamini S, et al. Distribution of a stable isotope of chromium (53Cr) in serum, urine, and breast milk in lactating women. Am J Clin Nutr. 1998;67:1250-1255. [pmid: 9625101].
Moller DR, Brooks SM, Bernstein DI, et al. Delayed anaphylactoid reaction in a worker exposed to chromium. J Allergy Clin Immunol. 1986;77(3):451-456. [pmid: 2936792].
Molyneux MJ, Davies MJ. Direct evidence for hydroxyl radical-induced damage to nucleic acids by chromium(VI)-derived species: Implications for chromium carcinogenesis. Carcinogenesis. 1995;16(4):875-882. [pmid: 7537182].
Montaldi A, Zentilin L, Zordan M, et al. Chromosomal effects of heavy metals (Cd, Cr, Hg, Ni and Pb) on cultured mammalian cells in the presence of nitrilotriacetic acid (NTA). Toxicol Environ Chem. 1987;14:183-200.
Mor S, Ben-Efraim S, Leibovici J, et al. Successful contact sensitization to chromate in mice. Int Arch Allergy Appl Immunol. 1988;85:452-457. [pmid: 3356475].
Morris B, MacNeil S, Fraser R, et al. Increased urine chromium excretion in normal pregnancy. Clin Chem. 1995b;41(10):1544-1545. [pmid: 7586539].
*. Morris BW, Gray T, MacNeil S. Evidence for chromium acting as an essential trace element in insulin-dependent glucose uptake in cultured mouse myotubes. J Endocrinol. 1995a;144:135-141. [pmid: 7891015].
Morselli PL, Franco-Morselli R, Bossi L. Clinical pharmacokinetics in newborns and infants. Clin Pharmacokin. 1980;5:485-527.
Moschandreas DJ, Karuchit S, Berry MR, et al. Exposure apportionment: Ranking food items by their contribution to dietary exposure. J Expo Anal Environ Epidemiol. 2002;12:233-243. [pmid: 12087429].
Moulin JJ, Wild P, Mantout B, et al. Mortality from lung cancer and cardiovascular diseases among stainless-steel producing workers. Cancer Causes Control. 1993;4:75-81. [pmid: 8386949].
Moxon AL, DuBois KP. The influence of arsenic and certain other elements on the toxicity of seleniferous grains. J Nutr. 1939;18:447-457.
Mudroch A, Sarazin L, Lomas T. Report: Summary of surface and background concentrations of selected elements in the Great Lakes sediments. J Great Lakes Res. 1988;14(2):241-251.
Munch D. Concentration profiles of arsenic, cadmium, chromium, copper, lead, mercury, nickel, zinc, vanadium and polynuclear aromatic hydrocarbons (PAH) in forest soil beside an urban road. Sci Total Environ. 1993;138:47-55.
Mundt KA, Dell LD. Carcinogenicity of trivalent and hexavalent chromium. OEM Report. 1997;11(11):95-100.
Murthy RC, Junaid M, Saxena DK. Ovarian dysfunction in mice following chromium (VI) exposure. Toxicol Lett. 1996;89:147-154. [pmid: 8960157].
*. Murthy RC, Saxena DK, Gupta SK, et al. Ultrastructural observations in testicular tissue or chromium-treated rats. Reprod Toxicol. 1991;5:443-447. [pmid: 1806154].
Muttamara S, Leong ST. Health implication among occupational exposed workers in a chromium alloy factory, Thailand. J Environ Sci. 2004;16(2):181-186.
Mutti A, Cavatorta A, Borghi L, et al. Distribution and urinary excretion of chromium: Studies on rats after administration of single and repeated doses of potassium dichromate. Med Lav. 1979;3:171-179. [pmid: 470819].
Mutti A, Lucertini S, Valcavi P, et al. Urinary excretion of brush-border antigen revealed by monoclonal antibody: Early indicator of toxic nephropathy. Lancet. 1985a;2(8461):914-917. [pmid: 2865419].
Mutti A, Pedroni C, Arfini G, et al. Merian E, Frei RW, Hardi W, et al., editors. Biological monitoring of occupational exposure to different chromium compounds at various valency states. Carcinogenic and mutagenic metal compounds: Environmental and analytical chemistry and biological effects. London. Gordon and Breach Science Publishers. 1985b:119-125.
Myers CR, Myers JM. Iron stimulates the rate of reduction of hexavalent chromium by human microsomes. Carcinogenesis. 1998;19(6):1029-1038. [pmid: 9667741].
Nadig RJ. Goldfrank LR, Weisman RS, Flomenbaum NE, et al., editors. Cadmium and other metals and metalloids. Goldfrank's toxicologic emergencies. 5th ed. Norwalk, CT. Appleton and Lange. 1994:1063-1069.
Nagaya T. No increase in sister-chromatid exchange frequency in lymphocytes of chromium platers. Mutat Res. 1986;170:129-132. [pmid: 3713723].
Nagaya T, Ishikawa N, Hata H, et al. Sister-chromatid exchanges in lymphocytes from 12 chromium platers: A 5-year follow-up study. Toxicol Lett. 1991;58:329-335. [pmid: 1957328].
Nakamura S, Oda Y, Shimada T, et al. SOS-inducing activity of chemical carcinogens and mutagens in Salmonella typhimurium TA1535/pSK1002: Examination with 151 chemicals. Mutat Res. 1987;192:239-246. [pmid: 3317033].
Nakamuro K, Yoshikawa K, Sayato Y, et al. Comparative studies of chromosomal aberration and mutagenicity of trivalent and hexavalent chromium. Mutat Res. 1978;58:175-181. [pmid: 745615].
NAS/NRC. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC. National Academy Press. 1989:15-35.
Nestmann ER, Matula TI, Douglas GR, et al. Detection of the mutagenic activity of lead chromate using a battery of microbial tests. Mutat Res. 1979;66:357-365. [pmid: 379631].
Nethercott J, Paustenbach D, Adams R, et al. A study of chromium induced allergic contact dermatitis with 54 volunteers: Implications for environmental risk assessment. Occup Environ Med. 1994;51:371-380. [pmid: 8044228].
Nettesheim P, Szakal AK. Morphogenesis of alveolar bronchiolization. Lab Invest. 1972;26(2):210-219. [pmid: 5059985].
Nettesheim P, Hanna MG, Doherty DG, et al. Effect of calcium chromate dust, influenza virus, and 100 R whole-body X-radiation on lung tumor incidence in mice. J Natl Cancer Inst. 1971;47(5):1129-1144. [pmid: 10787327].
Newbold RF, Amos J, Connell JR. The cytotoxic, mutagenic and clastogenic effects of chromium-containing compounds on mammalian cells in culture. Mutat Res. 1979;67:55-63. [pmid: 460294].
Newhouse ML. A cause of chromate dermatitis among assemblers in an automobile factory. Br J Ind Med. 1963;20:199-203. [pmid: 14046156].
NIOSH. National occupation exposure survey. Cincinnati, OH. U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health. 1989. March 29, 1989.
NIOSH. NIOSH recommendations for occupational safety and health. Compendium of Policy Documents and Statements. Categories of Pesticides. Atlanta, GA. National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. 1992. http://www.cdc.gov/niosh/92-100.html. April 29, 2008.
NIOSH. Elements in blood or tissue. Method: 8005. NIOSH manual of analytical methods. 4th ed. Cincinnati, OH. Department of Health and Human Services, National Institute of Occupational Safety and Health. 1994a. DHHS publication no. 94-113.
NIOSH. Metals in urine. Method: 8310. NIOSH manual of analytical methods. 4th ed. Cincinnati, OH. Department of Health and Human Services, National Institute of Occupational Safety and Health. 1994b. DHHS publication no. 94-113.
NIOSH. Chromium and chromium compounds, as Cr. Method: 7024. NIOSH manual of analytical methods. 4th ed. Cincinnati, OH. Department of Health and Human Services, National Institute of Occupational Safety and Health. 1994c. DHHS publication no. 94-113.
NIOSH. Elements by ICP. Method: 7300. NIOSH manual of analytical methods. 4th ed. Cincinnati, OH. Department of Health and Human Services, National Institute of Occupational Safety and Health. 1994d. DHHS publication no. 94-113.
NIOSH. Method 7605. Chromium, hexavalent by ion chromatography. NIOSH manual of analytical methods. National Institute for Occupational Safety and Health. 2003a. http://www.cdc.gov/niosh/docs/2003-154/pdfs/7605.pdf. May 29, 2012.
NIOSH. Method 7703. Chromium, hexavalent, by field-portable spectrophotometry. NIOSH manual of analytical methods. National Institute for Occupational Safety and Health. 2003b. http://www.cdc.gov/niosh/docs/2003-154/pdfs/7703.pdf. May 29, 2012.
NIOSH. Chromium. NIOSH pocket guide to chemical hazards. Atlanta, GA. National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. 2005. http://www.cdc.gov/niosh/npg/, April 24, 2008.
NIOSH. International chemical safety cards. U.S. national Version. National Institute for Occupational Safety and Health. 2008. http://www.cdc.gov/niosh/ipcsneng/neng0029.html. May 22, 2008.
Nishioka H. Mutagenic activities of metal compounds in bacteria. Mutat Res. 1975;31:185-189. [pmid: 805366].
*. Nomiyama K, Nomiyama H, Yotoriyama M. Low-molecular-weight proteins in urine from rabbits given nephrotoxic compounds. Ind Health. 1982;20:1-10. [pmid: 7068446].
Norseth T. The carcinogenicity of chromium and its salts. Br J Ind Med. 1986;43:649-651. [pmid: 3778833].
Norseth T, Alexander J, Aaseth J, et al. Biliary excretion of chromium in the rat: A role of glutathione. Acta Pharmacol Toxicol. 1982;51:450-455.
Novey HS, Habib M, Wells ID. Asthma and IgE antibodies induced by chromium and nickel salts. J Allergy Clin Immunol. 1983;72(4):407-412. [pmid: 6413567].
NRC. Pesticides in the diets of infants and children. Washington DC. National Academy Press, National Research Council. 1993.
NRCC. Effects of chromium in the Canadian environment. Ottawa, Canada. Subcommittee on Heavy Metals and Certain Other Compounds, National Research Council of Canada. 1976:92.
Nriagu JO. Nriagu JO, editor. Copper in the atmosphere and precipitation. Copper environment. New York, NY. John Wiley and Sons. 1979:43-75.
Nriagu JO, Pacyna JM. Quantitative assessment of worldwide contamination of air, water and soils by trace metals. Nature. 1988;333:134-139. [pmid: 3285219].
NTP. Final report on the reproductive toxicity of potassium dichromate (hexavalent) (CAS No. 7778-50-9) administered in diet to SD rats. National Institute of Environmental Health Sciences, National Toxicology Program. 1996a. PB97125355.
NTP. Final report on the reproductive toxicity of potassium dichromate (hexavalent) (CAS No. 7778-50-9) administered in diet to BALB/c mice. National Institute of Environmental Health Sciences, National Toxicology Program. 1996b. PB97125363.
NTP. Final report on the reproductive toxicity of potassium dichromate (CAS No. 7778-50-9) administered in diet to BALB/c mice. National Institute of Environmental Health Sciences, National Toxicology Program. 1997. PB97144919.
NTP. Report on carcinogens. 11th ed. Research Triangle Park, NC. U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. 2005. http://ntpserver.niehs.nih.gov/ntp/roc/toc11.html April 24, 2008.
NTP. NTP technical report on the toxicity studies of sodium dichromate dihydrate (CAS No. 7789-12-0) administered in drinking water to male and female F344/N rats and B6C3F1 mice and male BALB/c and am3-C57BL/6 mice. Toxicity Report Series Number 72. Washington, DC. National Toxicology Program. 2007. http://ntp.niehs.nih.gov/ntp/htdocs/ST_rpts/TOX72.pdf. October 7, 2008.
NTP. NTP technical report on the toxicology and carcinogenesis studies of sodium dichromate dihydrate (CAS No. 7789-12-0) in F344/N rats and B6C3F1 mice (drinking water studies). Washington, DC. National Toxicology Program. 2008a. NTP TR 546. http://ntp.niehs.nih.gov/files/546_web_FINAL.pdf. August 13, 2008.
NTP. NTP technical report on the toxicology and carcinogenesis studies of chromium picolinate monohydrate (CAS No. 27882-76-4)) in F344/N rats and B6C3F1 mice (feed studies). Washington, DC. National Toxicology Program. 2008b. Scheduled peer review date: February 27-28, 2008. NTP TR 556. http://ntp.niehs.nih.gov/files/TR556board_webRev.pdf. May 21, 2008.
O’Brien TJ, Brooks BR, Patierno SR. Nucleotide excision repair functions in the removal of chromium-induced DNA damage in mammalian cells. Mol Cell Biochem. 2005;279:85-95. [pmid: 16283517].
O’Brien TJ, Ceryak S, Patierno SR. Complexities of chromium carcinogenesis: Role of cellular response, repair and recovery mechanisms. Mutat Res. 2003;533(1–2):3-36. [pmid: 14643411].
Offenbacher EG, Pi-Sunyer FX. Beneficial effect of chromium-rich yeast on glucose tolerance and blood lipids in elderly subjects. Diabetes. 1980;29:919-925. [pmid: 7000589].
O’Flaherty EJ. Physiologically based models for bone-seeking elements. IV. Kinetics of lead disposition in humans. Toxicol Appl Pharmacol. 1993c;118:16-29. [pmid: 8430422].
O’Flaherty EJ. Physiologically based models for bone-seeking elementsVLead absorption and disposition in childhood. Toxicol Appl Pharmacol. 1995;131:297-308. [pmid: 7716770].
O’Flaherty EJ. A physiologically based model of chromium kinetics in the rat. Toxicol Appl Pharmacol. 1996;138:54-64. [pmid: 8658513].
O’Flaherty EJ, Kerger BD, Hays SM, et al. A physiologically based model for the ingestion of chromium(III) and chromium(VI) by humans. Toxicol Sci. 2001;60:196-213. [pmid: 11248132].
Ohanian EV. Health effects of corrosion products in drinking water. Trace Subst Environ Health. 1986;20:122-138.
O’Hara KA, Klei LR, Barchowsky A. Selective activation of Src family kinases and JNK by low levels of chromium(VI). Toxicol Appl Pharmacol. 2003;190(3):214-223. [pmid: 12902192].
O’Hara KA, Vaghjiani RJ, Nemec AA, et al. Cr(VI)-stimulated STAT3 tyrosine phosphorylation and nuclear translocation in human airway epithelial cells requires Lck. Biochem J. 2007;402(2):261-269. [pmid: 17078813].
Ohno H, Hanaoka F, Yamada MA. Inducibility of sister-chromatid exchanges by heavy-metal ions. Mutat Res. 1982;104:141-145. [pmid: 7078567].
Ohsaki Y, Abe S, Kimura K, et al. Lung cancer in Japanese chromate workers. Thorax. 1978;33:372-374. [pmid: 684674].
Okubo T, Tsuchiya K. An epidemiological study on lung cancer among chromium plating workers. Keio J Med. 1977;26:171-177. [pmid: 616469].
Okubo T, Tsuchiya K. Epidemiological study of chromium platers in Japan. Biol Trace Elem Res. 1979;1:35-44.
Olaguibel JM, Basomba A. Occupational asthma induced by chromium salts. Allergol Immunopathol (Madr). 1989;17(3):133-136. [pmid: 2816656].
Olivier P, Marzin D. Study of the genotoxic potential of 48 inorganic derivatives with the SOS chromotest. Mutat Res. 1987;189:263-269. [pmid: 3118206].
Olmedo P, Pla A, Hernandez AF, et al. Validation of a method to quantify chromium, cadmium, manganese, nickel and lead in human whole blood, urine, saliva and hair samples by electrothermal atomic absorption spectrometry. Anal Chim Acta. 2010;659(1–2):60-67. [pmid: 20103106].
Olvera O, Zimmering S, Arceo C, et al. The protective effects of chlorophyllin in treatment with chromium(VI) oxide in somatic cells of Drosophila. Mutat Res. 1993;301:201-204. [pmid: 7679204].
O'Neil MJ, Heckelman PE, Koch CB, et al., editors. The Merck index. 14th ed. Whitehouse Station, NJ. Merck & Co. Inc. 2006:370-372.
OSHA. Air contaminants; final rule. U.S. Department of Labor. Occupational Safety and Health Administration. Fed Regist. 1998a;54:2930.
*. OSHA. Industry group seeks updated data on hex chrome exposure. Occupational Safety and Health Administration. Inside OSHA. 1998b. August 24, 1998.
OSHA. Air contaminants, Occupational Safety and Health Administration. Code of Federal Regulations. 2007a. 29 CFR 1910.1000, Table Z 1 http://www.osha.gov/comp-links.html. April 24, 2008.
*. OSHA. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. 2007b. Code of Federal Regulations. 29 CFR 1926.55, Appendix A. http://www.osha.gov/comp-links.html. April 24, 2008.
*. OSHA. Limits for air contaminants. Occupational Safety and Health Administration. 2007c. Code of Federal Regulations. 29 CFR 1915.1000. http://www.osha.gov/comp-links.html. April 24, 2008.
OSHA. Chromium (VI). Occupational Safety and Health Administration. 2007d. Code of Federal Regulations. 29 CFR 1910.26. http://edocket.access.gpo.gov/cfr_2007/julqtr/pdf/29cfr1910.1026.pdf. October 07, 2008.
OSHA. 2007e. Chromium (VI). Code of Federal Regulations. Occupational Safety and Health Administration. 29 CFR 1915.1026. http://edocket.access.gpo.gov/cfr_2007/julqtr/pdf/29cfr1915.1026.pdf. October 07, 2008.
OSHA. Safety and health regulations for construction. Chromium (VI). Occupational Safety and Health Administration. 2007f. Code of Federal Regulations. 29 CFR 1926.1126. http://edocket.access.gpo.gov/cfr_2007/julqtr/pdf/29cfr1926.1126.pdf. October 07, 2008.
Osim EE, Tandayi M, Chinyanga HM, et al. Lung function, blood gases, pH and serum electrolytes of small-scale miners exposed to chrome ore dust on the Great Dyke in Zimbabwe. Trop Med Int Health. 1999;4(9):621-628. [pmid: 10540303].
OTA. Neurotoxicology: Identifying and controlling poisons of the nervous system. Washington, DC. Office of Technology Assessment. 1990. OTA-BA-438.
Owen GM, Brozek J. Falkner F, editor. Influence of age, sex, and nutrition on body composition during childhood and adolescence. Human development. Philadelphia, PA. Saunders. 1966:222-238.
Oygard JK, Mage A, Gjengedal E. Estimation of the mass-balance of selected metals in four sanitary landfills in Western Norway, with emphasis on the heavy metal content of the deposited waste and the leachate. Water Res. 2004;38:2851-2858. [pmid: 15223279].
Pacyna JM, Ottar B. Transport and chemical composition of the summer aerosol in the Norwegian Arctic. Atmos Environ. 1985;19(12):2109-2120.
Pacyna JM, Pacyna EG. An assessment of global and regional emissions of trace metals to the atmosphere from anthropogenic sources worldwide. Environ Rev. 2001;9(4):269-298.
Papp JF, Lipin BR. Chromium and chromium alloys. Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons, Inc. 2001:468-526. http://mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/chrowest.a01/current/pdf. May 21, 2008.
Park RM, Stayner LT. A search for thresholds and other nonlinearities in the relationship between hexavalent chromium and lung cancer. Risk Anal. 2006;26(1):79-88. [pmid: 16492182].
Park RM, Bena JF, Stayner LT, et al. Hexavalent chromium and lung cancer in the chromate industry: A quantitative risk assessment. Risk Anal. 2004;24(5):1099-1108. [pmid: 15563281].
Parks JL, McNeill L, Frey M, et al. Determination of total chromium in environmental water samples. Water Res. 2004;38(12):2827-2838. [pmid: 15223276].
Partington CN. Acute poisoning with potassium bichromate. Br Med J. 1950;2(4688):1097-1098. [pmid: 14772558].
Pascale LR, Waldstein SS, Engbring G, et al. Chromium intoxication with special reference to hepatic injury. J Am Med Assoc. 1952;149:1385-1389. [pmid: 14938189].
Paschin YV, Zacepilova TA, Kozchenko VI. Induction of dominant lethal mutations in male mice by potassium dichromate. Mutat Res. 1982;103:345-347. [pmid: 7087995].
Pastides H, Austin R, Lemeshow S, et al. A retrospective-cohort study of occupational exposure to hexavalent chromium. Am J Ind Med. 1994;25:663-675. [pmid: 8030637].
Pattison DI, Davies MJ, Levina A, et al. Chromium(VI) reduction by catechol(amine)s results in DNA cleavage in vitro: Relevance to chromium genotoxicity. Chem Res Toxicol. 2001;14(5):500-510. [pmid: 11368547].
Paustenbach DJ, Finley BL, Mowat FS, et al. Human health risk and exposure assessment of chromium(VI) in tap water. J Toxicol Environ Health A. 2003;66(14):1295-1339. [pmid: 12851114].
Paustenbach DJ, Hays SM, Brien BA, et al. Observation of steady state in blood and urine following human ingestion of hexavalent chromium in drinking water. J Toxicol Environ Health. 1996;49:453-461. [pmid: 8968407].
Paustenbach DJ, Panko JM, Fredrick MM, et al. Urinary chromium as a biological marker of environmental exposure: What are the limitations?. Regul Toxicol Pharmacol. 1997;26:S23-S34. [pmid: 9380834].
Paustenbach DJ, Sheehan PJ, Paull JM, et al. Review of the allergic contact dermatitis hazard posed by chromium-contaminated soil: Identifying a "safe" concentration. J Toxicol Environ Health. 1992;37:177-207. [pmid: 1522610].
*. Payne WW. Production of cancers in mice and rats by chromium compounds. Arch Ind Health. 1960;21:530-535.
Pellerin C, Booker SM. Reflections on hexavalent chromium. Health hazards of an industrial heavyweight. Environ Health Perspect. 2000;108(9):A402-A407. [pmid: 11017901].
Peltonen L, Fraki J. Prevalence of dichromate sensitivity. Contact Dermatitis. 1983;9:190-194. [pmid: 6222873].
Perrault G, Dufresne A, Strati G, et al. Physico-chemical fate of chromium compounds in the sheep lung model. J Toxicol Environ Health. 1995;44:247-262. [pmid: 7853424].
Petit A, Mwale F, Zukor DJ, et al. Effect of cobalt and chromium ions on bcl-2, bax, caspase-3, and caspase-8 expression in human U937 macrophages. Biomaterials. 2004;25(11):2013-2018. [pmid: 14741615].
Petrilli FL, De Flora S. Oxidation of inactive trivalent chromium to the mutagenic hexavalent form. Mutat Res. 1978b;58:167-173. [pmid: 370569].
Petrilli FL, Camoirano A, Bennicelli C, et al. Specificity and inducibility of the metabolic reduction of chromium(VI) mutagenicity by subcellular fractions of rat tissues. Cancer Res. 1985;45:3179-3187. [pmid: 4005851].
Petrilli FL, Romano M, Bennicelli C, et al. Serrone DM, editor. Metabolic reduction and detoxification of hexavalent chromium. Chromium symposium 1986: An update. Pittsburgh, PA. Industrial Health Foundation Inc. 1986a:112-130.
Petrilli FL, Rossi GA, Camoirano A, et al. Metabolic reduction of chromium by alveolar macrophages and its relationships to cigarette smoke. J Clin Invest. 1986b;77:1917-1924. [pmid: 2423559].
Petruzzelli G, Lubrano L, Cervelli S. Heavy metal uptake by wheat seedlings grown in fly ash-amended soils. Water Air Soil Pollut. 1987;32:389-395.
PHS. Health of workers in chromate producing industry: A study. Washington, DC. U.S. Public Health Service. 1953. Publication no. 192.
Pilliere F, Levy F, Renier A, et al. Induction of DNA-repair synthesis (UDS) in rat pleural mesothelial cells by urine of subjects exposed to genotoxic agents. Clin Toxicol. 1992;30(2):223-238.
Pippard EC, Acheson ED, Winter PD. Mortality of tanners. Br J Ind Med. 1985;42:285-287. [pmid: 3978050].
Pi-Sunyer F, Offenbacher EG. Chromium. Present knowledge in nutrition. 5th ed. Washington, DC. The Nutrition Foundation, Inc. 1984:571-586.
Plantz MR, Fritz JS, Smith FG, et al. Separation of trace metal complexes for analysis of samples of high salt content by inductively coupled plasma mass spectrometry. Anal Chem. 1989;61:149-153.
Polprasert C, Charnpratheep K. Heavy metal removal in attached-growth waste stabilization ponds. Water Research. 1989;23(5):625-632.
Powers WJ, Gad SC, Siino KM, et al. Serrone DM, editor. Effects of therapeutic agents on chromium-induced acute nephrotoxicity. Chromium symposium 1986: An update. Pittsburgh, PA. Industrial Health Foundation, Inc. 1986:79-86.
Pratt PF, Myers CR. Enzymatic reduction of chromium(VI) by human hepatic microsomes. Carcinogenesis. 1993;14(10):2051-2057. [pmid: 8222053].
Press RI, Geller J, Evans GW. The effect of chromium picolinate on serum cholesterol and apolipoprotein fractions in human subjects. West J Med. 1990;152:41-45. [pmid: 2408233].
Price JW. Elevated chromium levels and prosthetic joint implants. J Am Osteopath Assoc. 2011;111(9):548-550. [pmid: 21955535].
Proctor DM, Fredrick MM, Scott PK, et al. The prevalence of chromium allergy in the United States and its implications for setting soil cleanup: A cost-effectiveness case study. Regul Toxicol Pharmacol. 1998;28:27-37. [pmid: 9784430].
Proctor DM, Otani JM, Finley BL, et al. Is hexavalent chromium carcinogenic via ingestion? A weight-of-evidence review. J Toxicol Environ Health A. 2002;65(10):701-746. [pmid: 12028825].
Proctor DM, Suh M, Aylward LL, et al. Hexavalent chromium reduction kinetics in rodent stomach contents. Chemosphere [Epub ahead of print]. 2012.
Pulido MD, Parrish AR. Metal-induced apoptosis: Mechanisms. Mutat Res. 2003;533:227-241. [pmid: 14643423].
Qi W, Reiter RJ, Tan DX, et al. Chromium(III)-induced 8-hydroxydeoxyguanosine in DNA and its reduction by antioxidants: Comparative effects of melatonin, ascorbate, and vitamin E. Environ Health Perspect. 2000;108(5):399-402. (Comment in: Environ Health Perspect 109(6):A250). [pmid: 10811565].
Qi WB, Zhu LZ. Spectrophotometric determination of chromium in waste water and soil. Talanta. 1986;33(8):694-696. [pmid: 18964170].
Quievryn G, Goulart M, Messer J, et al. Reduction of Cr (VI) by cysteine: Significance in human lymphocytes and formation of DNA damage in reactions with variable reduction rates. Mol Cell Biochem. 2001;222(1–2):107-118. [pmid: 11678591].
Quinteros FA, Poliandri AHB, Machiavelli LI, et al. In vivo and in vitro effects of chromium VI on anterior pituitary hormone release and cell viability. Toxicol Appl Pharmacol. 2007;218:79-87. [pmid: 17141818].
Radivojevic S, Cooper PA. Extraction of hexavalent chromium from chromated copper arsenate treated wood under alkaline conditions. Environ Sci Technol. 2008;42:3739-3744. [pmid: 18546716].
Rafael AI, Almeida A, Santos P, et al. A role for transforming growth factor-beta apoptotic signaling pathway in liver injury induced by ingestion of water contaminated with high levels of Cr(VI). Toxicol Appl Pharmacol. 2007;224:163-173. [pmid: 17692352].
Raffetto G, Parodi S, Parodi C, et al. Direct interaction with cellular targets as the mechanism for chromium carcinogenesis. Tumori. 1977;63:503-512. [pmid: 601880].
*. Rafnsson V, Johannesdottir SG. Mortality among masons in Iceland. Br J Ind Med. 1986;43:522-525. [pmid: 3637113].
Raithel HJ, Ebner G, Schaller KH. Problems in establishing norm values for nickel and chromium concentrations in human pulmonary tissue. Am J Ind Med. 1987;12:55-70. [pmid: 3618600].
Ramelow GJ, Maples RS, Thompson RL, et al. Periphyton as monitors for heavy metal pollution in the Calcasieu River estuary. Environ Pollut. 1987;43:247-263. [pmid: 15092788].
Ramelow GJ, Webre CL, Mueller CS, et al. Variations of heavy metals and arsenic in fish and other organisms from the Calcasieu River and Lake, Louisiana. Arch Environ Contam Toxicol. 1989;18:804-818. [pmid: 2619321].
Randall JA, Gibson RS. Serum and urine chromium as indices of chromium status in tannery workers. Proc Soc Exp Biol Med. 1987;185:16-23. [pmid: 3575326].
Randall JA, Gibson RS. Hair chromium as an index of chromium exposure to tannery workers. Br J Ind Med. 1989;46:171-175. [pmid: 2930727].
Rao MV, Parekh SS, Chawla SL. Vitamin-E supplementation ameliorates chromium-and/or nickel induced oxidative stress in vivo. J Health Sci. 2006;52(2):142-147.
Räsänen L, Sainio H, Lehto M, et al. Lymphocyte proliferation test as a diagnostic aid in chromium contact sensitivity. Contact Dermatitis. 1991;25:25-29. [pmid: 1834411].
Rasmuson A. Mutagenic effects of some water-soluble metal compounds in a somatic eye-color test system in Drosophila melanogaster. Mutat Res. 1985;157:157-162. [pmid: 3927160].
Reddy KR, Chinthamreddy S. Electrokinetic remediation of heavy metal-contaminated soils under reducing environments. Waste Manag. 1999;19:269-282.
Reichelderfer TE. Accidental death of an infant caused by ingestion of ammonium dichromate. South Med J. 1968;61:96-97.
Reynolds M, Zhitkovich A. Cellular vitamin C increases chromate toxicity via a death program requiring mismatch repair but not p53. Carcinogenesis. 2007;28(7):1613-1620. [pmid: 17301063].
Rhodes MC, Hebert CD, Herbert RA, et al. Absence of toxic effects in F344/N rats and B6C3F1 mice following subchronic administration of chromium picolinate monohydrate. Food Chem Toxicol. 2005;43(1):21-29. [pmid: 15582192].
Richelmi P, Baldi C, Minoia C. Blood levels of hexavalent chromium in rats. in vitro and in vivo experiments. Int J Environ Anal Chem. 1984;17(3–4):181-186. [pmid: 6746187].
Riedel GF, Sanders JG. Trace element speciation and behavior in the tidal Delaware River. Estuaries. 1998;21(1):78-90.
Rifkin E, Gwinn P, Bouwer E. Chromium and sediment toxicity. Environ Sci Technol. 2004;38(14):267A-271A.
Robson M. Methodologies for assessing exposures to metals: Human host factors. Ecotoxicol Environ Saf. 2003;56:104-109. [pmid: 12915144].
Rodriguez-Arnaiz R, Martinez RFM. Genetic effects of potassium dichromate and chromium trioxide in Drosophila melanogaster. Cytologia. 1986;51:421-425.
Roe FJC, Carter RL. Chromium carcinogenesis: Calcium chromate as a potent carcinogen for the subcutaneous tissues of the rat. Br J Cancer. 1969;23:172-176. [pmid: 5768433].
Roginski EE, Mertz W. Effects of chromium(III) supplementation on glucose and amino acid metabolism in rats fed a low protein diet. J Nutr. 1969;97:525-530. [pmid: 5779850].
Rosas I, Belmont R, Baez A, et al. Some aspects of the environmental exposure to chromium residues in Mexico. Water Air Soil Pollut. 1989;48:463-476.
Rosenman KD, Stanbury M. Risk of lung cancer among former chromium smelter workers. Am J Ind Med. 1996;29:491-500. [pmid: 8732922].
Roto P, Sainio H, Reunala T, et al. Addition of ferrous sulfate to cement and risk of chromium dermatitis among construction workers. Contact Dermatitis. 1996;34:43-50. [pmid: 8789225].
Royle H. Toxicity of chromic acid in the chromium plating industry (1). Environ Res. 1975a;10:39-53. [pmid: 1175579].
Royle H. Toxicity of chromic acid in the chromium plating industry (2). Environ Res. 1975b;10:141-163. [pmid: 1175577].
Rubin MA, Miller JP, Ryan AS, et al. Acute and chronic resistive exercise increase urinary chromium excretion in men as measured with an enriched chromium stable isotope. J Nutr. 1998;128:73-78. [pmid: 9430605].
Russo P, Catassi A, Cesario A, et al. Molecular mechanisms of hexavalent chromium-induced apoptosis in human bronchoalveolar cells. Am J Respir Cell Mol Biol. 2005;33(6):589-600. [pmid: 16166740].
Sahuquillo A, Rigol A, Rauret G. Overview of the use of leaching/extraction tests for risk assessment of trace metals in contaminated soils and sediments. TrAC Trends Anal Chem. 2003;22(3):152-159.
Saleh FY, Parkerton TF, Lewis RV, et al. Kinetics of chromium transformations in the environment. Sci Total Environ. 1989;86:25-41. [pmid: 2602935].
Salnikow K, Zhitkovich A. Genetic and epigenetic mechanisms in metal carcinogenesis and cocarcinogenesis: Nickel, arsenic, and chromium. Chem Res Toxicol. 2008;21(1):28-44. [pmid: 17970581].
Saltzman BE, Cholak J, Schafer LJ, et al. Concentration of six metals in the air of eight cities. Environ Sci Technol. 1985;19:328-333. [pmid: 22283344].
Samitz MH. Ascorbic acid in the prevention and treatment of toxic effects from chromates. Acta Derm Venereol. 1970;50:59-64. [pmid: 4191890].
Samitz MH, Epstein E. Experimental cutaneous chrome ulcers in guinea pigs. Arch Environ Health. 1962;5:69-74.
Samitz MH, Shrager J. Patch test reactions to hexavalent and trivalent chromium compounds. Arch Dermatol. 1966;94:304-306. [pmid: 4951811].
*. Samitz MH, Gross S, Katz S. Inactivation of chromium ion in allergic eczematous dermatitis. J Invest Dermatol. 1962;38:5-12. [pmid: 14496608].
Samuel JB, Stanley JA, Roopha DP, et al. Lactational hexavalent chromium exposure-induced oxidative stress in rat uterus is associated with delayed puberty and impaired gonadotropin levels. Hum Exp Toxicol. 2011;30(2):91-101. [pmid: 20203132].
*. Sander JK, Camp CD. Chromium poisoning in infancy. Am J Med Sci. 1939;198:551-554.
Saner G, Yuzbasiyan V, Cigdem S. Hair chromium concentration and chromium excretion in tannery workers. Br J Ind Med. 1984;41:263-266. [pmid: 6372853].
*. Sargent T, Lim TH, Jenson R. Reduced chromium retention in patients with hemochromatosis, a possible basis of hemochromatotic diabetes. Metabolism. 1979;28:70-79. [pmid: 104124].
Sarkar D, Sharma A, Talukder G. Differential protection of chlorophyllin against clastogenic effects of chromium and chlordane in mouse bone marrow in vivo. Mutat Res. 1993;301:33-38. [pmid: 7677941].
Sarto F, Levis AG, Paulon C. Clastogenic activity of hexavalent and trivalent chromium in cultured human lymphocytes. Caryologia. 1980;33:239-250.
Sarto F, Cominato I, Bianchi V, et al. Increased incidence of chromosomal aberrations and sister chromatid exchanges in workers exposed to chromic acid (CrO_3_) in electroplating factories. Carcinogenesis. 1982;3(9):1011-1016. [pmid: 7139855].
Saryan LA, Reedy M. Chromium determinations in a case of chromic acid ingestion. J Anal Toxicol. 1988;12:162-164. [pmid: 3386214].
Sassi C. [Occupational pathology in a chromate plant.]. Med Lav. 1956;47(5):314-327. (Italian). [pmid: 13347567].
Sata F, Araki S, Murata K, et al. Behavior of heavy metals in human urine and blood following calcium disodium ethylenediamine tetraacetate injection: Observations in metal workers. J Toxicol Environ Health, A. 1998;54(3):167-178. [pmid: 9643870].
Sathwara NG, Patel KG, Vyas JB, et al. Chromium exposure study in chemical based industry. J Environ Biol. 2007;28(2):405-408. [pmid: 17929757].
Satoh K, Fukuda Y, Torrii K, et al. Epidemiological study of workers engaged in the manufacture of chromium compounds. J Occup Med. 1981;23(12):835-838.
Satoh N, Fukuda S, Takizawa M, et al. Chromium-induced carcinoma in the nasal region. A report of four cases. Rhinology. 1994;32:47-50. [pmid: 8029624].
Sawatari K. Sampling filters and dissolution methods for differential determination of water-soluble chromium(VI) and chromium(III) in particulate substances. Ind Health. 1986;24:111-116. [pmid: 3759509].
Saxena DK, Murthy RC, Jain VK, et al. Fetoplacental-maternal uptake of hexavalent chromium administered orally in rats and mice. Bull Environ Contam Toxicol. 1990a;45:430-435. [pmid: 2257339].
Sayato Y, Nakamuro K, Matsui S, et al. Metabolic fate of chromium compounds. I. Comparative behavior of chromium in rat administered with Na_2_^51^CrO_4_ and ^51^CrCl_3_. J Pharm Dyn. 1980;3:17-23.
Schaller H, Neeb R. Gas-chromatographic elemental analysis via di(trifluoroethyl)dithiocarbamato-3 chelates X. Capillary gas chromatography at the pg-level determination of Co and Cr[VI] besides Cr[III] in river water. Fresenius Z. Anal. Chem. 1987;327:170-174.
Schmidt JA, Andren AW. Deposition of airborne metals into the Great Lakes: An evaluation of past and present estimates. Adv Environ Sci Technol. 1984;14:81-103.
Schonwald S. Dart RC, editor. Chromium. Medical toxicology. 3rd ed. Philadelphia, PA. Lippicott Williams & Wilkins. 2004:415-1417.
Schroeder HA, Balassa JJ, Tipton IH. Abnormal trace metals in man: Chromium. J Chron Dis. 1962;15:941-964. [pmid: 13987070].
Schroeder HA, Balassa JJ, Vinton WH. Chromium, lead, cadmium, nickel and titanium in mice: Effect on mortality, tumors and tissue levels. J Nutr. 1964;83:239-250. [pmid: 14191424].
Schroeder HA, Balassa JJ, Vinton WH. Chromium, cadmium and lead in rats: Effects on life span, tumors and tissue levels. J Nutr. 1965;86:51-66. [pmid: 14291684].
*. Schroeder HA, Vinton WH, Balassa JJ. Effect of chromium, cadmium and other trace metals on the growth and survival of mice. J Nutr. 1963;80:39-47. [pmid: 13987072].
Schroeder WH, Dobson M, Kane DM, et al. Toxic trace elements associated with airborne particulate matter: A review. J Air Pollut Control Assoc. 1987;37(11):1267-1285.
Schuhmacher M, Domingo JL, Llobet JM, et al. Chromium, copper, and zinc concentrations in edible vegetables grown in Tarragona Province, Spain. Bull Environ Contam Toxicol. 1993;50:514-521. [pmid: 8467135].
Scott PK, Proctor DM. Evaluation of 10% minimum elicitation threshold for Cr(VI)-induced allergic contact dermatitis using benchmark dose methods. J Soil Contam. 1997;6(6):707-731.
Scott PK, Finley BL, Harris MA, et al. Background air concentrations of Cr(VI) in Hudson County, New Jersey: Implications for setting health-based standards for Cr(VI) in soil. J Air Waste Manage Assoc. 1997a;47:592-600.
Scott PK, Finley BL, Sung HM, et al. Identification of an accurate soil suspension/dispersion modeling method for use in estimating health-based soil cleanup levels of hexavalent chromium in chromite ore processing residues. J Air Waste Manage Assoc. 1997b;47:753-765.
Sedman RM, Beaumont J, McDonald TA, et al. Review of the evidence regarding the carcinogenicity of hexavalent chromium in drinking water. J Environ Sci Health Part C Environ Carcinogen Rev. 2006;24(1):155-182.
Seigneur C, Constantinous E. Chemical kinetic mechanism for atmospheric chromium. Environ Sci Technol. 1995;29:222-231. [pmid: 22200223].
Seoane AI, Dulout FN. Contribution to the validation of the anaphase-telophase test: Aneugenic and clastogenic effects of cadmium sulfate, potassium dichromate and nickel chloride in Chinese hamster ovary cells. Genet Mol Biol. 1999;22(4):551-555.
Setchell BP, Waites GMH. Creep RO, Astwood EB, editors. The blood testis barrier. Handbook of physiology: Endocrinology V. Washington, DC. American Physiological Society. 1975:143-172.
Shah M, Palmer IR. An ultrastructural study of chronic chromate hand dermatitis. Acta Derm Venereol. 2002;82(4):254-259. [pmid: 12361128].
Shanker AK, Cervantes C, Loza-Tavera H, et al. Chromium toxicity in plants. Environ Int. 2005;31:739-753. [pmid: 15878200].
Shara M, Kincaid AE, Limpach AL, et al. Long-term safety evaluation of a novel oxygen-coordinated niacin-bound chromium (III) complex. J Inorg Biochem. 2007;101(7):1059-1069. [pmid: 17555823].
Shara M, Yasmin T, Kincaid AE, et al. Safety and toxicological evaluation of a novel niacin-bound chromium (III) complex. J Inorg Biochem. 2005;99(11):2161-2813. [pmid: 16169591].
Sharma BK, Singhal PC, Chugh KS. Intravascular haemolysis and acute renal failure following potassium dichromate poisoning. Postgrad Med J. 1978;54:414-415. [pmid: 683912].
Sheehan P, Ricks R, Ripple S, et al. Field evaluation of a sampling and analytical method for environmental levels of airborne hexavalent chromium. Am Ind Hyg Assoc J. 1992;53(1):57-68. [pmid: 1590220].
Sheffet A, Thind I, Miller AM, et al. Cancer mortality in a pigment plant utilizing lead and zinc chromates. Arch Environ Health. 1982;37:44-52. [pmid: 7059230].
Shelnutt SR, Goad P, Belsito DV. Dermatological toxicity of hexavalent chromium. Crit Rev Toxicol. 2007;37(5):375-387. [pmid: 17612952].
Sheppard MI, Thibault DH. A four-year mobility study of selected trace elements and heavy metals. J Environ Qual. 1991;20:101-114.
Sheppard SC, Evenden WG, Schwartz WJ. Heavy metals in the environment: Ingested soil: Bioavailability of sorbed lead, cadmium, cesium, iodine, and mercury. J Environ Qual. 1995;24:498-505.
Sheridan PJ, Zoller WH. Elemental composition of particulate material sampled from the Arctic haze aerosol. J Atmos Chem. 1989;9:363-381.
Shi X, Dalal NS, Kasprzak KS. Generation of free radicals from hydrogen peroxide and lipid hydroperoxides in the presence of Cr(III). Arch Biochem Biophys. 1993;302(1):294-291. [pmid: 8385901].
Shi X, Dong Z, Dalal NS, et al. Chromate-mediated free radical generation from cysteine, penicillamine, hydrogen peroxide, and lipid hydroperoxides. Biochim Biophys Acta. 1994;1226:65-72. [pmid: 8155741].
Shi X, Leonard SS, Liu KJ, et al. Cr(III)-mediated hydroxyl radical generation via Haber-Weiss cycle. J Inorg Biochem. 1998;69:263-268.
*. Shimkin MB, Leiter J. Induced pulmonary tumors in mice III. The role of chronic irritation in the production of pulmonary tumors in strain A mice. J Natl Cancer Inst. 1940;1:241-254.
Shindo Y, Toyoda Y, Kawamura K, et al. Micronucleus test with potassium chromate(VI) administered intraperitoneally and orally to mice. Mutat Res. 1989;223:403-406. [pmid: 2747727].
Shmitova LA. [The course of pregnancy in women engaged in the production of chromium and its compounds.]. Vliy Prof Fakt Spet Funk Zhensk Organ, Sverd 108-111. 1978. (Russian).
Shmitova LA. [Content of hexavalent chromium in the biological substrates of pregnant women and women in the immediate post-natal period engaged in the manufacture of chromium compounds.]. Gig Trud Prof Zabol. 1980;2:33-35. (Russian).
Shrivastava R, Upreti RK, Seth PK, et al. Effects of chromium on the immune system. FEMS Immunol Med Microbiol. 2002;34:1-7. [pmid: 12208600].
Shubochkin LN, Pokhodzie YI. Toxic properties of strontium chromate. Gig Sanit. 1980;45:76-77. [pmid: 7429191].
Shumilla JA, Wetterhahn KE, Barchowsky A. Inhibition of NF-κB binding to DNA by chromium, cadmium, mercury, zinc, and arsenite in vitro: Evidence of a thiol mechanism. Arch Biochem Biophys. 1998;349(2):356-362. [pmid: 9448725].
Siegel NJ, Gaudio KM, Katz LA, et al. Beneficial effect of thyroxin on recovery from toxic acute renal failure. Kidney Int. 1984;25:906-911. [pmid: 6471672].
Silverstein M, Mirer F, Kotelchusk D, et al. Mortality among workers in a die-casting and electroplating plant. Scand J Work Environ Health. Suppl 4. 1981;7:156-165. [pmid: 7330627].
Simonoff M, Llabador Y, Hamon C, et al. Extraction procedure for the determination of trace chromium in plasma by proton-induced x-ray emission spectrometry. Anal Chem. 1984;56:454-457. [pmid: 6711820].
Simpson JR, Gibson RS. Hair, serum, and urine chromium concentrations in former employees of the leather tanning industry. Biol Trace Elem Res. 1992;32:155-159. [pmid: 1375052].
Singh I. Induction of reverse mutation and mitotic gene conversion by some metal compounds in Saccharomyces cerevisiae. Mutat Res. 1983;117:149-152. [pmid: 6339905].
Singh J, Carlisle DL, Pritchard DE, et al. Chromium-induced genotoxicity and apoptosis: Relationship to chromium carcinogenesis (review). Oncol Rep. 1998a;5:1307-1318. [pmid: 9769362].
Singh J, McLean JA, Pritchard DE, et al. Sensitive quantitation of chromium-DNA adducts by inductively coupled plasma mass spectrometry with a direct injection high-efficiency nebulizer. Toxicol Sci. 1998b;46:260-265. [pmid: 10048129].
Singh J, Pritchard DE, Carlilse DL, et al. Internalization of carcinogenic lead chromate particles by cultured normal human lung epithelial cells: Formation of intracellular lead-inclusion bodies and induction of apoptosis. Toxicol Appl Pharmacol. 1999;161:240-248. [pmid: 10620481].
Sipowicz MA, Anderson LM, Utermahlen WE, et al. Uptake and tissue distribution of chromium(III) in mice after a single intraperitoneal or subcutaneous administration. Toxicol Lett. 1997;93:9-14. [pmid: 9381486].
*. Sjogren B. A retrospective cohort study of mortality among stainless steel welders. Scand J Work Environ Health. 1980;6:197-200. [pmid: 6937824].
Sjogren B, Gustavsson A, Hedstrom L. Mortality in two cohorts of welders exposed to high- and low-levels of hexavalent chromium. Scand J Work Environ Health. 1987;13:247-251. [pmid: 3616554].
Sjogren B, Hedstrom L, Ulfvarson U. Urine chromium as an estimator of air exposure to stainless steel welding fumes. Int Arch Occup Environ Health. 1983;51:347-354. [pmid: 6862648].
Sluis-Cremer GK, du Toit RSJ. Pneumoconiosis in chromite miners in South Africa. Br J Ind Med. 1968;25:63-67. [pmid: 5642648].
Smith AR. Chrome poisoning with manifestation of sensitization. J Am Med Assoc. 1931;97(2):95-98.
Smith RA, Alexander RB, Wolman MG. Water-quality trends in the nation's rivers. Science. 1987;235:1607-1615. [pmid: 17795595].
Smyth HF, Carpenter CP, Weil CS, et al. Range finding toxicity data: List VII. Am Ind Hyg Assoc J. 1969;30:470-476. [pmid: 5823428].
Snow ET. A possible role of chromium(III) in genotoxicity. Environ Health Perspect. 1991;92:75-81. [pmid: 1935855].
Snow ET, Xu SL. Effects of chromium(III) on DNA replication in vitro. Biol Trace Elem Res. 1989;21:61-71. [pmid: 2484633].
Snyder CA, Valle CD. Immune function assays as indicators of chromate exposure. Environ Health Perspect. 1991;92:83-86. [pmid: 1834456].
*. Snyder CA, Sellakumar A, Waterman S. An assessment of the tumorigenic properties of a Hudson County soil sample heavily contaminated with hexavalent chromium. Arch Environ Health. 1997;52(3):220-226. [pmid: 9169633].
Snyder CA, Udasin I, Waterman SJ, et al. Reduced IL-6 levels among individuals in Hudson County, New Jersey, an area contaminated with chromium. Arch Environ Health. 1996;51(1):26-28. [pmid: 8629859].
Sorahan T, Burges DCL, Hamilton L, et al. Lung cancer mortality in nickel/chromium platers, 1946–95. Occup Environ Med. 1998;55:236-242. [pmid: 9624277].
Sorahan T, Burges DCL, Waterhouse JAH. A mortality study of nickel/chromium platers. Br J Ind Med. 1987;44:250-258. [pmid: 3567099].
Soudani N, Bouaziz H, Sefi M, et al. Toxic effects of chromium (VI) by maternal ingestion on liver function of female rats and their suckling pups. Environ Toxicol [Epub ahead of print]. 2011a.
Soudani N, Ibtissem Ben A, Troudi A, et al. Oxidative stress induced by chromium (VI) in bone of suckling rats. Toxicol Ind Health. 2011b;27(8):724-734. [pmid: 21543464].
Soudani N, Sefi M, Bouaziz H, et al. Nephrotoxicity induced by chromium (VI) in adult rats and their progeny. Hum Exp Toxicol. 2010b;30(9):1233-1245. [pmid: 21056946].
Soudani N, Sefi M, Ben Amara I, et al. Protective effects of Selenium (Se) on Chromium (VI) induced nephrotoxicity in adult rats. Ecotoxicol Environ Saf. 2010a;73(4):671-678. [pmid: 19913299].
Soudani N, Troudi A, Bouaziz H, et al. Cardioprotective effects of selenium on chromium (VI)induced toxicity in female rats. Ecotoxicol Environ Saf. 2011c;74(3):513-520. [pmid: 20580087].
*. Sparrow S, Magos L, Snowden R. The effect of sodium chromate pretreatment on mercuric chloride-induced nephrotoxicity. Arch Toxicol. 1988;61:440-443. [pmid: 3190441].
Spruit D, van Neer FCJ. Penetration of Cr(III) and Cr(VI). Dermatologica. 1966;132:179-182. [pmid: 5955344].
SRI. Directory of chemical producers: United States of America. Menlo Park, CA. Stanford Research Institute International. 1997:518-519.
SRI. 2007 Directory of chemical producers. Menlo Park, CA. SRI Consulting. 2007:526-527. Access Intelligence, LLC.
*. Srivastava L, Jain VK, Kachru DN, et al. Comparative toxicity of trivalent and hexavalent chromium(V): Enzymatic alterations in rat liver and kidneys. Ind Health. 1985;23:89-94. [pmid: 4055440].
Stackhouse RA, Benson WH. The effect of humic acid on the toxicity and bioavailability of trivalent chromium. Ecotoxicol Environ Safety. 1989;17:105-111. [pmid: 2523796].
Stearns DM. Is chromium a trace essential metal?. Biofactors. 2000;11(3):149-162. [pmid: 10875302].
Stearns DM, Belbruno JJ, Wetterhaun KE. A prediction of chromium(III) accumulation in humans from chromium dietary supplements. FASEB J. 1995a;9:1650-1657. [pmid: 8529846].
Stearns DM, Courtney KD, Giangrande PH, et al. Chromium (VI) reduction by ascorbate: Role of reactive intermediates in DNA damage in vitro. Environ Health Perspect. 1994;102:21-25. [pmid: 7843100].
Stearns DM, Silviers SM, Wolf KK, et al. Chromium(III) tris(picolinate) is mutagenic at the hypoxanthine (guanine) phosphoribosyltransferase locus in Chinese hamster ovary cells. Mutat Res. 2002;513(1–2):135-142. [pmid: 11719098].
Stearns DM, Wise JP, Patierno SR, Wetterhahn KE. Chromium(III) picolonate produces chromosome damage in Chinese hamster ovary cells. FASEB J. 1995b;9:1643-1649. [pmid: 8529845].
Steenland K, Loomis D, Shy C, et al. Review of occupational lung carcinogens. Am J Ind Med. 1996;29:474-490. [pmid: 8732921].
Steffee CH, Baetjer AM. Histopathologic effects of chromate chemicals. Arch Environ Health. 1965;11:66-75.
Steinhoff D, Gad SC, Hatfield GK, et al. Carcinogenicity studies with sodium dichromate in rats. Exp Pathol. 1986;30:129-141. [pmid: 3792485].
Stella M, Montaldi A, Rossi R, et al. Clastogenic effects of chromium on human lymphocytes in vitro and in vivo. Mutat Res. 1982;101:151-164. [pmid: 7099183].
Sterekhova NP, Zeleneva NI, Solomina SN, et al. [Gastric pathology in the workers of chromium salts industries.]. Gig Trud Prof Zabol. 1978;3:19-23. (Russian).
Stern AH, Bagdon RE, Hazen RE, et al. Risk assessment of the allergic dermatitis potential of environmental exposure to hexavalent chromium. J Toxicol Environ Health. 1993;40:613-641. [pmid: 8277522].
Stern FB, Beaumont JJ, Halperin WE, et al. Mortality of chrome leather tannery workers and chemical exposures in tanneries. Scand J Work Environ Health. 1987;13:108-117. [pmid: 3602964].
Stern RM. Langard S, editor. Chromium compounds: Production and occupational exposure. Biological and environmental aspects of chromium. New York, NY. Elsevier Biomedical Press. 1982:5-47.
Stern RM, Thomsen E, Furst A. Cr(VI) and other metallic mutagens in fly ash and welding fumes. Toxicol Environ Chem. 1984;8:95-108.
Stilwell DE, Gorny KD. Contamination of soil with copper, chromium, and arsenic under decks built from pressure treated wood. Bull Environ Contam Toxicol. 1997;58:22-29. [pmid: 8952921].
Stokinger HE. Clayton GD, Clayton FE, editors. Chromium, Cr. Patty's industrial hygiene and toxicology. 3rd ed. New York, NY. John Wiley & Sons. 1981;Vol. IIA:1589-1605.
Stridsklev IC, Schaller K, Langard S. Monitoring of chromium and nickel in biological fluids of stainless steel welders using the flux-cored-wire (FCW) welding method. Int Arch Occup Environ Health. 2004;77(8):587-591. [pmid: 15538617].
Subramanian S, Rajendiran G, Sekhar P, et al. Reproductive toxicity of chromium in adult bonnet monkeys (Macaca radiata Geoffrey). Reversible oxidative stress in the semen. Toxicol Appl Pharmacol. 2006;215:237-249. [pmid: 16678873].
Sugden KD, Burris RB, Rogers SJ. An oxygen dependence in chromium mutagenesis. Mutat Res. 1990;244:239-244. [pmid: 2195337].
Sugiyama M. Effects of vitamins on chromium(VI)-induced damage. Environ Health Perspect. 1991;92:63-70. [pmid: 1935852].
Sugiyama M, Tsuzuki K. Effect of glutathione depletion on formation of paramagnetic chromium in Chinese hamster V-79 cells. FEBS Lett. 1994;341:273-276. [pmid: 8137952].
Sugiyama M, Patierno SR, Cantoni O, et al. Characterization of DNA lesions induced by CaCrO_4_ in synchronous and asynchronous cultured mammalian cells. Mol Pharmacol. 1986a;29:606-613. [pmid: 3713704].
*. Sugiyama M, Wang XW, Costa M. Comparison of DNA lesions and cytotoxicity induced by calcium chromate in human, mouse, and hamster cell lines. Cancer Res. 1986b;46:4547-4551. [pmid: 3731109].
Sullivan MF, Miller BM, Goebel JC. Gastrointestinal absorption of metals (^51^Cr, ^65^Zn, ^95m^Tc, ^109^Cd, ^113^Sn, ^147^Pm, and ^238^Pu) by rats and swine. Environ Res. 1984;35:439-453. [pmid: 6510393].
Sunderman FW, Hopfer SM, Swift T, et al. Cobalt, chromium, and nickel concentrations in body fluids of patients with porous-coated knee or hip prostheses. J Orthop Res. 1989;7:307-315. [pmid: 2649648].
Suzuki Y, Fukuda K. Reduction of hexavalent chromium by ascorbic acid and glutathione with special reference to the rat lung. Arch Toxicol. 1990;64:169-176. [pmid: 2372230].
Suzuki Y, Serita F. Simultaneous determination of water-soluble trivalent and hexavalent chromium by anion exchange high-pressure liquid chromatography. Ind Health. 1985;23:207-220. [pmid: 3934115].
Suzuki Y, Homma K, Minami M, et al. Distribution of chromium in rats exposed to hexavalent chromium and trivalent chromium aerosols. Ind Health. 1984;22:261-267. [pmid: 6526701].
Swaine DJ, Mitchell RL. Trace-element distribution in soil profiles. J Soil Sci. 1960;11(2):347-368.
Tagliari KC, Cecchini R, Vargas VMF. Mutagenicity of chromium (VI) using the Salmonella microsuspension bioassay. Rev Bras Toxicol. 2004;17(2):45-50.
Takagi Y, Matsuda S, Imai S, et al. Trace elements in human hair: An international comparison. Bull Environ Contam Toxicol. 1986;36:793-800. [pmid: 3719115].
Takagi Y, Matsuda S, Imai S, et al. Survey of trace elements in human nails: An international comparison. Bull Environ Contam Toxicol. 1988;41:683-689. [pmid: 3233367].
Takahashi K, Okubo T. A prospective cohort study of chromium plating workers in Japan. Arch Environ Health. 1990;45(2):107-111. [pmid: 2334232].
Tandon SK, Behari JR, Kachru DN. Distribution of chromium in poisoned rats. Toxicology. 1979;13:29-34. [pmid: 516070].
*. Tandon SK, Saxena DK, Gaur JS, et al. Comparative toxicity of trivalent and hexavalent chromium. Environ Res. 1978;15:90-99. [pmid: 620663].
Taylor FH. The relationship of mortality and duration of employment as reflected by a cohort of chromate workers. Am J Public Health. 1966;56(2):218-229.
Teraoka H. Distribution of 24 elements in the internal organs of normal males and the metallic workers in Japan. Arch Environ Health. 1981;36(4):155-164. [pmid: 7271320].
Tezuka M, Keiko M, Toshiyuki E, et al. Protective effect of chromium (III) on acute lethal toxicity of carbon tetrachloride in rats and mice. J Inorg Biochem. 1991;42(1):1-8. [pmid: 1648594].
Tezuka M, Sadanobu S, Gomi K, et al. In vitro effect of chromium and other trace metals on mouse hepatotoxicity induced by carbon tetrachloride exposure. Biol Pharm Bull. 1995;18(2):256-261. [pmid: 7742794].
Thomas K, Colborn T. Colborn T, Clement C, editors. Organochlorine endocrine disruptors in human tissue. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ. Princeton Scientific Publishing. 1992:365-394.
Thompson RC, Hollis OL. Irradiation of the gastrointestinal tract of the rat by ingested ruthenium 106. Am J Physiol. 1958;194(2):308-312. [pmid: 13559468].
Thompson CM, Proctor DM, Haws LC, et al. Investigation of the mode of action underlying the tumorigenic response induced in B6C3F1 mice exposed orally to hexavalent chromium. Toxicol Sci. 2011;123(1):58-70. [pmid: 21712504].
Thompson CM, Proctor DM, Suh M, et al. Comparison of the effects of hexavalent chromium in the alimentary canal of F344 rats and B6C3F1 mice following exposure in drinking water: Implications for carcinogenic modes of action. Toxicol Sci. 2012;125(1):79-90. [pmid: 22011396].
Thomson WE. Note on a case of vesication of the cornea by potassium bichromate. Ophthalmoscope. 1903;1:214-216.
Tola S, Kilpio J, Virtamo M, et al. Urinary chromium as an indicator of the exposure of welders to chromium. Scand J Work Environ Health. 1977;3:192-202. [pmid: 594727].
Torgrimsen T. Langård S, editor. Analysis of chromium. Biological and environmental aspects of chromium. New York, NY. Elsevier Biomedical Press. 1982:65-99.
Tossavainen A, Nurminen P, Mutanen P, et al. Application of mathematical modeling for assessing the biological half-times of chromium and nickel in field studies. Br J Ind Med. 1980;37:285-291. [pmid: 7426481].
Trent LK, Thieding-Cancel D. Effects of chromium picolinate on body composition. J Sports Med Phys Fitness. 1995;35:273-280. [pmid: 8776075].
TRI09. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC. Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. 2011. http://www.epa.gov/triexplorer/. September 20, 2011.
Triebig G, Zschiesche W, Schaller KH, et al. Foa V, Emmett EA, Maroni M, Colombi A, editors. Studies on the nephrotoxicity of heavy metals in iron and steel industries. Occupational and environmental chemical hazards. Cellular and biochemical indices for monitoring toxicity. Chichester, UK. Ellis Horwood Limited. 1987:334-338.
Trivedi B, Saxena DK, Murthy RC, et al. Embryotoxicity and fetotoxicity of orally administered hexavalent chromium in mice. Reprod Toxicol. 1989;3:275-278. [pmid: 2520531].
Trzeciak A, Kowalik J, Malecka-Panas E, et al. Genotoxicity of chromium in human gastric mucosa cells and peripheral blood lymphocytes evaluated by the single cell gel electrophoresis (comet assay). Med Sci Monit. 2000;6(1):24-29. [pmid: 11208279].
Tsapakos MJ, Hampton TH, Sinclair PR, et al. The carcinogen chromate causes DNA damage and inhibits drug-mediated induction of porphyrin accumulation and glucuronidation in chick embryo hepatocytes. Carcinogenesis. 1983a;4(8):959-966. [pmid: 6872154].
Tsapakos MJ, Hampton TH, Wetterhahn KE. Chromium(VI)-induced DNA lesions and chromium distribution in rat kidney, liver, and lung. Cancer Res. 1983b;43:5662-5667. [pmid: 6640521].
Tsou TC, Chen CL, Liu TY, et al. Induction of 8-hydroxydeoxyguanosine in DNA by chromium(III) plus hydrogen peroxide and its prevention by scavengers. Carcinogenesis. 1996;17(1):103-108. [pmid: 8565117].
*. Tsuchiya K. The relation of occupation to cancer, especially cancer of the lung. Cancer. 1965;18:136-144. [pmid: 14254068].
Tsuda H, Kato K. Chromosomal aberrations and morphological transformation in hamster embryonic cells treated with potassium dichromate in vitro. Mutat Res. 1977;46:87-94. [pmid: 559933].
Uddin AN, Burns FJ, Rossman TG, et al. Dietary chromium and nickel enhance UVcarcinogenesis in skin of hairless mice. Toxicol Appl Pharmacol. 2007;221(3):329-338. [pmid: 17499830].
Ueno S, Kashimoto T, Susa N, et al. Detection of dichromate (VI)-induced DNA strand breaks and formation of paramagnetic chromium in multiple mouse organs. Toxicol Appl Pharmacol. 2001;170:56-62. [pmid: 11141356].
Ueno S, Sugiyama M, Nobuyuki S, et al. Effect of dimethylthiourea on chromium(VI)-induced DNA single-strand breaks in Chinese hamster V-79 cells. Mutat Res. 1995a;346:247-253. [pmid: 7753117].
*. Ueno S, Susa N, Furukawa Y, et al. The relationship between the development of toxicity and lipid peroxidation induced by chromium compounds in rats. Kitasato Arch of Exp Med. 1988;61:137-147. [pmid: 3210555].
Ueno S, Susa N, Furukawa Y, et al. Formation of paramagnetic chromium in liver of mice treated with dichromate(VI). Toxicol Appl Pharmacol. 1995b;135:165-171. [pmid: 8545823].
Umeda M, Nishimura M. Inducibility of chromosomal aberrations by metal compounds in cultured mammalian cells. Mutat Res. 1979;67:221-229. [pmid: 481448].
Urasa IT, Nam SH. Direct determination of chromium(III) and chromium(VI) with ion chromatography using direct current plasma emission as element-selective detector. J Chromatogr Sci. 1989;27:30-37. [pmid: 2925826].
USDI. Mineral yearbook: Chromium. U.S. Department of the Interior. Pittsburgh, PA. Bureau of Mines. 1988a.
USGS. Element concentrations in soils and other surficial materials of the conterminous United States. United States Geological Survey. USGS Professional Paper 1270. Washington, DC. U.S. Government Printing Office. 1984.
USGS. Concentrations of nine trace metals in ground water at the Idaho National Engineering Laboratory, Idaho. U.S. Geological Survey. Idaho Falls, Idaho. U.S. Geological Service, U.S. Department of Energy. 1989. DE88015177.
USGS. Chromium. Mineral commodity summaries 2008. U.S. Geological Survey. 2008a. http://minerals.usgs.gov/minerals/pubs/mcs/2008/mcs2008.pdf. May 22, 2008.
USGS. 2006 Minerals yearbook. Chromium. U.S. Geological Survey. 2008b. http://minerals.usgs.gov/minerals/pubs/commodity/chromium/myb1-2006-chrom.pdf. May 22, 2008.
*. Uyama T, Monden Y, Tsuyuguchi M, et al. Lung cancer in chromate workers: High-risk group for multiple lung cancer. J Surg Oncol. 1989;41:213-218. [pmid: 2755137].
Vaglenov A, Nosko M, Georgieva R, et al. Genotoxicity and radioresistence in electroplating workers exposed to chromium. Mutat Res. 1999;446(1):23-34. [pmid: 10613183].
Vasant C, Rajaram R, Ramasami T. Apoptosis of lymphocytes induced by chromium(VI/V) is through ROS-mediated activation of Src-family kinases and caspases-3. Free Radic Biol Med. 2003;35(9):1082-1100. [pmid: 14572611].
Veillon C. Analytical chemistry of chromium. Sci Total Environ. 1989;86:65-68. [pmid: 2602939].
Veillon C, Patterson KY, Bryden NA. Direct determination of chromium in human urine by electrothermal atomic absorption spectrometry. Anal Chim Acta. 1982;136:233-241.
Venier P, Montaldi A, Majone F, et al. Cytotoxic, mutagenic and clastogenic effects of industrial chromium compounds. Carcinogenesis. 1982;3(11):1331-1338. [pmid: 6758977].
Venier P, Montini R, Zordan M, et al. Induction of SOS response in Escherichia coli strain PQ37 by 16 chemical compounds and human urine extracts. Mutagenesis. 1989;4(1):51-57. [pmid: 2497301].
Venitt S, Levy LS. Mutagenicity of chromates in bacteria and its relevance to chromate carcinogenesis. Nature. 1974;250:493-495. [pmid: 4620019].
Vernot EH, MacEwen JD, Haun CC, et al. Acute toxicity and skin corrosion data for some organic and inorganic compounds and aqueous solutions. Toxicol Appl Pharmacol. 1977;42:417-423. [pmid: 595018].
Verschoor MA, Bragt PC, Herber RFM, et al. Renal function of chrome-plating workers and welders. Int Arch Occup Environ Health. 1988;60:67-70. [pmid: 3350606].
Vieira I, Sonnier M, Cresteil T. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem. 1996;238:476-483. [pmid: 8681961].
Visek WJ, Whitney IB, Kuhn USC, et al. Metabolism of Cr^51^ by animals as influenced by chemical state. Proc Soc Exp Biol Med. 1953;84:610-615. [pmid: 13134233].
Wagley D, Schmiedel G, Mainka E, et al. Direct determination of some essential and toxic elements in milk and milk powder by graphite furnace atomic absorption spectrometry. Atmos Spectrosc. 1989;10(4):106-111.
Wahba A, Cohen T. Chrome sensitivity in Israel. Contact Dermatitis. 1979;5:101-107. [pmid: 467022].
*. Wahlberg JE. Percutaneous toxicity of metal compounds: A comparative investigation in guinea pigs. Arch Environ Health. 1965;11:201-204. [pmid: 5832249].
Wahlberg JE. Percutaneous absorption of trivalent and hexavalent chromium (^51^Cr) through excised human and guinea pig skin. Dermatologica. 1970;141:288-296. [pmid: 5487487].
Wahlberg JE, Skog E. Percutaneous absorption of trivalent and hexavalent chromium. Arch Dermatol. 1965;92:315-318.
Wang J, Ashley K, Kennedy ER, et al. Determination of hexavalent chromium in industrial samples using ultrasonic extraction and flow injection analysis. Analyst. 1997a;122(11):1307-1312. [pmid: 9474812].
Wang J, Ashley K, Marlow D. Field method for the determination of hexavalent chromium by ultrasonication and strong anion-exchange solid-phase extraction. Anal Chem. 1999;71:1027-1032. [pmid: 10079763].
Wang JY, Tsukayama DT, Wicklund BH, et al. Inhibition of T and B cell proliferation by titanium, cobalt, and chromium: Role of IL-2 and IL-6. J Biomed Mater Res. 1996a;32:655-661. [pmid: 8953156].
Wang T, Jia G, Zhang J, et al. Renal impairment caused by chronic occupational chromate exposure. Int Arch Occup Environ Health. 2011a;84(4):393-401. [pmid: 20717692].
Wang TC, Jia G, Zhang J, et al. Vitamin B12 and folate deficiency and elevated plasma total homocysteine in workers with chronic exposure to chromate. Occup Environ Med. 2011b. http://www.oem.bmj.com.pdf/10.1136/oem.2010.063305. October 21, 2011.
Wang X, Xing M, Shen Y, et al. Oral administration of Cr(VI) induced oxidative stress, DNA damage and apoptotic cell death in mice. Toxicology. 2006;228(1):16-23. [pmid: 16979809].
*. Wang XW, Davies JWL, Sirvent RLZ, et al. Chromic acid burns and acute chromium poisoning. Burns. 1985;11:181-184.
Wani S, Weskamp C, Marple J, et al. Acute tubular necrosis associated with chromium picolinatecontaining dietary supplement. Ann Pharmacother. 2006;40:563-566. [pmid: 16492795].
Warren G, Schultz P, Bancroft D, et al. Mutagenicity of a series of hexacoordinate chromium(III) compounds. Mutat Res. 1981;90:111-118. [pmid: 7035934].
Wasser WG, Feldman NS, D'Agati VD. Chronic renal failure after ingestion of over-the-counter chromium picolinate. Ann Intern Med. 1997;126(5):410. [pmid: 9054292].
Watanabe K, Sakamoto K, Sasaki T. Comparisons on chemically-induced mutation among four bacterial strains, Salmonella typhimurium TA102 and TA2638, and Escherichia coli WP2/pKM101 and WP2 uvrA/pKM101: Collaborative study II. Mutat Res. 1998a;412:17-31. [pmid: 9508361].
Weast RC, editor. CRC handbook of chromium and physics. 66th ed. Boca Raton, FL. CRC Press, Inc. 1985. B-70, B-88-89, B-106, B-127, B-142, B-147, B-159, D-215.
Weber H. Long-term study of the distribution of soluble chromate-51 in the rat after a single intratracheal administration. J Toxicol Environ Health. 1983;11:749-764. [pmid: 6620410].
Wedeen RP, Haque S, Udasin I, et al. Absence of tubular proteinuria following environmental exposure to chromium. Arch Environ Health. 1996;51(4):321-323. [pmid: 8757413].
Werfel U, Langen V, Eickhoff I, et al. Elevated DNA single-strand breakage frequencies in lymphocytes of welders exposed to chromium and nickel. Carcinogenesis. 1998;19(3):413-418. [pmid: 9525274].
West JR, Smith HW, Chasis H. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatrics. 1948;32a:10-18.
Westbrook JH. Grayson M, editor. Chromium and chromium alloys. Kirk-Othmer encyclopedia of chemical technology, Vol. 6, 3rd ed. New York, NY. John Wiley and Sons. 1979:54-82.
Whiting RF, Stich HF, Koropatnick DJ. DNA damage and DNA repair in cultured human cells exposed to chromate. Chem Biol Interact. 1979;26:267-280. [pmid: 509690].
Whittaker P, San RHC, Clarke JJ, et al. Mutagenicity of chromium picolinate and its components in Salmonella typhimurium and L5178Y mouse lymphoma cells. Food Chem Toxicol. 2005;43(11):1619-1625. [pmid: 16040181].
WHO. Chromium. Environmental Health Criteria 61. Geneva. United Nations Environment Programme. International Labour Organisation. World Health Organization. 1988. http://www.inchem.org/documents/ehc/ehc/ehc61.htm. April 23, 2008.
WHO. Air quality guidelines. 2nd ed. Geneva, Switzerland. World Health Organization. 2000. http://www.euro.who.int/document/aiq/6_4chromium.pdf. May 14, 2008.
WHO. Chromium in drinking water. Background document for development of WHO guidelines for drinking water quality. Geneva. World Health Organization. 2003.
WHO. Guidelines for drinking-water quality. Vol. 1. Recommendations. 3rd ed. Geneva, Switzerland. World Health Organization. 2004. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. March 08, 2006.
Widdowson EM, Dickerson JWT. Comar CL, Felix F, editors. Chemical composition of the body. Mineral metabolism: An advanced treatise Volume II, The elements part A. New York, NY. Academic Press. 1964.
Wiegand HJ, Ottenwalder H, Bolt HM. The reduction of chromium(VI) to chromium(III) by glutathione: An intracellular redox pathway in the metabolism of the carcinogen chromate. Toxicology. 1984;33:341-348. [pmid: 6515663].
Wiegand HJ, Ottenwalder H, Bolt HM. Fast uptake kinetics in vitro of 51Cr (VI) by red blood cells of man and rat. Arch Toxicol. 1985;57(1):31-34. [pmid: 4015396].
Wiegand HJ, Ottenwalder H, Bolt HM. Bioavailability and metabolism of hexavalent chromium compounds. Toxicol Environ Chem. 1987;14:263-275.
Wiegand HJ, Ottenwalder H, Bolt HM. Recent advances in biological monitoring of hexavalent chromium compounds. Sci Total Environ. 1988;71:309-315. [pmid: 3406703].
Wiersema JM, Wright L, Rogers B, et al. Human exposure to potentially toxic elements through ambient air in Texas. Proceedings of the 77th meeting of Air Pollution Control Association, Vol. Austin, TX. 1984:2-15.
Wild D. Cytogenetic effects in the mouse of 17 chemical mutagens and carcinogens evaluated by the micronucleus test. Mutat Res. 1978;56:319-327. [pmid: 342949].
*. Williams MW, Hoeschele JD, Turner JE, et al. Chemical softness and acute metal toxicity in mice and Drosophila. Toxicol Appl Pharmacol. 1982;63:461-469. [pmid: 6808706].
Winder C, Carmody M. The dermal toxicity of cement. (Comment in: Toxicol Ind Health 19:183). Toxicol Ind Health. 2002;18:321-331. [pmid: 15068132].
Winston JR, Walsh EN. Chromate dermatitis in railroad employees working with diesel locomotives. J Am Med Assoc. 1951;147:1133-1134. [pmid: 14873639].
Wise JP, Orenstein JM, Patierno SR. Inhibition of lead chromate clastogenesis by ascorbate: Relationship to particle dissolution and uptake. Carcinogenesis. 1993;14(3):429-434. [pmid: 8453719].
Wise JP, Wise SS, Little JE. The cytotoxicity and genotoxicity of particulate and soluble hexavalent chromium in human lung cells. Mutat Res. 2002;517:221-229. [pmid: 12034323].
Wise SS, Holmes AL, Ketterer ME, et al. Chromium is the proximate clastogenic species for lead chromate-induced clastogenicity in human bronchial cells. Mutat Res. 2004;560:79-89. [pmid: 15099827].
Wise SS, Holmes AL, Ketterer M, et al. Chromium is the proximate genotoxic species in lead chromate-induced genotoxicity in human bronchial cells. Toxicologist. 2003;72(S-1):217.
Wise SS, Holmes AL, Wise JP. Particulate and soluble hexavalent chromium are cytotoxic and genotoxic to human lung epithelial cells. Mutat Res. 2006b;610(1–2):2-7. [pmid: 16872863].
Wise SS, Holmes AL, Xie H, et al. Chronic exposure to particulate chromate induces spindle assembly checkpoint bypass in human lung cells. Chem Res Toxicol. 2006a;19:1492-1498. [pmid: 17112237].
Wise SS, Kraus S, Shaffiey F, et al. Hexavalent chromium is cytotoxic and genotoxic to the North Atlantic right whale (Eubalaena glacialis) lung and testes fibroblasts. Mutat Res. 2008;650:30-38. [pmid: 18006369].
Witmer C, Faria E, Park H-S, et al. In vivo effects of chromium. Environ Health Perspect. 1994;102(3):169-176. [pmid: 7843092].
Witmer CM, Harris R, Shupack SI. Oral bioavailability of chromium from a specific site. Environ Health Persp. 1991;92:105-110.
Witmer CM, Park HS, Shupack SI. Mutagenicity and disposition of chromium. Sci Total Environ. 1989;86:131-148. [pmid: 2690337].
Wong SS, Chan MT, Gan SL, et al. Occupational chromate allergy in Singapore: A study of 87 patients and a review from 1983 to 1995. Am J Contact Dermatitis. 1998;9(1):1-5. [pmid: 9471980].
*. Woolliscroft J, Barbosa J. Analysis of chromium induced carbohydrate intolerance in the rat. J Nutr. 1977;107(9):1702-1706. [pmid: 894367].
Wroñska-Nofer T, Wisniewska-Knypl J, Wyszyñska K. Prooxidative and genotoxic effect of transition metals (cadmium, nickel, chromium, and vanadium) in mice. Trace Elem Electrolytes. 1999;15(2):87-92.
Wu F, Wu W, Kuo H, et al. Effect of genotoxic exposure to chromium among electroplating workers in Taiwan. Sci Total Environ. 2001;279:21-28. [pmid: 11712598].
Xu J, Bubley GJ, Detrick B, et al. Chromium(VI) treatment of normal human lung cells results in guanine-specific DNA polymerase arrest, DNA-DNA cross-links and S-phase blockade of cell cycle. Carcinogenesis. 1996;17(7):1511-1517. [pmid: 8706257].
Yamaguchi S, Sano K, Shimojo N. On the biological half-time of hexavalent chromium in rats. Ind Health. 1983;21:25-34. [pmid: 6841147].
Yamamoto A, Kohyama Y, Hanawa T. Mutagenicity evaluation of forty-one metal salts by the umu test. J Biomed Mater Res. 2002;59:176-183. [pmid: 11745551].
Yang JL, Hsieh YC, Wu CW, et al. Mutational specificity of chromium(VI) compounds in the hprt locus of Chinese hamster ovary-K1 cells. Carcinogenesis. 1992;13(11):2053-2057. [pmid: 1423875].
Yang L, Mester Z, Abranko L, et al. Determination of total chromium in seawater by isotope dilution sector field ICPMS using GC sample introduction. Analytical Chemistry. 2004;76(13):3510-3516. [pmid: 15228318].
Yao H, Guo L, Jiang BH, et al. Oxidative stress and chromium(VI) carcinogenesis. J Environ Pathol Toxicol Oncol. 2008;27(2):77-88. [pmid: 18540844].
Ye J, Zhang X, Young HA, et al. Chromium(VI)-induced nuclear factor-κB activation in intact cells via free radical reactions. Carcinogenesis. 1995;16(10):2401-2405. [pmid: 7586142].
Yeardley RB, Lazorchak JM, Paulsen SG. Elemental fish tissue contamination in Northeastern U.S. lakes: Evaluation of an approach to regional assessment. Environ Toxicol Chem. 1998;17(9):1875-1884.
Yousef MI, El-Demerdash FM, Kamil KI, et al. Ameliorating effect of folic acid on chromium(VI)-induced changes in reproductive performance and seminal plasma biochemistry in male rabbits. Reprod Toxicol. 2006;21(3):322-328. [pmid: 16249067].
Zahid ZR, Al-Hakkak ZS, Kadhim AHH, et al. Comparative effects of trivalent and hexavalent chromium on spermatogenesis of the mouse. Toxicol Environ Chem. 1990;25:131-136.
Zatka VJ. Speciation of hexavalent chromium in welding fumes interference by air oxidation of chromium. Am Ind Hyg Assoc J. 1985;46(6):327-331. [pmid: 4014009].
Zhang J, Li S. Cancer mortality in a Chinese population exposed to hexavalent chromium in water. (Comment in: J Occup Environ Med 48(7): 749). J Occ Env Med. 1997;39(4):315-319.
Zhang J, Li X. Chromium pollution of soil and water in Jinzhou. J Chinese Prev Med. 1987;21:262-264.
Zhang M, Chen Z, Chen Q, et al. Investigating DNA damage in tannery workers occupationally exposed to trivalent chromium using comet assay. Mutat Res. 2008;654(1):45-51. [pmid: 18541454].
Zhang XH, Zhang X, Wang XC, et al. Chronic occupational exposure to hexavalent chromium causes DNA damage in electroplating workers. BMC Public Health. 2011;11:224. http://www.biomedcentral.com/content/pdf/1471-2458-11-224.pdf. October 20, 2011. [pmid: 21481275].
Zhitkovich A. Importance of chromium-DNA adducts in mutagenicity and toxicity of chromium(VI). Chem Res Toxicol. 2005;18:3-11. [pmid: 15651842].
Zhitkovich A, Voitkun V, Costa M. Formation of the amino acid-DNA complexes by hexavalent and trivalent chromium in vitro: Importance of trivalent chromium and the phosphate group. Biochemistry. 1996;35:7275-7282. [pmid: 8679557].
Ziegler EE, Edwards BB, Jensen RL, et al. Absorption and retention of lead by infants. Pediatr Res. 1978;12:29-34. [pmid: 643372].
Zimmering S, Mason JM, Valencia R, et al. Chemical mutagenesis testing in Drosophila. II. Results of 20 coded compounds tested for the National Toxicology Program. Environ Mutagen. 1985;7:87-100. [pmid: 3917911].