# REGULATIONS, ADVISORIES, AND GUIDELINES

MRLs are substance specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

An MRL of 5×10^−6^ mg chromium(VI)/m^3^ has been derived for intermediate- and chronic-duration inhalation exposure to chromium(VI) as chromium trioxide mist and other dissolved hexavalent chromium aerosols and mists. The MRL is based on a LOAEL of 0.002 mg chromium(VI)/m^3^ for upper respiratory effects in humans in the occupational exposure study by Lindberg and Hedenstierna (1983), which spanned both intermediate and chronic durations.

An MRL of 0.0003 mg chromium(VI)/m^3^ has been derived for intermediate-duration inhalation exposure to chromium(VI) as particulate hexavalent chromium compounds. The MRL is based on a benchmark concentration of 0.016 mg chromium(VI)/m^3^ for increases in lactate dehydrogenase activity in broncholavage fluid from rats in the study by Glaser et al. (1990).

An MRL of 0.005 mg chromium(VI)/kg/day has been derived for intermediate-duration oral exposure to hexavalent chromium compounds for hematological effects (e.g., microcytic, hypochromic anemia) in rats using data from a study by NTP (2008a). Because several hematological parameters are used to define the clinical picture of anemia, the MRL is based on the average BMDL2sd values for hemoglobin, MCV, and MCH of 0.52 mg chromium(VI)/kg/day.

An MRL of 0.0009 mg chromium(VI)/kg/day has been derived for chronic-duration oral exposure to hexavalent chromium compounds. The MRL is based on a benchmark dose of 0.09 mg chromium(VI)/kg/day for diffuse epithelial hyperplasia of the duodenum in mice in a study by NTP (2008a).

An MRL of 0.005 mg chromium(III)/m^3^ has been derived for intermediate-duration inhalation exposure to insoluble trivalent chromium particulate compounds. The MRL is based on a minimal LOAEL of 3 mg chromium(III)/m^3^ for trace-to-mild septal cell hyperplasia and chronic interstitial inflammation of the lung in rats in the study by Derelanko et al. (1999).

An MRL of 0.0001 mg chromium(III)/m^3^ has been derived for intermediate-duration inhalation exposure to soluble trivalent chromium particulate compounds. The MRL is based on a LOAEL of 3 mg chromium(III)/m^3^ for nasal and larynx lesions in rats in the study by Derelanko et al. (1999).

A chronic oral reference dose (RfD) of 0.003 mg chromium(VI)/kg/day has been derived and verified by EPA for soluble salts of chromium(VI) (e.g., potassium chromate, sodium chromate, potassium dichromate, and sodium dichromate) (IRIS 2008). The RfD is based on a NOAEL for systemic effects in rats exposed to 2.5 mg chromium(VI)/kg/day as potassium chromate in the drinking water for 1 year in the study by MacKenzie et al. (1958).

A chronic inhalation RfC of 0.008 µg chromium(VI)/m^3^ has been derived and verified by EPA for chromic acid mists and dissolved chromium(VI) aerosols (IRIS 2008). The RfC is based on a LOAEL for nasal septum atrophy in workers exposed to 0.002 mg chromium(VI)/m^3^ (Lindberg and Hedenstierna 1983).

A chronic inhalation RfC of 0.0001 mg chromium(VI)/m^3^ has been derived and verified by EPA for chromium(VI) particulates (IRIS 2008). The RfC is based on a benchmark concentration of 0.016 mg chromium(VI)/m^3^ derived from data for lactate dehydrogenase activity in bronchoalveolar lavage fluid in rats exposed to sodium dichromate (Glaser et al. 1990).

A chronic oral RfD of 1.5 mg chromium(III)/kg/day has been derived and verified by EPA for insoluble salts of chromium(III) (e.g., chromium oxide and chromium sulfate) (IRIS 2008). The RfD is based on a NOAEL for systemic effects in rats fed 1,800 mg chromium(III)/kg/day for 5 days/week for 600 feedings (840 total days) in the study by Ivankovic and Preussmann (1975). EPA has determined that the data are inadequate for the development of an RfC for chromium(III) due to the lack of relevant toxicity study addressing the respiratory effects of chromium(III) (IRIS 2008).

The Institute of Medicine (IOM) of the National Academy of Sciences (NAS) determined an adequate intake (e.g., a level typically consumed by healthy individuals) of 20–45 µg chromium(III)/day for adolescents and adults (IOM 2001)

The international and national regulations, advisories, and guidelines regarding chromium in air, water, and other media are summarized in Table 8-1.

Table 8-1 Regulations, Advisories, and Guidelines Applicable to Chromium

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | | IARC 2008
IARC | Chromium, metallic | Group 3^a^ | IARC 2008
IARC | Chromium (III) compounds | Group 3^a^ | IARC 2008
IARC | Chromium (VI) | Group 1^b^ | IARC 2008
WHO | Air quality guidelines | | WHO 2000
WHO | Chromium (VI) | 1 µg/m^3^ for a lifetime risk of 4×10^−2^ | WHO 2000
WHO | Drinking water quality guidelines | | WHO 2004
WHO | Chromium (for total chromium) | 0.05 mg/L^c^ | WHO 2004
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA) | | ACGIH 2007
ACGIH | Calcium chromate (as Cr) | 0.001 mg/m^3^ | ACGIH 2007
ACGIH | Chromium and inorganic compounds (as Cr) | | ACGIH 2007
ACGIH | Metal and chromium (III) compounds | 0.5 mg/m^3^ | ACGIH 2007
ACGIH | Water-soluble chromium (VI) compounds | 0.05 mg/m^3^ | ACGIH 2007
ACGIH | Insoluble chromium (VI) compounds | 0.01 mg/m^3^ | ACGIH 2007
ACGIH | Lead chromate | | ACGIH 2007
ACGIH | As Pb | 0.05 mg/m^3^ | ACGIH 2007
ACGIH | As Cr | 0.012 mg/m^3^ | ACGIH 2007
ACGIH | Strontium chromate (as Cr) | 0.0005 mg/m^3^ | ACGIH 2007
ACGIH | Zinc chromates (as Cr) | 0.01 mg/m^3^ | ACGIH 2007
ACGIH | TLV basis (critical effects) | | ACGIH 2007
ACGIH | Calcium chromate (as Cr) | Lung cancer | ACGIH 2007
ACGIH | Chromium | | ACGIH 2007
ACGIH | Metal and chromium (III) compounds | Upper respiratory tract and skin irritation | ACGIH 2007
ACGIH | Water-soluble chromium (VI) compounds | Upper respiratory tract irritation and cancer | ACGIH 2007
ACGIH | Insoluble chromium (VI) compounds | Lung cancer | ACGIH 2007
ACGIH | Lead chromate | Male reproductive damage, teratogenic effects, and vasoconstriction | ACGIH 2007
ACGIH | As Pb | Male reproductive damage, teratogenic effects, and vasoconstriction | ACGIH 2007
ACGIH | As Cr | Male reproductive damage, teratogenic effects, and vasoconstriction | ACGIH 2007
ACGIH | Strontium chromate (as Cr) | Cancer | ACGIH 2007
ACGIH | Zinc chromates (as Cr) | Nasal cancer | ACGIH 2007
EPA | AEGL-1, -2, and -3 | No data | EPA 2007a
EPA | Second list of AEGL priority chemicals for guideline development | | EPA 2008a
EPA | Chromium (III) chloride | Yes | EPA 2008a
EPA | Hazardous air pollutant | | EPA 2007b 42 USC 7412
EPA | Chromium compounds | Yes | EPA 2007b 42 USC 7412
NIOSH | REL (8-hour TWA) | | NIOSH 2005
NIOSH | Chromium, metal, chromium (II), and chromium (III) compounds | 0.5 mg/m^3^ | NIOSH 2005
NIOSH | REL (10-hour TWA) | | NIOSH 2005
NIOSH | Chromium (VI) trioxide (as Cr)^d,e^ | 0.001 mg/m^3^ | NIOSH 2005
NIOSH | IDLH | | NIOSH 2005
NIOSH | Chromium, metal (as Cr) | 250 mg/m^3^ | NIOSH 2005
NIOSH | Chromium (VI) trioxide (as chromium [Vl])^e^ | 15 mg/m^3^ | NIOSH 2005
NIOSH | Target organs | | NIOSH 2005
NIOSH | Chromium, metal | Eyes, skin, and respiratory system | NIOSH 2005
NIOSH | Chromium (VI) trioxide | Blood, respiratory system, liver, kidneys, eyes, and skin | NIOSH 2005
NIOSH | Category of pesticides | | NIOSH 1992
NIOSH | Potassium chromate | Group 1 pesticide | NIOSH 1992
NIOSH | Potassium dichromate | Group 1 pesticide | NIOSH 1992
NIOSH | Sodium chromate | Group 1 pesticide | NIOSH 1992
OSHA | PEL (8-hour TWA) for general industry (ceiling limit) | | OSHA 2007a 29 CFR 1910.1000, Table Z-2
OSHA | Chromium (II) compounds (as Cr) | 0.5 mg/m^3^ | OSHA 2007a 29 CFR 1910.1000, Table Z-2
OSHA | Chromium (III) compounds (as Cr) | 0.5 mg/m^3^ | OSHA 2007a 29 CFR 1910.1000, Table Z-2
OSHA | Chromium metal and insoluble salt (as Cr) | 1.0 mg/m^3^ | OSHA 2007a 29 CFR 1910.1000, Table Z-2
OSHA | Chromium (VI) compounds | 5 µg/m^3^ | OSHA 2007d 29 CFR 1910.1026
OSHA | PEL (8-hour TWA) for shipyard industry (ceiling limit) | | OSHA 2007c 29 CFR 1915.1000
OSHA | Chromium (II) compounds (as Cr) | 0.5 mg/m^3^ | OSHA 2007c 29 CFR 1915.1000
OSHA | Chromium (III) compounds (as Cr) | 0.5 mg/m^3^ | OSHA 2007c 29 CFR 1915.1000
OSHA | Chromium metal and insoluble salt (as Cr) | 1.0 mg/m^3^ | OSHA 2007c 29 CFR 1915.1000
OSHA | Chromium (VI) compounds | 0.5 µg/m^3^ | OSHA 2007e 29 CFR 1915.1026
OSHA | PEL (8-hour TWA) for construction industry (ceiling limit) | | OSHA 2007b 29 CFR 1926.55, Appendix A
OSHA | Chromium (II) compounds (as Cr) | 0.5 mg/m^3^ | OSHA 2007b 29 CFR 1926.55, Appendix A
OSHA | Chromium (III) compounds (as Cr) | 0.5 mg/m^3^ | OSHA 2007b 29 CFR 1926.55, Appendix A
OSHA | Chromium metal and insoluble salt (as Cr) | 1.0 mg/m^3^ | OSHA 2007b 29 CFR 1926.55, Appendix A
OSHA | Chromium (VI) compounds | 0.5 µg/m^3^ | OSHA 2007f 29 CFR 1926.1126
b. Water
EPA | Designated as hazardous substances in accordance with Section 311 (b)(2)(A) of the Clean Water Act | | EPA 2008b 40 CFR 116.4
EPA | Ammonium dichromate | Yes | EPA 2008b 40 CFR 116.4
EPA | Calcium chromate | Yes | EPA 2008b 40 CFR 116.4
EPA | Chromium (III) sulfate | Yes | EPA 2008b 40 CFR 116.4
EPA | Potassium chromate | Yes | EPA 2008b 40 CFR 116.4
EPA | Strontium chromate | Yes | EPA 2008b 40 CFR 116.4
EPA | Drinking water standards and health advisories | | EPA 2006a
EPA | Chromium (total) | | EPA 2006a
EPA | 1-day health advisory for a 10-kg child | 1 mg/L | EPA 2006a
EPA | 10-day health advisory for a 10-kg child | 1 mg/L | EPA 2006a
EPA | DWEL | 0.1 mg/L | EPA 2006a
EPA | Lifetime | No data | EPA 2006a
EPA | National secondary drinking water standards | | EPA 2003
EPA | Chromium (total) | | EPA 2003
EPA | MCL | 0.1 mg/L | EPA 2003
EPA | Public health goal | 0.1 mg/L | EPA 2003
EPA | National recommended water quality criteria^g^ | No data | EPA 2006b
EPA | Chromium (III) | | EPA 2006b
EPA | Freshwater CMC | 570 µg/L | EPA 2006b
EPA | Freshwater CCC | 74 µg/L | EPA 2006b
EPA | Chromium (VI) | | EPA 2006b
EPA | Freshwater CMC | 16 µg/L | EPA 2006b
EPA | Freshwater CCC | 11 µg/L | EPA 2006b
EPA | Saltwater CMC | 1,100 µg/L | EPA 2006b
EPA | Saltwater CCC | 50 µg/L | EPA 2006b
EPA | Toxic pollutants designated pursuant to Section 307(a)(1) of the Clean Water Act | | EPA 2008i 40 CFR 401.15
EPA | Chromium and compounds | Yes | EPA 2008i 40 CFR 401.15
EPA | Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | | EPA 2008c 40 CFR 117.3
EPA | Chromium (III) sulfate | 100 pounds | EPA 2008c 40 CFR 117.3
EPA | Potassium chromate | 10 pounds | EPA 2008c 40 CFR 117.3
EPA | Strontium chromate | 10 pounds | EPA 2008c 40 CFR 117.3
c. Food
EPA | Inert ingredients permitted for use in nonfood use pesticide products | | EPA 2008e
EPA | Chromium (III) oxide | Yes | EPA 2008e
EPA | Sodium chromate | Yes | EPA 2008e
FDA | Bottled drinking water | | FDA 2007a 21 CFR 165.110
FDA | Chromium | 0.1 mg/L | FDA 2007a 21 CFR 165.110
FDA | EAFUS^h^ | No data | FDA 2008
FDA | Indirect food additives: adhesives and components of coatings | | FDA 2007b 21 CFR 175.105
FDA | Sodium chromate | Yes | FDA 2007b 21 CFR 175.105
FDA | Recommended daily intake | | FDA 2007c 21 CFR 101.9
FDA | Chromium | 120 µg | FDA 2007c 21 CFR 101.9
d. Other
ACGIH | Carcinogenicity classification | | ACGIH 2007
ACGIH | Calcium chromate (as Cr) | A2^i^ | ACGIH 2007
ACGIH | Chromium | | ACGIH 2007
ACGIH | Metal and chromium (III) compounds | A4^j^ | ACGIH 2007
ACGIH | Water-soluble chromium (VI) compounds | A1^k^ | ACGIH 2007
ACGIH | Insoluble chromium (VI) compounds | A1^k^ | ACGIH 2007
ACGIH | Lead chromate | | ACGIH 2007
ACGIH | As Pb | A2^i^ | ACGIH 2007
ACGIH | As Cr | A2^i^ | ACGIH 2007
ACGIH | Strontium chromate (as Cr) | A2^i^ | ACGIH 2007
ACGIH | Zinc chromates (as Cr) | A1^k^ | ACGIH 2007
ACGIH | Biological exposure indices | | ACGIH 2007
ACGIH | Chromium | | ACGIH 2007
ACGIH | Water-soluble chromium (VI) fume | | ACGIH 2007
ACGIH | Total chromium in urine at end of shift at end of workweek | 25 µg/L | ACGIH 2007
ACGIH | Total chromium in urine increase during shift | 10 µg/L | ACGIH 2007
EPA | Carcinogenicity classification | | IRIS 2008
EPA | Chromium(III), insoluble salts | Group D^l^ | IRIS 2008
EPA | Chromium (VI) | | IRIS 2008
EPA | Inhalation route of exposure | Group A^m^ | IRIS 2008
EPA | Oral route of exposure | Group D^l^ | IRIS 2008
EPA | RfC | | IRIS 2008
EPA | Chromium(III), insoluble salts | Not available | IRIS 2008
EPA | Chromium (VI) | | IRIS 2008
EPA | Chromic acid mists and dissolved Cr (VI) aerosols | 8×10^−6^ mg/m^3^ | IRIS 2008
EPA | Cr(VI) particulates | 1×10^−4^ mg/m^3^ | IRIS 2008
EPA | RfD | | IRIS 2008
EPA | Chromium(III), insoluble salts | 1.5 mg/kg/day | IRIS 2008
EPA | Chromium (VI) | 3×10^−3^ mg/kg/day | IRIS 2008
EPA | Master Testing List | Yes^n^ | EPA 2008f
EPA | RCRA waste minimization PBT priority chemical list | | EPA 1998c 63 FR 60332
EPA | Chromium | Yes | EPA 1998c 63 FR 60332
EPA | Standards for owners and operators of hazardous waste TSD facilities; groundwater monitoring list | | EPA 2008d 40 CFR 264, Appendix IX
EPA | Chromium (total) | Yes | EPA 2008d 40 CFR 264, Appendix IX
EPA | Superfund, emergency planning, and community right-to-know | | EPA 2008d 40 CFR 264, Appendix IX
EPA | Designated CERCLA hazardous substance | | EPA 2008j 40 CFR 302.4
EPA | Ammonium dichromate | Yes^o^ | EPA 2008j 40 CFR 302.4
EPA | Calcium chromate | Yes^o,p^ | EPA 2008j 40 CFR 302.4
EPA | Chromium | Yes^q^ | EPA 2008j 40 CFR 302.4
EPA | Chromium and compounds | Yes^r^ | EPA 2008j 40 CFR 302.4
EPA | Chromium (III) sulfate | Yes^o^ | EPA 2008j 40 CFR 302.4
EPA | Potassium chromate | Yes^o^ | EPA 2008j 40 CFR 302.4
EPA | Strontium chromate | Yes^o^ | EPA 2008j 40 CFR 302.4
EPA | Superfund, emergency planning, and community right-to-know | | EPA 2008j 40 CFR 302.4
EPA | Reportable quantity | | EPA 2008j 40 CFR 302.4
EPA | Ammonium dichromate | 10 pounds | EPA 2008j 40 CFR 302.4
EPA | Chromium | 5,000 pounds | EPA 2008j 40 CFR 302.4
EPA | Calcium chromate | 10 pounds | EPA 2008j 40 CFR 302.4
EPA | Chromium and compounds | None^s^ | EPA 2008j 40 CFR 302.4
EPA | Chromium (III) sulfate | 1,000 pounds | EPA 2008j 40 CFR 302.4
EPA | Potassium chromate | 10 pounds | EPA 2008j 40 CFR 302.4
EPA | Strontium chromate | 10 pounds | EPA 2008j 40 CFR 302.4
EPA | Effective date of toxic chemical release reporting | | EPA 2008h 40 CFR 372.65
EPA | Chromium | 01/01/1987 | EPA 2008h 40 CFR 372.65
EPA | Extremely Hazardous Substances | | EPA 2008g 40 CFR 355, Appendix A
EPA | Chromium (III) chloride | | EPA 2008g 40 CFR 355, Appendix A
EPA | Reportable quantity | 1 pound | EPA 2008g 40 CFR 355, Appendix A
EPA | Threshold planning quantity | 1,000 pounds | EPA 2008g 40 CFR 355, Appendix A
NTP | Carcinogenicity classification | | NTP 2005
NTP | Chromium (VI) compounds | Known to be human carcinogens | NTP 2005
NTP | Calcium chromate | Known to be human carcinogens | NTP 2005
NTP | Chromium (VI) trioxide | Known to be human carcinogens | NTP 2005
NTP | Ferrochromite | Known to be human carcinogens | NTP 2005
NTP | Lead chromate | Known to be human carcinogens | NTP 2005
NTP | Strontium chromate | Known to be human carcinogens | NTP 2005
NTP | Zinc chromate | Known to be human carcinogens | NTP 2005

a Group 3: The agent is not classifiable as to its carcinogenicity to humans.

b Group 1: The agent is carcinogenic to humans.

c Provisional guideline value, as there is evidence of a hazard, but the available information on health effects is limited.

d The NIOSH REL (10-hour TWA) is 0.001 mg Cr(VI)/m^3^ for all hexavalent chromium (Cr[(VI]) compounds. NIOSH considers all chromium (VI) compounds (including chromic acid, tert-butyl chromate, zinc chromate, and chromyl chloride) to be potential occupational carcinogens.

e NIOSH potential occupational carcinogen.

f Group 1 pesticides: contains the pesticides that pose a significant risk of adverse acute health effects at low concentrations.

g The CMC is an estimate of the highest concentration of a material in surface water to which an aquatic community can be exposed briefly without resulting in an unacceptable effect. The CCC is an estimate of the highest concentration of a material in surface water to which an aquatic community can be exposed indefinitely without resulting in an unacceptable effect.

h The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

i A2: Suspected human carcinogen.

j A4: Not classifiable as a human carcinogen.

k A1: Confirmed human carcinogen.

l Group D: not classified as to its human carcinogenicity.

m Group A: known human carcinogen by the inhalation route of exposure.

n Chromium was recommended to the MTL by ATSDR in 1994 and the testing needs development is currently underway. The testing needs include acute toxicity, neurotoxicity, reproductive, and immunotoxicity health effects.

o Designated CERCLA hazardous substance pursuant to Section 311(b)(2) of the Clean Water Act.

p Designated CERCLA hazardous substance pursuant to Section 3001 of the Resource Conservation and Recovery Act.

q Designated CERCLA hazardous substance pursuant to Section 307(a) of the Clean Water.

r Designated CERCLA hazardous substance pursuant to Section 307(a) of the Clean Water Act and Section 112 of the Clean Air Act.

s Indicates that no reportable quantity is being assigned to the generic or broad class.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; CCC = Criterion Continuous Concentration; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; CMC = Criteria Maximum Concentration; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FR = Federal Register; GRAS = Generally Recognized As Safe; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MTL = Master Testing List; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PBT = persistant, bioacumulative, and toxic; PEL = permissible exposure limit; RCRA = Resource Concervation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TSD = transport, storage, and disposal; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization