# CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of chromium is located in Table 4-1.

The synonyms, trade name, chemical formula, and identification numbers of chromium and selected salts are reported in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of chromium is located in Table 4-2.

Chromium is a metallic element with oxidation states ranging from chromium(-II) to chromium(+VI) with the trivalent (III) and hexavalent (VI) sates being the most predominant. The Chemical Abstracts Service (CAS) Registry numbers for trivalent and hexavalent chromium are 16065-83-3 and 18540-29-9, respectively. Elemental chromium, chromium(0), does not occur naturally. Although there is a divalent state, chromium II (chromous), it is relatively unstable under environmental conditions and is readily oxidized to the trivalent (III or chromic) state. Chromium compounds are most stable in the trivalent state under environmental conditions and occur in nature in ores, such as ferrochromite (FeCr_2_O_4_). The hexavalent (VI or chromate) is the second most stable state; however, it only occurs naturally in rare minerals such as crocoite (PbCrO_4_) (Hurlbut 1971; Papp and Lipin 2001). Hexavalent chromium compounds primarily arise from anthropogenic sources (Alimonti et al. 2000; Barceloux 1999; EPA 1984a; Johnson et al. 2006; Shanker et al. 2005).

The solubility of chromium compounds varies, depending primarily on the oxidation state. Trivalent chromium compounds, with the exception of acetate, hexahydrate of chloride, and nitrate salts, are generally insoluble in water (Table 4-2). The zinc and lead salts of chromic acid are practically insoluble in cold water (Table 4-2). The alkaline metal salts (e.g., calcium, strontium) of chromic acid are slightly soluble in water. Some hexavalent compounds, such as chromium(VI) oxide (or chromic acid), and the ammonium and alkali metal salts (e.g., sodium and potassium) of chromic acid are readily soluble in water. The hexavalent chromium compounds are reduced to the trivalent form in the presence of oxidizable organic matter. However, in natural waters where there is a low concentration of reducing materials, hexavalent chromium compounds are more stable (EPA 1984a; Loyaux-Lawniczak et al. 2001).

Table 4-1 Chemical Identity of Chromium and Compounds

Characteristic | Information
Chemical name | Chromium(O) | Chromium(III) acetate, monohydrate | Chromium(III) nitrate, nonahydrate
Synonym(s) | Chrome; Chrom (German); Chrome (French) | Acetic acid, chromium salt, hydrate; chromic acetate, hydrate | Nitric acid, chromium (III) salt, nonahydrate; chromium nitrate, nonahydrate
Registered trade name(s) | Chrome | No data | No data
Chemical formula | Cr | Cr(CH_3_COO)_3_•H_2_) | Cr(NO_3_)_3_•9H_2_O
Chemical structure | Cr
Identification numbers:
CAS registry | 7440-47-3 | 25013-82-5 | 7789-02-8
NIOSH RTECS | GB420000 | AG3053333 | GB6300000
EPA hazardous waste | D007 | No data | No data
OHM/TADS | 7216647 | No data | No data
DOT/UN/NA/IMDG shipping | Not assigned | No data | No data
HSDB | 910 | No data | No data
NCI | Not assigned | No data | No data
Chemical name | Chromium(III) chloride | Chromium(III) chloride, hexahydrate | Chromite (Cr_2_FeO_4_) (Chromium[III])
Synonym(s) | Chromium trichloride | Hexaaquachromium (III) chloride | Chromite; chromite ore; chromite homog mineral; chromite (mineral)
Registered trade name(s) | C177295 | No data | No data
Chemical formula | CrCI_3_ | Cr(CI)_3_•6H_2_O | FeCr_2_O_4_
Chemical structure | | Cr[CI_2_(H_2_O)_4_]CI•2H_2_O | FeOCr_2_O_3_
Identification numbers:
CAS registry | 10025-73-7 | 10060-12-5 | 1308-31-2
NIOSH RTECS | GB5425000 | GB5450000 | GB4000000
EPA hazardous waste | No data | No data | D007
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMDG shipping | No data | No data | No data
HSDB | No data | No data | 2963
NCI | No data | No data | No data
Chemical name | Chromium(III) oxide | Chromium(III) phosphate | Chromium(III) sulfate
Synonym(s) | Chromium sesquioxide; dichromium trioxide; chromic oxide | Chromumorthophos-phate; phosphoric acid, chromium (III) salt | Sulfuric acid, chromium (III) salt
Registered trade name(s) | No data | Amaudon's Green | Chromitan B
Chemical formula | Cr_2_O_3_ | CrPO_4_ | Cr_2_(SO_4_)_3_
Chemical structure | O=Cr-O-Cr=O | | SO_4_=Cr-SO_4_-Cr=SO_4_
Identification numbers:
CAS registry | 1308-38-9 | 7789-04-0 | 10101-53-8
NIOSH RTECS | GB6475000 | GB6840000 | GB7200000
EPA hazardous waste | D007 | No data | D0007
OHM/TADS | Not assigned | No data | 7800052
DOT/UN/NA/IMDG shipping | Not assigned | No data | Not assigned
HSDB | 1619 | No data | 2543
NCI | Not assigned | No data | Not assigned
Chemical name | Sodium chromite (Chromium[III]) | Chromium hydroxide sulfate (Chromium III) | Chromium(III) picolinate
Synonym(s) | No data | Chromium hydroxide sulfate (Cr(OH)(SO_4_)); basic chromium sulfate | CrPic; Chromium 2-pyridinecarboxylate; Chromium tris(picolinato)-; Picolinic acid, chromium salt
Registered trade name(s) | No data | No data | No data
Chemical formula | NaCrO_2_ | CrOHSO_4_ | C_18_H_12_CrN_3_O_6_
Chemical structure | NaO-Cr=O
Identification numbers:
CAS registry | 12314-42-0 | 12336-95-7 | 14639-25-9
NIOSH RTECS | No data | GB6240000 | No data
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMDG shipping | No data | No data | No data
HSDB | No data | No data | No data
NCI | No data | No data | No data
Chemical name | Chromic acid (Chromium VI) | Chromium(IV) oxide | Ammonium dichromate (Chromium[VI])
Synonym(s) | Acide chromique; chromic(VI) acid | Chromium dioxide | Chromic acid, diamonium salt
Registered trade name(s) | No data | No data | No data
Chemical formula | H_2_CrO_4_ | CrO_2_ | (NH_4_)_2_Cr_2_O_7_
Chemical structure | | O=Cr=O
Identification numbers:
CAS registry | 7738-94-5 | 12018-01-8 | 7789-09-5
NIOSH RTECS | GB6650000 | GB6400000 | HX7650000
EPA hazardous waste | No data | D007 | Not assigned
OHM/TADS | No data | No data | 7217321
DOT/UN/NA/IMDG shipping | 1755 | No data | UN1439; IM05.1
HSDB | 6769 | 1620 | 481
NCI | No data | No data | No data
Chemical name | Calcium chromate (Chromium[VI]) | Chromium(VI) trioxide | Lead chromate (Chromium[VI])
Synonym(s) | Chromic acid, calcium salt | Chromic acid, chromium anhydride | Chromic acid, lead salt
Registered trade name(s) | Calcium Chrome Yellow | No data | Chrome Yellow G
Chemical formula | CaCrO_4_ | CrO_3_ | PbCrO_4_
Chemical structure
Identification numbers:
CAS registry | 13765-19-0 | 1333-82-0 | 7758-97-6
NIOSH RTECS | GB2750000 | GB6650000 | GB2975000
EPA hazardous waste | U032; D007 | D007 | D007; D008
OHM/TADS | 7800051 | Not assigned | Not assigned
DOT/UN/NA/IMDG shipping | NA9096 | YB1463/UNI5.1; IM05.1 | Not assigned
HSDB | 248 | 518;NA1463 | 1650
NCI | Not assigned | UN1463 | Not assigned
Chemical name | Potassium chromate (Chromium[VI]) | Potassium dichromate (Chromium[VI]) | Sodium chromate (Chromium[VI])
Synonym(s) | Chromic acid, dipotassium salt | Chromic acid, dipotassium salt | Chromic acid, disodium salt
Registered trade name(s) | No data | No data | Caswell No. 757
Chemical formula | K2CrO4 | K_2_Cr_2_O_7_ | Na_2_CrO_4_
Chemical structure
Identification numbers:
CAS registry | 7789-00-6 | 7778-50-9 | 7775-11-3
NIOSH RTECS | GB2940000 | HX7680000 | GB2955000
EPA hazardous waste | No data | No data | D007
OHM/TADS | 7217277 | 7217278 | 7216891
DOT/UN/NA/IMDG shipping | NA9142 | NA1479; IM09.0 | No data
HSDB | 1249 | 1238 | 2962
NCI | Not assigned | Not assigned | Not assigned
Chemical name | Sodium dichromate, dihydrate (Chromium[VI]) | Strontium chromate (Chromium[VI])
Synonym(s) | Chromic acid, disodium salt; dihydrate | Chromic acid, strontium salt
Registered trade name(s) | No data | No data
Chemical formula | NaCr_2_O_7_-2H_2_O | SrCrO_4_
Chemical structure
Identification numbers:
CAS registry | 7789-12-0 | 7789-06-2
NIOSH RTECS | HX7750000 | GB3240000
EPA hazardous waste | No data | D007
OHM/TADS | No data | 780058
DOT/UN/NA/IMDG shipping | No data | NA9149
HSDB | No data | 2546
NCI | No data | Not assigned
Chemical name | Zinc chromate (Chromium[VI]) | Sodium dichromate (Chromium VI)
Synonym(s) | Chromic acid, zinc salt | Chromic acid (H_2_Cr_2_O_7_), sodium salt (1:2)
Registered trade name(s) | Cl Pigment Yellow | No data
Chemical formula | ZnCrO_4_ | Na_2_Cr_2_O_7_
Chemical structure
Identification numbers:
CAS registry | 13530-65-9 | 10588-01-9
NIOSH RTECS | GB3290000 | HX7700000
EPA hazardous waste | D007 | D007
OHM/TADS | 7217401 | No data
DOT/UN/NA/IMDG shipping | Not assigned | 3288
HSDB | 6188 | 737
NCI | Not assigned | No data

Sources: HSDB 2012; NIOSH 2005

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Chromium and Compounds

Property | Chromium | Chromium(III) acetate, monohydrate | Chromium(III) nitrate, nonahydrate | Chromium(III) chloride
Molecular weight | 51.996 | 229.13 | 400.15 | 158.35
Color | Steel-gray | Gray-green or bluish-green | Purple or violet | Violet or purple
Physical state | Solid | Solid | Solid | Solid
Melting point | 1,90±10 °C | No data | 60 °C | ≈1,150 °C
Boiling point | 2,642 °C | No data | Decomposes at 100 °C | Decomposes at 1,300 °C
Density at 20 °C | 7.14 (28 °C)^a^ | No data | No data | 2.87 (25 °C)^a^
Odor | odorless | No data | No data | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water at 20 °C | Insoluble | Soluble | Soluble | Slightly soluble in hot water
Organic solvents | Insoluble in common organic solvents | 45.4 g/L in methanol (15 °C); 2 g/L in acetone (15 °C) | Soluble in ethanol and acetone | Insoluble in cold water, acetone, methanol, and ether
Partition coefficients:
Log K_ow_ | Not applicable | Not applicable | Not applicable | Not applicable
Log K_oc_ | Not applicable | Not applicable | Not applicable | Not applicable
Vapor pressure at 20 °C | 1 mmHg (1,616 °C) | No data | No data | No data
Henry's law constant at 25 °C | Not applicable | Not applicable | Not applicable | Not applicable
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data
Conversion factors | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data

Property | Chromium(III) chloride, hexahydrate | Ferrochromite (Chromium [III]) | Chromium(III) oxide | Chromium(III) phosphate
Molecular weight | 266.45 | 223.84 | 151.99 | 146.97
Color | Violet | Brown-black | Green | Gray-brown to black^d^
Physical state | Solid | Solid | Solid | Solid
Melting point | 83 °C | No data | 2,435 °C | >1,800 °C
Boiling point Density at 20 °C | No data 1.76^b^ | No data 4.97 (20 °C) | 3,000 °C 5.22 (25 °C)^b^ | No data 2.94 (32.5 °C)^a, c^
Odor | No data | No data | No data | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water at 20 °C | 58.5 g/100 cc at 25 °C | Insoluble | Insoluble | Insoluble^c^
Organic solvents | Soluble in ethanol | No data | Insoluble in ethanol | Insoluble in alcohol, acetone
Partition coefficients:
Log K_ow_ | No data | Not applicable | Not applicable | Not applicable
Log K_oc_ | No data | Not applicable | Not applicable | Not applicable
Vapor pressure at 20 °C | No data | No data | No data | No data
Henry's law constant at 25 °C | No data | Not applicable | Not applicable | Not applicable
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data
Conversion factors | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data

Property | Chromium (III) sulfate | Sodium chromite (Chromium[III]) | Chromium hydroxide sulfate (Chromium III)^e^ | Chromium(III) picolinate
Molecular weight | 392.18 | 106.98 | 165.1 | 418.3^c^
Color | Violet, red, peach | No data | Green powder | Ruby red^d^
Physical state | Solid | No data | Solid | Crystal^d^
Melting point | No data | No data | >900 °C | No data
Boiling point | No data | No data | No data | No data
Density at 20 °C | 3.012 | No data | 1.25 | No data
Odor | No data | No data | No data | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water at 20 °C | Insoluble | No data | 2,000 g/L | 1 ppm at 25 °C^d^
Organic solvents | soluble in alcohols | No data | No data | >6 g/L (DMSO)^d^
Partition coefficients:
Log K_ow_ | Not applicable | Not applicable | Not applicable | 1.753^f^
Log K_oc_ | Not applicable | Not applicable | Not applicable | No data
Vapor pressure at 20 °C | No data | No data | No data | No data
Henry's law constant at 25 °C | Not applicable | Not applicable | Not applicable | No data
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data
Conversion factors | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data

Property | Chromic acid (Chromium[VI]) | Chromium(IV) oxide | Ammonium dichromate (Chromium[VI])
Molecular weight | 118 | 83.99 | 252.07
Color | Dark purple-red | Brown-black | Orange
Physical state | Solid | Solid | Solid
Melting point | 196 °C | Decomposes at 300 °C | Decomposes at 180 °C
Boiling point | Decompose before boiling | Not applicable | Not applicable
Density at 20 °C | 1.67–2.82 | No data | 2.15 (25 °C)^a^
Odor | No data | No data | odorless
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water at 20 °C | 1x10^6^ mg/L at 17 °C | Insoluble | In water (wt/wt): 15.5% (0 °C); 26.67% (20 °C); 36.99% (40 °C); 46.14% (60 °C); 54.20% (80 °C)
Organic solvents | Soluble in alcohol and mineral acids | No data | Soluble in alcohols, insoluble in acetone
Partition coefficients:
Log K_ow_ | Not applicable | Not applicable | Not applicable
Log K_oc_ | Not applicable | Not applicable | Not applicable
Vapor pressure at 20 °C | No data | No data | No data
Henry's law constant at 25 °C | Not applicable | Not applicable | Not applicable
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | No data | No data | No data
Conversion factors | No data | No data | No data
Explosive limits | No data | No data | No data

Property | Calcium chromate (Chromium[VI]) | Chromium(VI) trioxide | Lead chromate (Chromium[VI]) | Potassium chromate (Chromium[VI])
Molecular weight | 156.07 | 99.99 | 323.19 | 194.19
Color | Yellow | Red | Yellow | Yellow
Physical state | Solid | Solid | Solid | Solid
Melting point | No data | 197 °C | 844 °C | 975 °C
Boiling point | No data | Decomposes | Decomposes | No data
Density at 20 °C | 2.89^b^ | 2.70 (25 °C) | 6.12 (15 °C) | 2.732 (18 °C)
Odor | No data | Odorless | No data | Odorless
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water at 20 °C | 2.23g/100mL | 61.7g/100ccat 0°C | 5.8 (ig/100 mL | 62.9 g/100 at 20 °C
Organic solvents | No data | Soluble in ethanol, ethyl ether, sulfuric and nitric acids Soluble 61.7 g/100 cc water (0°C) 67.45 g/100 cc water (100 °C) 167.299 lb/100 Ib water (70 °F) Soluble in acetic acid and acetone | Soluble 0.2 mg/l water Insoluble in acetic acid; soluble in dilute nitric acid and in solution of fixed alkali hydroxides Soluble in acid, insoluble in ammonia | 62.9 G/100 cc water (20 °C) 79.2 g/100 cc water (100 °C) Insoluble in alcohol
Partition coefficients:
Log K_ow_ | Not applicable | Not applicable | Not applicable | Not applicable
Log K_oc_ | Not applicable | Not applicable | Not applicable | Not applicable
Vapor pressure at 20 °C | No data | No data | No data | 0
Henry's law constant at 25 °C | Not applicable | Not applicable | Not applicable | Not applicable
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data
Conversion factors | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data

Property | Potassium dichromate (Chromium[VI]) | Sodium chromate (Chromium[VI]) | Sodium dichromate, dihydrate (Chromium[VI])
Molecular weight | 294.18 | 161.97 | 298.00
Color | Red | Yellow | Red
Physical state | Solid | Solid | Solid
Melting point | 398 °C | 792 °C | 356.7 °C
Boiling point | Decomposes at 500 °C | No data | Decomposes at 400 °C
Density at 20 °C | 2.676 (25 °C) | 2.710B2.736b | 2.52 (13 °C)
Odor | No data | No data | No data
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water at 20 °C | 4.9 g/100 cc at 0 °C | 87.3 g/100 cc at 30 °C | 230 g/100 cc at 0 °C
Organic solvents | Insoluble in ethanol and acetone | Soluble in methanol | Insoluble in ethanol
Partition coefficients:
Log K_ow_ | Not applicable | Not applicable | Not applicable
Log K_oc_ | Not applicable | Not applicable | Not applicable
Vapor pressure at 20 °C | No data | No data | No data
Henry's law constant at 25 °C | Not applicable | Not applicable | Not applicable
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | No data | No data | No data
Conversion factors | No data | No data | No data
Explosive limits | No data | No data | No data

Property | Strontium chromate (Chromium[VI]) | Zinc chromate (Chromium[VI]) | Sodium dichromate (Chromium[VI])
Molecular weight | 203.61 | 181.97 | 262
Color | Yellow | Lemon-yellow | Bright orange-red
Physical state | Solid | Solid | Solid
Melting point | No data | No data | 356.7 °C
Boiling point | No data | No data | Decomposes at 400 °C
Density at 20 °C | 3.895 (15 °C) | 3.40b | 2.52 at 13 °C
Odor | No data | Odorless | Odorless
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water at 20 °C | 0.12 g/100 cc at 15 °C | Insoluble | 2,380 g/L at 0 °C
Organic solvents | Soluble in acetyl acetone | Insoluble in acetone | 513.4 g/L (methanol)
Partition coefficients:
Log K_ow_ | Not applicable | Not applicable | Not applicable
Log K_oc_ | Not applicable | Not applicable | Not applicable
Vapor pressure at 20 °C | No data | No data | No data
Henry's law constant at 25 °C | Not applicable | Not applicable | Not applicable
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | No data | No data | No data
Conversion factors | No data | No data | No data
Explosive limits | No data | No data | No data

a Temperature at which the densities were measured has been given only when such data are available

b Temperature at which density was measured was not specified.

c O’Neil et al. 2006

d Broadhurst et al. 1997

e IPCS 2004

f Chakov et al. 1999

DMSO=dimethylsulfoxide

In humans, chromium(III) is an essential nutrient that may play a role in glucose, fat, and protein metabolism possibly by potentiating the action of insulin. However, there is some emerging controversy whether chromium(III) is essential and more work has been suggested to elucidate its mechanism of action. Chromium picolinate, a trivalent form of chromium complexed with picolinic acid, is used as a dietary supplement, because it is claimed to speed metabolism and may have anti-diabetic effects (Broadhurst et al. 1997). However, there still remains controversy over the use of chromium(III) in diabetes, and several researchers claim no demonstrated effects of chromium(III) on diabetes or insulin resistance (Althuis et al. 2002). Currently, the mechanism of transport and absorption of chromium picolinate has not been determined, although spectroscopic analysis has shown that chromium picolinate is a very stable complex in the body and its absorption properties may be due to its ability to cross membranes (Chakov et al. 1999).