# REGULATIONS, ADVISORIES, AND GUIDELINES

MRLs are substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

ATSDR has derived an acute-duration inhalation MRL of 0.03 µg Cd/m^3^ for cadmium. This MRL is based on a LOAEL of 0.088 mg Cd/m^3^ (LOAEL_HEC_ of 0.01 mg Cd/m^3^) for respiratory effects in rats exposed to cadmium oxide 6.2 hours/day, 5 days/week for 2 weeks (NTP 1995) and an uncertainty factor of 300 (10 for the use of a LOAEL, 3 for extrapolation from animals to humans with dosimetric adjustments, and 10 for human variability).

ATSDR has derived a chronic-duration inhalation MRL of 0.01 µg Cd/m^3^ for cadmium. This MRL is based on the 95% lower confidence limit of the urinary cadmium level associated with a 10% extra risk of low molecular weight proteinuria (UCDL_10_) estimated from a meta-analysis of environmental exposure data. An air concentration that would result in this urinary cadmium level (0.5 µg/g creatinine), assuming a dietary cadmium intake of 0.3 µg/kg/day, was estimated using biokinetic models. The estimated air concentration of 0.1 µg Cd/m^3^ was divided by an uncertainty factor of 3 for human variability and a modifying factor of 3.

The EPA has not established a reference concentration (RfC) for cadmium.

ATSDR has derived an intermediate-duration oral MRL of 0.5 µg Cd/kg/day for cadmium. This MRL is based on a BMDL_std1_ of 0.05 mg Cd/kg/day for skeletal effects in young female rats exposed to cadmium chloride in drinking water for 6, 9, or 12 months (Brzóska and Moniuszko-Jakoniuk 2005d) and an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

ATSDR has derived a chronic-duration oral MRL of 0.1 µg Cd/kg/day for cadmium. This MRL is based on the UCDL_10_ for low molecular weight proteinuria estimated from a meta-analysis of environmental exposure data. A cadmium intake that would result in the UCDL_10_ (0.5 µg/g creatinine) at age 55 was estimated using pharmacokinetic models. The cadmium intake of 0.33 µg/kg/day was divided by an uncertainty factor of 3 for human variability.

The EPA has established a reference dose (RfD) of 5×10^−4^ mg/kg/day in water and 1×10^−3^ mg/kg/day in food (IRIS 2012). The RfD is based on a chronic intake that would result in a kidney concentration of 200 µg/g ww.

The international and national regulations, advisories, and guidelines regarding cadmium in air, water, and other media are summarized in Table 8-1.

Cadmium compounds are included on the list of 189 chemicals listed as hazardous air pollutants under Section 112 of the Clean Air Act as amended (EPA 2007). Cadmium also is on the list of chemicals appearing in the Emergency Planning and Community Right-To-Know Act of 1986 (EPA 2008g). Under Title III of this statute, owners and operators of facilities that manufacture, import, process, or otherwise use the chemicals on this list of report annually their release of those chemicals to any environmental media.

Cadmium and cadmium chloride are designed as hazardous substances under Section 311 of the Clean Water Act; any discharge of these chemicals over a specified threshold level into navigable waters is subject to reporting requirements (EPA 2008c).

Cadmium is a hazardous waste under the Resource Conservation and Recovery Act (RCRA) under several circumstances. Groundwater monitoring is required at municipal solid waste landfills (EPA 2008d) and cadmium is considered a priority persistent, bioaccumulative, and toxic (PBT) chemical under RCRA waste minimization chemical listing (EPA 1998).

Table 8-1 Regulations, Advisories, and Guidelines Applicable to Cadmium

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | | IARC 2008
IARC | Cadmium and cadmium compounds | Group 1^a^ | IARC 2008
WHO | Air quality guidelines | | WHO 2000
WHO | Cadmium^b,c^ | 5 ng/m^3^ | WHO 2000
WHO | Drinking water quality guidelines | | WHO 2004
WHO | Cadmium | 0.003 mg/L | WHO 2004
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | Biological exposure indices | | ACGIH 2007
ACGIH | Cadmium and inorganic compounds | | ACGIH 2007
ACGIH | Cadmium in urine | 5 µg/g creatinine | ACGIH 2007
ACGIH | Cadmium in blood | 5 µg/L | ACGIH 2007
ACGIH | TLV (8-hour TWA) | | ACGIH 2007
ACGIH | Cadmium | 0.01 mg/m^3^ | ACGIH 2007
ACGIH | Hazardous air pollutant | | EPA 2007
ACGIH | Cadmium compounds | Yes | 42 USC 7412
NIOSH | REL (10-hour TWA) | | NIOSH 2005
NIOSH | Cadmium^f^ | Potential occupational carcinogens | NIOSH 2005
NIOSH | Cadmium oxide | Potential occupational carcinogens | NIOSH 2005
NIOSH | IDLH | | NIOSH 2005
NIOSH | Cadmium (as Cd) | 9 mg/m^3^ | NIOSH 2005
NIOSH | Cadmium oxide (as Cd) | 9 mg/m^3^ | NIOSH 2005
NIOSH | Category of pesticides | | NIOSH 1992b
NIOSH | Cadmium carbonate | Group II pesticide^g^ | NIOSH 1992b
NIOSH | Cadmium chloride | Group I pesticide^h^ | NIOSH 1992b
NIOSH | Cadmium sulfate | Group II pesticide^g^ | NIOSH 1992b
OSHA | PEL (8-hour TWA) for general industry | | OSHA 2007a
OSHA | Cadmium (as Cd) | 5 µg/m^3^ | 29 CFR 1910.1027
OSHA | PEL (8-hour TWA) for shipyard industry | | OSHA 2007b
OSHA | Cadmium (as Cd) | 5 µg/m^3^ | 29 CFR 1915.1027
OSHA | PEL (8-hour TWA) for construction industry | | OSHA 2007c
OSHA | Cadmium (as Cd) | 5 µg/m^3^ | 29 CFR 1926.1127
b. Water
EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | | EPA 2008b 40 CFR 116.4
EPA | Cadmium chloride | Yes | EPA 2008b 40 CFR 116.4
EPA | Drinking water standards and health advisories | | EPA 2011b
EPA | Cadmium | | EPA 2011b
EPA | 1-day health advisory for a 10-kg child | 0.04 mg/L | EPA 2011b
EPA | 10-day health advisory for a 10-kg child | 0.04 mg/L | EPA 2011b
EPA | DWEL | 0.02 mg/L | EPA 2011b
EPA | Lifetime | 0.005 mg/L | EPA 2011b
EPA | National primary drinking water standards | | EPA 2009b
EPA | Cadmium | | EPA 2009b
EPA | MCL | 0.005 mg/L | EPA 2009b
EPA | Public health goal | 0.005 mg/L | EPA 2009b
EPA | Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | | EPA 2008c 40 CFR 117.3
EPA | Cadmium chloride | 10 pounds | EPA 2008c 40 CFR 117.3
EPA | Toxic pollutants designated pursuant to Section 307(a)(1) of the Clean Water Act | | EPA 2008h 40 CFR 401.15
EPA | Cadmium and compounds | Yes | EPA 2008h 40 CFR 401.15
c. Food
FDA | Bottled drinking water | | FDA 2007
FDA | Cadmium | 0.005 mg/L | 21 CFR 165.110
FDA | EAFUS | No data | FDA 2008
d. Other
ACGIH | Carcinogenicity classification | | ACGIH 2007
ACGIH | Cadmium | A2^j^ | ACGIH 2007
ACGIH | Cadmium compounds (as Cd) | A2^j^ | ACGIH 2007
EPA | Carcinogenicity classification | | IRIS 2012
EPA | Cadmium | Group B1^k^ | IRIS 2012
EPA | Inhalation unit risk | | IRIS 2012
EPA | Cadmium | 1.8×10^−3^ per µg/m^3^ | IRIS 2012
EPA | RfC | | IRIS 2012
EPA | Cadmium | No data | IRIS 2012
EPA | RfD | | IRIS 2012
EPA | Cadmium | | IRIS 2012
EPA | Food | 1×10^−3^ mg/kg-day | IRIS 2012
EPA | Water | 5×10^−4^ mg/kg-day | IRIS 2012
EPA | RCRA waste minimization PBT priority chemical list | | EPA 1998 63 FR 60332
EPA | Cadmium | Yes | EPA 1998 63 FR 60332
EPA | Standards for owners and operators of hazardous waste TSD facilities; groundwater monitoring list | | EPA 2008d 40 CFR 264, Appendix IX
EPA | Cadmium | Yes | EPA 2008d 40 CFR 264, Appendix IX
EPA | Superfund, emergency planning, and community right-to-know | | EPA 2008d 40 CFR 264, Appendix IX
EPA | Designated CERCLA hazardous substance | | EPA 2008e 40 CFR 302.4
EPA | Cadmium | Yes^l,m^ | EPA 2008e 40 CFR 302.4
EPA | Cadmium and compounds | Yes^n^ | EPA 2008e 40 CFR 302.4
EPA | Cadmium chloride | Yes^o^ | EPA 2008e 40 CFR 302.4
EPA | Reportable quantity | | EPA 2008e 40 CFR 302.4
EPA | Cadmium | 10 pounds | EPA 2008e 40 CFR 302.4
EPA | Cadmium and compounds | None^p^ | EPA 2008e 40 CFR 302.4
EPA | Cadmium chloride | 10 pounds | EPA 2008e 40 CFR 302.4
EPA | Superfund, emergency planning, and community right-to-know | | EPA 2008e 40 CFR 302.4
EPA | Effective date of toxic chemical release reporting | | EPA 2008g 40 CFR 372.65
EPA | Cadmium | 01/01/1987 | EPA 2008g 40 CFR 372.65
EPA | Cadmium compounds^q^ | 01/01/1987 | EPA 2008g 40 CFR 372.65
EPA | Extremely Hazardous Substances | | EPA 2008f
EPA | Cadmium oxide | | 40 CFR 355, Appendix A
EPA | Reportable quantity | 100 pounds | 40 CFR 355, Appendix A
EPA | Threshold planning quantity | 100/10,000 pounds | 40 CFR 355, Appendix A
NTP | Carcinogenicity classification | | NTP 2011
NTP | Cadmium and cadmium compounds | Known to be human carcinogens | NTP 2011

a Group 1: The agent is carcinogenic to humans.

b The guideline value is based on the prevention of a further increase of cadmium in agricultural soils, which is likely to increase the dietary intake.

c TWA based on effects other than cancer or odor/annoyance using an averaging time of 1 year.

d Respriable fraction.

e Higher current priority chemical for guideline development.

f REL applies to all cadmium compounds (as Cd).

g Group II pesticide: Contains the pesticides that pose as significant risk of carcinogenic, teratogenic, neurotoxic, or reproductive effects

h Group I pesticide: Contains the pesticides that pose as significant risk of adverse acute health effects at low concentrations

i The CMC is an estimate of the highest concentration of a material in surface water to which an aquatic community can be exposed briefly without resulting in an unacceptable effect. The CCC is an estimate of the highest concentration of a material in surface water to which an aquatic community can be exposed indefinitely without resulting in an unacceptable effect.

j A2: Suspected human carcinogen.

k Group B1: Probable human carcinogen based on limited evidence of carcinogenicity in humans.

l Designated CERCLA hazardous substance pursuant to Section 307(a) of the Clean Water Act.

m No reporting of releases of this hazardous substance is required if the diameter of the pieces of the solid metal released is larger than 100 micrometers (0.004 inches).

n Designated CERCLA hazardous substance pursuant to Section 307(a) of the Clean Water Act and Section 112 of the Clean Air Act.

o Designated CERCLA hazardous substance pursuant to Section 311(b)(2) of the Clean Water Act.

p Indicates that no reportable quantity is being assigned to the generic or broad class.

q Cadmium compounds: Includes any unique chemical substance that contains cadmium as part of that chemical's infrastructure.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; CCC = Criterion Continuous Concentration; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; CMC = Criteria Maximum Concentration; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PBT = persistant, bioaccumulative, and toxic; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TSD = treatment, storage, and disposal; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization