# ANALYTICAL METHODS

The purpose of this chapter is to describe the analytical methods that are available for detecting, measuring, and/or monitoring cadmium, its metabolites, and other biomarkers of exposure and effect to cadmium. The intent is not to provide an exhaustive list of analytical methods. Rather, the intention is to identify well-established methods that are used as the standard methods of analysis. Many of the analytical methods used for environmental samples are the methods approved by federal agencies and organizations such as EPA and the National Institute for Occupational Safety and Health (NIOSH). Other methods presented in this chapter are those that are approved by groups such as the Association of Official Analytical Chemists (AOAC) and the American Public Health Association (APHA). Additionally, analytical methods are included that modify previously used methods to obtain lower detection limits and/or to improve accuracy and precision.

## 7.1 BIOLOGICAL MATERIALS

The most common analytical procedures for measuring cadmium concentrations in biological samples use the methods of atomic absorption spectroscopy (AAS) and inductively coupled plasma atomic emission spectroscopy (ICP/AES). These basic methods of analysis are well defined and generally accepted for the analysis of cadmium.

Samples are prepared for AAS and ICP/AES methods in a variety of ways. Digestion with nitric acid is most common (Roberts and Clark 1986; Sharma et al. 1982). Cadmium in blood and plasma measured by graphite furnace atomic absorption spectroscopy (GFAAS) facilitated by a wet ashing pretreatment of samples resulted in good accuracy and reproducibility. The sample detection limit using this method was 0.4 µg/L (Roberts and Clark 1986). This method was also precise and highly reproducible in determining cadmium in whole blood, urine, and hair with 99–99.4% recoveries reported (Sharma et al. 1982). The matrix may also be modified with diammonium hydrogen phosphate or other agents such as palladium (Pd)-based modifiers (Moreira et al. 1995). Detection limits as low as 0.1 µg/L with recoveries ranging from 93 to 111% are reported using this technique (Subramanian and Meranger 1981; Subramanian et al. 1983). If the concentration of cadmium in the dissolved sample is below the detection limit, preconcentration techniques, such as chelation and extraction, may be employed (Gross et al. 1976; Sharma et al. 1982). Various ICP methods have been developed for measuring cadmium levels in biological materials. ICP dynamic reaction cell mass spectrometry (ICP-DRC-MS) has been shown to eliminate molybdenum-based polyatomic interferences, resulting in a reduction of observed urine cadmium concentrations, as compared to ICP-MS measurements (Jarrett et al. 2008). Since cadmium is a ubiquitous element, the risk of contamination during sampling, processing, and analysis must be minimized by strict laboratory procedures (Elinder and Lind 1985). In procedures for micro-determination, all glass and plastic-ware should be acid-washed and subsequently rinsed with double-distilled water.

Current analytical improvements deal primarily with the methods of sample preparation and sample introduction to the analytical systems in order to lower the detection limits or decrease sample analysis time. Various improvements in the methods of extraction, preconcentration, chelation, complexation, and sample introduction have been developed for use with biological media. Detection limits as low as 0.003 µg/L were reported (Espinosa Almendro et al. 1992; Cordero et al. 1994; Jeng et al. 1994; Katskov et al. 1994; Komárek et al. 1991; Ma et al. 1994b; Welz et al. 1991).

The cadmium concentration in biological samples may also be measured by a number of other methods such as radiochemical neutron activation analysis (RNAA). One RNAA procedure involving a rapid two-step solvent extraction was used for determining cadmium in tissue samples (Tandon et al. 1994). Another method to determine cadmium in biological materials is based on the ion-exchange scheme developed by SAMSAHL where cadmium is trapped on an anion exchange resin. With this method, recovery of 98% and a detection limit of 4 µg/kg were reported. The accuracy of the method was estimated by three different approaches: analysis using radiotracers in inactive sample solutions; by analyzing standards, pipetted on filter paper, and processed as samples; and determination by RNAA (Woittiez and Tangonan 1992).

Cadmium concentration in tissue may be measured both in vivo (Ellis 1985; Scott and Chettle 1986) and in vitro (Lieberman and Kramer 1970) by neutron activation analysis (NAA). Direct in vivo assessment of body burden in humans focused on the measurements of cadmium in the kidney and liver by NAA. The detection limits reported are approximately 2 mg cadmium for the total kidney and 1.5 µg/g for the liver (Ellis 1985); 1.9 mg cadmium for the kidney; and 1.3 µg/g for the liver (Scott and Chettle 1986).

X-ray fluorescence is also used for in vivo measurement of cadmium in the kidney (Christoffersson et al. 1987; Nilsson and Skerfving 1993; Scott and Chettle 1986; Skerfving and Nilsson 1992). The in vivo techniques are used for clinical measurements of individuals occupationally exposed to cadmium. Additional methods applicable to the analysis of cadmium in biological media include ICP/MS (Stroh 1993; Vanhoe et al. 1994), ICP/AES (Cordero et al. 1994; Espinosa Almendro et al. 1992), and high performance liquid chromatography (HPLC) (Chang and Robinson 1993; Steenkamp and Coetzee 1994).

Electrothemal vaporization ICP/MS has been utilized for the analysis of dentin and enamel from teeth (Grünke et al. 1996). Electrochemical methods such as adsorptive cathodic stripping voltametry (ACSV) and potentiometric stripping analysis (PSA) have been applied to hair analysis (Zhang et al. 1993), animal tissues (LaBar and Lamberts 1994), and body fluids (Ostapczuk 1993).

Table 7-1 summarizes some of the methods used for sample preparation and analysis of cadmium in biological samples.

## 7.2 ENVIRONMENTAL SAMPLES

Analysis for cadmium in environmental samples is usually accomplished by AAS or AES techniques, with samples prepared by digestion with acid, preconcentrated with a chelating resin, or direct aspiration with no preparation (APHA 1977a, 1977b; EPA 1983a, 1983b, 1997b; OSHA 2002a, 2004; USGS 1985). Since cadmium in air is usually associated with particulate matter, standard methods involve collection of air samples on glass fiber or membrane filters, acid extraction of the filters, and subsequent analysis (APHA 1977a, 1977b; OSHA 2002a, 2002b). Inductively-coupled plasma spectrometry (ICP) analysis in standard methods is also popular. ICP analysis for water and air samples can be run in tandem with mass spectrometry (MS) or AES (EPA 1996b, 1997b, 2003; NIOSH 2003; OSHA 2002b). ACSV (Nimmo and Fones 1994), differential pulse anodic stripping voltametry (DP-ASV) (Nam et al. 1994), and epithermal NAA (Landsberger and Wu 1993) have also been used for air analysis. The accuracy of the analysis of cadmium in acid digested atmospheric samples, measured by ACSV, was evaluated and compared with GFAAS and ICP/MS.

Several methods standardized by EPA (1983a, 1983b, 1994b, 1996a, 1996b, 1997b, 2000, 2003) are used for measuring concentrations of cadmium in water. Techniques to compensate for chemical and matrix interferences in all three methods are described by EPA (1983a, 1983b, 1994b, 1996a, 1996b, 1997b, 2000, 2003). After soils and solid wastes are extracted or solubilized by acid digestion, they may be analyzed for cadmium by the same AAS methods that are used for water (EPA 1986d, 1986e). Water can also be analyzed for cadmium by NAA methods (Saleh et al. 1993), PSA methods (Ostapczuk 1993), and anodic stripping voltametry (ASV) (Daih and Huang 1992).

Sediment and soil samples have been analyzed for cadmium using the methods of GFAAS (Klemm and Bombach 1995). Preparation of the samples is generally accomplished by treatment with HCl and HNO_3_.

Table 7-1 Analytical Methods for Determining Cadmium in Biological Materials

Sample matrix | Preparation method | Analytical method | Sample detection limit | Percent recovery | Reference
Blood | Digestion with nitric acid; chelation with APDC and extraction with MIBK | AAS | <1 ng/mL^a^ | 99 | Sharma et al. 1982
Blood | Modification of matrix with diammonium hydrogen phosphate/Triton X-100 | GFAAS | 0.1 µg/L | 100.8±4.3 | Subramanian and Meranger 1981
Blood/plasma | Digestion with nitric acid; wet ashed | GFAAS | 0.4 µg/L | No data | Roberts and Clark 1986
Serum | Dilution with ammonia/Triton X-100 | ICP/MS | 0.01 ng/mL | No data | Stroh 1993
Tissue and blood | Microwave digestion | FAAS/flow injection system | 0.15 µg/L | No data | Welz et al. 1991
Human milk | Dilution with deionized and double distilled water | AAS | <0.01 ppb^a^ | No data | Schulte-Lobbert and Bohn 1977
Hair | Digestion with nitric acid | AAS | 0.07 µg/g^a^ | 99 | Sharma et al. 1982
Kidney | None (in vivo) | XRF | 170.1 µg/g | No data | Christoffersson et al. 1987
Kidney/liver | Chelation and extraction with solvent | AAS/direct aspiration | 0.01 ppm^a^ (liver) 1.9 mg (kidney) | No data | Gross et al. 1976
Kidney/liver | None (in vivo) | NAA | 1.3 µg/g (liver) 1.9 mg (kidney) | No data | Scott and Chettle 1986
Muscle | Wet ashed with concentrated sulfuric acid | NAA | 50 ppb | 50–65 | Lieberman and Kramer 1970
Urine | Dilution with nitric acid | ETAAS | 0.045 µg/L | 97–101 | Komárek et al. 1991
Urine | Modification of matrix with diammonium hydrogen phosphate/nitric acid | GFAAS | 0.09 ng/mL | 92.7–111.1 | Subramanian et al. 1983
Urine | Digestion with nitric acid | AAS | 5.67 ng/mL^a^ | 99.4 | Sharma et al. 1982
Biological materials | Microwave digestion followed by extraction with APTH in MlBK | ICP/AES | 0.15 ng/mL | No data | Cordero et al. 1994
Biological materials | Extraction with 1,5-bis(di-2-pyridylmethylene) thiocarbonohydrazide in MlBK | ICP/AES | 0.1 ng/mL | No data | Espinosa Almendro et al. 1992
Biological materials | Digestion with acid | GFAAS/flow injection system | 0.003 µg/L | No data | Ma et al. 1994a
Biological fluids (blood, urine) | Acidification | PSA | 0.001 µg/kg | No data | Ostapczuk 1993
Biological materials | Dry tissues; irradiation followed by acid digestion | RNAA | 4 µg/kg | 98 | Woittiez et al. 1992
Teeth, dentin, and enalmel | Digested in nitric acid, diluted with water | ETV-ICP-MS PN-ICP-MS | No data | No data | Grünke et al. 1996
Whole blood, urine | Modified with palladium based modifier | ETAAS | 0.22 µg/L | No data | Moreira et al. 1995
Biological materials | Digested with nitric acid and hydrogen peroxide | B-9001-95; ICP-AES | No data | 93 | USGS 1996

a Lowest concentration found

AAS = atomic absorption spectroscopy; APDC = ammonium pyrrolidenedithiocarbamate; APTH = 1,3-bis-[1-(2-pyridyl)ethylidene] thiocarbon-hydride; ETAAS = electrothermal atomic absorption spectroscopy; FAAS = flame atomic absorption; GFAAS = graphite furnace atomic absorption; ICP/AES = inductively coupled plasma atomic emission spectroscopy; ICPIMS = inductively coupled plasma mass spectrometry; MlBK = methyl isobutyl ketone; NAA = neutron activation analysis; PSA = potentiometric stripping analysis; RNAA = radio chemical neutron activation analysis; XRF = x-ray fluorescence

The most common method for analysis of cadmium in foods is AAS (Bruhn and Franke 1976; Dabeka 1979; Muys 1984), with GFAAS being one of the most common AAS methods used (Cabrera et al. 1995). The FDA’s Total Diet Study 1991–1996 analyzed cadmium and other element concentrations in food by dry ash mineralization and GFAAS (Capar and Cunningham 2000). RNAA (Greenberg et al. 1979), differential pulse ASV (Satzger et al. 1982, 1984), and the calorimetric dithizone method (AOAC 1984) may also be employed. The AAS techniques appear to be most sensitive, with recoveries ranging from 94 to 109% (Bruhn and Franke 1976; Muys 1984). A method used to isolate cadmium by first extracting with bismuth diethyldithiocarbamate (Bi[DDC]_3_) and then with zinc diethyldithiocarbamate (Zn[DDC]_2_) in chloroform and then measuring by RNAA showed 94–106% recovery (Greenberg et al. 1979).

Table 7-2 summarizes some of the methods used for sample preparation and analysis of cadmium in environmental samples.

## 7.3 ADEQUACY OF THE DATABASE

Section 104(i)(5) of CERCLA, as amended, directs the Administrator of ATSDR (in consultation with the Administrator of EPA and agencies and programs of the Public Health Service) to assess whether adequate information on the health effects of cadmium is available. Where adequate information is not available, ATSDR, in conjunction with NTP, is required to assure the initiation of a program of research designed to determine the health effects (and techniques for developing methods to determine such health effects) of cadmium.

The following categories of possible data needs have been identified by a joint team of scientists from ATSDR, NTP, and EPA. They are defined as substance-specific informational needs that if met would reduce the uncertainties of human health assessment. This definition should not be interpreted to mean that all data needs discussed in this section must be filled. In the future, the identified data needs will be evaluated and prioritized, and a substance-specific research agenda will be proposed.

### 7.3.1 Identification of Data Needs

#### Methods for Determining Biomarkers of Exposure and Effect

Exposure. Measurements of cadmium in liver and kidney are all useful biological indices for human exposure to cadmium (Roels et al. 1981b). Human milk, human placentas, and maternal and neonatal blood have been investigated as means to determine exposures of women and infants to cadmium (Baranowska 1995; Abadin et al. 1997). Sensitive and selective methods are available for the detection and quantitation of cadmium in these biological materials (Elinder and Lind 1985; Sharma et al. 1982). Improved methods for sample preparation and in vivo analysis of liver and kidney content are needed to assist in monitoring environmentally exposed populations.

Table 7-2 Analytical Methods for Determining Cadmium in Environmental Samples

Sample matrix | Preparation method | Analytical method | Sample detection limit | Percent recovery | Reference
Air | Collection on glass fiber filter; ashed with hydrochloric and nitric acids | Method 311; AAS | 0.005 µg/m^3^ | 90 | APHA 1977b
Air | Collection on membrane filter; ashed with hydrochloric and nitric acids | Method 7048; AAS | 0.05 µg per sample | No data | NIOSH 1994
Air | Collection on membrane filter; digestion with nitric acid and perchloric acid | Method 7300; ICP | 0.3 ng/mL | 99.8–105.2 | NIOSH 2003
Air | Collection using filters, wipes, or bulk materials; desorbed with water extractions and mineral acid digestions | Method 121; AAS/AES | 0.004 µg/mL | 99.5 | OSHA 2002a
Air | Collection on membrane filter; digested in nitric acid, sulfuric acid, and hydrogen peroxide | Method 125G; ICP-AES | 0.14 µg^a^ 0.47 µg^b^ | No data | OSHA 2002b
Air | Collection on membrane filter; digested with nitric acid and small amounts of hydrochloric acid | Method 189; AAS/AAS-HGA | 0.2 µg/m^3^ (AAS)^a^ 0.70 µg/m^3^ (AAS)^b^ 0.007µg/m^3^ (AAS-HGA)^a^ 0.025 µg/m^3^ (AAS-HGA)^b^ | No data | OSHA 2004
Air | Collection on membrane filter, wipe, or bulk material; digest with nitric and hydrochloric acids | Method 206; ICP-AES | 0.0062 µg/mL^a^ 0.0205 µg/mL^b^ | No data | OSHA 1991
Air | Irradiation UF filters | Epithermal NAA | 8 ng | No data | Landsberger et al. 1993
Air (aerosols) | Acid digestion with filters | ACSV | 0.6 ng/mL | 100 | Nimmo and Fones 1994
Atmospheric particles | Direct analysis | ETV-ICP-MS | pg/m^3^ range | No data | Lüdke et al. 1997
Water | Digestion with nitric acid | Method 213.1; AAS/direct aspiration | 5 µg/L | 94±24 | EPA 1983a
Water | Digestion with nitric acid | Method 213.2; AAS/GFAAS | 0.1 µg/L | 96–99 | EPA 1983b
Water | On-line preconcentration with ion exchange or sorbent extraction columns | GFAAS/flow injection system | 0.8 ng/L | No data | Welz et al. 1992
Water | Digestion with nitric acid | Method 1637; chelation and GFAAS | 0.0075 µg/L | No data | EPA 1996a
Water | Digestion with nitric acid | Method 1638; ICP-MS | 0.025 µg/L | No data | EPA 1996b
Water | Preconcentrated with chelating resin | Method 1640; Online Chelation/ICP-MS | 0.0024 µg/L | No data | EPA 1997b
Water | Digested with hydrochloric and nitric acids | Method 200.5; AVICP-AES | 0.1 µg/L | 98±1.1 | EPA 2003
Water and Wastes | Digestion with acids | Method 200.7; ICP-AES | 1 µg/L (aqueous); 0.2 mg/kg (solids) | 82–98 | EPA 1994a
Various | Digestion with nitric and hydrochloric acids | Method 6010C; ICP-AES | No data | 97 | EPA 2000
Water and sediments | No preconcentration or pretreatment | I-1135; AAS | 10 µg/L | No data | USGS 1985
Water | Digested with whole water | I-4471-97; ICP-OES | 5 µg/L | No data | USGS 1998a
Various | Direct aspiration with no preconcentration or pretreatment | I-5135; AAS | 10 µg/L | No data | USGS 1985
Soil | Digestion with nitric acid | Method 7130; AAS/direct aspiration | 0.005 mg/L | No data | EPA 1986e
Soil | Digestion with nitric acid | Method 7131; GFAAS | 0.1 µg/L | No data | EPA 1986d
Soil and sediment | Ultrasonic slurry in dilute nitric acid | GFAAS | No data | 100±10 | Klemm and Bombach 1995
Sediment | Digestion with hydrochloric and nitric acid | LEAFS | 500 fg | No data | Zhou et al. 1998
Soil and sediment | Digestion with hydrofluoric acid and nitric acid; complexation with DDPA using on-line sorbent extraction system | GFAAS/flow injection system | 0.8 µg/L | No data | Ma et al. 1994b
Food | Dry ashed; oxidization with nitric acid | ASV/differential pulse | 1 ng/g | 99–108 | Satzger et al. 1984
Food | Dry ashed; complexation with APCD; extraction with isoamyl acetate | AAS | 0.1 ng/g | 97.5±2.5 | Bruhn and Franke 1976
Food | Extraction with Bi(DDC)_3_ then with Zn(DDC)_2_ in chloroform | RNAA | 0.029 µg/g^c^ | 94–106 | Greenberg et al. 1979
Food (24 hour diet) | Microwave digestion with nitric acid and hydrogen peroxide | GFAAS | 0.004 µg/g | 94–101 | Yang et al. 1995
Food | Dry ashed; complexation with NaDDTC; extraction with IBMK | GFAAS | 0.1 ppb^c^ | 94–109 | Muys 1984
Food | Homogenization followed by wet ashing | GFAAS | 0.01 ppb | 94–108 | Zhang et al. 1997
Fruit | Homogenized fruit slurried with zirconia | ETAAS | 0.3 ng/g | 97.7±0.3 | Cabrera et al. 1995

a Qualitative detection limit

b Quantitative detection limit

c Lowest concentration found

AAS = atomic absorption spectroscopy; ACSV = adsorptive cathodic stripping voltametry; APCD = ammonium pyrrolidino carbodithioate; ASV = anodic stripping voltametry; AVICP-AES = axially viewed inductively coupled plasma-atomic emission spectrometry; Bi(DDC)3 = bismuth diethyldithiocarbamate; DDPA = ammonium diethyldithiophosphate; ETV-ICP-MS = electrothermal vaporization inductively coupled plasma mass spectrometry; GFAAS = graphite furnace atomic absorption; HGA = heated graphite atomizer; IBMK = isobutyl methyl ketone; ICP = inductively coupled plasma; LEAFS = laser-excited atomic fluorescence spectrometry; MS = mass spectrometry; NAA = neutron activation analysis; NaDDTC = sodiumdiethyl-dithiocarbomate; OES = optical emission spectroscopy; RNAA = radiochemical neutron activation analysis; Zn(DDC)2 = zinc diethyldithiocarbamate

Effect. Sensitive methods are also available for measuring biological markers of cadmium effect, particularly urine or serum concentration of β2-microglobulin, retinol-binding protein, metallothionein, and creatinine (Kawada et al. 1990; Roels et al. 1989; Topping et al. 1986).

#### Methods for Determining Parent Compounds and Degradation Products in Environmental Media

Cadmium is ubiquitous in the environment and does not degrade. It is found in air, water, soil, sediments, and food. Analytical methods exist for the analysis of cadmium in all of these environmental media, and these methods have the sensitivity to measure background levels and detect elevated concentrations due to anthropogenic sources such as hazardous waste sites (EPA 1983a, 1983b, 1994b, 1996a, 1996b, 1997b, 2000, 2003). Additional research to reduce chemical and matrix interferences are needed to improve the speed and accuracy of the analyses.

### 7.3.2 Ongoing Studies

The National Report on Human Health Exposure to Environmental Chemicals is an ongoing biomonitoring assessment conducted by CDC. This survey measures over 200 chemicals in blood and urine from random samples collected from participants in the National Health and Nutrition Examination Survey (NHANES). The National Exposure Report was last published in 2009 and an update of biomonitoring levels for some of the chemicals, including cadmium, was published in 2012 (CDC 2012).

The information in Table 7-3 was found as a result of a search of the Federal Research in Progress database (FEDRIP 2008).

Table 7-3 Ongoing Analytical Methods Studies on Cadmium

Investigator | Affiliation | Research description | Sponsor
Parker D | University of California | Isotopic dilution methods for probing the bioavailability of trace elements in soils and sediments | U.S. Department of Agriculture
Pierzynski G | Kansas State University | Chemistry, bioavailability, and toxicity of constituents in residuals and residual treated soils | U.S. Department of Agriculture
Schwab AP; Joern B; Johnston C | Purdue University | Chemistry and bioavailability of waste constituents in soils | U.S. Department of Agriculture
Santra S | University of Central Florida | Selective detection of toxic heavy metal ions using highly sensitive quantum dot probes | National Science Foundation
Swain G | Michigan State University | Diamond microelectrode arrays: New materials for the electrochemical detection of aqueous analytes | U.S. Department of Agriculture

Source: FEDRIP 2008