# CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Table 4-1 lists the common synonyms, trade names, and other pertinent identification information for cadmium and its most important compounds.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Table 4-2 lists important physical and chemical properties of cadmium and its most important compounds.

Table 4-1 Chemical Identity of Cadmium and Compounds^a^

Characteristic | Information
Chemical name | Cadmium | Cadmium carbonate | Cadmium chloride
Synonym(s) | Colloidal cadmium | Otavite^b^; cadmium monocarbonate; carbonic acid; cadmium salt | Caddy^b^; Vi-Cad^b^; cadmium dichloride; dichlorocadmium
Registered trade name(s) | No data | No data | No data
Chemical formula | Cd^b^ | CdCO_3_^b^ | CdCl_2_^b^
Chemical structure | Cd^b^ | CdCO_3_^b^ | CdCl_2_^b^
Identification numbers:
CAS registry | 7440-43-9^b^ | 513-78-0^b^ | 10108-64-2
NIOSH RTECS | No data | No data | No data
EPA hazardous waste | D006 | D006 | D006
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMDG shipping | No data | No data | NA2570/IMCO 6.1
HSDB | 282 | 1612 | 278
NCI | No data | No data | No data
Synonym(s) | Aska-Rid^b^; cadmium fume; cadmium monoxide | Cadmium sulphate; sulfuric acid; cadmium (2+) salt | Cadmium monosulfide; cadmium yellow; cadmium orange; cadmopur yellow; greenockite^b^; capsebon^b^
Registered trade name(s) | No data | No data | No data
Chemical formula | CdO^b^ | CdSO_4_^b^ | CdS^b^
Chemical structure | CdO^b^ | CdSO_4_^b^ | CdS^b^
Identification numbers:
CAS registry | 1306-19-0^b^ | 10124-36-4^b^ | 1306-23-6^b^
NIOSH RTECS | No data | No data | No data
EPA hazardous waste | D006 | D006 | D006
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMDG shipping | UN2570/IMCO 6.1 | No data | No data
HSDB | 1613 | 274 | 1614
NCI | No data | No data | No data

a All information obtained from HSDB 2008 except where noted.

b O’Neil et al. 2006.

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Cadmium and Compounds^a^

Property | Cadmium | Cadmium carbonate
Molecular weight | 112.41^b^ | 172.42^b^
Color | Silver-white^b^ | White^c^
Physical state | Lustrous metal^b^ | Powder or rhombohedral leaflets^b^
Melting point | 321 °C^b^ | Decomposes at 357 °C
Boiling point | 765 °C^b^ | No data
Density at 20 °C | 8.65 g/cm^3^ at 25 °C^b^ | 4.58 g/cm^3^ f
Odor | Odorless | No data
Odor threshold:
Water | No data | No data
Air | No data | No data
Solubility:
Water at 20 °C | Insoluble^b^ | Insoluble^f^
Organic solvents | Acids, NH_4_NO_3_^f^ | Acids, especially HNO_3_, concentrated NH_4_ solution^c^
Partition coefficients:
Log K_ow_ | No data | No data
Log K_oc_ | No data | No data
Vapor pressure | 7.5×10^−3^ mmHg at 257 °C | No data
Henry's law constant at 25 °C | No data | No data
Autoignition temperature | 250 °C | No data
Flashpoint | No data | No data
Flammability limits | No data | No data
Conversion factors | No data | No data
Explosive limits | No data | No data
Molecular weight | 183.32 | 128.41^b^
Color | White^c^ | Dark brown^b^
Physical state | Rhombohedral crystals^b^ | Infusible powder or cubic crystals^b^
Melting point | 568 °C^b^ | Decomposes at 950 °C
Boiling point | 960 °C^b^ | Decomposes at 950 °C
Density at 20 °C | 4.047g/cm^3^ at 25 °C^e^ | Crystals 8.15 g/cm^3^; amorphous powder 6.95 g/cm^3^c
Odor | Odorless^c^ | Odorless
Odor threshold:
Water | No data | No data
Air | No data | No data
Solubility:
Water at 20 °C | Soluble^b^ | Insoluble^b^
Organic solvents | Acetone, slightly soluble in MEOH and ETOH^b^ | Dilute acid, slowly soluble in NH4 salts^b^
Partition coefficients:
Log K_ow_ | No data | No data
Log K_oc_ | No data | No data
Vapor pressure | 10 mmHg at 656 °C^e^, 40 mmHg at 736 °C^d^, 760 mmHg at 967 °C^d^ | 1 mmHg at 1,000 °C^e^; 10 mm Hg at 1149 °C; 40 mm Hg at 1257 °C
Henry's law constant at 25 °C | No data | No data
Autoignition temperature | No data | No data
Flashpoint | No data | No data
Flammability limits | No data | No data
Conversion factors | No data | No data
Explosive limits | No data | No data
Molecular weight | 208.47^b^ | 144.48^b^
Color | Colorless^c^ | Light yellow or orange^b^; brown^c^
Physical state | Monoclinic crystals (hydrate)^b^ | Cubic or hexagonal structure^b^
Melting point | 1,000 °C^c^ | 1,750 °C^c^
Boiling point | No data | Sublimes in N_2_ at 980 °C^c^
Density at 20 °C | 4.69 g/cm^3^b | 4.82 g/cm^3^, hexagonal structure^b^, 4.5 g/cm^3^, cubic structure^b^
Odor | Odorless | No data
Odor threshold:
Water | No data | No data
Air | No data | No data
Solubility:
Water at 20 °C | Soluble^c^ | Soluble at 1.3 mg/L at 18 °C^b^
Organic solvents | Insoluble in alcohol^c^, acetone, ammonia^f^ | Concentrated or warm dilute mineral acids^b^
Partition coefficients:
Log K_ow_ | No data | No data
Log K_oc_ | No data | No data
Vapor pressure at 20 °C | No data | No data
Henry's law constant at 25 °C | No data | No data
Autoignition temperature | No data | No data
Flashpoint | No data | No data
Flammability limits | No data | No data
Conversion factors | No data | No data
Explosive limits | No data | No data

a All information from HSDB 2008, except where noted.

b O’Neil et al. 2006.

c Sax and Lewis 2001.

d Farnsworth 1980.

e Sax and Lewis 2000.

f Lide 2005.