# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Methylenedianilines are diphenylmethane compounds with an amino group added to each benzene ring. Depending on the position of the amino group, methylenedianilines can exist in six isomeric forms: 2,2’-methylenedianiline; 2,3’-methylenedianiline; 2,4’-methylenedianiline; 3,3’-methylenedianiline; 3,4’-methylenedianiline; and 4,4´-methylenedianiline. Of the six isomers, 2,2’-methylenedianiline and 2,4’-methylenedianiline are produced on a small scale as research chemicals (HSDB 1996). The isomer 4,4´-methylenedianiline is produced in the United States for industrial use. Therefore, this profile will limit its discussion to 4,4´-methylenedianiline. Information regarding the chemical identity of 4,4´-methylenedianiline is presented in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of 4,4´-methylenedianiline is presented in Table 3-2. Exposure of 4,4´-methylenedianiline to air and light results in polymerization and oxidation of the compound, as evidenced by darkening of color and polymerization leading to the formation of polymeric amines (IARC 1986; Moore 1978). When heated to decomposition, 4,4´-methylenedianiline emits toxic fumes of aniline and nitrogen oxides (NIEHS 1994). It is a weak base (pH 7.7, Allied Chemical Corp. 1978), but its experimentally determined pk_a_ value was not located in the literature. The estimated pk_a_ for this compound is 4.88 (EPA 1995). Since 4,4´-methylenedianiline is a base, it forms dihydrochloride salts with hydrochloric acid (IARC 1986). The dihydrochloride of 4,4´-methylenedianiline or other salts of the compound with strong inorganic acids will be more water soluble than the free base. The dihydrochloride salt is soluble in water (NIEHS 1994).

Table 3-1 Chemical identity of 4,4′-Methylenedianilme

Characteristic | Information | Reference
Chemical name | 4,4′-Methylenedianiline
Synonym(s) | 4,4′-Methylene-bis(benzeneamine); | RTECS 1996
Synonym(s) | 4,4′-diaminodiphenylmethane; | RTECS 1996
Synonym(s) | 4,4′-methylenebisaniline; | RTECS 1996
Synonym(s) | p,p′-methylenedianiline; MDA; | RTECS 1996
Synonym(s) | Methylenedianiline | RTECS 1996
Registered trade name(s) | Ancamine TL; Epicure DDM; Tonox Jeffamine AP-20 | IARC 1986; RTECS 1996
Chemical formula | C_13_H_14_N_2_ | Merck 1989
Chemical structure | [image] | Merck 1989
Identification numbers:
CAS Registry | 101-77-9 | HSDB 1996
NIOSH RTECS | BY5425000 | HSDB 1996
EPA Hazardous Waste | No data
OHM/TADS | No data
DOT/UN/NA/IMCO | UN2651 | RTECS 1996
HSDB | 2541 | HSDB 1996
NCI | C54604 | HSDB 1996

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; IARC = International Agency for Research on Cancer; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 3-2 Physical and Chemical Properties of 4,4′-Methylenedianiline

Property | Information | Reference
Molecular weight | 198.27 | Lide 1994
Color | Colorless to pale yellow or light brown | IARC 1986; Lewis 1993
Physical state | Crystalline solid | Moore 1978
Melting point | 92-3 °C | Lide 1994
Boiling point | 398-9 °C | Lide 1994
Specific gravity | 1.1 | IARC 1986
Odor | Faint amine-like | Moore 1978
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 25 °C | 1,000 mg/L; slightly soluble | Moore 1978; Merck 1989
Organic solvent(s) | Very soluble in ethanol, benzene and diethyl ether | Merck 1989; Lide 1994
Partition coefficients:
Log K_ow_ | 1.59 | HSDB 1996
Log K_oc_ | 2.24 (estimated) | Lyman 1990
Vapor pressure:
at 25 °C | 2.15×10^7^ mm Hg (estimated from H and water solubility) | Thomas 1990
at 197 °C | 1 mm Hg | IARC 1986
Henry’s law constant (H) at 25°C | 5.6×10^−11^ atm-m^3^/mole (estimated) | HSDB 1996
Autoignition temperature | No data
Flashpoint | 221.1 °C (closed cup);; 220 °C (closed cup) | Moore 1978; NFPA 1994
Flammability limits at 25 °C | No data
NFPA Hazard Class: | | NFPA 1994
Health | 3 (material extremely hazardous to health)
Flammability | 1 (material must be preheated before ignition)
Reactivity | 0 (material normally stable even under fire conditions and is not reactive with water)
Conversion factors (25 °C) | 1 mg/m^3^ = 8.11 ppm; 1 ppm = 0.123 mg/m^3^ | IARC 1986
Explosive limits | No data

NFPA = National Fire Protection Association