# APPENDIX A ATSDR MINIMAL RISK LEVEL

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Super-fund Amendments and Reauthorization Act (SARA) [Pub. L. 99-4991, requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (I-14 days), intermediate (15-364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agencywide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road, Mailstop E-29, Atlanta, Georgia 30333.

## 4,4′-Methylenedianiline Acute Oral

APPENDIX A MINIMAL RISK LEVEL WORKSHEET

Chemical Name: | 4,4′-Methylenedianiline
CAS Number: | 101-77-9
Date: | November 1997
Profile Status: | Final Draft Post Public
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 6r
Species: | Rat

[underlined: Minimal Risk Level]: [underlined: 0.2] [X] mg/kg/day [ ] ppm

[underlined: Reference]: Bailie . 1993. Characterization of acute 4,4’-methylenedianiline hepatotoxicity in the rat. Environ Health Perspect 10(2): 130–133 .

[underlined: Experimental design]: Groups of male Sprague-Dawley rats (3-5/group) (175-300 g body weight) were administered orally a single dose of 0 (vehicle alone) or 25, 50, 75, 100, 125, or 225 mg 4,4’-methylene-dianiline/kg in com oil. Twenty-four hours after dosing, the rats were anesthetized, the bile duct was cannulated, bile was collected for 30 minutes and then the rats were sacrificed; indicators of liver injury were assessed. Additional groups of rats received a dose of 100 mg/kg and were sacrificed at various intervals for histopathological examination of the liver. The possible involvement of the cytochrome P-450 system in the toxicity of 4,4’-methylenedianiline was investigated. The inhibitors of monooxygenase (MO) function used were aminobenzotriazol (ABT) and SKF-525A (both administered intraperitoneally 2 hours before 4,4’-methylenedianiline). The inducers of MO function used were phenobarbital (PB) and P-naphthoflavone (BNF) (both administered intraperitoneally daily for 3 days before 4,4’-methylenedianiline).

[underlined: Effects noted in study and corresponding doses]: Administration of 4,4’-methylenedianiline caused a dose-dependent change in all markers of hepatic parenchyma injury: increased serum alanine aminotransferase (ALT) and gamma-glutamyl transferase, increased serum bilirubin, decreased bile flow, and increased relative liver weight. The minimal effective dose was between 25 and 75 mg/kg. Histologically, a dose of 100 mg/kg caused hepatocellular necrosis with hemorrhage and moderate neutrophil infiltration. Lesions associated with the portal triads consisted of bile ductular necrosis, portal edema with fibrin exudate, and neutrophil infiltration. The earliest change identified (at 4 hours) was bile ductular necrosis. A segmental necrotizing vasculitis of the portal vein was also observed. The severity of the effects continued to increase over a 16-hour period. Time-course experiments showed that the first significant biochemical markers of liver injury appeared about 8 hours after dosing. Pretreatment with ABT ameliorated the hepatic effects of 4,4’-methylenedianiline, but SKF-525A did not. This according to the authors, may have reflected a difference in the spectrum of cytochrome P-450 isozymes inhibited by the two agents. Pretreatment with PB had no effect after a 100 mg/kg dose of 4,4’-methylenedianiline, but attenuated the hepatotoxicity of a 50 mg/kg dose. BNF had a small attenuating effect.

[underlined: Dose and end point used for MRL derivation]: 25 mg/kg; minimal liver effects.

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 3 for use of a minimal LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

A modifying factor of 0.5 was used in the derivation of the MRL in order to account for the possibility of increased absorption of 4,4’-methylenedianiline due to the com oil vehicle.

[underlined: Was a conversion factor used from ppm in food or water to a mg/bodv weight dose]?

No

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]:

NA

[underlined: Was a conversion used from intermittent to continuous exposure]?

No

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Several other studies support the findings of Bailie et al. (1993). For example, Bailie et al. (1994) observed cholestasis, biliary epithelial injury, and hepatic parenchymal damage in the livers from rats treated with a single dose of 5 mg 4,4’-methylenedianiline/kg. Schmidt et al. (1980) reported bile duct necrosis and increased serum transaminases in rats also after a single dose of 50 mg/kg. The liver is a known target of 4,4’-methylenedianiline in humans and animals. An outbreak of toxic hepatitis was described in a group of individuals who ate bread contaminated with 4,4’-methylenedianiline (Kopelman et al. 1966). Liver toxicity has also been reported in humans and animals exposed by the dermal route (Brooks et al. 1979; DuPont 1976a; McGill and Motto 1974; Williams et al. 1974)

[underlined: Agency Contact (Chemical Manager)]: Zemoria Rosemond

## 4,4′-Methylenedianiline Intermediate Oral

MINIMAL RISK LEVEL WORKSHEET

Chemical Name: | 4,4′-Methylenedianiline
CAS Number: | 101-77-9
Date: | November 1997
Profile Status: | Final Draft Post Public
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 23r
Species: | Rat

[underlined: Minimal Risk Level]: 0.08 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Pludro . 1969. Toxicological and chemical studies of some epoxy resins and hardeners. I Determination of acute and subacute toxicity of phthalic acid anhydride, 4,4-methylenedianiline, 4,4’-diaminophenylmethane and of the epoxy resin: epilox EG-34. Acta Pol Pharm 26:352–357 .

[underlined: Experimental design]: Groups of male and female Wistar rats (10/sex/group) were administered 0 (vehicle alone) 8.3, or 83 mg 4,4’-methylenedianiline by gavage in propylene glycol once a day for 12 weeks. End points evaluated included body weight, serum protein profile, hemoglobin levels and erythrocyte counts, and gross and histopathological appearance of liver, kidneys, and spleen.

[underlined: Effects noted in study and corresponding doses]: The only reported effects observed with the 8.3 mg/kg/day dose of 4,4’-methylenedianiline were unspecified histological lesions in the liver of one animal and unspecified lesions in the spleens from all rats. Administration of 83 mg 4,4’-methylene-dianiline/kg/day did not affect body weight, hemoglobin levels, or red blood cell count. Analysis of electrophoretic patterns of serum showed an increase in beta-globulin and a decrease in the albumin fraction. On gross examination, the liver and kidneys appeared enlarged and their relative weights were markedly increased. Flatulence and intestinal occlusion were also described. Microscopical examination of the liver revealed intense degenerative lesions in all animals consisting of atrophy of the parenchyma accompanied by hyperplasia of the stroma, particularly at portal areas. The 8.3 mg/kg/day is considered a NOAEL although the authors noted unspecified spleen lesions in all rats. The significance of these lesions is unknown since a 13-week study conducted by NTP (1983) observed no gross or histopathological alterations in the spleen, thymus, and lymph nodes from rats treated with up to 141 mg 4,4’-methylenedianiline/kg/day in the drinking water. No lesions were observed in the same organs from mice treated similarly with up to 116 mg/kg/day (NTP 1983).

[underlined: Dose and end point used for MRL derivation]: 8.3 mg/kg/day; liver effects.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation:]

- [] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]?

No

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]:

NA

[underlined: Was a conversion used from intermittent to continuous exposure]?

No

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The liver is a known target for 4,4’-methylenedianiline toxicity in humans and animals regardless of the route of exposure. The LOAEL of 83 mg/kg/day for liver effects is consistent with LOAELs identified in a number of intermediate-duration studies (Fukushima et al. 1979, 1981; Hagiwara et al. 1993; Miyamoto et al. 1977; NTP 1983). These LOAELs ranged from 67 to 100 mg/kg/day. With the exception of the NTP (1983) study, all of these studies tested only one dose level, therefore, no NOAELs could be established. The NTP (1983) study defined a NOAEL of 35 mg/kg/day for hepatic effects in rats and 58 mg/kg/day for mice.

[underlined: Agency Contact (Chemical Manager)]: Zemoria Rosemond