# CHAPTER 8 REFERENCES

*Cited in text

Acedo GN, Redei G. 1982. Accuracy of the identification of carcinogens and noncarcinogens by arabidopsis. Arabidopsis Information Service (19):103–107.
*ACGIH. 1990. Threshold limit values for chemical substances and physical agents and biological exposure indices for 1990–1991. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*ACGIH. 2001. Documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*ACGIH. 2016. TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*AIHA. 2015. Current ERPG Values (2015). Fairfax, VA: American Industrial Hygiene Association. https://www.aiha.org/get-involved/AIHAGuidelineFoundation/EmergencyResponsePlanningGuidelines/Documents/2015%20ERPG%20Levels.pdf. March 22, 2016.
*Ames BN, McCann J, Yamasaki E. 1975. Methods for detecting carcinogens and mutagens with the Salmonella/mammalian-microsome mutagenicity test. Mutation Res 31:347–363.768755
Anderson D, Styles JA. 1978. An evaluation of 6 short-term tests for detecting organic chemical carcinogens: Appendix 2. The bacterial mutation test. Br J Cancer 37:924–930.354673
*Angerer J, Schaller KH. 1985. Analyses of hazardous substances in biological materials. Germany: VCH Verlagsgesellschaft mbH, 1:17–30.
Ashby J, Paton D, Callander RD. 1988. Potent mutagenicity to salmonella of equimolar mixture of 52 chemicals used in five collaborative studies. Mutagenesis 3(4):345–348.3062324
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
*ATSDR. 1991. Agency for Toxic Substances and Disease Registry Annual report FY 1991. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 2017. 4,4’-methylenebis(2-chloroaniline). Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention. http://www.atsdr.cdc.gov/SPL/resources/index.html. October 6, 2017.
*Baker RS, Bonin AM. 1981. Study of 42 coded compounds with the Salmonella/mammalian microsome assay. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:249–260.
*Barek J, Pacakova V, Stulik K, 1985. Monitoring of aromatic amines by HPLC with electrochemical detection: Comparison of methods for destruction of carcinogenic aromatic amines in laboratory wastes. Talanta 32(4):279–283.18963843
*Barnes DC, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Barnes JR. 1964. Toxicity study on “MOCA” 4,4’-methylene-bis(2-chloroaniline). DuPont Haskell Lab Study no. MR-652. Sept. 10.
Benigni R, Giulani A. 1985. Cluster analysis of short-term tests: A new methodological approach. Mutat Res 147(4):139–152.4022030
Bertazzi PA. 1975. [Methylene-bis-o-chloroaniline (MBOCA): A new chemical carcinogen.] Med Lav 66(2):81–84. (Italian)1134441
Brookes P, Preston RJ. 1981. Summary report on the performance of in vitro mammalian assays. In: Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:77–85.
*Brooks TM, Dean BJ. 1981. Mutagenic activity of 42 coded compounds in the Salmonella/microsome assay with preincubation. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:261–270.
*Butler MA, Guengerich FP, Kadlubar FF. 1989. Metabolic oxidation of the carcinogens 4-aminobiphenyl and 4,4’-methylene-bis(2-chloroaniline) by human hepatic microsomes and by purified rat hepatic cytochrome P-450 monooxygenases. Cancer Res 49(1):25–31.2908851
Carpenter AV, Flanders WD, Frome EL, 1988. Chemical exposures and central nervous system cancers: A case-control study among workers at two nuclear facilities. Am J Ind Med 13(3):351–362.3354584
Cartwright RA. 1990. Bladder cancer screening in the UK. In: International conference on bladder cancer screening in high-risk g roups, September 13–14, 1989. J Occup Med 32(9):878–880.2074512
*Caspary WJ, Daston DS, Myhr BC, 1988. Evaluation of the L5178Y mouse lymphoma cell mutagenesis assay: Interlaboratory reproducibility and assessment. Environ Mol Mutagen 12(Suppl 13): 195–229.3416840
Casto BC. 1980. Detection of chemical carcinogens and mutagens in hamster cells by enhancement of adenovirus transformation. Adv Mod Environ Toxicol 1:241.
*Casto BC. 1983. Comparison of the sensitivity of rodent and human cells to chemical carcinogens using viral transformation, DNA damage, and cytotoxicity assays. Basic Life Sci 24:429–449.6305332
CDC/ATSDR. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary and immune systems. Atlanta, GA: CDC/ATSDR Subcommittee on Biomarkers of Organ Damage and Dysfunction, Centers for Disease Control, Agency for Toxic Substances and Disease Registry. Summary Report, August 27, 1990.
*Cheever KL, DeBord DG, Swearengin TF. 1991. 4,4’-Methylenebis(2-chloroaniline) (MOCA): The effect of multiple oral administration, route and phenobarbital induction on macromolecular adduct formation in the rat. Fundam Appl Toxicol 16(1):71–80.2019352
*Cheever KL, Richards DE, Weigel WW, 1988. Macromolecular adduct formation by 4,4’methylene-bis(2-chloroaniline) in adult male rat. Scand J Work Environ Health 14:57–59.3393883
*Cheever KL, Richards DE, Weigel WW, 1990. 4,4’-Methylene-bis(2-chloraniline) (MOCA): Comparison of macromolecular adduct formation after oral or dermal administration in the rat. Fundam Appl Toxicol 14(2):273–283.2318352
*Chen H, Chi T, Ko S, 2014. 4,4’-Methylenebis(2-chloroaniline) (MBOCA) may be highly toxic and a carcinogen based on an experimental study with mice. Adv Biol Chem 4(3):203–213. 10.4236/abc.2014.43025.
*Chen HI Liou SH, Ho SF, 2007. Oxidative DNA damage estimated by plasma 8-hydroxydeoxyguanosine (8-OHdG): Influence of 4, 4’-methylenebis (2-chloroaniline) exposure and smoking. J Occup Health 49(5):389–398.17951971
*Chen TH, Kuslikis BI, Braselton WE Jr. 1989. Hydroxylation of 4,4’-methylenebis(2-chloroaniline) by canine, guinea pig, and rat liver microsomes. Drug Metab Dispos 17(4):406–413.2571481
*Chen TH, Kuslikis BI, Braselton WE Jr. 1991. Unlabeled hemoglobin adducts of 4,4’-methylenebis(2-chloroaniline) in rats and guinea pigs. Arch Toxicol 65(3):177–185.2053844
*Chin B, Tobes MC, Han SS. 1983. Absorption of 4,4’-methylenebis(2-chloroaniline) by human skin. Environ Res 32(1):167–178.6617609
*CIS 1992. Chemical Information Systems, Inc. Baltimore, MD.
*Clapp DE, Piacitelli GM, Zaebst DD, 1991. Assessing exposure to 4,4’-methylenebis(2-chloroaniline) (MBOCA) in the workplace. Appl Occup Environ Hyg 6(2):125–130.
*Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cocker J, Wilson HK. 1989. Determination of 4,4’-methylenebis(2-chloroaniline) in urine: Letter. Clin Chem 35(3):506.
*Cocker J, Boobis AR, Davis DS. 1986. Routes of activation of 4,4’-methylenebis(2-chloroaniline) and 4,4’-methylenedianiline to bacterial mutagens. In: International Conference on practical in vitro toxicology, Berkshire, England, September 18–20, 1985. Food Chem Toxicol 24(6–7):755–756.
*Cocker J, Boobis AR, Davis DS. 1988. Determination of the n-acetyl metabolites of 4,4’-methylene dianiline and 4,4’-methylene-bis(2-chloroaniline) in urine. Biomed Environ Mass Spectrom 17(3):161–167.3214672
*Cocker J, Boobis AR, Gibson JF, 1985. The metabolic activation of 4,4’methylenebis(2-chlorobenzeneamine) to a bacterial mutagen by hepatic postmitochondrial supernatant from human and other species. Environ Mutagen 7(4):501–509.3902462
*Cocker J, Boobis AR, Wilson HK, 1990. Evidence that a beta-n-glucuronide of 4,4’-methylene-bis(2-chloroaniline) (MBOCA) is a major urinary metabolite in man: Implications for biological monitoring. Br J Ind Med 47(3):154–161.2328222
Cocker J, Gristwood W, Wilson HK. 1986. Assessment of occupational exposure to 4,4’-diaminodiphenylmethane (methylene dianiline) by gas chromatography-mass spectrometry analysis of urine. Br J Ind Med 43(9):620–625.3756114
*Cowles SR. 1978. Cancer in the workplace--Percivall Pott to the present. Milit Med 143(6):395–400.
*Daniel MR, Dehnel JM. 1981. Cell transformation test with baby hamster kidney cells. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:626–637.
Debord DG, Cheever KL, Swearengin RF. 1990. Alterations in histone phosphorylation in rat spleen cells after in vitro treatment with 4,4’-methylene-bis(2-chloroaniline) (MOCA). In: Society of Toxicology 29th Annual Meeting, Miami Beach, Florida, February 12–16, 1990. Washington, DC: Society of Toxicology, 417.
*DeBord DG, Cheever KL, Werren DM, 1996. Determination of 4,4’-methylene-bis(2-chloroaniline)-DNA adduct formation in rat liver and human uroepithelial cells by the ^32^P postlabeling assay. Fundam Appl Toxicol 30(1):138–144.8812257
De Serres FJ, Hoffmann GR. 1981. Summary report on the performance of yeast assays. In: Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:68–76.
DOE. 1979. MOCA permeation of protective clothing. Contract no. W-7405ENG-26. Washington, DC: U.S. Department of Energy.
*Donner M, Hytonen S, Sorsa M. 1983. Application of the sex-linked recessive lethal test in Drosophila melanogaster for monitoring the work environment of a rubber factory. Hereditas 99(1):7–10.6417061
*DOE. 2016a. Table 3: Protective Action Criteria (PAC) Rev. 29 based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. May 2016. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/teel/Revision_29_Table3.pdf. February 28, 2017.
*DOE. 2016b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29 for Chemicals of Concern - May 2016. Oak Ridge, TN: U.S. Department of Energy. https://energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels-rev-29-chemicals-concern-may-2016. February 28, 2017.
*Dost A, Straughan JK, Sorahan T. 2009. Cancer incidence and exposure to 4,4’-methylene-bis-orthochloroaniline (MbOCA). Occup Med 59(6):402–405. 10.1093/occmed/kqp093.
*Ducos P, Gaudin R. 1983. Methylene bis orthochloroaniline (“MOCA”). Evaluation of the occupational exposure in France. Cahiers de notes Documentaires 1X3:517–522.
*Ducos P, Maire C, Gaudin R. 1985. Assessment of occupational exposure to 4,4’-methylenebis(2-chloroaniline) (MOCA) by a new sensitive method for biological monitoring. Int Arch Occup Environ Health 55(2):159–167.3988358
*Dunkel VC, Pienta RJ, Sivak A, 1981. Comparative neoplastic transformation responses of Balb/3T3 cells, Syrian hamster embryo cells, and Rauscher murine leukemia virus-infected Fischer 344 rat embryo cells to chemical carcinogens. J Natl Cancer Inst 67(6):1303–1312.6947113
*Dunkel VC, Zeiger E, Brusick D, . 1984. Reproducibility of microbial mutagenicity assays: 1. Tests with Salmonella typhimurium and Escherichia coli using a standardized protocol. Environ Mutagen (Supp1 2):1–254.
*Ebell GF, Fleming DE, Genovese JH, . 1980. Simultaneous determination of 2,4- and 2,6-diisocyanatotoluene (TDI) and 3,3’-dichloro-4,4’-diaminodiphenylmethane (MOCA) in air. Ann Occup Hyg 23(2):185–188.6254424
*Edwards JW, Priestly BG. 1992. Biological and biological-effect monitoring of workers exposed to 4,4’- methylene-bis(2-chloroaniline). Hum Exp Toxicol 11(3):229–236.1352119
*Endo Y, Hara I. 1991. DNA-adduct detection in rats administered with 4,4’-methylenedianiline or 4,4’-methylenebis(2-chloroaniline). J Ind Health 33:430–431.
*EPA. 1979. Treatability of carcinogenic and other hazardous organic compounds. Contract no. CI-68-03-2559. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA600279097.
*EPA. 1981a. Development of analytical test procedures for organic pollutants in wastewater - application to pesticides. Contract no. 68-03-2711. Cincinnati, OH: U.S. Environmental Protection Agency, Industrial Environmental Research Laboratory, Office of Research and Development. EPA600481017. PB82182507.
*EPA. 1981b. Engineering handbook for hazardous waste incineration. Contract no. 68-3-3025. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Environmental Engineering and Technology. PB81248163.
EPA. 1984. Data acquisition for environmental transport and fate screening for compound of interest to the Office of Emergency and Remedial Response. Contract no. 68-03-2981. Athens, GA: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. PB84245281.
*EPA. 1985. List of hazardous substances and reportable quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
*EPA. 1986. 4,4’-Methylenebis (2-chloroaniline): Final reporting and record keeping requirements. U.S. Environmental Protection Agency. Fed Regist 51(75):13220–13224.
EPA. 1987a. Effects of 4,4’-methylene-(2-chloroaniline) and benzotrichloride in humans and/or animal tissues. Cooperative agreement no. CR-812121. Research Triangle Park, NC: U.S. Environmental Protection Agency, Health Effects Research Laboratory. PB88117882.
EPA. 1987b. Letter from NIOSH to USEPA forwarding more information on workers exposed to 4,4’-methylenebis(2-chloroaniline) and diagnosed as having a bladder tumor (5/29/87). Washington, DC. U.S. Environmental Protection Agency. EPA FYI-OTS-0687-0552.
EPA. 1987c. Toxic air pollutant/source crosswalk - a screening tool for locating possible sources emitting toxic air pollutants. Washington, DC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards.
*EPA. 1988a. Hazardous waste management system: Identification and listing of hazardous waste. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.
*EPA. 1988b. Hazardous waste management system: Identification and listing of hazardous waste. U.S. Environmental Protection Agency. Fed Regist 53(78): 13382–13393.
*EPA. 1988c. Measurement of hydrolysis rate constants for evaluation of hazardous waste land disposal. Volume 3: Data on 70 chemicals. Athens, GA: U.S. Environmental Protection Agency, Office of Research and Development. EPA600388028. PB88234042.
*EPA. 1988d. Toxic chemical release reporting: Community right-to-know. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.
*EPA. 1988e. Toxic chemical release reporting: Community right-to-know. U.S. Environmental Protection Agency. Fed Regist 53(30):4500–4554.
*EPA. 1988f. TSCA comprehensive assessment information rule: Reporting and record keeping requirements. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 704.
*EPA. 1989. List of hazardous substances and reportable quantities. U.S. Environmental Protection Agency. Fed Regist 54(155):33426–33484.
*EPA. 1990a. Interim methods for development of inhalation reference doses. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600890066A.
*EPA. 1990b. Health and environmental effects document for 4,4’-methylenebis(2-chloroaniline). Cincinnati, OH. U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Responses. EPA600x85371.
*EPA. 1991a. Land disposal restrictions. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.
*’EPA. 1991b. Land disposal restrictions. U.S. Environmental Protection Agency. Fed Regist 56(21):3876–3928.
*EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
*EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. February 28, 2017.
*EPA. 2012. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822S12-001. https://www.epa.gov/sites/production/files/2015-09/documents/dwstandards2012.pdf. February 28, 2017.
*EPA. 2016. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/aegl/access-acute-exposure-guideline-levels-aegls-values#chemicals. February 28, 2017.
*Farmer PB, Rickard J, Robertson S. 1981. The metabolism and distribution of 4,4’-methylenebis(2-chloroaniline) (MBOCA) in rats. J Appl Toxicol 1(6):317–322.7185894
*FDA. 2013. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. February 28, 2017.
FEDRIP. 1991. Federal Research in Progress. Dialog Information Service, Inc. December 1991.
Fielder RJ, Dale EA, Smith AM, 1983. Trimellitic anhydride (TMA); 4,4’-methylenebis-(2- chloroaniline) (MBOCA): N-nitrosodiethanolamine (nDELA). London, England: H.M. Stationery Office.
Fishbein L. 1984. Aromatic amines. In: The handbook of environmental chemistry: Anthropogenic substances. Berlin, Germany: Springer-Verlag, 3:1–40.
*Galloway SM, Bloom AD, Resnick M, 1985. Development of a standard protocol for in vitro cytogenetic testing with Chinese hamster ovary cells: Comparison of results for 22 compounds in two laboratories. Environ Mutagen 21–51.
*Garner RC, Welch A, Pickering C. 1981. Mutagenic activity of 42 coded compounds in the Salmonella/microsome assay. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:280–284.
*Gatehouse D. 1981. Mutagenic activity of 42 coded compounds in the “microtiter” fluctuation test. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:376–386.
*GISO. 1985. General Industry Safety Orders: California Title 8, Section 5215:886–890; effective July 1985.
Goutet P. 1981. 4,4’-Methylenebis(2-chloroaniline): Toxicological hazards and exposure at work. Cahiers de notes Documentaires 104:387–393.
Graul RJ, Stanley RL. 1982. Specific gravity adjustment of urine analysis results. Am Ind Hyg Assoc J 43(11):863.7168444
*Gristwood W, Robertson SM, Wilson HK. 1984. The determination of 4,4’-methylenebis(2-chloroaniline) in urine by electron capture gas chromatography. J Anal Toxicol 8(3):101–105.6737997
*Groth DH, Weigel WW, Tolos WP, 1984. 4,4’-Methylene-bis-ortho-chloroaniline (MBOCA): Absorption and excretion after skin application and gavage. Environ Res 34(1):38–54.6723608
*Grundmann E, Steinhoff D. 1970. Liver and lung tumors in rats from 3,3’-dichloro-4,4’-diaminodiphenyl-methane. Z Krebsforschung 74:28–39.
Haworth S, Lawlor T, Mortelmans K, 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 5(Suppl):3–142.
HAZDAT. 1993. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. February 13, 1992.
Hendry WF, Blandy JP, Glashan RW, 1988. Occupational bladder cancer: A guide for clinicians. Br J Urol 61(3):183–191.3359119
Henning HF. 1974. Precautions in the use of methylene-bis-o-chloroaniline (MBOCA). Ann Occup Hyg 17(2):137–142.4451319
Henschler D. 1983. Methods of determination of harmful industrial substances. Volume 2: Analyses of biological matter. Germany: Verlag Chemie, 7th Supplement.
Henschler D. 1987. Risk assessment and evaluation of chemical carcinogens present and future strategies. J Cancer Res Clin Oncol 133(1):1–7.
*Hesbert A, Bottin MC, DeCeaurriz J. 1985. Mutagenicity of 4,4’-methylenebis(2-chloroaniline) “MOCA” and its n-acetyl derivatives in S. typhimurium. Int Arch Occup Environ Health 55(2):169–174.3886557
*Hogan TJ. 1993. Case study “Carcinogens”: The MBOCA TLV example. Am Ind Hyg Assoc J 54(S):458–460.8213489
*Hosein HR, Van Roosmalen PB. 1978. Acute exposure to methylene-bis-ortho chloroaniline (MOCA). Am Ind Hyg A ssoc J 39(6):496–497.
*Hotchkiss SA, Hewitt P, Caldwell J. 1993. Percutaneous absorption of 4,4’-methylene-bis(2-chloroaniline) and 4,4’-methylenedianiline through rat and human skin in vitro. Toxicol in Vitro 7(2):141–148.20732182
*Howard PH, Boethling RS, Jarvis WF, 1991. Handbook of Environmental degradation rates. Chelsea, MI: Lewis Publishers, 348–349.
*HSDB. 1991. 4,4’-Methylenebis(2-chloraniline). Hazardous Substances Data Bank. Bethesda, MD: National Library of Medicine, National Toxicology Information Program. October 17, 1991.
*Hubbard SA, Green MHL, Bridges BA, 1981. Fluctuation test with S9 and hepatocyte activation. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1361–370.
*IARC. 1974. IARC monographs on the evaluation of the carcinogenic risk of chemicals to man: Some aromatic amines, hydrazine and related substances, n-nitroso compounds and miscellaneous alkylating agents. Vol. 4:65–71. Lyon, France: World Health Organization, International Agency for Research on Cancer.
*IARC. 1987. IARC monographs on the evaluation of the carcinogenic risk to man: Summary table. Suppl 7:66. Lyon, France: World Health Organization, International Agency for Research on Cancer.
IARC. 1990. Cancer: Causes, occurrence and control. Lyon, France: World Health Organization, International Agency for Research on Cancer. IARC Sci Publ 100:129–130.
*IARC. 2012. 4,4’-Methylenebis(2-chlorobenzenamine). IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 100F. Chemical agents and related occupations. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/List_of_Classifications.pdf. June 15, 2017.
*IARC. 2017. Agents classified by the IARC Monographs, Volumes 1–118. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/List_of_Classifications.pdf. June 15, 2017.
*Ichikawa Y, Yoshida M, Okayama A, 1990. Biological monitoring for workers exposed to 4,4’-methylenebis(2-chloroaniline). Am Ind Hyg Assoc J 51(1):5–7.2301252
*Ichinotsubo D, Mower H, Mandel M. 1981a. Mutagen testing of a series of paired compounds with the Ames Salmonella testing system. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:298–301.
*Ichinotsubo D, Mower H, Mandel H. 1981b. Testing of a series of paired compounds (carcinogen and noncarcinogenic structural analog) by DNA repair-deficient E. coli strains. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:195–198.
Igaku S. 1991. [DNA-adduct detection in rats administered with 4,4’-methylenedianiline or 4’,4-methylene bis(2-chloraniline).] Endo, Yoko: Hara, Ichiro (Department of Public Health, Kansai Med Univ Moriguchi 570) 33(5):430–431. (Japanese)
*IRIS. 2017. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris_drafts/simple_list.cfm?list_type=alpha. March 2, 2017.
*Jagannath DR, Vultaggio DM, Brusick DJ. 1981. Genetic activity of 42 coded compounds in the mitotic gene conversion assay using Saccharomyces cerevisiae strain D4. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:456–467.
*James RH, Adams, Finkel JM, 1985. Evaluation of analytical methods for the determination of POHC in combustion products. J Air Pollut Control Assoc 35(9):959–969.
Jedrzejczak K, Gaind VS. 1992. Determination of 4,4’-methylenebis(2-chloroaniline) in urine using capillary gas chromatography and negative ion chemical ionization mass spectrometry. Analyst 117:1417–1420.1443639
Johnson LD. 1985. Air pollution - “toxic” or “hazardous” air pollutants. International Congress Symposium Series - Royal Soc Med 82:15–23.
*Kada T. 1981. The DNA-damaging activity of 42 coded compounds in the Ret-assay. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:175–182.
*Kada T, Green M, Mandel M, 1981. Summary report on the performance of bacterial repair, phage induction, degranulation, and nuclear enlargement assay. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:33–48.
*Kaderlik KR, Talaska G, DeBord DG, 1993. 4,4’-Methylene-bis(2-chloroaniline)-DNA adduct analysis in human exfoliated urothelial cells by ^32^P-postlabeling. Cancer Epidemiol Biomarkers Prev 2(1):63–69.8420614
Kadlubar FF. 1987. Metabolism and DNA binding of carcinogenic aromatic amines. ISI Atlas Sci Pharmacol 1(2):129–132.
Kadlubar FF, Culp SJ, Turesky RJ, 1990. Biochemical mechanisms of DNA adduct formation in human tissues by carcinogenic aromatic amines. In: 15th International Cancer Congress, Hamburg, Germany, August 16–22, 1990. J Cancer Res Clin Oncol 116(Supp1, part 2):1062.
Karstadt M, Bobal R. 1982. Availability of epidemiologic data on humans exposed to animal carcinogens: 2. Chemical uses and production volume. Teratog Carcinog Mutagen 2(2):151–168.6126936
Karstadt M, Bobal R, Selikoff IJ. 1981. A survey of availability of epidemiologic data on humans exposed to animal carcinogens. In: Peto R, Schneiderman M, eds. Banbury report, volume 9. Quantification of occupational cancer meeting, March 29-April 2, 1981. Cold Spring Harbor, NY: Cold Spring Harbor Laboratory, 223–246.
*Kassinova GV, Kovaltsova SV, Marfin SV, 1981. Activity of 40 coded compounds in differential inhibition and mitotic crossing-over assays in yeast. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:434–455.
*Katz M, Heddle JA, Salamone MF. 1981. Mutagenic activity of polycyclic aromatic hydrocarbons and other Environmental pollutants. In: Dennis AJ, ed. Chemical analytical and biological fate: Polynuclear aromatic hydrocarbons, 5th International Symposium. Columbus, OH: Battelle Press, 519–528.
*Keen C, Coldwell M, McNally K, 2012. A follow up study of occupational exposure to 4,4’-methylene-bis(2-chloroaniline) (MbOCA) and isocyanates in polyurethane manufacture in the UK. Toxicol Lett 213(1):3–8. 10.1016/j.toxlet.2011.04.003.21501672
*Keeslar FL. 1986. The removal and control of methylene-bis orthochloroaniline in residential and industrial areas of Adrian, Michigan. In: Ludwigson J, ed. Proceedings of the 1986 Conference on Hazardous Material Spills, Preparedness, Prevention Control, and Cleanup of Releases, St. Louis, MO, May 5–8, 1986. Rockville, MD: Government Institute Inc., 93–97.
*Kommineni C, Groth DH, Frockt IJ, 1979. Determination of the tumorigenic potential of methylene-bis-orthochloroaniline. J Environ Pathol Toxicol 2(5):149–171.512554
*Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RS H, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
*Kugler-Stegmeier ME, Friederich U, Graf U, 1989. Genotoxicity of aniline derivatives in various short-term tests. Mutat Res 211(2):279–289.2494442
Kuslikis BI. 1989. Metabolic activation in the rat, dog, guinea pig and human of the suspect carcinogen 4,4’-methylenebis(2-chloroaniline). Diss Abstr Int 50(3):825-B.
*Kuslikis BI, Tosko JE, Braselton WE Jr. 1991. Mutagenicity and effect on gap-junctional intercellular communication of 4,4’-methylenebis(2-chloroaniline) and its oxidized metabolites. Mutagenesis 6(1):19–24.2038268
Lichtenberg JJ, Longbottom JE, Bellar TA. 1987. Analytical methods for the determination of volatile nonpolar organic chemicals in water and water related environments. In: Suffet IH, Malaiyandi M, eds. Advances in chemistry, Series 214, organic pollutants in water: Sampling, analysis, and toxicity testing. 188th Meeting of the American Chemical Society, Philadelphia, PA, August 29–31, 1984. Washington, DC: American Chemical Society, 63–82.
*Lin IS, Fan PL, Chen HI, 2013. Rapid and intermediate N-acetylators are less susceptible to oxidative damage among 4,4’-methylenebis(2-chloroaniline) (MBOCA)-exposed workers. Int J Hyg Environ Health 216(4):515–520. 10.1016/j.ijheh.2013.02.001.23491024
Linch AL. 1974. Biological monitoring for industrial exposure to cyanogenic aromatic nitro and amino compounds. Am Ind Hyg A ssoc J 35:426–432.
*Linch AL, O’Connor GB, Barnes JR, 1971. Methylene-bis-ortho-chloroaniline (MOCA): Evaluation of hazards and exposure control. Am Ind Hyg Assoc J 32(12):802–819.5149396
*Liu CS, Liou SH, Loh CH, 2005. Occupational bladder cancer in a 4,4 -methylenebis(2-chloroaniline) (MBOCA)-exposed worker. Environ Health Perspect 113(6):771–774.15929884
Locke J. 1986. Fixing exposure limits for toxic chemicals in the UK - some case studies. Sci Total Environ 51:237–260.3016893
*Lowry LK, Clapp DE. 1992. Urinary 4,4’-methylenebis(2-chloroaniline) (MBOCA): A case for biological monitoring. Appl Occup Environ Hyg 7:593–598.
*MacDonald DJ. 1981. Salmonella/microsome tests on 42 coded chemicals. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:285–297.
Manis MO, Braselton WE. 1982. Enzymatic and chromatographic characterization of the major urinary metabolite of 4,4’-methylenebis-2-chloroaniline in dogs. In: 66th Annual Meeting of the Federation of American Societies for Experimental Biology, New Orleans, LA, April 15–23, 1982. Fed Proc 41(5):Abstract 7646.
Manis MO, Braselton WE. 1983. Protein binding and structure identification of the major urinary metabolite of 4,4’-methylenebis-2-chloroaniline in dogs. In: 67th Annual Meeting of the Federation of American Societies for Experimental Biology, Chicago, IL, April 10–15, 1983. Fed Proc 42(3):Abstract 354.
*Manis MO, Braselton WE. 1984. Structure elucidation and in vitro reactivity of the major metabolite of 4,4’-methylenebis(2-chloroaniline) (MBOCA) in canine urine. Fundam Appl Toxicol 4(6):1000–1008.6549168
Manis MO, Braselton WE. 1986. Metabolism of 4,4’-methylenebis(2-chloroaniline) by canine liver and kidney slices. Drug Metab Dispos 14(2):166–174.2870890
*Manis MO, Williams DE, McCormack KM, 1984. Percutaneous absorption, disposition, and excretion of 4,4’-methylenebis(2-chloroaniline) in dogs. Environ Res 33(1):234–245.
*Martin CN, McDermid AC. 1981. Testing of 42 coded compounds for their ability to induce unscheduled DNA repair synthesis in HeLa cells. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:533–537.
*Martire G, Vricella G, Perfumo AM, 1981. Evaluation of the mutagenic activity of coded compounds in the Salmonella test. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:271–279.
*Mason TJ, Vogler WJ. 1990. Bladder cancer screening at the DuPont Chambers Works: A new initiative. J Occup Med 32(9):874–877.2074511
*Matsushima T, Takamoto Y, Shirai A, 1981. Reverse mutation test on 42 coded compounds with the E. coli WP2 system. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:387–395.
*McCann J, Choi E, Yamasaki E, 1975. Detection of carcinogens as mutagens in the Salmonella/microsome test: Assay of 300 chemicals. Proc Natl Acad Sci 72:5135–5139.1061098
*McKerrell PJ, Saunders GA, Geyer R. 1987. Determination of 4,4’-methylenebis(2-chloroaniline) in urine by high-performance liquid chromatography. J Chromatogr 408:399–401.3429537
McQueen CA, Williams GM. 1982. Cytotoxicity of xenobiotics in adult rat hepatocytes in primary culture. Fundam Appl Toxicol 2(3):139–144.6309593
*McQueen CA, Williams GM. 1987. The hepatocyte primary culture/DNA repair test using hepatocytes from several species. Cell Biol Toxicol 3(2):209–218.3507256
McQueen CA, Williams GM. 1990. Review of the genotoxicity and carcinogenicity of 4,4’-methylene-dianiline and 4,4’-methylene-bis-2-chloroaniline. Mutat Res 239(2):133–142.2200958
*McQueen CA, Maslansky CJ, Crescenzi SB, 1981. The genotoxicity of 4,4’-methylenebis-2-chloroaniline in rat, mouse and hamster hepatocytes. Toxicol Appl Pharmacol 58(2):231–235.7245198
*McQueen CA, Maslansky CJ, Williams GM. 1983. Role of the acetylation polymorphism in determining susceptibility of cultured rabbit hepatocytes to DNA damage by aromatic amines. Cancer Res 43(7): 3120–3123.6850620
*Mehta RD, Von Borstel RC. 1981. Mutagenic activity of 42 encoded compounds in the haploid yeast reversion assay, strain XV185-14C. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:414–423.
*Messerly EA, Fekete JE, Wade DR, 1987. Structure-mutagenicity relationships of benzidine analogues. Environ Mol Mutagen 10(3):263–274.3315653
Mitchell AD, Myhr BC, Rudd CJ, 1988. Evaluation of the L5178Y mouse lymphoma cell mutagenesis assay: Methods used and chemicals evaluated. Environ Mol Mutagen 12(Suppl 13):1–18.
Morales R, Rappaport SM, Hermes RE. 1979. Air sampling and analytical procedures for benzidine, 3,3’-dichlorobenzidine and their salts. Am Ind Hyg Assoc J 40(11):970–978.532783
Mori H, Tanaka T, Niwa K, 1989. Induction of altered hepatocellular foci of hamster for a possible short-term assay for carcinogens. Res Commun Chem Pathol Pharmacol 63(3):451–454.2727394
*Mori H, Yoshimi N, Sugie S, 1988. Genotoxicity of epoxy resin hardeners in the hepatocyte primary culture/DNA repair test. Mutat Res 204(4):683–688.3352649
Morton KC, King CM, Vaught JB, 1983. Prostaglandin H synthase-mediated reaction of carcinogenic arylamines with tRNA and homopolyribonucleotides. Biochem Biophy Res Commun 111(1):96–103.
*Morton KC, Lee MS, Siedlik P, 1988. Metabolism of 4,4’-methylenebis-2-chloroaniline (MOCA) by rats in vitro and formation of n-hydroxy MOCA by rat and human liver microsomes. Carcinogenesis 9(5):731–739.3365833
*Murray EB, Edwards JW. 1999. Micronuclei in peripheral lymphocytes and exfoliated urothelial cells of workers exposed to 4,4’-methylenebis-(2-chloroaniline) (MOCA). Mutat Res 446(2):175–180.10635339
*Murray EB, Edwards JW. 2005. Differential induction of micronuclei in peripheral lymphocytes and exfoliated urothelial cells of workers exposed to 4,4’-methylenebis-(2-chloroaniline) (MOCA) and bitumen fumes. Rev Environ Health 20(3):163–176.16335575
*Myhr BC, Caspary WJ. 1988. Evaluation of the L5178Y mouse lymphoma cell mutagenesis assay: Intralaboratory results for sixty-three coded chemicals tested at Litton Bionetics, Inc. Environ Mol Mutagen 12(Suppl 13):103–194.3416838
*Nagao M, Takahashi Y. 1981. Mutagenic activity of 42 coded compounds in the Salmonella/microsome assay. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1302–313.
Nakamura S, Oda Y, Oki I, 1986. A simple test system (Umu test) for the detection of environmental mutagens: 5. Further evaluation of the Umu test as a primary screening for carcinogens. Mutat Res 164:275.
*NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
NATICH. 1992. Data base report on state, local, and EPA air toxics activities. National Air Toxics Information Clearinghouse. Washington, DC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. March 12, 1992.
*Nesnow S, Triplett LL, Slaga TJ, 1985. Carcinogenesis: A comprehensive survey. Volume 8. In: Mass MJ, Kaufman DG, Siegfried JM, eds. Cancer of the respiratory tract: Predisposing factors. New York, NY: Raven Press, 257–277.
*Niemenen EH, Saarinen LH, Laakso JR. 1983. Simultaneous determination of aromatic isocyanates and some carcinogenic amines in the work atmosphere by reversed-phase high-performance liquid chromatography. J Liq Chromatogr 6(3):453–469.
NIOSH. 1973. Hazard review of 4,4’-methylene-bis(2-chloroaniline). Rockville, MD: National Institute for Occupational Safety and Health. PB87210837.
NIOSH. 1977. 104-Week carcinogenicity study in male rats 4,4’-methylene-bis(2-chloroaniline) (MOCA). Cincinnati, OH: National Institute for Occupational Safety and Health. PB83239475.
NIOSH. 1978a. Health hazard evaluation determination. Report no. 77-125-547, Amphenol Cadre, Longmont, Colorado. Cincinnati, OH: National Institute for Occupational Safety and Health, Health Hazard and Technical Assistance Branch. PB81143794.
*NIOSH. 1978b. Special hazard review with control recommendations for 4,4’-methylenebis(2-chloroaniline). U. S. Department of Health, Education and Welfare, National Institute for Occupational Safety and Health. Publication no. 78–188.
*NIOSH. 1984. 1985 Supplement to NIOSH manual of analytical methods. 3rd edition. Cincinnati, OH: National Institute for Occupational Safety and Health, Division of Physical Sciences and Engineering. Department of Health and Human Services. Publication no. 84–100.
*NIOSH. 1985. Health hazard evaluation report HETA 84-508-1626, Steinmetz and Sons, Moscow, Pennsylvania. Cincinnati, OH: National Institute for Occupational Safety and Health, Hazard Evaluations and Technical Assistance Branch. PB86191830.
*NIOSH 1986a. Health hazards evaluation report HETA 85-407-1692, Parkway P roducts, Inc. Contract no. HETA 85-407-1692. Cincinnati, OH: National Institute for Occupational Safety and Health, U.S. Department of Health and Humans Services. PB87108023.
*NIOSH. 1986b. Industrial hygiene survey report, Parkway Products, Inc. Cincinnati, OH: National Institute for Occupational Safety and Health, Department of Health and Human Services. PB87222360.
*NIOSH. 2016. 4,4’-Methylenebis(2-chloroaniline). NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgd0411.html. June 15, 2017.
*NOES. 1992. National Occupational Exposure Survey (1981–1983). Cincinnati, OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, Division of Surveillance, Hazard Evaluations, and Field Studies (Unpublished provisional data as of 7/l/90).
*NRC. 1981. Aromatic Amines: An assessment of the biological and environmental effects. Washington, DC: National Academy Press, 19, 168–197.
*NTP. 1991a. National Toxicology Program: Fiscal Year 1991 Annual Plan. Atlanta, GA: National Toxicology Program, 72–73.
*NTP. 1991b. National Toxicology Program: Sixth annual report on carcinogens: 1991 Summary. Atlanta, GA. National Toxicology Program.
*NTP. 2016. 4,4′-Methylenebis(2-chloroaniline) CAS No. 101-14-4. Report on Carcinogens, Fourteenth Edition. CASRN Index in MS Excel. Research Triangle Park, NC: National Toxicology Program, U.S. Department of Health and Human Services, Public Health Service. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/methylenebis_chloroaniline.pdf. June 15, 2017.
*OHM/TADS. 1985. 4,4’-Methylenebis(2-chloraniline). Oil and Hazardous Materials/Technical Assistance Data System. Baltimore, MD: Chemical Information Systems, Inc. December 1985.
*Okayama A, Ichikawa Y, Yoshida M, 1988. Determination of 4,4’-methylenebis(2-chloroaniline) in urine by liquid chromatography with ion-paired solid-phase extraction and electrochemical detection. Clin Chem 34(10):2122–2125.3168228
*OSHA. 1987. Access to employee exposure and medical records. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.20.
*OSHA. 1988. Access to employee exposure and medical records. Occupational Safety and Health Administration. Fed Regist 53(189): 30163–30164.
*OSHA. 1989a. Toxic and hazardous substances. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
*OSHA. 1989b. Toxic and hazardous substances. Part 1910. Occupational Safety and Health Administration. Fed Regist 54(12): 2920–2960.
*OSHA. 2016a. Subpart D Occupational health and environment controls. Section 1926.55 - Gases, vapors, fumes, dusts, and mists. Appendix A to Part 1926.55 - threshold limit values of airborne contaminants for construction. Occupational Safety and Health Standards. Code of Federal Regulations. 29 CFR 1926.55. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol8/pdf/CFR-2016-title29-vol8-sec1926-55.pdf. March 6, 2017.
*OSHA. 2016b. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Standards. Code of Federal Regulations. 29 CFR 1910.1000. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol6/pdf/CFR-2016-title29-vol6-sec1910-1000.pdf. March 6, 2017.
*OSHA. 2016c. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z - Shipyards. Occupational Safety and Health Standards. Code of Federal Regulations. 29 CFR 1915.1000. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol7/pdf/CFR-2016-title29-vol7-sec1915-1000.pdf. March 6, 2017.
*Osorio AM, Clapp D, Ward E, 1990. Biological monitoring of a worker acutely exposed to MBOCA. Am J Ind Med 18 (5): 577–589.2244630
OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment, U.S. Congress. OTA-BA-436. April 1990.
*Parkes HG. 1976. The epidemiology of the aromatic amine cancers. In: Searle CE, ed. Chemical carcinogens. Washington, DC: American Chemical Society, American Chemical Society Monograph, 173.
*Parkes HG. 1979. The identification and control of occupational bladder cancer. IARC Sci Publ 25:462–480.
*Parris GE, Diachenko GW, Entz RC, 1980. Waterborne methylene bis-2-chloroaniline and 2-chloroaniline contamination around Adrian, Michigan. Bull Environ Contam Toxicol 24(4):497–503.7378596
*Parry JM, Sharp DC. 1981. Induction of mitotic aneuploidy in the yeast strain D6 by 42 coded compounds. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:468–480.
Pereira MA. 1985. Mouse liver tumor data assessment of carcinogenic activity. In: An International Symposium on Advances in Health Risk Assessment for Systemic Toxicants and Chemical Mixtures. Toxicol Ind Health 1(4):311–334.
*Perry PE, Thomson EJ. 1981. Evaluation of the sister chromatid exchange method in mammalian cells as a screening system for carcinogens. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:560–569.
Piegorsch WW, Hoel DG. 1988. Exploring relationships between mutagenic and carcinogenic potencies. Mutat Res 196(2):161–176.3419441
Purchase IFH, Longstaff E, Ashby J, 1978. Mutagenicity studies. Br J Cancer 37:873.354672
*Purnell CJ, Warwick CJ. 1980. Application of electrochemical detection to the measurement of 4,4’-methylenebis(2-chloroaniline) and 2-chloroaniline concentrations in air by high-performance liquid chromatography. Analyst 105(1254):861–867.
*Purnell CJ, Warwick CJ. 1981. Method 3 - analysis of 3,3’-dichloro-4,4’-diaminodiphenyl methane (MOCA) and 2-chloroaniline in air. In: Egan H, ed. Environmental carcinogens: Selected methods of analysis. Vol. 4: Some aromatic amines and azo dyes in the general and industrial environment. Lyon, France: World Health Organization, International Agency for Research on Cancer. IARC Sci Publ 40, 133–140.
*Rao TK, Dorsey GF, Allen BE, 1982. Mutagenicity of 4,4’-methylenedianiline derivatives in the Salmonella histidine reversion assay. Arch Toxicol 49(3–4):185–190.7092557
*Rappaport SM, Morales R. 1979. Air-sampling and analytical method for 4,4’-methylenebis (2-chloroaniline). Anal Chem 51(1):19–23.420394
*Reid TM, DeBord DG, Cheever KL, 1998. Mutagenicity of N-OH-MOCA (4-amino-4’-hydroxylamino-bis-3,3’-dichlorodiphenylmethane) and PBQ (2-phenyl-1,4-benzoquinone) in human lymphoblastoid cells. Toxicol Lett 95(3):205–210.9704822
*Rice JR, Kissinger PT. 1981. Method for determination of benzidine, 3,3’-dimethoxybenzidine, 4-aminobiphenyl, 3,3’-dichlorobenzidine, and 4,4’-methylene-bis(2-chloroaniline) (MOCA) in soil samples’ surface water and groundwater by liquid chromatography with electrochemical detection. In: Egan H, Fishbein L, Castegnaro M, eds. Environmental carcinogens: Selected methods of analysis. Volume 4: Some aromatic amines and azo dyes in the general and industrial environment. Lyon, France: World Health Organization, International Agency for Research on Cancer, 141–151.
*Rice JR, Kissinger PT. 1982. Liquid chromatography with precolumn sample preconcentration and electrochemical detection: Determination of aromatic amines in environmental samples. Environ Sci Technol 16(5):263–268.22257250
Richold M, Jones E. 1981. Mutagenic activity of 42 coded compounds in the salmonella/microsome assay. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1314–322.
Ringen K. 1988. Regulate 4,4’-methylene-bis(2-chloroaniline). Am J Ind Med 14(3):255–256.3189342
*Robbiano L, Baroni D, Novello L, 2006. Correlation between induction of DNA fragmentation in lung cells from rats and humans and carcinogenic activity. Mutat Res 605(1–2):94–102. 10.1016/j.mrgentox.2006.03.001.16690349
*Robert A, Ducos P, Francin JM. 1999a. Biological monitoring of workers exposed to 4,4’-methylene-bis-(2-orthochloroaniline) (MOCA). I. A new and easy determination of "free" and "total" MOCA in urine. Int Arch Occup Environ Health 72(4):223–228.10491776
*Robert A, Ducos P, Francin JM. 1999b. Biological monitoring of workers exposed to 4,4’-methylene-bis-(2-orthochloroaniline) (MOCA). II. Comparative interest of "free" and "total" MOCA in the urine of exposed workers. Int Arch Occup Environ Health 72(4):229–237.10491777
Rosenkranz HS, Ennever FK, D imayuga M, 1990. Significant differences in the structural basis of the induction of sister chromatid exchanges and chromosomal aberrations in Chinese hamster ovary cells. Environ Mol Mutagen 16(3):149–177.2209572
*Rosenkranz HS, Hyman J, Leifer Z. 1981. DNA polymerase deficient assay. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:210–218.
*Rowland I, Severn B. 1981. Mutagenicity of carcinogens and noncarcinogens in the Salmonella/microsome test. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:323–332.
*Russfield AB, Hornburger F, Boger E, 1975. The carcinogenic effect of 4,4’-methylene-bis-(2-chloroaniline) in mice and rats. Toxicol Appl Pharmacol 31(1):47–54.1129788
*Sabbioni G, Neumann HG. 1990. Quantification of hemoglobin binding of 4,4’-methylenebis (2-chloroaniline) (MOCA) in rats. Arch Toxicol 64(6):451–458.1703404
Salamone MF. 1981. Toxicity of carcinogens and noncarcinogenic analogues. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:682–685.
*Salamone MF, Heddle JA, Katz M. 1981. Mutagenic activity of 41 compounds in the in vivo micronucleus assay. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:686–697.
Savage RE, Weigel WW, Krieg EF. 1992. Induction of ornithine decarboxylase activity by 4,4’-methylenebis(2-chloroaniline) in the rat. Cancer Lett 62:63–68.1540933
*Sawicki E, Belsky T, Friedel RA, 1975. 3,3’-Dichloro-4,4’-diaminodiphenylmethane (MOCA) in air analytical method. Health Lab Sci 12(4):415–418.
*Sax NI, Lewis RJ. 1987. Hawley’s condensed chemical dictionary. 11th ed. New York, NY: Van Nostrand Reinhold Company, 767.
Schmitt CR, Cagle GW. 1975. Sulfamic acid cleaning solution for 4,4’-methylene-bisorthochloroaniline (MOCA). Am Ind Hyg Assoc J 36(3):181–186.1146681
*Schulte PA. 1990. Screening for bladder cancer in high-risk groups: Delineation of the problem. J Occup Med 32(9):789–792.2074499
*Schulte PA, Ward E, Boeniger M, 1988. Occupational exposure to n-substituted aryl compounds. In: King CM, Romano LJ, Schuetzle D, eds. Carcinogenic and mutagenic responses to aromatic amines and nitroarenes. New York, NY: Elsevier, 23–35.
*Searle CE, ed. 1984. Chemical carcinogens: Second edition, revised and expanded. ACS Monograph 182. Washington, DC: American Chemical Society, 1:283–284.
*Segerback D, Kadlubar FF. 1992. Characterization of 4,4’-methylenebis(2-chloroaniline)-DNA adducts formed in vivo and in vitro. Carcinogenesis 13:1587–1592.1394844
*Sharp DC, Parry JM. 1981. Induction of mitotic gene conversion by 41 coded compounds using the yeast culture JDl. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:491–501.
*Shivapurkar N, Lehman TA, Schut HA, 1987. DNA binding of 4,4’-methylenebis(2-chloroaniline) (MOCA) in explant cultures of human and dog bladder. Cancer Lett 38(1–2):41–48.3690513
*Silk NA, Lay JO Jr, Martin CN. 1989. Covalent binding of 4,4’-methylenebis-2-chloroaniline) to rat liver DNA in vivo and of its N-hydroxylated derivative to DNA in vitro. Biochem Pharmacol 38(2):279–287.2914011
*Simmon VF, Shepherd CF. 1981. Mutagenic activity of 42 coded compounds in the Salmonella/microsome assay. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 133–342.
*Skarping G, Renman L, Sangoe C, 1985. Capillary gas chromatographic method for the determination of complex mixture of isocyanates and amines. J Chromatogr 346:191–204.
Skarping G, Renman L, Smith BE. 1983. Trace analysis of amines and isocyanates using glass capillary gas chromatography and selective detection: I. Determination of aromatic amines as perfluoro fatty acid amides using electron-capture detection. J Chromatogr 267(2):315–327.
*Skopek TR, Andon BM, Kaden DA, 1981. Mutagenic activity of 42 coded compounds using 8-azaguanine resistance as a genetic marker in Salmonella typhimurium. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1371–375.]
*Smith AM, Woodward KN. 1983. 4,4’-Methylene bis-(2-chloroaniline) (MBOCA). Toxic Rev 8, Part 2:1–19.
Smyth WF, Smyth MR. 1987. Electrochemical analysis of organic pollutants. Pure & Appl Chem 59(2):245–256.
Spiegelhalder B. 1983. Carcinogens in the workroom air in the rubber industry. Scand J of Work Environ Health 9(Suppl 2):15–26.
Steinhoff D, Grundmann E. 1969. Carcinogenic effect of 3,3’-dichloro-4,4’-diaminophemylmethane in rats. Naturwissenschaften 56(4):215–216.
Steinhoff D, Grundmann E. 1971. Cancerogenic effect of 3,3’dichloro-4,4’-diaminodiphenylmethane in rats. Naturwissenschaften 58(11):578
Stewart PA, Lee JS, Marano DE, 1991. Retrospective cohort mortality study of workers at an aircraft maintenance facility: II. Exposures and their assessment. Br J Ind Med 48(8):531–537.1878309
Stoner GD. 1988. Metabolism of 4,4’-methylene-bis(2-chloroaniline) in explant cultures of human and dog bladder and dog liver cell cultures. In: Proceeding of the Fourth NCI/EPA/NIOSH Collaborative Workshop: Progress on Joint Environmental and Occupational Cancer Studies, April 22–23, 1986. Rockville, MD: National Institutes of Health. Publication no. 88-2960, 343–350.
Stoner GD, Shivapurkar NM, Schut HAJ, 1987. Metabolism of 4,4’-methylenebis-2-chloroaniline in explant cultures of human and dog bladder and dog liver cell cultures. In: Symposium on Predictive Toxicology Held at the 16th Conference on Environmental Toxicology. Toxicology 47(1–2):205.
*Stoner GD, Shivapurkar NM, Schut HAJ, 1988. DNA binding and adduct formation of 4,4’-methylene-bis(2-chloroaniline) (MOCA) in explant cultures of human and dog bladder. In: King CM, Romano LJ, Schultzle D, eds. Carcinogenic and mutagenic responses to aromatic amines and nitroarenes. New York, NY: Elsevier, 237–240.
*Stula EF, Barnes JR, Sherman H, 1977. Urinary bladder tumors in dogs from 4,4’-methylenebis(2-chloroaniline) (MOCA). J Environ Pathol Toxicol 1(1):31–50.553139
*Stula EF, Sherman H, Zapp JA Jr, 1975. Experimental neoplasia in rats from oral administration of 3,3’-dichlorobenzidine, 4,4’-methylene-bis(2-chloroaniline), and 4,4’-methylene-bis(2-methylaniline). Toxicol Appl Pharmacol 31:159–176.1129785
*Styles JA. 1981. Activity of 42 coded compounds in the BHK-21 cell transformation test. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:638–646.
*Tabak HH, Quave SA, Mashni CI, 1981. Biodegradability studies for predicting the Environmental fate of organic priority pollutants. In: Test protocols for environmental fate and movement of toxicants. Proceedings of a Symposium of the Association of Official Analytical Chemists 94th Annual Meeting, Washington, DC, October 21, 1980. Arlington, VA: AOAC, 267–327.
Tang C. 1990. [Rapid determination of 4,4’-methylenebis-(2-chloroaniline) by TLC during elastomer synthesis.] Sepu 8(6):389–391. (Chinese)
*Thomas JD, Wilson HK. 1984. Biological monitoring of workers exposed to 4,4’-methylenebis (2-chloroaniline) (MBOCA). Br J Ind Med 41(4):547–551.6498117
*Thomson JA. 1981. Mutagenic activity of 42 coded compounds in the lambda induction assay. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:224–235.
*Tobes MC Brown LE, Chin B, 1983. Kinetics of tissue distribution and elimination of 4,4’-methylenebis-(2-chloroaniline) in rats. Toxicol Lett 17(1–2):69–76.6623511
Tosato ML, Cesareo D, Passerini L, 1988. PLS assessment of the performance of short-term tests for carcinogens. J Chemometrics 2(3):171–187.
*Traul KA, Takayama K, Kachevsky V, 1981. A rapid in vitro assay for carcinogenicity of chemical substances in mammalian cells utilizing an attachment-independence endpoint: 2. Assay validation. J Appl Toxicol 1(3):190–195.7185884
TRI90. 1992. Toxic Chemical Release Inventory. Bethesda, MD: National Library of Medicine, National Toxicology Information Program.
*TRI16. 2017. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: U.S. Environmental Protection Agency, Office of Information Analysis and Access, Office of Environmental Information. Toxics Release Inventory. http://www.epa.gov/triexplorer/. September 29, 2017.
*Trippel-Schulte P, Zeiske J, Kettrup A. 1986. Trace analysis of selected benzidine and diaminodiphenylmethane derivatives in urine by means of liquid chromatography using precolumn sample preconcentration, UV and electrochemical detection. Chromatographia 22(1–6)138–146.
*Trueman RW. 1981. Activity of 42 coded compounds in the Salmonella reverse mutation test. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:343–350.
*Tsuchimoto T, Matter BE. 1981. Activity of coded compounds in the micronucleus test. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:705–711.
*Tweats DJ. 1981. Activity of 42 coded compounds in a differential killing test using Escherichia coli strains WP2, WP67 (uvrA polA), and CM871 (uvrA 1exA recA). In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:199–209.
Uziel M, Munro NB, Katz DS, 199 2. DNA adduct formation by 12 chemicals with populations potentially suitable for molecular epidemiological studies. Mutat Res 27735–90.
*Van H Deyrup CA, Kavaler AR, , eds. 1992. OPD chemical buyers directory. 79th ed. New York, NY: Schell Publishing Company, Inc., 13, 27–28, 575.
*Van Roosmalen PB, Klein AL, Drummond I. 1979. An improved method for determination of 4,4’-methylenebis-(2-chloroaniline) (MOCA) in urine. Am Ind Hyg Assoc J 40(1):66–69.484452
*Van Roosmalen PB, Klein Al, Drummond I. 1981. Method 8 - determination of 3,3’-dichloro-4,4’diaminodiphenylmethane (MOCA) in urine, In: Egan H, ed. Environmental carcinogens: Selected methods of analysis. Vol 4: Some aromatic amines and azo dyes in the general and industrial environment. Lyon, France: International Agency for Research on Cancer, IARC Sci Publ 40:183–191.
*Vantulder PJM, Howard CC, Riggin RM. 1981. High performance liquid chromatographic determination of aromatic amines in body fluid and commercial dyes. In: Choudhary G, ed. Chemical hazards in the workplace: Measurement and control. Washington, DC: ACS Symposium Series 149:413–427.
*Vaughan GT, Kenyon RS. 1996. Monitoring for occupational exposure to 4,4’-methylenebis(2-chloroaniline) by gas chromatographic-mass spectrometric analysis of haemoglobin adducts, blood, plasma and urine. J Chromatogr B 678(2):197–204.
*Venitt S, Crofton-Sleigh C. 1981. Mutagenicity of 42 coded compounds in a bacterial assay using Escherichia coli and Salmonella typhimurium. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1351–360.
*Vogel E, Blijleven WG, Kortselius MJ, 1981. Mutagenic activity of 17 coded compounds in the sex-linked recessive lethal test in Drosophila melanogaster. In: deSerres FJ, Ashby J. eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:660–665.
*Voorman R, Penner D. 1986a. Fate of MBOCA (4,4’-methylene-bis(2-chloroaniline)) in soil. Arch Environ Contam Toxicol 15(5):595–602.
*Voorman R, Penner D. 1986b. Plant uptake of MBOCA (4,4’-methylenebis-(2-chloroaniline)). Arch Environ Contam Toxicol 15(5):589–593.
*WAC. 1988. Control of hazardous pollutants. Wisconsin Administrative Code. Chapter NR 455. Department of Natural Resources, Madison, WI, 446-4–446-16.
*Wakata A, Miyamae Y, Sato S, 1998. Evaluation of the rat micronucleus test with bone marrow and peripheral blood: Summary of the 9th collaborative study by CSGMT/JEMS. Environ Mol Mutagen 32(1):84–100.9707102
*Walker CG. 1984. Mutagenesis and inducible responses to deoxyribonucleic acid damage in Escherichia coli. Microbial Rev 48(1):60–93
Wallace DMA. 1988. Occupational urothelial cancer. Br J of Urology 61(3):175–182.
*Wan KC, Dare BR, Street NR. 1989. Biomedical surveillance of workers exposed to 4,4’-methylene-bis-(2-chloroaniline) (MBOCA) in Perth, Western Australia. J R Sot Health 109(5):159–165.
*Wang CC, Chen WL, Hsiung CN, 2017. Effect of CYP3A4 genetic polymorphisms on the genotoxicity of 4,4’-methylene-bis(2-chloroaniline)-exposed workers. Occup Environ Med 74(1):30–38. 10.1136/oemed-2016-103816.27679675
*Ward E. 1993. Response to “case study ‘carcinogenesis’: The MBOCA TLV example”. Am Ind Hyg Assoc J 54(8):461–463.
*Ward E, Clapp D, Tolos W, 1986. Efficacy of urinary monitoring for 4,4’-methylenebis-(2-chloroaniline). J Occup Med 28(8):637–642.3746484
*Ward E, Smith AB, Halperin W. 1987. 4,4’-Methylenebis(2-chloroaniline): An unregulated carcinogen. Am J Ind Med 12(5):537–549.3318415
*Ward E, Halperin W, Thun M, 1988. Bladder tumors in two young males occupationally exposed to MBOCA. Am J Ind Med 14(3):267–272.3189344
*Ward E, Halperin W, Thun M, 1990. Screening workers exposed to 4,4’-methylenebis-(2-chloroaniline) for bladder cancer by cystoscopy. In: International Conference on Bladder Cancer Screening in High-Risk Groups, September 13–14, 1989. J Occup Med 32(9):865–868.
*Weeks RW Jr, Dean BJ. 1977. Permeation of methanolic aromatic amine solutions through commercially available glove materials. J Am Ind Hyg Assoc 38(12):721–725.
Weigel WW, Savage RE Jr. 1990. Induction of ornithine decarboxylase activity of 4,4’-methylenebis (2-chloroaniline) (MOCA) in the rat. In: Society of Toxicology 29th Annual Meeting, Miami Beach, FL, February 12–16, 1990. Washington, DC: Society of Toxicology, 760.
*WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. January 08, 2014.
*WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Williams DE. 1979. Progress report on the analysis and control of exposure to 4,4’-methylene bis (2-chloroaniline. Lansing, MI: Michigan Department of Public Health, Division of Occupational Health, Division of Environmental Epidemiology.
*Williams GM, Laspia MF, Dunkel VC. 1982. Reliability of the hepatocyte primary culture/DNA repair test in testing of coded carcinogens and noncarcinogens. Mutat Res 97(5):359–370.
Wilson JD. 1978. Review of in vitro systems with potential for use in teratogenicity screening. J Environ Pathol Toxicol 2(1):149.363968
Wu K, Leslie CL, Stacy NH. 1989. Effects of mutagenic and non-mutagenic aniline derivatives on rat liver drug-metabolizing enzymes. Xenobiotica 19(11):1275–1283.2618080
*Yasuda SK. 1975. Determination of 3,3’-dichloro-4,4’-diaminodiphenylmethane in air. J Chromatogr 104(2):283–290.1150762
*Yoneyama K, Matsumura F. 1984. Microbial metabolism of 4,4’-methylenebis(2-chloroaniline). Arch Environ Contam Toxicol 13(4):501–507.
*Yoshikura H, Matsushima T. 1981. MLV test (integration enhancement test) of 42 coded compounds in mouse kidney cells. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:647–650.
Yun C, Shimada T, Guengerich FP, 1991. Purification and characterization of human liver microsomal cytochrome P-450 2A6. Mol Pharmacol 40(5):679–685.1944238
Yun CH, Shimada T, Guengerich FP. 1992. Contributions of human liver cytochrome P450 enzymes to the n-oxidation of 4,4’-methylene-bis(2-chloroaniline). Carcinogenesis 13:217–222.1740010
Zimmermann FK, Scheel I. 1981. Induction of mitotic gene conversion in strain D7 of saccharomyces cerevisiae by 42 coded chemicals. In: deSerres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Prog Mutat Res 1:481–490.