# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Dennis Jones, D.V.M.
- ATSDR, Division of Toxicology and Human Health Sciences, Atlanta, GA
- Kimberly Zaccaria, PhD, DABT
- SRC, Inc., North Syracuse, NY