# VERSION HISTORY

Date | Description
May 1994 | Final toxicological profile released
October 2017 | Update of data in Chapters 2, 3, and 7