# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of MBOCA is located in Table 4-1.

Table 4-1 Chemical Identity of 4,4’-Methylenebis(2-chloroaniline) (MBOCA)

Characteristic | Information | Reference
Chemical name | 4,4’-Methylenebis(2-chloroaniline)
Synonym(s) and registered trade name(s)^a^ | MBOCA, 3,3’-dichloro-4,4’-diaminodiphenylmethane; 4,4’-methylene(bis)-chloroaniline; 4,4’-methylenebis(o-chloroaniline); 4,4’-methylene-bis[2-chlorobenzenamine]; bis(3-chloro-4-aminopropyl) methane; aniline, 4,4’methylene-bis[2-chloro-; bis-(4-amino-3-chlorophenyl) methane; di(4-amino-3-chlorophenyl) methane; bis amine; MCA, CL-MDA; DACPM; Cuamin-M; Activator-M; CA-800; DAC; Bis-Amine A; Curene 442; MOCA; and others | CIS 1992; HSDB 1991; NRC 1981; OHM/TADS 1985; Smith and Woodward 1983
Chemical formula | C_13_H_12_Cl_2_N_2_ | IARC 1974
Chemical structure | [image] | NRC 1981
CAS Registry Number | 101-14-4 | HSDB 1991

a MBOCA trade names that are not in use: Curalin M, Curalon M, Cyanaset, and LD_813_.

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of MBOCA is located in Table 4-2.

Table 4-2 Physical and Chemical Properties of 4,4’-Methylenebis(2-chloroaniline) (MBOCA)

Property | Information | Reference
Molecular weight | 267 | IARC 1974
Color
Pure form | Colorless crystals | IARC 1974
Technical form | Yellow, tan, or brown pellets | Smith and Woodward 1983; NRC 1981
Physical state | Solid | HSDB 1991
Melting point | 110 °C | HSDB 1991
Boiling point | No data
Density at 20 °C | 1.44 g/mL | NRC 1981; Sax and Lewis 1987
Odor | Nearly odorless | NRC 1981
Odor threshold: | No data
Solubility:
Water at 24 °C | 13.9 mg/L | Voorman and Penner 1986a
Organic solvents | Soluble in hot methyl ethyl ketone, alcohol, acetones, trichloroethylene, toluene, ether, esters, and lipids | HSDB 1991; OHM/TADS 1985; Smith and Woodward 1983
Partition coefficients:
Log K_ow_ | 3.94^a^ | HSDB 1991
Log K_oc_ | 4810 | HSDB 1991
Vapor pressure
at 25 °C | 1.0×10^−5^ mmHg | Smith and Woodward 1983
at 60 °C | 1.3×10^−5^ mmHg | NRC 1981
at 100 °C | 3.5×10^−5^ mmHg | Smith and Woodward 1983
at 120 °C | 5.4×10^−5^ mmHg | NRC 1981
Henry’s law constant at 25 °C | 4×10^−11^ atm m^3^/mole
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | No data
Conversion factors | No data
Explosive limits | No data

a Estimated value.