# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## 4,4’-Methylenebis(2-chloroaniline) (MBOCA) Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4,4’-Methylenebis(2-chloroaniline) (MBOCA)
CAS Numbers: | 101-14-4
Date: | May 1994 March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute inhalation MRL.

Rationale for Not Deriving an MRL: No acute inhalation studies were identified for MBOCA.

Agency Contact (Chemical Manager): Dennis Jones, D.V.M.

## 4,4’-Methylenebis(2-chloroaniline) (MBOCA) Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4,4’-Methylenebis(2-chloroaniline) (MBOCA)
CAS Numbers: | 101-14-4
Date: | May 1994 March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: No intermediate-duration inhalation studies were identified for MBOCA.

Agency Contact (Chemical Manager): Dennis Jones, D.V.M.

## 4,4’-Methylenebis(2-chloroaniline) (MBOCA) Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4,4’-Methylenebis(2-chloroaniline) (MBOCA)
CAS Numbers: | 101-14-4
Date: | May 1994 March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: No chronic-duration inhalation studies were identified for MBOCA.

Agency Contact (Chemical Manager): Dennis Jones, D.V.M.

## 4,4’-Methylenebis(2-chloroaniline) (MBOCA) Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4,4’-Methylenebis(2-chloroaniline) (MBOCA)
CAS Numbers: | 101-14-4
Date: | May 1994 March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: Acute oral studies were limited to a single dose study in dogs reporting methemoglobinemia (Barnes, 1964); however, dose information was not available.

Agency Contact (Chemical Manager): Dennis Jones, D.V.M.

## 4,4’-Methylenebis(2-chloroaniline) (MBOCA) Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4,4’-Methylenebis(2-chloroaniline) (MBOCA)
CAS Numbers: | 101-14-4
Date: | May 1994 March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL.

Rationale for Not Deriving an MRL: Only one intermediate-duration oral study was identified (Chen et al. 2014). This study exposed male ICR mice to 0, 50, 100, or 200 mg/kg/day for 3 months via drinking water. Mice were then given standard water for an additional 6 months prior to sacrifice. All high-dose animals died prior to scheduled sacrifice. Effects reported in animals that survived until scheduled sacrifice included degeneration and/or dysplasia in several organs at the lower doses (stomach, intestines, liver, kidney, bladder); however, incidence data for all lesions in each organ were combined for surviving animals from these dose groups. Due to examination of a limited number of endpoints, inadequate data reporting, and long recovery period (6 months) prior to examination, this study is considered inadequate to use as the basis of the intermediate-duration oral MRL.

Agency Contact (Chemical Manager): Dennis Jones, D.V.M.

## 4,4’-Methylenebis(2-chloroaniline) (MBOCA) Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4,4’-Methylenebis(2-chloroaniline) (MBOCA)
CAS Numbers: | 101-14-4
Date: | May 1994 March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL | 0.003 mg/kg/day
Critical Effect: | Hepatic toxicity (increased ALT, nodular hepatic hyperplasia)
Reference: | Stula et al. 1997
Point of Departure: | LOAEL of 10 mg/kg/day
Uncertainty Factor: | 3,000
LSE Graph Key: | 9
Species: | Dog

MRL Summary: A chronic-duration oral MRL of 0.003 mg/kg/day was derived for MBOCA based on evidence of hepatic toxicity in dogs exposed to concentrations ≥10 mg/kg/day via capsule for 9 years (3–5 days/week), including elevated ALT and nodular hepatic hyperplasia; a NOAEL was not identified for hepatic effects (Stula et al. 1977). The MRL is based on the LOAEL of 10 mg/kg/day for hepatic effects and a total uncertainty factor of 3,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, 10 for human variability, and 3 for limitations in the database).

Selection of the Critical Effect: Available chronic oral studies were predominately focused on carcinogenic effects of MBOCA. Based on review of the limited data regarding nonneoplastic results (see Table A-1), the most sensitive effect appears to be liver effects in dogs exposed to 10 mg/kg/day (Stula et al. 1977). Effects noted at higher doses in rats included decreased body weight at 25 mg/kg/day (Russfield et al. 1975) and various hepatic lesions in rats exposed to 50 mg/kg/day (Stula et al. 1975); no NOAELs were identified for these effects.

Table A-1 Summary of Candidate Critical Effects for Chronic Oral MRL for MBOCA

Species | Duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Hepatic effects^a^
Dog | 9 years | ND | 10 | Increased ALT, nodular hepatic hyperplasia | Stula et al. 1977
Rat | 2 years | ND | 50 (SLOAEL) | Hepatocytomegaly, fatty change, necrosis, fibrosis, bile duct proliferation | Stula et al. 1975
Body weight effects
Rat | 18 months | ND | 25 | Decreased body weight | Russfield et al. 1975

a Selected critical effect.

LOAEL = lowest observed adverse effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; SLOAEL = serious LOAEL

Selection of the Principal Study: The study with the lowest identified LOAEL for the critical effect of hepatic toxicity was selected as the principal study (Stula et al. 1977).

Summary of the Principal Study:

Stula EF, Barnes JR, Sherman H, 1977. Urinary bladder tumors in dogs from 4,4’-methylenebis(2-chloroaniline) (MOCA). J Environ Pathol Toxicol 1(1):31–50.553139

Six 1-year old female Beagle dogs were given a gelatin capsule with 100 mg of MBOCA for 3 days/week for the first 6 weeks, then 5 days/week for up to 9 years. The dose was 8–15 mg/kg/day with an average of 10 mg/kg/day for the 9-year period. Six untreated female dogs served as control. Dogs were weighed weekly. Blood was collected periodically (∼2 times/year) for hematology and biochemistry. Urine was collected at the same time for urinalysis and urine sediment cytology. A complete necropsy was performed on all animals with histopathological examination for tumors.

One of six female beagle dogs died after 3.4 years of oral administration; however, the report concludes that the death was not MBOCA-related, because the dog died from pyelonephritis. No evidence of an association between pyelonephritis and MBOCA was identified. No clinical signs of toxicity or body weight effects were noted. No changes in hemoglobin, hematocrit, erythrocyte count, or mononuclear leukocyte count were noted. Statistically significant increase in ALT was observed in MBOCA treated dogs, but not in controls. The highest level of ALT occurred during the first 2 years and after 7–8.5 years of treatment. This change was an indication of liver damage. Histopathology revealed nodular hepatic hyperplasia in 3/5 treated dogs. There was also a disruption of liver architecture; all of these changes were MBOCA-related and were absent in the control animals. Nonmalignant focal liver cell alterations were common in both treated and control dogs. Cystic hyperplasia of the pars intermedia of the anterior pituitary gland was found in one of five female beagle dogs after 8.3 years of treatment. This change was not present in other treated dogs or in controls and was not considered to be treatment related.

Urine sediment cytology revealed abnormalities suggestive of neoplasia of the genitourinary system in dogs after 7 years of MBOCA treatment. The observed changes correspond to grades IV and V of human urinary cells by the Papanicolaou technique. Two of the treated dogs had small amount of blood in the urine observed after 8 years of MBOCA treatment. Three dogs had papillary transitional cell carcinoma of the urinary bladder, tumors infiltrated the lamina propria but not the muscle layer of the bladder. There was no evidence of metastasis to other organs. One dog developed a tumor close to the urethra. Histologically, it was a combined infiltrating transitional cell carcinoma and adenocarcinoma of the urethra. The adenocarcinoma seems to have metastasized to part of the tumor. In spite of the use of a small number of animals, this study shows that the ingestion of MBOCA over 9 years was associated with the incidence of urinary bladder cancer.

Selection of the Point of Departure for the MRL: The LOAEL of 10 mg/kg/day for hepatic toxicity in dogs was selected as the point of departure for derivation of the chronic-duration oral MRL.

Calculations: Average dose per dog was calculated by study authors based on average body weight.

Uncertainty Factor: The LOAEL is divided by a total uncertainty factor of 3,000:

- 10 for use of a LOAEL
- 10 for extrapolation from animals to humans
- 10 for human variability
- 3 for database limitations (e.g., limited examination of nonneoplastic endpoints, lack of reproductive/developmental studies)
  - MRL = The LOAEL ÷ uncertainty factors
    - 10 mg/kg/day ÷ (10 × 10 × 10 × 3) = 0.003 mg/kg/day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: As shown in Table A-1, nonneoplastic effects have been observed in both dogs and rats following chronic oral exposure at the lowest doses evaluated (Stula et al. 1975, 1977). Hepatic degeneration and/or dysplasia have also been observed in mice following subchronic oral or dermal exposure to MBOCA (Chen et al. 2014).

Agency Contact (Chemical Manager): Dennis Jones, D.V.M.