# 7 REGULATIONS AND ADVISORIES

The national regulations and guidelines regarding 2-butoxyethanol and 2-butoxyethanol acetate in air, water, and other media are summarized in Table 7-1.

An MRL of 6 ppm has been derived for acute-duration inbalation exposure (14 days or less) to 2-butoxyethanol, based on a NOAEL of 50 ppm for hematotoxicity in pregnant rats (Tyl et al. 1984). An MRL of 3 ppm has been derived for intermediate-duration inhalation exposure to 2-butoxyethanol, based on a NOAEL of 25 ppm for hematotoxicity in rats (Dodd et al. 1983). An MRL of 0.2 ppm has been derived for chronic inhalation exposure (365 days or longer) to 2-butoxyethanol, based on a NOAEL in humans for statistically significant decreased hematocrit aud increased mean corpuscular hemoglobin concentrations (Haufroid et al. 1992). The observed changes were still witbin the range of normal human variability.

An MRL of 0.4 mg/kg/day has been derived for acute-duration oral exposure to 2-butoxyethanol, based on a LOAEL of 32 mg/kg for hematotoxicity in 16-month old rats (Ghanayem et al. 1987a). An MRL of 0.07 mg/kg/day has been derived for intermediate-duration oral exposure to 2-butoxyethanol, based on a LOAEL of 69 mg/kg/day for mild hepatic toxicity in rats (NTP 1993).

There is no reference dose (RfD) for 2-butoxyethanol or 2-butoxyethanol acetate. A risk assessment to establish a reference concentration (RfC) for 2-butoxyethanol is under review by an EPA Workgroup (IRIS 1995).

OSHA requires employers of workers who are occupationally exposed to 2-butoxyethanol to institute engineering controls and work practices to reduce employee exposure and maintain it at or below permissible exposure limits (PEL). The PEL for 2-butoxyethanol is 50 ppm (OSHA 1974). Workers exposed to 2-butoxyethanol should wear personal protective equipment such as gloves, coveralls, and goggles to protect exposure to the skin (OSHA 1974). NIOSH recommends that industrial hygiene surveys be completed at work places where airborne exposure to 2-butoxyethanol or 2-butoxyethanol acetate may occur (NIOSH 1990). If exposure levels are at or above one-half the recommended exposure limit (REL = 5 ppm), NIOSH recommends that a program of personal monitoring be instituted so that the exposure of each worker can be estimated. If exposure levels are at or greater than the REL, or if there is a potential for skin contact, NIOSH recommends that 2-butoxyacetic acid be measured in the urine of the workers.

Table 7-1 Regulations and Guidelines Applicable to 2-Butoxyethanol and 2-Butoxyethanol Acetate

Agency | Description | Information | References
[underlined: INTERNATIONAL]
Guidelines:
WHO | No information available | | WHO 1984
[underlined: NATIONAL]
Regulations:
a. Air:
EPA OAQPS | List of Chemicals Produced By Affected Facilities (2-butoxyethanol acetate) | Yes | 40 CFR 60.489; EPA 1977
EPA OAQPS | List of Chemicals Produced By Affected Facilities (2-butoxyethanol) | Yes | 40 CFR 60.489; EPA 1977
EPA OAQPS | Chemicals Affected By Standards of Performance for Volatile Organic Emissions from Synthetic Organic Chemical Manufacturing Industry Distillation Operations (2-butoxyethanol) | Yes | 40 CFR 60.667; EPA 1990b
EPA OAQPS | Chemicals Affected by Standards of Performance for Volatile Organic Compound Emissions from Synthetic Organic Chemical Manufacturing Industry Reactor Processes (2-butoxyethanol) | Yes | 40 CFR 60.707; EPA 1993a
EPA OAQPS | Synthetic Organic Chemical Manufacturing Industry Chemicals (2-butoxyethanol) | Yes | 40 CFR 63.106; EPA 1992
EPA OAQPS | Synthetic Organic Chemical Manufacturing Industry Chemicals (2-butoxyethanol acetate) | Yes | 40 CFR 63.106; EPA 1992
EPA OAQPS | Organic HAPs Subject to the Wastewater Provisions for Process Units at New and Existing Sources and Corresponding Fraction Removed (Fr) Values (2-butoxyethanol acetate) | Yes | 40 CFR 63; Subpart G; EPA 1994
OSHA | Permissible Exposure Limit (TWA)^a^ (2-butoxyethanol) | 50 ppm (240 mg/m^3^) skin^b^ | 29 CFR 1910.100; OSHA 1974
b. Water:
EPA OW | Effluent Guidelines and Standards - Organic Chemicals, Plastics, and Synthetic Fibers - Bulk Organic Chemicals (2-butoxyethanol) | Yes | 40 CFR 414; Subpart G; EPA 1987
c. Other:
EPA OPPTS | Tolerance Range for Agriculture Products (2-butoxyethanol) | Conditionally Exempted From Tolerance | 40 CFR 180.1001; EPA 1971
EPA OPPTS | Preliminary Assessment Information Manufacturer Report (2-butoxyethanol) | Yes | 40 CFR 712.30; EPA 1982
EPA OPPTS | Substance Subject to All Provisions of Health and Safety Data Reporting (2-butoxyethanol) | Yes | 40 CFR 716.120; EPA 1986
DOT | Hazardous Materials and Special Provisions - Table 1 (2-butoxyethanol) | Yes | 49 CFR 172.101; DOT 1990
Guidelines:
a. Air:
ACGIH | TLV-TWA for Occupational Exposure (2-butoxyethanol)^c^ | 25 ppm (121 mg/m^3^) skin^b^ | ACGIH 1997
NIOSH | Recommended Exposure Limit for Occupational Exposure (TWA) (2-butoxyethanol)^d^ | 5 ppm (24 mg/m^3^) skin^b^ | NIOSH 1994
NIOSH | Recommended Exposure Limit for Occupational Exposure (TWA) (2-butoxyethanol acetate)^d^ | 5 ppm (33 mg/m^3^) skin^b^ | NIOSH 1994
b. Other:
ACGIH | Under Study to Establish or Change Biological Exposure Indices (2-butoxyethanol) | Yes | ACGIH 1997
[underlined: STATE]
Regulations and Guidelines:
a. Air: | Average Acceptable Ambient Air Concentrations (2-butoxyethanol) | | NATICH 1992
AZ | 24 hours | 9 mg/m^3^ | NATICH 1992
CT | 8 hours | 2.4 mg/m^3^ | NATICH 1992
FL (Pinellas Co.) | 8 hours | 1.2 mg/m^3^ | NATICH 1992
FL (Pinellas Co.) | 24 hours | 0.3 mg/m^3^ | NATICH 1992
ND | 8 hours | 1.21 mg/m^3^ | NATICH 1992
OK | 24 hours | 2.42 mg/m^3^ | NATICH 1992
SD | 8 hours | 24 mg/m^3^ | NATICH 1992
TX | 30 minutes | 1.21 mg/m^3^ | NATICH 1992
TX | Annual | 0.121 mg/m^3^ | NATICH 1992
VA | 24 hours | 2 mg/m^3^ | NATICH 1992
VT | 8 hours | 12 mg/m^3^ | NATICH 1992
WA-SWEST | 24 hours | 0.4 mg/m^3^ | NATICH 1992
| Average Acceptable Ambient Air Concentrations (2-butoxyethanol acetate) | | NATICH 1992
AZ | 1 hour | 720 μg/m^3^ | NATICH 1992
AZ | 24 hours | 190 μg/m^3^ | NATICH 1992
TX | 30 minutes | 1.35 mg/m^3^ | NATICH 1992
TX | Annual | 135 μg/m^3^ | NATICH 1992

a Time-Weighted average concentrations that must not be exceeded during any 8-hour work shift of a 40-hour work week.

b Skin designation that there is a potential for dermal absorption and that skin exposure should be prevented through the use of gloves, coveralls, goggles, and other appropriate equipment.

c ACGIH TLV-TWA is the time-weighted average concentration for an 8-hour workday and a 40-hour workweek, to which it is believed that nearly all workers may be repeatedly exposed, day after day, without adverse effects.

d Recommended exposure limit is a time-weighted average concentration for up to a 10-hour workday during a 40-hour workweek.

ACGIH = American Conference of Governmental Industrial Hygienists; DOT = Department of Transportation; EPA = Environmental Protection Agency; HAPs = Hazardous Air Pollutants; NATICH = National Air Toxics Information Clearinghouse; NIOSH = National Institute for Occupational Safety and Health; OAQPS = Office of Air Quality Planning and Standards; OPPTS = Office of Pollution Prevention and Toxic Substances; OS HA = Occupational Safety and Health Administration; OW = Office of Water; TLV = Threshold Limit Value; TWA = Time Weighted Average; WHO = World Health Organization

2-Butoxyethanol is regulated under the Clean Water Act’s Effluent Guidelines as stated in Title 40, Part 414 of the Code of Federal Regulations. The point source category for which 2-butoxyethanol is controlled as a bulk organic chemical is organic chemicals, plastics, and synthetic fibers (EPA 1987).

Both 2-butoxyethanol and 2-butoxyethanol acetate are regulated under the Clean Air Act, including National Emission Standards for Hazardous Air Pollutants (NESHAPs).