# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of 2-butoxyethanol and 2-butoxyethanol acetate is located in Tables 3-1 and 3-2, respectively.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of 2-butoxyethanol and 2-butoxyethanol acetate is located in Tables 3-3 and 3-4, respectively.

Table 3-1 Chemical Identity of 2-Butoxyethanol

Characteristic | Information | Reference
Chemical name | 2-Butoxyethanol | Merck 1989
Synonyms | Ethylene glycol monobutyl ether; ethylene glycol, butyl ether; ethylene glycol mono-n-butyl ether; ethylene glycol n-butyl ether; monobutyl ethylene glycol ether; monobutyl glycol ether; glycol butyl ether; n-butoxyethanol; 2-butoxy-1-ethanol; butoxyethanol; butyl glycol; butyl oxitol; beta-butoxyethanol; 2-butossi-etanolo (Italian); 2-butoxy-aethanol (German); butoksyetylowy alkohol (Polish); butylglycol (French, German); Butyl Cellosolve; Butyl Cellu-Sol; Caswell No. 121; Chimec NR Ether; Gafcol EB; Dowanol EB; Poly-Solv EB; Ektasolve EB; Eastman EB | Merck 1989; Weast and Astle 1985; HSDB 1995
Registered trade name | Butyl Cellosolve | Merck 1989
Chemical formula | C_6_H_14_O_2_ | Merck 1989
Chemical structure | CH_3_-CH_2_-CH_2_-CH_2_-O-CH_2_-CH_2_-OH | Weast and Astle 1985
Identification numbers:
CAS Registry | 111-76-2 | Weast and Astle 1985
NIOSH RTECS | KJ8575000 | HSDB 1995
EPA Hazardous Waste | No data
OHM/TADS | 7216719 | HSDB 1995
DOT/UN/NA/IMCO | UN 2369 Ethylene glycol monobutyl ether | HSDB 1995
| IMO 6.1 Ethylene glycol monobutyl ether 538 | HSDB 1995
HSDB | No data
NCI | No data

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 3-2 Chemical Identity of 2-Butoxyethanol Acetate

Characteristic | Information | Reference
Chemical name | 2-Butoxyethanol acetate | Sax 1984
Synonyms | Ethylene glycol monobutyl ether acetate; 2-butoxyethanol acetate; acetic acid, 2-butoxyethyl ester; butoxyethyl acetate; butyl glycol acetate; ethylene glycol butyl ether acetate; glycol monobutyl ether acetate; Butyl Cellosolve acetate; Ektasolve EB acetate; Eastman EB Acetate | HSDB 1995
Registered trade name(s) | No data
Chemical formula | C_8_H_16_O_3_ | Sax 1984
Chemical structure | [image] | HSDB 1995
Identification numbers:
CAS Registry | 112-07-2 | Sax 1984
NIOSH RTECS | KJ8925000 | Sax 1984
EPA Hazardous Waste | No data
OHM/TADS | No data
DOT/UN/NA/IMCO | No data
HSDB | 435 | HSDB 1995
NCI | No data

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 3-3 Physical and Chemical Properties of 2-Butoxyethanol

Property | Information | Reference
Molecular weight | 118.17 | Merck 1989
Color | Colorless | Marsden and Mann 1963
Physical state | Liquid | Merck 1989
Melting point | -70 °C | HSDB 1995
Melting point | -75 °C | ASTER 1995a
Boiling point | 171 °C at 760 mmHg | Weast 1975
Boiling point | 50 °C at 4 mm Hg | Weast 1989
Density at 20°C | 0.9019 g/mL | Merck 1989
Odor | Faint odor | Marsden and Mann 1963
Odor | Mild ethereal odor | ACGIH 1991
Odor threshold:
Air | 0.10 ppm (v/v) | Amoore and Hautala 1983
Air | 0.4 ppm (v/v) | OSHA 1990
Water | No data
Solubility:
Water at 25°C | Soluble in all proportions | Riddick and Bunger 1970; Weast 1975
Organic solvent(s) | Miscible with alcohol, ether | Weast 1975
Organic solvent(s) | Soluble in most organic solvents | Merck 1989
Partition coefficients:
Log K_ow_ | 0.83 | HSDB 1995
Log K_ow_ | 0.84 | ASTER 1995a
Log K^oc^ | 1.83 (calculated) | HSDB 1995; Lyman et al. 1982
Log K^oc^ | 1.79 (calculated) | ASTER 1995a
Bioconcentration factor
Log K_BCF_ | 0.40 (calculated) | HSDB 1995; Lyman et al. 1982
Vapor pressure
At 20°C | 0.76 mmHg | HSDB 1995; OSHA 1990
At 25°C | 0.88 mmHg | DOW 1993
Henry’s law constant (atm-m^3^/mol) | 2.08×10^-8^ (calculated) | Howard 1993; HSDB 1995
Henry’s law constant (atm-m^3^/mol) | 5.44×10^-6^ (calculated) | ASTER 1995a
Vapor-phase rate constant for reaction with photochemically produced hydroxy radicals | 1.96×10^-11^ cm^3^/molecule-second at 25°C (estimated) | Atkinson 1987
Atmospheric half-life at 25°C and 5×10^5^ hydroxyl radicals/m^3^ | 17 hours (calculated) | HSDB 1995
Autoignition temperature | 238°C | HSDB 1995
Autoignition temperature | 244°C | Marsden and Mann 1963; OSHA 1990
Flashpoint | 60°C (closed cup) | Merck 1989
Flashpoint | 62°C (closed cup) | HSDB 1995
Flashpoint | 69°C (open cup) | OSHA 1990
Flashpoint | 74°C (open cup) | Marsden and Mann 1963
Flammability | May be ignited by heat, sparks, or open flame | HSDB 1995
NFPA Classifications | Health = 2^a^;; Flammability = 2^b^;; Reactivity = 0^c^ | HSDB 1995
Conversion factors at 25°C, 1 atm | 1 ppm (v/v) = 4.8 mg/m^3^ | Calculated
Conversion factors at 25°C, 1 atm | 1 mg/m^3^ = 0.21 ppm | Calculated
Explosive limits | 1.1% (lower);; 10.1% (upper) | OSHA 1990

a Materials hazardous to human health. Areas may be entered freely with full-face mask self-contained breathing apparatus which provides eye protection.

b Materials must be moderately heated before ignition will occur. Water spray may be used to extinguish the fire because the material can be cooled below its flashpoint.

c Materials that (in themselves) are normally stable even under fire exposure conditions and that are not reactive with water. Normal firefighting procedures may be used.

HSDB = Hazardous Substance Data Bank; NFPA = National Fire Protection Association; OSHA = Occupational Safety and Health Administration; Pa = Pascal (133 Pa = 1 mm Hg)

Table 3-4 Physical and Chemical Properties of 2-Butoxyethanol Acetate

Property | Information | Reference
Molecular weight | 160.24 | Sax 1984
Color | Colorless | Verschueren 1983
Physical state | Liquid | Verschueren 1983
Melting point | −63.5°C | Sax 1984
Boiling point | 192.3°C | Verschueren 1983
Density at 20°C | 0.94 g/mL | Verschueren 1983
Odor | Fruity | Verschueren 1983
Odor threshold:
Air | 0.1 ppm (absolute threshold) | Verschueren 1983
Air | 0.35-0.48 ppm (recognition) | Verschueren 1983
Water | No data
Solubility:
Fresh water at 20 °C | 11 g/L | HSDB 1995
Fresh water at 20 °C | 1 g/100 g | OSHA 1990
Organic solvent(s) | Soluble in hydrocarbons and organic solvents | OSHA 1990
Partition coefficients:
Log K_ow_ | 1.71 | ASTER 1995b
Log K_oc_ | 1.41 (calculated) | HSDB 1995
Log K_oc_ | 2.27 (calculated) | ASTER 1995b
Bioconcentration factor (log K_BCF_) | 0.51 (calculated) | HSDB 1995
Vapor pressure at 20°C | 0.375 mm Hg | HSDB 1995
Vapor pressure at 20°C | 0.579 mm Hg (calculated) | ASTER 1995b
Henry’s law constant (atm-m^3^/mol) | 7.19x10^−6^ (calculated) | Howard 1993; HSDB 1995
Henry’s law constant (atm-m^3^/mol) | 1.56x10^−5^ | ASTER 1995b
Vapor-phase rate constant with photochemically produced hydroxyl radicals | 20.9x10^−12^ cm^3^/molecule-second at room temperature (calculated) | Atkinson 1987; HSDB 1995
Atmospheric half-life at 25°C and 5x10^5^ hydroxy radicals/m^3^ | 18.4 hours (calculated) | Atkinson 1987; HSDB 1995
Hydrolysis half-life | >1,000 days | ASTER 1995b
Autoignition temperature | 340°C | OSHA 1990
Flashpoint | 73.9°C (closed cup) | OSHA 1990
Flashpoint | 87.8°C (open cup) | OSHA 1990
Flammability | Moderate fire hazard when exposed to heat, flame, or oxidizers | HSDB 1995
NFPA Classifications | Health = 1^a^ | HSDB 1995
NFPA Classifications | Flammability = 2^b^ | HSDB 1995
NFPA Classifications | Reactivity = 0^c^ | HSDB 1995
Conversion factors at 25°C and 1 atm | 1 ppm (v/v) = 6.54 mg/m^3^ | HSDB 1995
Conversion factors at 25°C and 1 atm | 1 mg/m^3^ = 0.157 ppm | HSDB 1995
Explosive limits | 0.88% at 93°C lower; 8.54% at 135°C upper | HSDB 1995

a Materials only slightly hazardous to health. It may be desirable to wear self-contained breathing apparatus.

b Materials that must be moderately heated before ignition will occur. Water spray may be used to extinguish fire because material can be cooled below its flashpoint.

c Materials that (in themselyes) are normally stable even under fire exposure conditions and that are not reactive with water. Normal firefighting procedures may be used.

NFPA = National Fire Protection Association