# 7 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding 2,4,6-trinitrotoluene in air, water, and other media are summarized in Table 7-1.

ATSDR has derived an MRL of 0.0005 mg/kg/day for intermediate oral exposure to 2,4,6-trinitrotoluene (see Section 2.4). EPA (IRIS 1994) assigned 2,4,6-trinitrotoluene a reference dose (RfD) of 5.00x10^−4^ mg/kg/day with an uncertainty factor of 1,000 based on liver effects observed in dogs in a 26-week feeding study (Army 1983a).

EPA has assigned 2,4,6-trinitrotoluene a weight-of-evidence carcinogenic classification of C, which indicates that 2,4,6-trinitrotoluene is a possible human carcinogen (IRIS 1994).

The Drinking Water Equivalent Level (DWEL), a lifetime exposure at which adverse health effects would not be expected to occur, is 20 µg/L for 2,4,6-trinitrotoluene (EPA 1989b, 1994). Because of the lack of appropriate data for determination of the One-day Health Advisory and the Ten-day Health Advisory, it is suggested that the DWEL be used as a conservative estimate. The Longer-term Health Advisory for both children and adults is 20 µg/L, which is equivalent to the DWEL. The Lifetime Health Advisory is 2 µg/L.

Based on EPA Guidelines, an acceptable daily intake of 44.25 µg/L was calculated (Army 1987d). The available data for calculating water quality criteria for 2,4,6-trinitrotoluene were insufficient to meet all of the EPA guidelines requirements. However, enough information was available to calculate a reasonable estimate of the criterion maximum concentration, 557 µg/L, to protect aquatic life. The other component of the criteria, the criterion continuous concentration, needs further research. The criterion to protect human health has been estimated to be 135 µg/L, but further research is needed to confirm this value.

TABLE 7-1 Regulations and Guidelines Applicable to 2,4,6-Trinitrotoluene

Agency | Description | Information | References
[underlined: NATIONAL]
Regulations:
a. Air:
OSHA | PEL TWA (skin designation) | 0.5 mg/m^3^ | OSHA 1989a (29 CFR 1910.1000); OSHA 1989b
b. Other:
EPA OSW | Listing as a hazardous waste: | Yes | EPA 1989c
EPA OSW | Wastewater treatment sludge from the manufacturing and processing of explosives | Yes | EPA 1989c
DOT | Designated as a hazardous substance subject to requirements for packaging, labeling, and transportation | Yes | DOT 1989a (49 CFR 172.101); Appendix A); DOT 1989b
DOT | TNT dry--class A explosive (high explosive) | | DOT 1989a (49 CFR 172.101); Appendix A); DOT 1989b
DOT | TNT wet--flammable solid | | DOT 1989a (49 CFR 172.101); Appendix A); DOT 1989b
Guidelines:
a. Air:
ACG1H | TLV TWA (skin designation) | 0.5 mg/m^3^ | ACGIH 1993
NIOSH | REL TWA (10 hours) | 0.5 mg/m^3^ | NIOSH 1990
ACGIH | STEL | No data | ACGIH 1993
b. Water
EPA ODW | Health advisories | | EPA 1993
EPA ODW | DWEL | 20 μg/L | EPA 1993
EPA ODW | One-day | 20 μg/L | EPA 1993
EPA ODW | Ten-day | 20 μg/L | EPA 1993
EPA ODW | Longer term | 20 μg/L | EPA 1993
EPA ODW | Lifetime | 2 μg/L | EPA 1993
EPA ODW | 10^−4^ Cancer risk level | 100 μg/L | EPA 1993
EPA ODW | MCL | No data | EPA 1993
EPA ODW | MCLG | No data | EPA 1993
c. Other:
EPA
EPA | RfD (oral) | 5.0x 10^−1^ mg/kg/day | EPA 1993
EPA | Carcinogenic classification | Group C^a^ | EPA 1993
EPA | Unit risk (air) | No data | IRIS 1994
EPA | Unit risk (water) | No data | IRIS 1994
[underlined: STATE]
Regulations and Guidelines:
a. Air: | Acceptable Ambient Air Concentrations | | NATICH 1992
Connecticut | (8 hours) | 1.00x10^1^ μg/m^3^ | NATICH 1992
Florida-Pinellas | (8 hours) | 5.00 μg/m^3^ | NATICH 1992
Florida-Pinellas | (24 hours) | 1.20 μg/m^3^ | NATICH 1992
Nevada | (8 hours) | 1.20x10^−2^ mg/m^3^ | NATICH 1992
North Dakota | (8 hours) | 5.00x10^−3^ mg/m^3^ | NATICH 1992
Oklahoma | (24 hours) | 5.00x10^1^ μg/m^3^ | NATICH 1992
Texas | (30 minutes) | 5.00 μg/m^3^ | NATICH 1992
Texas | (Annual) | 5.00x10^−1^ μg/m^3^ | NATICH 1992
Virginia | (24 hours) | 8.30 μg/m^3^ | NATICH 1992
b. Other:
| Transportation of explosives is in accordance with the U.S. Department of Transportation hazardous materials regulations (49 CFR 171-190) and the motor carrier safety regulations (49 CFR 390-398) with some exceptions or additional requirements that vary from state to state | | CELDS 1991
Alabama | | Yes | CELDS 1991
Alaska | | Yes | CELDS 1991
Arizona | | Yes | CELDS 1991
California | | Yes | CELDS 1991
Connecticut | | Yes | CELDS 1991
Colorado | | Yes | CELDS 1991
Delaware | | Yes | CELDS 1991
Florida | | Yes | CELDS 1991
Georgia | | Yes | CELDS 1991
Hawaii | | Yes | CELDS 1991
Idaho | | Yes | CELDS 1991
Indiana | | Yes | CELDS 1991
Iowa | | Yes | CELDS 1991
Louisiana | | Yes | CELDS 1991
Maryland | | Yes | CELDS 1991
Massachusetts | | Yes | CELDS 1991
Michigan | | Yes | CELDS 1991
Minnesota | | Yes | CELDS 1991
Mississippi | | Yes | CELDS 1991
Missouri | | Yes | CELDS 1991
Montana | | Yes | CELDS 1991
Nebraska | | Yes | CELDS 1991
New Jersey | | Yes | CELDS 1991
New Mexico | | Yes | CELDS 1991
North Carolina | | Yes | CELDS 1991
North Dakota | | Yes | CELDS 1991
New York | | Yes | CELDS 1991
Ohio | | Yes | CELDS 1991
Oregon | | Yes | CELDS 1991
Rhode Island | | Yes | CELDS 1991
South Dakota | | Yes | CELDS 1991
Tennessee | | Yes | CELDS 1991
Texas | | Yes | CELDS 1991
Utah | | Yes | CELDS 1991
Virginia | | Yes | CELDS 1991
Vermont | | Yes | CELDS 1991
Washington | | Yes | CELDS 1991
Washington, D.C. | | Yes | CELDS 1991
West Virginia | | Yes | CELDS 1991
Wisconsin | | Yes | CELDS 1991
Wyoming | | Yes | CELDS 1991
| Rules and regulations for air quality control and/or solid waste disposal have been established for explosives in general. The regulations vary from state to state. | | CELDS 1991
Alabama | Pretreatment standards for discharge | Yes | CELDS 1991
Alabama | Hazardous waste: thermal treatment | Yes | CELDS 1991
Arizona | Solid waste collection | Yes | CELDS 1991
Arkansas | Solid waste storage and collection | Yes | CELDS 1991
Colorado | Fugitive dust | Yes | CELDS 1991
Connecticut | Hazardous waste; thermal treatment | Yes | CELDS 1991
Florida | Hazardous waste: thermal treatment | Yes | CELDS 1991
Georgia | Open burning | Yes | CELDS 1991
Illinois | Sewer discharge | Yes | CELDS 1991
Indiana | Open burning | Yes | CELDS 1991
Kentucky | Hazardous waste management | Yes | CELDS 1991
Louisiana | Open burning | Yes | CELDS 1991
Minnesota | Hazardous waste management | Yes | CELDS 1991
New Hampshire | Open burning | Yes | CELDS 1991
New Jersey | Hazardous waste management | Yes | CELDS 1991
New Mexico | Hazardous waste management | Yes | CELDS 1991
Nevada | Hazardous waste management | Yes | CELDS 1991
North Carolina | Hazardous waste: thermal treatment | Yes | CELDS 1991
North Dakota | Fugitive emissions | Yes | CELDS 1991
Pennsylvania | Fugitive emissions | Yes | CELDS 1991
South Carolina | Open burning | Yes | CELDS 1991
Tennessee | Hazardous waste: thermal treatment | Yes | CELDS 1991
Utah | Hazardous waste management | Yes | CELDS 1991
Vermont | Open burning | Yes | CELDS 1991
Virginia | Solid waste management | Yes | CELDS 1991
Wisconsin | Open burning and malodorous emissions | Yes | CELDS 1991
| Explosive control laws regulate storage, manufacture, and use (regulations vary from state to state) | | CELDS 1991
Alaska | | Yes | CELDS 1991
California | | Yes | CELDS 1991
Connecticut | | Yes | CELDS 1991
Georgia | | Yes | CELDS 1991
Hawaii | | Yes | CELDS 1991
Indiana | | Yes | CELDS 1991
Iowa | | Yes | CELDS 1991
Kansas | | Yes | CELDS 1991
New Jersey | | Yes | CELDS 1991
Massachusetts | | Yes | CELDS 1991
Nebraska | | Yes | CELDS 1991
New Jersey | | Yes | CELDS 1991
Oklahoma | | Yes | CELDS 1991
Oregon | | Yes | CELDS 1991
Washington, D.C. | | Yes | CELDS 1991
West Virginia | | Yes | CELDS 1991
Wisconsin | | Yes | CELDS 1991

a Group C=Possible human carcinogen

ACGIH = American Conference of Governmental Industrial Hygienists; DOT = Department of Transportation; DWEL = Drinking Water Equivalent Level; EPA = Environmental Protection Agency; NIOSH = National Institute for Occupational Safety and Health; ODW = Office of Drinking Water; OSHA = Occupational Safety and Health Administration; OSW = Office of Solid Waste; PEL = Permissible Exposure Limit; REL = Recommended Exposure Limits; RfD = Reference Dose; TLV = Threshold Limit Value; TNT = 2,4,6-Trinitrotoluene; TWA = Time-Weighted Average

Under the Hazardous Materials Transportation Act, 2,4,6-trinitrotoluene is designated as a hazardous substance subject to special requirements for packaging, labeling, and transportation as a result of its explosive/flammable properties (DOT 1989a, 1989b).