# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of 2,4,6-trinitrotoluene is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of 2,4,6-trinitrotoluene is located in Table 3-2.

TABLE 3-1 Chemical Identity of 2,4,6-Trinitrotoluene

Characteristic | Information | Reference
Chemical name | 2,4,6-Trinitrotoluene | HSDB 1990
Synonym(s) | sym-trinitotoluene; 1-methy 1-2,4,6-trinitrobenzene; 2-methyl-1,3,5-trinitrobenzene; alpha-TNT; TNT; alpha-trinitrotoluol; tolit; tritol; trotyl oil; trilit | HSDB 1990
Registered trade name(s) | No data
Chemical formula | C_7_H_5_N_3_O_6_ | Budavari et al. 1989
Chemical structure | [image] | Sax and Lewis 1987
Identification numbers:
CAS registry | 118-96-7 | Budavari et al. 1989
NIOSH RTECS | XUO175000 | HSDB 1990
EPA hazardous waste | No data
OHM/TADS | 7217371 | HSDB 1990
DOT/UN/NA/IMCO shipping | TNT, dry or wetted with <30% water (UN 0209/IMO 1.1) TNT, wetted with >30% water (UN 1356/IMO 4.1) | HSDB 1990
HSDB | 1146 | HSDB 1990
NCI | C56155 | HSDB 1990

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

TABLE 3-2 Physical and Chemical Properties of 2,4,6-Trinitrotoluene

Property | Information | Reference
Molecular weight | 227.13 | Budavari et al. 1989
Color | Yellow | Budavari et al. 1989
Physical state | Monoclinic needles | Budavari et al. 1989
Melting point | 80.1°C | Budavari et al. 1989
Boiling point | 240°C (explodes) | HSDB 1990
Specific gravity | 1.654 | Budavari et al. 1989
Odor | Odorless | NIOSH 1990
Odor Threshold:
Water | No data
Air | No data
Solubility:
Water at 20°C | 130 mg/L | HSDB 1990
Organic solvent(s) | Soluble in acetone and benzene; soluble in alcohol and ether | Budavari et al. 1989
Partition coefficients:
Log K_ow_ | 1.60; 2.2 (measured)–2.7 (estimated) | HSDB 1990; Spanggord et al. 1985
K_oc_ | 300 (estimated)–1,100 (measured) | Spanggord et al. 1985
Vapor pressure at 20°C | 1.99x10^−4^ mmHg | HSDB 1990
Henry’s law constant:
at 20°C | 4.57x10^−7^atm m^3^/mole | HSDB 1990
at 30°C | No data | HSDB 1994
Autoignition temperature | No data | HSDB 1994
Flashpoint | Explodes | NIOSH 1994
Flammability and Reactivity | 4.4 | HSDB 1994
Conversion factors | 1 ppm = 9.28 mg/m^3^; 1 mg/m^3^ = 0.108 ppm | NIOSH 1973
Explosive temperature | 464°F | HSDB 1994
Explosive limits | No data | NIOSH 1990