# 8 REFERENCES

* Cited in text

*Anderson RA, Harland WA. 1980. The analysis of volatiles in blood from fire fatalities. Forensic Toxicol, Proceedings of the European Meeting of the International Association of Forensic Toxicologists, 279–292.
*Barnes D, Bellin J, DeRosa C, . 1988. Reference dose (RfD): Description and use in health risk assessments. Vol. I. Appendix A: Integrated risk information system supportive documentation. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA/600/8-86/032a.
Boyd MR. 1980. Biochemical mechanisms in chemical-induced lung injury: Roles of metabolic activation. CRC Crit Rev Toxicol 7:103–176.
*Boyd MR. 1981. Toxicity mediated by metabolites of furans. Adv Exp Med Biol 136B:865–879.
Branen AL, Davidson PM, Salminen S, ed. 1990. Food additives. New York, NY: Marcel Dekker, Inc.
Brown EV, Coleman RL. 1973. Carcinogenic activity of benzofuran and dibenzofuran analogs of p-dimethylaminoazobenzene. J Med Chem 16:717–718.4197545
*Carrabba MM, Edmonds RB, Rauh RD. 1987. Feasibility studies for the detection of organic surface and subsurface water contaminants by surface-enhanced Raman spectroscopy on silver electrodes. Anal Chem 59:2559–2563.3688445
CCTTE. 1988. Computerized listing of chemicals being tested for toxic effects. United Nations Environment Programme, International Programme on Chemical Safety, International Register of Potentially Toxic Chemicals, Geneva, Switzerland.
CFR. 1978. Code of Federal Regulations. 21 CFR Ch. 1, 172.515.
*CFR. 1989a. Code of Federal Regulations. 21 CFR Ch. 1, 172.215.
CFR. 1989b. Code of Federal Regulations. 21 CFR Ch. 1, 172.515.
*CFR. 1989c. Code of Federal Regulations. 21 CFR Ch. 1, 175.105.
*CFR. 1989d. Code of Federal Regulations. 21 CFR Ch. 1, 177.2600.
*CFR. 1989e. Code of Federal Regulations. 40 CFR Ch. 1, 180.1001.
*Cha Y-N, Thompson DC, Heine HS, . 1985. Differential effects of indole, indole-3-carbinol and benzofuran on several microsomal and cytosolic enzyme activities in mouse liver. Korean J Pharmacol 21:1–11.
Christos T, Forshey DR. 1981. Thermal degradation products of solvents and hydraulic fluids used in mining. Report to U.S. Department of the Interior, Bureau of Mines, Washington, DC, by Bureau of Mines, Pittsburgh Research Center, Pittsburgh, PA. NTIS No. PB81-197154.
Clayson DB, Cooper EH. 1970. Cancer of the urinary tract. Adv Cancer Res 13:27i–381.
*CLPSD. 1990. Contract Laboratory Program Statistical Database. Viar and Company. Management Services Division, Alexandria, VA. January 2, 1990.
Curtis CW, Guin JA, Tarrer AR. 1987. Interactive chemistry of coal-petroleum processing. Quarterly progress report for September 15, 1987 to December 15, 1987. Auburn University, Chemical Engineering Department, Auburn, AL. DOE/PC/80502--T8.
*Curvall M, Enzell CR, Pettersson B. 1984. An evaluation of the utility of four [underlined: in vitro] short term tests for predicting the cytotoxicity of individual compounds derived from tobacco smoke. Cell Biol Toxicol 1:173–193.6400922
De Voogt P, Govers H. 1986. Structural and chromatographic predictors of n-octanol/water partition coefficients. Chemosphere 15:1467–1472.
Domimrose AM, Figge K. 1988. Analysis of organic trace compounds in the atmosphere and the correlation between meteorological situation and concentration of reference substances. Fresenius Z Anal Chem 332:606–611.
EPA. 1981. The analysis of aromatic chemicals in water by the purge and trap method-method 503.1. Cincinnati, OH. U.S. Environmental Protection Agency, Office of Research and Development, Environmental Monitoring and Support Laboratory.
EPA. 1982. Nitroaromatics and isophorone-method 609. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory.
EPA. 1984a. Carcinogen assessment of coke oven emissions. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA-600/6-82-003F. NTIS No. PB84 170182.
EPA. 1984b. U.S. Environmental Protection Agency. Federal Register 49:10103–10106.
EPA. 1986a. Aromatic volatile organics-method 8020. In: Test methods for evaluating solid waste. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1986b. Gas chromatography/mass spectrometry for semivolatile organics: Packed column technique method 8250. In: Test methods for evaluating solid waste. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1986c. Gas chromatography/mass spectrometry for semivolatile organics: Capillary column technique-method 8270. In: Test methods for evaluating solid waste. SW-846. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1986d. Capillary column analysis of semivolatile organic compounds by gas chromatography/Fourier transform infrared (GC/FTIR) spectrometry-method 8410. In: Test methods for evaluating solid waste. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1989. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA 600/8-88/066F.
*Erickson MD, Pellizzari ED. 1978. Analysis of organic air pollutants in the Kanawha Valley, WV and the Shenandoah Valley, VA. Report to U.S. Environmental Protection Agency, Region III, Philadelphia, PA, by Research Triangle Institute, Research Triangle Park, NC. EPA-903/9-78-007. NTIS No. PB-286 141.
Fatome M, Andieu L, Laval J-D, . 1976. [Effects radioprotecteurs de ▲^3^-chromenes substitutes en 3 par un groupement electro-attractif.] Eur J Med Chem 11:81–82. (French)
Fatome M, Andrieau L, Laval J-D, . 1977. [Comparaison des activities radioprotectrices de derives pareillement substitutes du benzofuranne et du 2H-chromene.] Eur J Med Chem 12:383–384. (French)
FDA. 1977a. U.S. Food and Drug Administration. Federal Register 42:14606–14608.
FDA. 1977b. U.S. Food and Drug Administration. Federal Register 42:14495.
Fedotou AS. 1970. [The combined action of VNIINP-360 and benzofurancarboxylic acid (BFK) type on the operational properties of M12V oil.] Report to U.S. Air Force, Air Force Systems Command by Foreign Technology Division, Wright-Patterson Air Force Base, OH. NTIS No. AD 730 082.
*Ferretti A, Flanagan VP. 1971. Volatile constituents of whey powder subjected to accelerated browning. J Dairy Sci 54:1764–1768.
*Florin I, Rutberg L, Curvall M, . 1980. Screening of tobacco smoke constituents for mutagenicity using the Ames’ Test. Toxicology 18:219–232.
Frossard H, Fatome M, Royer R, . 1973. [Sur les proprietes radioprotectrices de derives du benzofuranne.] Chimie Therapeutiquq 8:32–35. (French).
Fujinuma K, Kanmuri M, Nakazato M, . 1981. [Analysis of coumarone-indene resin coated on citrus fruits.] J Food Hyg Sot Jpn 22:263–269. (Japanese)
Govers H, de Voogt P. 1986. Indices for the prediction of environmental properties of hetero-atomic polycyclic aromatic pollutants. Comm Eur Commun Eur 10388 Org Micropollut Aquat Environ, 475–483.
Green DR, Le Pape D. 1987. Stability of hydrocarbon samples on solid-phase extraction columns. Anal Chem 59:699–703.
*Hampton CV, Pierson WR, Harvey TM, . 1982. Hydrocarbon gases emitted from vehicles on the road. 1. A qualitative gas chromatography/mass spectrometry survey. Environ Sci Technol 16:287–298.22257255
*Hassett JJ, Banwart WL, Griffin RA. 1983. Correlation of compound properties with sorption characteristics of nonpolar compounds by soils and sediments: Concepts and limitations. In: Francis, CW, Auerbach SI, eds. Environment and solid wastes: Characterization, treatment, and disposal. Boston, MA: Butterworths, 161–176.
*Haworth S, Lawlor T, Mortelmans K, . 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen Suppl 1:3–142.
*Heine HS, Stoskopf MK, Thompson DC, . 1986. Enhancement of epoxide hydrolase activity in hepatic microsomes of mice given heterocyclic compounds. Chem Biol Interact 59:219–230.3769053
*HSDB. 1989. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. December 15, 1989.
*HSDB. 1992. Hazardous Substance Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. June 1992.
*Humenick MJ, Britton LN, Mattox CF. 1982. Natural restoration of groundwater in UCG. In Situ 6:107–125.
*Hunt GT, Kindya RJ, Hall RR, . 1982. The polycyclic aromatic environment of the fluidized-bed coal combustion process - an investigation of chemical and biological activity. Proc 6th Int Phys Biol Chem Symp, Polynucl Aromat Hydrocarbons, 367–381.
IRIS. 1990. Integrated Risk Information System. U.S. Environmental Protection Agency, Washington, DC. January 1990.
*Junk GA, Ford CS. 1980. A review of organic emissions from selected combustion processes. Chemosphere 9:187–230.
*Juttner F. 1986. Analysis of organic compounds (VOC) in the forest air of the Southern Black Forest. Chemosphere 15:985–992.
Karasek FW. 1981. Trace analysis of toxic organic substances in the environment. Proc 8th Int Microchem Symp, Nat, Aim Methods Microchem, 175–189.
Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Safety 4:26–38.7379718
Kenaga EE, Goring CA. 1980. Relationship between water solubility, soil sorption, octanol-water partitioning, and concentration of chemicals in biota. In: Eaton JG, Parrish PR, Hendricks AC, eds. Philadelphia, PA: American Society for Testing and Materials, 78–115.
Kharchenko TF, Petrovskaia OG. 1975. [Hygienic assessment of coumarone in connection with the use of polymeric building material.] Gig Sanit, 11–14. (Russian).
*King JW. 1989. Fundamentals and applications of supercritical fluid extraction in chromatographic science. J Chromatog Sci 27:355–364.
Kirk-Othmer. 1966. Kirk-Othmer encyclopedia of chemical technology. 2nd ed. Vol. 10. Food additives to heterocyclic compounds. New York, NY: Interscience Publishers, 907–908.
Lao RC, Thomas RS, Chiu C, . 1985. Analysis of PAH and organic compounds in environmental samples. In: Cooke M, Dennis AJ, ed. Polynuclear aromatic hydrocarbons. Columbus, OH: Battelle, 813–826.
*Leo A, Hansch C, Elkins D. 1971. Partition coefficients and their uses. Chem Rev 71:525,581.
*Lucas SV. 1984. GC/MS analysis of organics in drinking water concentrates and advanced waste treatment concentrates. Vol. 1. Analysis results for 17 drinking water, 16 advanced waste treatment and 3 process blank concentrates. Report to U.S. Environmental Protection Agency, Health Effects Research Laboratory, Cincinnati, OH, by Battelle Columbus Laboratory, Columbus, OH. EPA-600/l-84-020a. NTIS No. PB85-128221.
*McGregor DB, Brown A, Cattanach P, et al. 1988. Responses of the L5178Y tk+/tk− mouse lymphoma cell forward mutation assay II: 18 coded chemicals. Environ Mol Mutagen 11:91–118.3338442
*McMurtry RJ, Mitchell JR. 1977. Renal and hepatic necrosis after metabolic activation of 2-substituted furans and thiophenes, including furosemide and cephaloridine. Toxicol Appl Pharmacol 42:285–300.595008
Mehrle PM, Buckler DR, Little EE, . 1988. Toxicity and bioconcentration of 2,3,7,8-tetrachlorodibenzodioxin and 2,3,7,8-tetrachlorodibenzofuran in rainbow trout. Environ Toxicol Chem 7:47–62.
Melnikov NN. 1971. I. Introduction. In: Gunther FA, Gunther JD, ed. Residue reviews: Residues of pesticides and other foreign chemicals in foods and feeds. Vol. 36. New York, NY: Springer-Verlag.
Michael LC, Pellizzari ED, Wiseman RW. 1988. Development and evaluation of a procedure for determining volatile organics in water. Environ Sci Technol 22:565–570.22195629
*Morris GE. 1953. Vinyl plastics: Their dermatological and chemical aspects. AMA Arch Ind Hyg Occup Med 8:535–539.13103827
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
NCI. 1978. Summary of data for benzofuran. National Cancer Institute, Bethesda, MD.
*Neeley WB, Branson DR, Blau GE. 1974. Partition coefficient to measure bioconcentration potential of organic chemicals in fish. Environ Sci Technol 8:1113–1115.
*NIOSH. 1978. Criteria for a recommended standard. Occupational exposures in coal gasification plants. Cincinnati, OH: Department of Health, Education, and Welfare, National Institute for Occupational Safety and Health. DHEW(NIOSH) Publication No. 78-191.
NIOSH. 1984a. (Method released as a supplement 5/15/89). Furfuryl alcohol-method 2505. In: NIOSH manual of analytical methods 3rd ed. Cincinnati, OH: National Institute for Occupational Safety and Health, DHHS (NIOSH) Publication No. 84-100.
NIOSH. 1984b. (Method released as a supplement 5/15/87). Furfural-method 2529. In: NIOSH manual of analytical methods 3rd ed. Cincinnati, OH: National Institute for Occupational Safety and Health, DHHS (NIOSH) Publication No. 84-100.
*NLM. 1989. Chemline. National Library of medicine, Bethesda, MD. December 15, 1989.
NTP. 1979. Executive summary on benzofuran. National Toxicology Program, Bethesda, MD.
*NTP. 1989. National Toxicology Program -- technical report series no. 370. Toxicology and carcinogenesis studies of benzofuran (CAS No. 271-89-6) in F344/N rats and B6C3F_1_ mice (gavage studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health.
*Pankow JF, Rosen ME. 1988. Determination of volatile compounds in water by purging directly to a capillary column with whole column cryotrapping. Environ Sci Technol 22:398–405.
*Pellizzari ED, Castillo NP, Willis S, . 1979. Identification of organic components in aqueous effluents from energy-related processes. In: Van Hall CE, ed. Measurement of organic pollutants in water and wastewater. Philadelphia, PA: American Society for Testing and Materials, 256–274. ASTM STP 686.
*Pellizzari ED, Hartwell TD, Harris BSH III, . 1982. Purgeable organic compounds in mother’s milk. Bull Environ Contam Toxicol 28:322–328.7082873
Perrin DD. 1964. The effect of temperature on pK values of organic bases. Aust J Chem 17:484–488.
*Pettersson B, Curvall M, Enzell CR. 1982. Effects of tobacco smoke compounds on the ciliary activity of the embryo chicken trachea in vitro. Toxicol 23:41–55.
*Powers PO. 1980. Hydrocarbon resins. In: Kirk-Othmer encyclopedia of chemical technology. 2nd ed. Vol 11. Hexanes to ion exchange. New York, NY: Interscience Publishers, 242–262.
Quillardet P, Huisman O, D’ari R, . 1982. SOS chromotest, a direct assay of induction of an SOS function in [underlined: Escherichia coli] K-12 to measure genotoxicity. Proc Nat1 Acad Sci USA 79:5971–5975.
*Ravindranath V, Burka LT, Boyd MR. 1984. Reactive metabolites from the bioactivation of toxic methylfurans. Science 224:884–886.6719117
*Reynolds SH, Stowers SJ, Patterson RM, . 1987. Activated oncogenes in B6C3Fl mouse liver tumors: Implications for risk assessment. Science 237:1309–1316.3629242
*Rostad CE, Pereira WE, Hult MF. 1985. Partitioning studies of coal-tar constituents in a two-phase contaminated ground-water system. Chemosphere 14:1023–1036.
*Roy WR, Griffin RA. 1985. Mobility of organic solvents in water-saturated soil materials. Environ Geol Water Sci 7:241–247.
*Sax NI. 1984. Dangerous properties of industrial materials. 6th ed. New York, NY: Van Nostrand Reinhold Company, 377.
*Sax NI, Lewis RJ Sr. 1987. Hawley’s condensed chemical dictionary. 11th ed. New York, NY: Van Nostrand Reinhold Company, 318.
*Schlotzhauer WS, Chortyk OT. 1987. Recent advances in studies on the pyrosynthesis of cigarette smoke constituents. J Anal Appl Pyrolysis 12:193–222.
*Schwartz L. 1936. Dermatitis from synthetic resins and waxes. Am J Public Health Nations Health 26:586–592.18014442
*Sehnert SS, Risby TH. 1988. Chromatographic modeling of the release of particle-adsorbed molecules into synthetic alveolar surfactant. Environ Health Perspect 78:185–195.3203638
*Seizinger DE, Dimitriades B. 1972. Oxygenates in exhaust from simple hydrocarbon fuels. J Air Pollut Control Assoc 22:47–51.4109317
Sheftel VO, Rozhko GM, Kuzmina AI, . 1968. [The harmful effect of volatiles released by indene-coumarone resin at 20 and 40 degrees.] Gig Sanit 33:98–100. (Russian)
Smith RM. 1988. Supercritical fluid chromatography. Royal Society of Chemistry, Letchworth, England.
SRI. 1986. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International, 900.
SRI. 1987. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International, 889, 900.
SRI. 1988. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International, 869, 880.
*SRI. 1989. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International, 875, 886.
Stankevich KI. 1962. [Experimental findings on the blastomogenic effect of coumaron and polychlorvinyl plates.] Vrach Delo 11:108–114. (Russian)
Svec HJ, Fritz JS, Calder GV. 1974. Trace soluble organic compounds in potable water supplies. Report to U.S. Department of Interior, Office of Water Resources Research, by Iowa State University, Department of Chemistry, Ames, IA. NTIS No. PB-228523.
TRI. 1989. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
Tsendrovskaya VA. 1973. [Separate determination of indene, coumarone, styrene, cyclopentadiene and dicyclopentadiene by thin-layer chromatography.] Gig Sanit 38:62–65. (Russian)
USITC. 1987. Synthetic organic chemicals: United States production and sales, 1986. Washington, DC: U.S. International Trade Commission. USITC Publication 2009.
USITC. 1988. Synthetic organic chemicals: United Stated production and sales, 1987. Washington, DC: –U.S. International Trade Commission. USITC Publication 2118.
*van Netten C, Shirtliffe C, Svec J. 1988. Formaldehyde release characteristics from a Swedish floor finish. Bull Environ Contam Toxicol 40:672–677.3382783
Verschueren K. 1983. Handbook of environmental data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Company, 257.
*View Database. 1989. Agency for Toxic Substances and Disease Registry (ATSDR), Office of External Affairs, Exposure and Disease Registry Branch, Atlanta, GA. September 25, 1989.
Volodchenko VA. 1968. [Skin damaging and resorptive effect of mastics made from epoxide and coumaron resins.] Vrach Delo 9:95–97. (Russian)4244202
Wardowski WF, Nagy S, Grierson W, ed. 1986. Fresh citrus fruits. New York, NY: Van Nostrand Reinhold Company, Inc.
*Weast RC. 1985. CRC handbook of chemistry and physics. 66th ed. Boca Raton, FL: CRC Press, Inc., C-126.
*Weill-Thevenet N, Buisson J-P, Royer R, . 1981. Mutagenic activity of benzofurans and naphthofurans in the Salmonella/microsome assay: 2-Nitro-7-methoxy-naphtho[2,1-blfuran (R7000), a new highly potent mutagenic agent. Mutat Res 88:355–362.7019691
Wieboldt RC, Adams GE, Later DW. 1988. Sensitivity improvement in infrared detection for supercritical fluid chromatography. Anal Chem 60:2422–2427.
*Wilson RH, McCormick WE. 1960. Plastics: The toxicology of synthetic resins. AMA Arch Ind Health 21:536–548.13845120
*Windholz M, Budavari S, Blumetti RF, . 1983. The Merck index: An encyclopedia of chemicals, drugs, and biologicals. 10th ed. Rahway, NJ: Merck and Company, Inc., 155.
*Zachara JM, Felice LJ, Riley RG. 1984. The selection of, organic chemicals for subsurface transport research. Report to U.S. Department of Energy by Pacific Northwest Laboratory, Richland, WA. NTIS No. DE85 007876.