# 7 REGULATIONS AND ADVISORIES

No regulations or advisories that apply specifically to 2,3-benzofuran were located. 2,3-Benzofuran is one component of coumarone-indene resin and a number of regulations and guidelines have been established for coumaron-eindene resin by various national agencies. These values are summarized in Table 7-1.

TABLE 7-1 Regulations and Guidelines Applicable to 2, 3-Benzofuran^a^

Agency | Description | Information | References
[underlined: NATIONAL]
Regulations:
a. Food:
FDA | Coumarone-indene resin as a protective coating on citrus fruit-maximum residue | 200 ppm | CFR 1989a (21 CFR 172.215)
FDA | Coumarone-indene resin as a component of adhesives approved for use in food packaging | Yes | CFR 1989c (21 CFR 175.105)
FDA | Coumarone-indene resin as a plasticizer in rubber articles intended for repeated use in contact vith food | Yes | CFR 1989d (21 CFR 177.2600)
EPA OPP | Exemption from tolerance Coumarone-indene resin used as coating on citrus fruit | Yes | CFR 1989e (A0 CFR 180.1001)

EPA = Environmental Protection Agency; FDA = Food and Drug Administration; OPP = Office of Pesticide Products

a There are no regulations or advisories specifically applicable to 2,3-benzofuran. Because 2,3-benzofuran is one component of coumarone-indene resin, the regulations applicable to Coumarone-indene resin are presented in this table.