# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Table 3-1 lists common synonyms, trade names, and other pertinent identification information for 2,3-benzofuran.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Table 3-2 lists important physical and chemical properties of 2,3-benzofuran.

TABLE 3-1 Chemical Identity of 2,3-Benzofuran

Characteristic | Information | Reference
Chemical name | 2,3-Benzofuran | CLPSD 1990
Synonyms | Benzofuran; cumaron; couroarone; benzo(b)furan; benzofurfuran; l-oxindene | Windholz et al. 1983; Sax 1984
Trade names | No data
Chemical formula | C_8_H_6_0 | Weast 1985
Chemical structure | [image] | Windholz et al. 1983
Identification numbers:
CAS registry | 271-89-6 | Sax 1984
NIOSH RTECS | DF6423800 | Sax 1984
EPA hazardous waste | No data
OHM/TADS | No data
DOT/UN/NA/IMCO shipping | No data
HSDB | 4173 | NLM 1989
NCI | C56166 | NLM 1989

CAS = Chemical Abstracts Service; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

TABLE 3-2 Physical and Chemical Properties of 2,3-Benzofuran

Property | Information | Reference
Molecular weight | 118.14 | Weast 1985
Color | Colorless | Sax and Lewis 1987
Physical state | Liquid | Sax and Lewis 1987
Melting point | −18°C | Weast 1985
Boiling point | 175°C | Weast 1985
Density at 20°C | 1.0948 | Powers 1980
Odor | Aromatic | Windholz et al. 1983
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 20°C | Insoluble | Windholz et al. 1983
Organic solvents | Miscible with benzene, petroleum ether, absolute alcohol and ether
Partition coefficients:
Log octanol/water | 2.67 | Leo et al. 1971
Log K_oc_ | No data
Vapor pressure at 20°C | No data
Henry’s law constant: at 20°C | No data
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | No data
Conversion factors | 1 ppm = 4.83 mg/m^3^ (calculated); 1 mg/m^3^ = 0.21 ppm (calculated)
Explosive limits | No data