# APPENDIX B ACRONYMS, ABBREVIATIONS, AND SYMBOLS

ACGIH: American Conference of Governmental Industrial Hygienists
ADME: Absorption, Distribution, Metabolism, and Excretion
ATSDR: Agency for Toxic Substances and Disease Registry
BCF: bioconcentration factor
BSC: Board of Scientific Counselors
CDC: Centers for Disease Control
CEL: Cancer Effect Level
CERCL: Comprehensive Environmental Response, Compensation, and Liability Act
CFR: Code of Federal Regulations
CLP: Contract Laboratory Program
cm: centimeter
CNS: central nervous system
DHEW: Department of Health, Education, and Welfare
DHHS: Department of Health and Human Services
DOL: Department of Labor
ECG: electrocardiogram
EEG: electroencephalogram
EPA: Environmental Protection Agency
EKG: see ECG
FAO: Food and Agricultural Organization of the United Nations
FEMA: Federal Emergency Management Agency
FIFRA: Federal Insecticide, Fungicide, and Rodenticide Act
f_1_: first generation
fpm: feet per minute
ft: foot
FR: Federal Register
g: gram
GC: gas chromatography
HPLC: high performance liquid chromatography
hr: hour
IDLH: Immediately Dangerous to Life and Health
IARC: International Agency for Research on Cancer
ILO: International Labor Organization
in: inch
Kd: adsorption ratio
kg: kilogram
Koc: octanol-soil partition coefficient
Kow: octanol-water partition coefficient
L: liter
LC: liquid chromatography
LC_Lo_: lethal concentration low
LC_50_: lethal concentration 50 percent kill
LD_Lo_: lethal dose low
LD_50_: lethal dose 50 percent kill
LOAEL: lowest-observed-adverse-effect level
LSE: Levels of Significant Exposure
m: meter
mg: milligram
min: minute
mL: milliliter
mm: millimeters
mmol: millimole
mppcf: millions of particles per cubic foot
MRL: Minimal Risk Level
MS: mass spectroscopy
NIEHS: National Institute of Environmental Health Sciences
NIOSH: National Institute for Occupational Safety and Health
NIOSHTIC: NIOSH’s Computerized Information Retrieval System
nm: nanometer
ng: nanogram
NHANES: National Health and Nutrition Examination Survey
nmol: nanomole
NOAEL: no-observed-adverse-effect level
NOES: National Occupational Exposure Survey
NOHS: National Occupational Hazard Survey
NPL: National Priorities List
NRC: National Research Council
NTIS: National Technical Information Service
NTP: National Toxicology Program
OSHA: Occupational Safety and Health Administration
PEL: permissible exposure limit
Pg: picogram
pmol: picomole
PHS: Public Health Service
PMR: proportional mortality ratio
ppb: parts per billion
ppm: parts per million
ppt: parts per trillion
REL: recommended exposure limit
RfD: Reference Dose
RTECS: Registry of Toxic Effects of Chemical Substances
sec: second
SCE: sister chromatid exchange
SIC: Standard Industrial Classification
SMR: standard mortality ratio
STEL: short-term exposure limit
STORET: STORAGE and RETRIEVAL
TLV: threshold limit value
TSCA: Toxic Substances Control Act
TRI: Toxic Release Inventory
TWA: time-weighted average
U.S.: United States
UF: uncertainty factor
WHO: World Health Organization

>: greater than
≥: greater than or equal to
=: equal to
<: less than
≤: less than or equal to
%: percent
α: alpha
β: beta
δ: delta
γ: gamma
μm: micron
μg: microgram