# REFERENCES

* Not cited in text

Abi Esper L, El-Fadel M, Nuwayhid I, et al. The effect of different ventilation modes on in-vehicle carbon monoxide exposure. Atmos Environ. 2007a;41:3644-3657.
*. Abi Esper L, El-Fadel M, Shihadeh A. Comparison of trip average in-vehicle and exterior CO determinations by continuous and grab sampling using an electrochemical sensing method. Atmos Environ. 2007b;41:6087-6094.
Abram SR, Hodnett BL, Summers RL, et al. Quantitative circulatory physiology: An integrative mathematical model of human physiology for medical education. Adv Physiol Educ. 2007;31:202-210. [pmid: 17562912].
ACGIH. Carbon monoxide. Threshold limit values for chemical substances and physical agents and biological exposure indices. 2008. Cincinnati, OH. American Conference of Governmental Industrial Hygienists.
Adams KF, Koch G, Chatterjee B, et al. Acute elevation of blood carboxyhemoglobin to 6% impairs exercise performance and aggravates symptoms in patients with ischemic heart disease. J Am Coll Cardiol. 1988;12(4):900-909. [pmid: 3417989].
Adinolfi M. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol. 1985;27(4):532-537. [pmid: 4029526].
Adir Y, Merdler A, Haim SB, et al. Effects of exposure to low concentrations of carbon monoxide on exercise performance and myocardial perfusion in young healthy men. Occup Environ Med. 1999;56:535-538. [pmid: 10492650].
Adlercreutz H. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environmental Health Perspectives Supplement. 1995;103(7):103-112.
Agency for Toxic Substances and Disease Registry. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Fed Regist. 1989;54(174):37618-37634.
Agency for Toxic Substances and Disease Registry. Toxicological profile for methylene chloride. 2000. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/toxprofiles/tp14.pdf. June 11, 2009.
Agency for Toxic Substances and Disease Registry. Toxicological profile for carbon tetrachloride. 2005. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/toxprofiles/tp30.pdf. June 11, 2009.
AIHA. Emergency Response Planning Guidelines (ERPG). 2008. Fairfax, VA. American Industrial Hygiene Association. http://www.aiha.org/1documents/Committees/ERP-erpglevels.pdf. May 19, 2009.
Alcantara RE, Xu C, Spiro TG, et al. A quantum-chemical picture of hemoglobin affinity. Proc Natl Acad Sci USA. 2007;104(47):18451-18455. [pmid: 18003918].
Alcaraz MJ, Fernandez P, Guillen MI. Anti-inflammatory actions of the heme oxygenase-1 pathway. Curr Pharm Des. 2003;9:2541-2551. [pmid: 14529552].
Allred EN, Bleecker ER, Chaitman BR, et al. Short-term effects of carbon monoxide exposure on the exercise performance of subjects with coronary artery disease. N Engl J Med. 1989;321(21):1426-1432. [pmid: 2682242].
Allred EN, Bleecker ER, Chaitman BR, et al. Effects of carbon monoxide on myocardial ischemia. Environ Health Perspect. 1991;91:89-132. [pmid: 2040254].
Alonso J, Cardellach F, Lopez S, et al. Carbon monoxide specifically inhibits cytochrome c oxidase of human mitochondrial respiratory chain. Pharmacol Toxicol. 2003;93:142-146. [pmid: 12969439].
Altman PL, Dittmer DS. Total body water: Man. Altman PL, Dittmer DS, editors. Biological handbooks: Biology data book. 2nd ed. Bethesda, MD. Federation of American Societies of Experimental Biology. 1974;Vol. III:1987-2008. 2041.
Andersen ME, Krishnan K. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. Salem H, editor. Animal test alternatives: Refinement, reduction, and replacement. New York, NY. Marcel Dekker Inc. 1994:9-25.
Andersen ME, Clewell HJ, Gargas ML, et al. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol. 1987;87(2):185-205. [pmid: 3824380].
Andersen ME, Clewell HJ, Gargas ML, et al. Physiologically based pharmacokinetic modeling with dichloromethane, its metabolite, carbon monoxide, and blood carboxyhemoglobin in rats and humans. Toxicol Appl Pharmacol. 1991;108:14-27. [pmid: 1900959].
*. Andersen ZJ, Wahlin P, Raaschou-Nielsen O, et al. Ambient particle source apportionment and daily hospital admissions among children and elderly in Copenhagen. J Expo Sci Environ Epidemiol. 2007;17:625-636. [pmid: 17495872].
Anderson EW, Andelman RJ, Strauch JM, et al. Effect of low-level carbon monoxide exposure on onset and duration of angina pectoris. Ann Intern Med. 1973;79:46-50. [pmid: 4578639].
*. Anderson HR, Bremner SA, Atkinson RW, et al. Particulate matter and daily mortality and hospital admissions in the west midlands conurbation of the United Kingdom: Associations with fine and coarse particles, black smoke and sulphate. Occup Environ Med. 2001;58:504-510. [pmid: 11452044].
Andre L, Boissiere J, Reboul C, et al. Carbon monoxide pollution promotes cardiac remodeling and ventricular arrhythmia in healthy rats. Am J Respir Crit Care Med. 2010;181(6):587-595. [pmid: 20019346].
API. A study to characterize air concentrations of methyl tertiary butyl ether (MTBE) at service stations in the northeast. American Petroleum Institute. API publication number 4619. 1994.
Arbex MA, de Souza Conceicao GM, Cendon SP, et al. Urban air pollution and chronic obstructive pulmonary disease-related emergency department visits. J Epidemiol Community Health. 2009;63(10):777-783. [pmid: 19468016].
Arruda MA, Rossi AG, de Freitas MS, et al. Heme inhibits human neutrophil apoptosis: Involvement of phosphoinositide 3-kinase, MAPK, and NF-κB. J Immunol. 2004;173:2023-2030. [pmid: 15265937].
Astrup P, Olsen HM, Trolle D, et al. Effect of moderate carbon-monoxide exposure on fetal development. Lancet. 1972;2(7789):1220-1222. [pmid: 4117709].
*. Atkinson RW, Anderson HR, Strachan DP, et al. Short-term associations between outdoor air pollution and visits to accident and emergency departments in London for respiratory complaints. Eur Respir J. 1999;13:257-265. [pmid: 10065665].
Baccarelli A, Zanobetti A, Martinelli I, et al. Effects of exposure to air pollution on blood coagulation. J Thromb Haemost. 2007;5(2):252-260. [pmid: 17083648].
Baldauf R, Thoma E, Khlystov A, et al. Impacts of noise barriers on near-road air quality. Atmos Environ. 2008;42:7502-7507.
*. Ballester F, Rodriguez P, Iniguez C, et al. Air pollution and cardiovascular admissions association in Spain: Results within the EMECAS project. J Epidemiol Comm Health. 2006;60:328-336.
Ballester F, Tenias JM, Perez-Hoyos S. Air pollution and emergency hospital admissions for cardiovascular diseases in Valencia, Spain. J Epidemiol Community Health. 2001;55:57-65. [pmid: 11112952].
Barnes DG, Dourson M. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol. 1988;8(4):471-486. [pmid: 3222488].
Barnett AG, Williams GM, Schwartz J, et al. The effects of air pollution on hospitalizations for cardiovascular disease in elderly people in Australian and New Zealand cities. Environ Health Perspect. 2006;114(7):1018-1023. [pmid: 16835053].
*. Bedeschi E, Campari C, Candela S, et al. Urban air pollution and respiratory emergency visits at pediatric unit, Reggio Emilia, Italy. J Toxicol Environ Health A. 2007;70:261-265. [pmid: 17365587].
Bell ML, Ebisu K, Belanger K. Ambient air pollution and low birth weight in Connecticut and Massachusetts. Environ Health Perspect. 2007;115(7):1118-1124. [pmid: 17637932].
*. Bell ML, Levy JK, Lin Z. The effect of sandstorms and air pollution on cause-specific hospital admissions in Taipei, Taiwan. Occup Environ Med. 2008;65(2):104-111. [pmid: 17626134].
Bell ML, Peng RD, Dominici F, et al. Emergency hospital admissions for cardiovascular diseases and ambient levels of carbon monoxide: results for 126 United States urban counties, 1999–2005. Circulation. 2009;120(11):949-955. [pmid: 19720933].
*. Bellini P, Baccini M, Biggeri A, et al. The meta-analysis of the Italian studies on short-term effects of air pollution (MISA): Old and new issues on the interpretation of the statistical evidences. Environmetrics. 2007;18:219-229.
Beltran-Parrazal L, Acuna D, Ngan AM, et al. Neuroglobin, cytoglobin, and transcriptional profiling of hypoxia-related genes in the rat cerebellum after prenatal chronic very mild carbon monoxide exposure (25 ppm). Brain Res. 2010;1330:61-71. [pmid: 20230802].
Benignus VA. Behavioral effects of carbon monoxide: Meta analyses and extrapolations. J Appl Physiol. 1994;76(3):1310-1316. [pmid: 8005876].
Benignus VA. A model to predict carboxyhemoglobin and pulmonary parameters after exposure to O_2_, CO_2_, and CO. Aviat Space Environ Med. 1995;66(4):369-374. [pmid: 7794231].
Benignus VA, Annau Z. Carboxyhemoglobin formation due to carbon monoxide exposure in rats. Toxicol Appl Pharmacol. 1994;128(1):151-157. [pmid: 8079348].
Benignus VA, Hazucha MJ, Smith MV, et al. Prediction of carboxyhemoglobin formation due to transient exposure to carbon monoxide. J Appl Physiol. 1994;76:1739-1745. [pmid: 8045854].
Benignus VA, Muller KE, Malott CM. Dose-effects functions for carboxyhemoglobin and behavior. Neurotoxicol Teratol. 1990;12(2):111-118. [pmid: 2185416].
Benowitz NL. The role of nicotine in smoking-related cardiovascular disease. Prev Med. 1997;26:412-417. [pmid: 9245658].
Benowitz NL. Cigarette smoking and cardiovascular disease: Pathophysiology and implications for treatment. Prog Cardiovasc Dis. 2003;46(1):91-111. [pmid: 12920702].
Berger GS, editor. Epidemiology of endometriosis. Endometriosis: Modern surgical management of endometriosis. New York, NY. Springer-Verlag. 1994:3-7.
Berger A, Zareba W, Schneider A, et al. Runs of ventricular and supraventricular tachycardia triggered by air pollution in patients with coronary heart disease. JOEM. 2006;48(11):1149-1158. [pmid: 17099451].
Berk PD, Blaschke TF, Scharschmidt BF, et al. A new approach to quantitation of the various sources of bilirubin in man. J Lab Clin Med. 1976;87(5):767-780. [pmid: 1270887].
Berk PD, Rodkey FL, Blaschke TF, et al. Comparison of plasma bilirubin turnover and carbon monoxide production in man. J Lab Clin Med. 1974;83(1):29-37. [pmid: 4808654].
Bhuyan AK, Kumar R. Kinetic barriers to the folding of horse cytochrome c in the reduced state. Biochemistry. 2002;41:12821-12834. [pmid: 12379125].
*. Biggeri A, Baccini M, Bellini P, et al. Meta-analysis of the Italian studies of short-term effects of air pollution (MISA) 1990–1999. Int J Occup Environ Health. 2005;11(1):107-122. [pmid: 15859200].
Botros FT, Laniado-Schwartzman M, Abraham NG. Regulation of cyclooxygenase- and cytochrome p450-derived eicosanoids by heme oxygenase in the rat kidney. Hypertension. 2002;39:639-644. [pmid: 11882623].
*. Botter DA, Jorgensen B, Peres AA. A longitudinal study of mortality and air pollution for Sao Paulo, Brazil. J Expo Anal Environ Epidemiol. 2002;12(5):335-343. [pmid: 12198582].
*. Braga AL, Saldiva PH, Pereira LA, et al. Health effects of air pollution exposure on children and adolescents in Sao Paulo, Brazil. Pediatr Pulmonol. 2001;31(2):106-113. [pmid: 11180685].
Brauer M, Lencar C, Tamburic L, et al. A cohort study of traffic-related air pollution impacts on birth outcomes. Environ Health Perspect. 2008;116(5):680-686. [pmid: 18470315].
*. Bremner SA, Anderson HR, Atkinson RW, et al. Short-term associations between outdoor air pollution and mortality in London 1992-4. Occup Environ Med. 1999;56(4):237-244. [pmid: 10450240].
Brown SD, Piantadosi CA. Recovery of energy metabolism in rat brain after carbon monoxide hypoxia. J Clin Invest. 1992;89:666-672. [pmid: 1737854].
Brown DB, Mueller GL, Golich FC. Hyperbaric oxygen treatment for carbon monoxide poisoning in pregnancy: A case report. Aviat Space Environ Med. 1992;63:1011-1014. [pmid: 1445151].
Bruce EN, Bruce MC. A multicompartment model of carboxyhemoglobin and carboxymyoglobin responses to inhalation of carbon monoxide. J Appl Physiol. 2003;95:1235-1247. [pmid: 12754170].
Bruce MC, Bruce EN. Analysis of factors that influence rates of carbon monoxide uptake, distribution, and washout from blood and extravascular tissues using a multicompartment model. J Appl Physiol. 2006;100:1171-1180. [pmid: 16339350].
Bruce EN, Bruce MC, Erupaka K. Prediction of the rate of uptake of carbon monoxide from blood by extravascular tissues. Respir Physiol Neurobiol. 2008;161(2):142-159. [pmid: 18313993].
Bruinen De Bruin Y, Carrer P, Jantunen M, et al. Personal carbon monoxide exposure levels: Contribution of local sources to exposures and microenvironment concentrations in Milan. J Expo Anal Environ Epidemiol. 2004a;14:312-322. [pmid: 15254478].
Bruinen De Bruin Y, Hanninen O, Carrer P, et al. Simulation of working population exposures to carbon monoxide using EXPOLIS-Milan microenvironment concentration and time-activity data. J Expo Anal Environ Epidemiol. 2004b;14:154-163. [pmid: 15014546].
Brune B, Ullrich V. Inhibition of platelet aggregation by carbon monoxide is mediated by activation of guanylate cyclase. Mol Pharmacol. 1987;32(3):497-504. [pmid: 2890093].
Brvar M, Mozina H, Osredkar J, et al. S100B protein in carbon monoxide poisoning: A pilot study. Resuscitation. 2004;61:357-360. [pmid: 15172716].
Buckley NA, Juurlink DN, Isbister G, et al. Hyperbaric oxygen for carbon monoxide poisoning. Cochrane Database Syst Rev. 2011;(4):CD002041. [pmid: 21491385].
Burge CM, Skinner SL. Determination of hemoglobin mass and blood volume with CO: Evaluation and application of a method. J Appl Physiol. 1995;79(2):623-631. [pmid: 7592227].
Burmester T, Weich B, Reinhardt S, et al. A vertebrate globin expressed in the brain. Nature. 2000;407(6803):520-523. [pmid: 11029004].
*. Burnett RT, Brook J, Dann T, et al. Association between particulate- and gas-phase components of urban air pollution and daily mortality in eight Canadian cities. Inhal Toxicol. Suppl 4. 2000;12:15-39. [pmid: 12881885].
*. Burnett RT, Smith-Doiron M, Stieb D, et al. Effects of particulate and gaseous air pollution on cardiorespiratory hospitalizations. Arch Environ Health. 1999;54(2):130-139. [pmid: 10094292].
Burnett RT, Smith-Doiron M, Stieb D, et al. Association between ozone and hospitalization for acute respiratory diseases in children less than 2 years of age. Am J Epidemiol. 2001;153(5):444-452. [pmid: 11226976].
Burnett RT, Stieb D, Brook JR, et al. Associations between short-term changes in nitrogen dioxide and mortality in Canadian cities. Arch Environ Health. 2004;59(5):228-236. [pmid: 16201668].
Cagiano R, Ancona D, Cassano T, et al. Effects of prenatal exposure to low concentrations of carbon monoxide on sexual behaviour and mesolimbic dopaminergic function in rat offspring. Br J Pharmacol. 1998;125:909-915. [pmid: 9831932].
Cairns J, Denhardt DT. Effect of cyanide and carbon monoxide on the replication of bacterial DNA in vivo. J Mol Biol. 1968;36:335-342. [pmid: 4939630].
*. Cakmak S, Dales RE, Blanco Vidal C. Air pollution and mortality in Chile: Susceptibility among the elderly. Environ Health Perspect. 2007;115(4):524-527. [pmid: 17450219].
Cakmak S, Dales RE, Judek S. Do gender, education, and income modify the effect of air pollution gases on cardiac disease?. JOEM. 2006;48(1):89-94. [pmid: 16404215].
Campbell ME, Benson BA, Muir MA. Urban air quality and human health: A Toronto perspective. Can J Public Health. 1995;86(5):351-357. [pmid: 8556685].
Canova C, Torresan S, Simonato L, et al. Carbon monoxide pollution is associated with decreased lung function in asthmatic adults. Eur Respir J. 2010;35(2):266-272. [pmid: 19679604].
Caravati EM, Adams CJ, Joyce SM, et al. Fetal toxicity associated with maternal carbon monoxide poisoning. Ann Emerg Med. 1988;17(7):714-717. [pmid: 3382073].
Carlsson GH, Nicholls P, Svistunenko D, et al. Complexes of horseradish peroxidase with formate, acetate and carbon monoxide. Biochemistry. 2005;44:635-642. [pmid: 15641789].
Carmines EL, Rajendran N. Evidence for carbon monoxide as the major factor contributing to lower fetal weights in rats exposed to cigarette smoke. Toxicol Sci. 2008;102(2):383-391. [pmid: 18203688].
Carratu MR, Cagiano R, Desantis S, et al. Prenatal exposure to low levels of carbon monoxide alters sciatic nerve myelination in rat offspring. Life Sci. 2000a;67:1759-1772. [pmid: 11021360].
Carratu MR, Cagiano R, Tattoli M, et al. Prenatal exposure model simulating CO inhalation in human cigarette smokers: Sphingomyelin alterations in the rat sciatic nerve. Toxicol Lett. 2000b;117(1–2):101-106. [pmid: 11033239].
Carratu MR, Renna G, Giustino A, et al. Changes in peripheral nervous system activity produced in rats by prenatal exposure to carbon monoxide. Arch Toxicol. 1993;67:297-301. [pmid: 8368938].
Carraway MS, Ghio AJ, Suliman HB, et al. Carbon monoxide promotes hypoxic pulmonary vascular remodeling. Am J Physiol Lung Cell Mol Physiol. 2002;282:L693-L702. [pmid: 11880294].
Castillo A, Llapur CJ, Martinez T, et al. Measurement of single breath-hold carbon monoxide diffusing capacity in healthy infants and toddlers. Pediatr Pulmonol. 2006;41(6):544-550. [pmid: 16617450].
CDC. NIOSH health hazard evaluation report. Glen Canyon National Recreation Area Arizona and Utah. HETA#002-0325-2956, HETA#2000-0400-2956. 2005. www.cdc.gov/niosh/hhe/reports/pdfs/2000-0400-2956.pdf. May 24, 2012.
CDC. Carbon monoxide poisonings after two major hurricanes-Alabama and Texas, August–October, 2005. MMWR. 2006;55(09):236-2239. www.cdc.gov/mmwr/preview/mmwrhtml/mm5509a4.htm. May 24, 2012. [pmid: 16528230].
CDC. Carbon monoxide-related deaths-United States, 1999–2004. Morb Mortal Wkly Rep. 2007;56(50):1309-1312. http://www.cdc.gov/mmwr/preview/mmwrhtml/mm5650a1.htm. August 5, 2009.
CDC. Nonfatal, unintentional, non fire-related carbon monoxide exposures United States, 2004–2006. JAMA. 2008;300(20):2362-2363.
Chakraborty S, Balakotalah V, Bidani A. Diffusing capacity reexamined: Relative roles of diffusion and chemical reaction in red cell uptake of O_2_, CO, CO_2_, and NO. J Appl Physiol. 2004;97:2284-2302. [pmid: 15322062].
Chambers CA, Hopkins RO, Weaver LK, et al. Cognitive and affective outcomes of more severe compared to less severe carbon monoxide poisoning. Brain Inj. 2008;22(5):387-395. [pmid: 18415719].
Chan C, Chuang K, Chien L, et al. Urban air pollution and emergency admissions for cerebrovascular diseases in Taipei, Taiwan. Eur Heart J. 2006;27:1238-1244. [pmid: 16537554].
Chan C, Chuang K, Su T, et al. Association between nitrogen dioxide and heart rate variability in susceptible population. Eur J Cardiovasc Prev Rehabil. 2005;12:580-586. [pmid: 16319549].
Chang C, Tsai S, Ho S, et al. Air pollution and hospital admissions for cardiovascular disease in Taipei, Taiwan. Environ Res. 2005;98:114-119. [pmid: 15721891].
Chang LT, Koutrakis P, Catalano PJ, et al. Hourly personal exposures to fine particles and gaseous pollutants–results from Baltimore, Maryland. J Air Waste Manag Assoc. 2000;50(7):1223-1235. [pmid: 10939215].
Chen GD, Fechter LD. Potentiation of octave-band noise induced auditory impairment by carbon monoxide. Hear Res. 1999;132(1–2):149-159. [pmid: 10392557].
Chen H, Namedo A, Bell M. Classification of road traffic and roadside pollution concentrations for assessment of personal exposure. Environ Modell Software. 2008;23:282-287.
*. Chen L, Jennison BL, Yang W, et al. Elementary school absenteeism and air pollution. Inhal Toxicol. 2000;12:997-1016. [pmid: 11015140].
Chen L, Yang W, Jennison BL, et al. Air pollution and birth weight in Northern Nevada, 1991–1999. Inhal Toxicol. 2002;14(2):141-157. [pmid: 12122577].
Chen PC, Lai YM, Chan CC, et al. Short-term effect of ozone on the pulmonary function of children in primary school. Environ Health Perspect. 1999;107(11):921-925. [pmid: 10544161].
*. Cheng M, Tsai S, Wu T, et al. Air pollution and hospital admissions for pneumonia in a tropical city: Kaohsiung, Taiwan. J Toxicol Environ Health A. 2007;70:2021-2026. [pmid: 18049991].
Chevalier RB, Krumholz RA, Ross JC. Reaction of nonsmokers to carbon monoxide inhalation. Cardiopulmonary responses at rest and during exercise. JAMA. 1966;198(10):1061-1064. [pmid: 5953543].
*. Cho B, Choi J, Yum Y. Air pollution and hospital admissions for respiratory disease in certain area of Korea. J Occup Health. 2000;42:185-191.
*. Chock DP, Winkler SL, Chen C. A study of the association between daily mortality and ambient air pollutant concentrations in Pittsburgh, Pennsylvania. J Air Waste Manage Assoc. 2000;50:1481-1500.
Choi IS. Carbon monoxide poisoning: Systemic manifestations and complications. J Korean Med Sci. 2001;16(3):253-261. [pmid: 11410684].
Choi IS. Parkinsonism after carbon monoxide poisoning. Eur Neurol. 2002;48:30-33. [pmid: 12138307].
*. Cifuentes LA, Vega J, Kopfer K, et al. Effect of the fine fraction of particulate matter versus the coarse mass and other pollutants on daily mortality in Santiago, Chile. J Air Waste Manage Assoc. 2000;50:1287-1298.
Clark NA, Demers PA, Karr CJ, et al. Effect of early life exposure to air pollution on development of childhood asthma. Environ Health Perspect. 2010;118(2):284-290. [pmid: 20123607].
Clewell HJ, Andersen ME. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health. 1985;1(4):111-131. [pmid: 3843496].
Coburn RF. Enhancement by phenobarbital and diphenylhydantoin of carbon monoxide production in normal man. N Engl J Med. 1970a;283(10):512-515. [pmid: 5434134].
*. Coburn RF. The carbon monoxide body stores. Ann N Y Acad Sci. 1970b;174:11-22. [pmid: 4943970].
Coburn RF, Mayers LB. Myoglobin oxygen tension determined from measurements of carboxymyoglobin in skeletal muscle. Am J Physiol. 1971;220:66-74. [pmid: 5538674].
Coburn RF, Blakemore WS, Forster RE. Endogenous carbon monoxide production in man. J Clin Invest. 1963;42(7):1172-1178. [pmid: 14021853].
Coburn RF, Forster RE, Kane PB. Considerations of the physiological variables that determine the blood carboxyhemoglobin concentration in man. J Clin Invest. 1965;44(11):1899-1910. [pmid: 5845666].
Coburn RF, Williams WJ, Forster RE. Effect of erythrocyte destruction on carbon monoxide production in man. J Clin Invest. 1964;43(6):1098-1103. [pmid: 14171787].
*. Conceicao GM, Miraglia SGEK, Kishi HS, et al. Air pollution and child mortality: A time-series study in Sao Paulo, Brazil. Environ Health Perspect. Suppl 3. 2001;109:347-350. [pmid: 11427383].
Conrad R, Seiler W. Influence of the surface microlayer on the flux of nonconservative trace gases (CO, H2, CH4, N2O) across the ocean-atmosphere interface. J Atmos Chem. 1988;6:83-94.
Cramer CR. Fetal death due to accidental maternal carbon monoxide poisoning. J Toxicol Clin Toxicol. 1982;19(3):297-301. [pmid: 7131616].
Cronje FJ, Carraway MS, Freiberger JJ, et al. Carbon monoxide actuates O2-limited heme degradation in the rat brain. Free Radic Biol Med. 2004;37(11):1802-1812. [pmid: 15528039].
Dadvand P, Rankin J, Rushton S, et al. Ambient air pollution and congenital heart disease: A register-based study. Environ Res. 2011;111(3):435-441. [pmid: 21329916].
Dahms TE, Younis LT, Wiens RD, et al. Effects of carbon monoxide exposure in patients with documented cardiac arrhythmias. J Am Coll Cardiol. 1993;21(2):442-450. [pmid: 7678844].
Dales R. Ambient carbon monoxide may influence heart rate variability in subjects with coronary artery disease. JOEM. 2004;46(12):1217-1221. [pmid: 15591973].
D'Amico G, Lam F, Hagen T, et al. Inhibition of cellular respiration by endogenously produced carbon monoxide. J Cell Sci. 2006;119:2291-2298. [pmid: 16723735].
Dart RC, editor. Medical toxicology. 3rd ed. Philadelphia, PA. Lippincott Williams & Wilkins. 2004:1208.
Davidson SB, Penney DG. Time course of blood volume change with carbon monoxide inhalation and its contribution to the overall cardiovascular response. Arch Toxicol. 1988;61:306-313. [pmid: 3377685].
Davies B, Morris T. Physiological parameters in laboratory animals and humans. Pharm Res. 1993;10(7):1093-1095. [pmid: 8378254].
Davies DM, Smith DJ. Electrocardiographic changes in healthy men during continuous low-level carbon monoxide exposure. Environ Res. 1980;21(1):197-206. [pmid: 7389699].
Davutoglu V, Gunay N, Kocoglu H, et al. Serum levels of NT-ProBNP as an early cardiac marker of carbon monoxide poisoning. Inhal Toxicol. 2006;18:155-158. [pmid: 16393930].
*. de Hartog JJ, Hoek G, Peters A, et al. Effects of fine and ultrafine particles on cardiorespiratory symptoms in elderly subjects with coronary heart disease. Am J Epidemiol. 2003;157(7):613-623. [pmid: 12672681].
De Leon SF, Thurston GD, Ito K. Contribution of respiratory disease to nonrespiratory mortality associations with air pollution. Am J Respir Crit Care Med. 2003;167:1117-1123. [pmid: 12684250].
*. Delfino RJ, Gong H Jr, Linn WS, et al. Asthma symptoms in Hispanic children and daily ambient exposures to toxic and criteria air pollutants. Environ Health Perspect. 2003;111:647-656. [pmid: 12676630].
Delivoria-Papadopoulos M, Coburn RF, Forster RE. Cyclic variation of rate of carbon monoxide production in normal women. J Appl Physiol. 1974;36(1):49-51. [pmid: 4809863].
Dennekamp M, Akram M, Abramson MJ, et al. Outdoor air pollution as a trigger for out-of-hospital cardiac arrests. Epidemiology. 2010;21(4):494-500. [pmid: 20489649].
Denninger JW, Marletta MA. Guanylate cyclase and the NO/cGMP signaling pathway. Biochim Biophys Acta. 1999;1411(2–3):334-350. [pmid: 10320667].
De Salvia MA, Cagiano R, Carratu MR, et al. Irreversible impairment of active avoidance behavior in rats prenatally exposed to mild concentrations of carbon monoxide. Psychopharmacology. 1995;122:66-71. [pmid: 8711066].
Di Cera E, Doyle ML, Morgan MS, et al. Carbon monoxide and oxygen binding to human hemoglobin FO. Biochemistry. 1989;28(6):2631-2638. [pmid: 2471551].
Dioum EM, Rutter J, Tuckerman JR, et al. NPAS2: A gas-responsive transcription factor. Science. 2002;298:2385-2387. [pmid: 12446832].
D'Ippoliti D, Forastiere F, Ancoma C, et al. Air pollution and myocardial infarction in Rome. Epidemiology. 2003;14(5):528-535. [pmid: 14501267].
Dix-Cooper L, Eskenazi B, Romero C, et al. Neurodevelopmental performance among school age children in rural Guatemala is associated with prenatal and postnatal exposure to carbon monoxide, a marker for exposure to woodsmoke. Neurotoxicology. 2011. [Epub ahead of print].
Doblar DD, Santiago TV, Edelman NH. Correlation between ventilatory and cerebrovascular responses to inhalation of CO. J Appl Physiol. 1977;43(3):455-462. [pmid: 583633].
Dobos K, Zimmer G. Performance of carbon monoxide-sensitive MOSFET's with metal-oxide semiconductor gates. IEEE Trans Electron Devices ED. 1985;32(7):1165-1169.
Dockery DW, Luttmann-Gibson H, Rich DQ, et al. Association of air pollution with increased incidence of ventricular tachyarrhythmias recorded by implanted cardioverter defibrillators. Environ Health Perspect. 2005;113(6):670-674. [pmid: 15929887].
Dolan MC. Carbon monoxide poisoning. Can Med Assoc J. 1985;133:392-399. [pmid: 4027805].
Dominici F, McDermott A, Daniels M, et al. Mortality among residents of 90 cities. Revised analyses of time-series studies of air pollution and health. Special report. 2003b. Health Effects Institute. http://pubs.healtheffects.org/getfile.php?u=21. October 13, 2009.
Dominici F, Sheppard L, Clyde M. Health effects of air pollution: A statistical review. Int Stat Rev. 2003a;71:243-276.
Duci A, Chaloulakou A, Spyrellis N. Exposure to carbon monoxide in the Athens urban area during commuting. Sci Total Environ. 2003;309(1–3):47-58. [pmid: 12798091].
Dutton SJ, Hannigan MP, Miller SL. Indoor pollutant levels from the use of unvented natural gas fireplaces in Boulder, Colorado. J Air Waste Manage Assoc. 2001;51:1654-1661.
Elkharrat E, Raphael JC, Korach JM, et al. Acute carbon monoxide intoxication and hyperbaric oxygen in pregnancy. Intensive Care Med. 1991;17(5):289-292. [pmid: 1939875].
Ellis HV, Hong CB, Lee CC, et al. Subchronic and chronic toxicity studies of 2,4-dinotrotoluene. Part I. Beagle Dogs. Journal of The American College of Toxicology. 1985;4(4):233-242.
Engel RR, Rodkey FL, O'Neal JD, et al. Relative affinity of human fetal hemoglobin for carbon monoxide and oxygen. Blood. 1969;33(1):37-45. [pmid: 5763632].
EPA. Air quality criteria for carbon monoxide. 1991. Washington, DC. U.S. Environmental Protection Agency, Office of Research and Development. EPA600890045F.
EPA. Special report on environmental endocrine disruption: An effects assessment and analysis. 1997. Washington, DC. U.S. Environmental Protection Agency, Risk Assessment Forum.
EPA. Air quality criteria for carbon monoxide. 2000. Washington, DC. U.S. Environmental Protection Agency. EPA600P66001F. http://www.epa.gov/NCEA/pdfs/coaqcd.pdf. June 9, 2009.
EPA. National primary drinking water regulations. 2003. Washington, DC. Office of Ground Water and Drinking Water, U.S. Environmental Protection Agency. http://www.epa.gov/safewater/contaminants/index.html. May 19, 2009.
EPA. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the emergency planning and community right-to-know act (Title III of the Superfund Amendments and Reauthorization Act of 1986). 2005. U.S. Environmental Protection Agency, Office of Environmental Information.
EPA. Drinking water standards and health advisories. 2006a. Washington, DC. U.S. Environmental Protection Agency, Office of Water. EPA822R04005. http://epa.gov/waterscience/criteria/drinking/. May 19, 2009.
EPA. National recommended water quality criteria. 2006b. Washington, DC. U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. http://www.epa.gov/waterscience/criteria/wqcriteria.html. May 11, 2009.
EPA. EPA's 2008 report on the environment. 2008. Washington, DC. U.S. Environmental Protection Agency. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=190806. July 16, 2009.
EPA. An introduction to indoor air quality. Carbon monoxide. 2009a. U.S. Environmental Protection Agency. http://www.epa.gov/iaq/co.html. May 8, 2009.
EPA. Acute exposure guideline levels (AEGLs). 2009b. Washington, DC. U.S. Environmental Protection Agency. http://www.epa.gov/oppt/aegl/. May 19, 2009.
EPA. Hazardous air pollutants. Clean Air Act. 2009c. U.S. Environmental Protection Agency. United States Code. 42 USC 7412 http://www.epa.gov/ttn/atw/orig189.html. May 19, 2009.
EPA. National Ambient Air Quality Standards (NAAQS). 2009d. Washington, DC. U.S. Environmental Protection Agency, Office of Air and Radiation. http://www.epa.gov/air/criteria.html. May 19, 2009.
EPA. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notifications. 2009e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://www.epa.gov/lawsregs/search/40cfr.html. May 20, 2009.
EPA. Superfund, emergency planning, and community right-to-know programs. Toxic chemical release reporting. 2009f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://www.epa.gov/lawsregs/search/40cfr.html. May 11, 2009.
EPA. Integrated science assessment for carbon monoxide-first external review draft. 2009g. Research Triangle Park, NC. U.S. Environmental Protection Agency. EPA600R09019.
EPA. 1970–2008 Average annual emissions, all criteria pollutants in MS Excel, June 2009. National Emissions Inventory (NEI) air pollutant emissions trends data. 2009h. U.S. Environmental Protection Agency. http://www.epa.gov/ttn/chief/trends/index.html. June 10, 2009.
EPA. Carbon monoxide. Query AQS Data. 2009i. U.S. Environmental Protection Agency. http://www.epa.gov/aqspubl1/annual_summary.html. June 11, 2009.
EPA. Integrated science assessment for carbon monoxide. 2010. U.S. Environmental Protection Agency. EPA600R09019F. http://ofmpub.epa.gov/eims/eimscomm.getfile?p_download_id=494434. May 24, 2012.
EPA. Carbon monoxide emissions. 2012. U.S. Environmental Protection Agency. http://cfpub.epa.gov/eroe/index.cfm&fuseaction=detail.viewInd&lv=list.listBySubTopic&r=219652&subt op=341&ch=46 (http://cfpub.epa.gov/eroe/index.cfm?fuseaction=detail.viewInd&lv=list.listBySubTopic&r=219652&subt op=341&ch=46). May 24, 2012.
Ernst A, Zibrak JD. Carbon monoxide poisoning. N Engl J Med. 1998;339(22):1603-1608. [pmid: 9828249].
Estabrook RW, Franklin MR, Hildebrandt AG. Factors influencing the inhibitory reactions. Biological effects of carbon monoxide. New York, NY. New York Academy of Sciences. 1980:218.
*. Estrella B, Estrella R, Oviedo J, et al. Acute respiratory diseases and carboxyhemoglobin status in school children of Quito, Ecuador. Environ Health Perspect. 2005;113(5):607-611. [pmid: 15866771].
Fabian P, Borchers R, Weiler KH, et al. Simultaneously measured vertical profiles of H_2_, CH_4_, CO, N_2_O, CFCl_3_, and CF_2_Cl_2_in the mid-latitude stratosphere and troposphere. J Geophys Res. 1979;84(C6):3149-3154.
*. Fairley D. Daily mortality and air pollution in Santa Clara County, California, 1989–1996. Environ Health Perspect. 1999;107(8):637-641. [pmid: 10417361].
*. Farhat SCL, Paulo RLP, Shimoda TM, et al. Effect of air pollution on pediatric respiratory emergency room visits and hospital admissions. Braz J Med Biol Res. 2005;38:227-235. [pmid: 15785834].
Farrow JR, Davis GJ, Roy TM, et al. Fetal death due to nonlethal maternal carbon monoxide poisoning. J Forensic Sci. 1990;35(6):1448-1452. [pmid: 2262778].
Favory R, Lancel S, Marechal X, et al. Cardiovascular protective role for activated protein C during endotoxemia in rats. Intensive Care Med. 2006a;32:899-905. [pmid: 16601957].
*. Favory R, Lancel S, Tissier S, et al. Myocardial dysfunction and potential cardiac hypoxia in rats induced by carbon monoxide inhalation. Am J Respir Crit Care Med. 2006b;174(3):320-325. [pmid: 16690979].
FDA. Everything added to food in the United States (EAFUS). 2008. Washington, DC. U.S. Food and Drug Administration. http://vm.cfsan.fda.gov/~dms/eafus.html. May 19, 009.
Fechter LD, Annau Z. Toxicity of mild prenatal carbon monoxide exposure. Science. 1977;197(4304):680-682. [pmid: 877585].
Fechter LD, Annau Z. Prenatal carbon monoxide exposure alters behavioral development. Neurobehav Toxicol. 1980;2(1):7-11. [pmid: 7442921].
Fechter LD, Karpa MD, Proctor B, et al. Disruption of neostriatal development in rats following perinatal exposure to mild, but chronic carbon monoxide. Neurotoxicol Teratol. 1987a;9(4):277-281. [pmid: 2891023].
Fechter LD, Thakur M, Miller B, et al. Effects of prenatal carbon monoxide exposure on cardiac development. Toxicol Appl Pharmacol. 1980;56(3):370-375. [pmid: 6452716].
Fechter LD, Thorne PR, Nuttall AL. Effects of carbon monoxide on cochlear electrophysiology and blood flow. Hear Res. 1987b;27:37-45. [pmid: 3583935].
Fechter LD, Young JS, Carlisle L. Potentiation of noise induced threshold shifts and hair cell loss by carbon monoxide. Hear Res. 1988;34:39-48. [pmid: 3403384].
FEDRIP. Carbon monoxide. Federal Research in Progress database. 2009. Springfield, VA. National Technical Information Service.
Fein A, Grossman RF, Jones JG, et al. Carbon monoxide effect on alveolar epithelial permeability. Chest. 1980;78:726-731. [pmid: 6775882].
Fenn WO. The burning of CO in tissues. Ann N Y Acad Sci. 1970;174(1):64-71. [pmid: 4332409].
*. Fischer P, Hoek G, Brunekreef B, et al. Air pollution and mortality in the Netherlands: Are the elderly more at risk?. Eur Respir J. 2003;21:34S-38S.
Fischer PH, Steerenberg PA, Snelder JD, et al. Association between exhaled nitric oxide, ambient air pollution and respiratory health in school children. Int Arch Occup Environ Health. 2002;75:348-353. [pmid: 11981674].
Fisher AB, Hyde RW, Baue AE, et al. Effect of carbon monoxide on function and structure of the lung. J Appl Physiol. 1969;26(1):4-12. [pmid: 5762875].
Fisher JA, Rucker J, Sommer LZ, et al. Isocapnic hyperpnea accelerates carbon monoxide elimination. Am J Respir Crit Care Med. 1999;159:1289-1292. [pmid: 10194179].
Florkowski CM, Rossi ML, Carey MP, et al. Rhabdomyolysis and acute renal failure following carbon monoxide poisoning: Two case reports with muscle histopathology and enzyme activities. J Toxicol Clin Toxicol. 1992;30(3):443-454. [pmid: 1512816].
Fomon SJ. Body composition of the infant: Part 1: The male reference infant. Faulkner F, editor. Human development. Philadelphia, PA. WB Saunders. 1966:239-246.
Fomon SJ, Haschke F, Ziegler EE, et al. Body composition of reference children from birth to age 10 years. Am J Clin Nutr. Suppl 5. 1982;35:1169-1175. [pmid: 7081099].
*. Forastiere F, Stafoggia M, Picciotto S, et al. A case-crossover analysis of out-of-hospital coronary deaths and air pollution in Rome, Italy. Am J Respir Crit Care Med. 2005;172:1549-1555. [pmid: 15994461].
*. Forastiere F, Stafoggia M, Tasco C, et al. Socioeconomic status, particulate air pollution, and daily mortality: Differential exposure or differential susceptibility. Am J Ind Med. 2007;50:208-216. [pmid: 16847936].
Forster RE. Carbon monoxide and the partial pressure of oxygen in tissue. Ann N Y Acad Sci. 1970;174:233-241. [pmid: 5289598].
Fritsch T, Hering P, Murtz M. Infrared laser spectroscopy for online recording of exhaled carbon monoxide - a progress report. J Breath Res. 2007;1(014002):R1-R7.
Fujita T, Toda K, Karimova A, et al. Paradoxical rescue from ischemic lung injury by inhaled carbon monoxide driven by derepression of fibrinolysis. Nat Med. 2001;7(5):598-604. [pmid: 11329062].
*. Fung KY, Khan S, Krewski D, et al. Association between air pollution and multiple respiratory hospitalizations among the elderly in Vancouver, Canada. Inhal Toxicol. 2006;18(13):1005-1011. [pmid: 16966300].
Fung KY, Luginaah I, Gorey KM, et al. Air pollution and daily hospital admissions for cardiovascular diseases in Windsor, Ontario. Can J Public Health. 2005;96(1):29-33. [pmid: 15682690].
*. Fusco D, Forastiere F, Michelozzi P, et al. Air pollution and hospital admissions for respiratory conditions in Rome, Italy. Eur Respir J. 2001;17:1143-1150. [pmid: 11491157].
Gautier M, Antier D, Bonnet P, et al. Continuous inhalation of carbon monoxide induces right ventricle ischemia and dysfunction in rats with hypoxic pulmonary hypertension. Am J Physiol Heart Circ Physiol. 2007;293:H1046-H1052. [pmid: 17483237].
George C. Carbon monoxide. Kirk-Othmer encyclopedia of chemical technology. 2001. John Wiley & Sons, Inc. http://mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/carbpier.a02/current/pdf. May 7, 2009.
Geuens E, Brouns I, Flamez D, et al. A globin in the nucleus!. J Biol Chem. 2003;278:30417-30420. [pmid: 12796507].
Ghio AJ, Stonehuerner JG, Dailey LA, et al. Carbon monoxide reversibly alters iron homeostasis and respiratory epithelial cell function. Am J Respir Cell Mol Biol. 2008;38(6):715-723. [pmid: 18203974].
Gibson QH, Olson JS, McKinnie RE, et al. A kinetic description of ligand binding to sperm whale myoglobin. J Biol Chem. 1986;261(22):10228-10239. [pmid: 3733708].
Gilboa SM, Mendola P, Olshan AF, et al. Relation between ambient air quality and selected birth defects, seven county study, Texas, 1997–2000. Am J Epidemiol. 2005;162(3):238-252. [pmid: 15987727].
Giustino A, Cagiano R, Carratu MR, et al. Immunological changes produced in rats by prenatal exposure to carbon monoxide. Pharmacol Toxicol. 1993;73(5):274-278. [pmid: 8115310].
Giustino A, Cagiano R, Carratu MR, et al. Prenatal exposure to low concentrations of carbon monoxide alters habituation and non-spatial working memory in rat offspring. Brain Res. 1999;844:201-205. [pmid: 10536278].
Giustino A, Carratu MR, Brigiani GS, et al. Changes in the frequency of splenic immunocompetent cells in rats exposed to carbon monoxide during gestation. Immunopharmacol Immunotoxicol. 1994;16(2):281-292. [pmid: 8077611].
Giwercman A, Carlsen E, Keiding N, et al. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl. 1993;101(2):65-71.
Gold DR, Litonjua A, Schwartz J, et al. Ambient pollution and heart rate variability. Circulation. 2000;101:1267-1273. [pmid: 10725286].
Gold DR, Litonjua AA, Zanobetti A, et al. Air pollution and ST-segment depression in elderly subjects. Environ Health Perspect. 2005;113(7):883-887. [pmid: 16002377].
*. Goldberg MS, Burnett RT, Bailar JC, et al. Identification of persons with cardiorespiratory conditions who are at risk of dying from the acute effects of ambient air particles. Environ Health Perspect. Suppl 4. 2001;109:487-494. [pmid: 11544152].
*. Goldberg MS, Burnett RT, Valois MF, et al. Associations between ambient air pollution and daily mortality among persons with congestive heart failure. Environ Res. 2003;91:8-20. [pmid: 12550083].
*. Goldberg MS, Burnett RT, Yale JF, et al. Associations between ambient air pollution and daily mortality among persons with diabetes and cardiovascular disease. Environ Res. 2006;100:255-267. [pmid: 15982650].
Gordon CJ. Thermal biology of the laboratory rat. Physiol Rev. 1990;47:963-991.
Gorman D, Drewry A, Huang YL, et al. The clinical toxicology of carbon monoxide. Toxicology. 2003;187(1):25-38. [pmid: 12679050].
*. Goss CH, Newsom SA, Schildcrout JS, et al. Effect of ambient air pollution on pulmonary exacerbations and lung function in cystic fibrosis. Am J Respir Crit Care Med. 2004;169:816-821. [pmid: 14718248].
*. Gouveia N, Fletcher T. Time series analysis of air pollution and mortality: Effects by cause, age and socioeconomic status. J Epidemiol Community Health. 2000;54:750-755. [pmid: 10990478].
Gouveia N, Bremner SA, Novaes HMD. Associations between ambient air pollution and birth weight in Sao Paulo, Brazil. J Epidemiol Community Health. 2004;58:11-17. [pmid: 14684720].
Graham LA, Noseworthy L, Fugler D, et al. Contribution of vehicle emissions from an attached garage to residential indoor air pollution levels. J Air Waste Manage Assoc. 2004;54:563-584.
Greingor JL, Tosi JM, Ruhlmann S, et al. Acute carbon monoxide intoxication during pregnancy. One case report and review of the literature. Emerg Med J. 2001;18(5):399-401. [pmid: 11559621].
*. Guo YL, Lin YC, Sung FC, et al. Climate, traffic-related air pollutants, and asthma prevalence in middle-school children in Taiwan. Environ Health Perspect. 1999;107(12):1001-1006. [pmid: 10585904].
Guzelian PS, Henry CJ, Olin SS. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC. International Life Sciences and Press Institute Press. 1992:1-283.
*. Gwynn RC, Burnett RT, Thurston GD. A time-series analysis of acidic particulate matter and daily mortality and morbidity in the Buffalo, New York, region. Environ Health Perspect. 2000;108(2):125-133. [pmid: 10656852].
Ha EH, Hong YC, Lee BE, et al. Is air pollution a risk factor for low birth weight in Seoul?. Epidemiology. 2001;12:643-648. [pmid: 11679791].
Ha EH, Lee JT, Kim H, et al. Infant susceptibility of mortality to air pollution in Seoul, South Korea. Pediatrics. 2003;111:284-290. [pmid: 12563052].
*. Hajat S, Anderson HR, Atkinson RW, et al. Effects of air pollution on general practitioner consultations for upper respiratory diseases in London. Occup Environ Med. 2002;59:294-299. [pmid: 11983844].
*. Hajat S, Haines A, Goubet SA, et al. Association of air pollution with daily GP consultations for asthma and other lower respiratory conditions in London. Thorax. 1999;54(7):597-605. [pmid: 10377204].
Hampson NB. Carboxyhemoglobin elevation due to hemolytic anemia. J Emerg Med. 2007;33(1):17-19. [pmid: 17630069].
Hampson NB, Hauff NM. Carboxyhemoglobin levels in carbon monoxide poisoning: Do they correlate with the clinical picture?. Am J Emerg Med. 2008;26(6):665-669. [pmid: 18606318].
Hampson NB, Zmaeff JL. Outcome of patients experiencing cardiac arrest with carbon monoxide poisoning treated with hyperbaric oxygen. Ann Emerg Med. 2001;38:36-41. [pmid: 11423810].
Hampson NB, Rudd RA, Hauff NM. Increased long-term mortality among survivors of acute carbon monoxide poisoning. Crit Care Med. 2009;37(6):1941-1947. [pmid: 19384195].
Hanninen OO, Alm S, Katsouyanni K, et al. The EXPOLIS study: Implications for exposure research and environmental policy in Europe. J Expo Anal Environ Epidemiol. 2004;14:440-456. [pmid: 15026774].
*. Hapcioglu B, Issever H, Kocyigit E, et al. The effect of air pollution and meteorological parameters on chronic obstructive pulmonary disease at an Istanbul hospital. Indoor Built Environ. 2006;15(2):147-153.
Hauck H, Neuberger M. Carbon monoxide uptake and the resulting carboxyhemoglobin in man. Eur J Appl Physiol Occup Physiol. 1984;53(2):186-190. [pmid: 6439560].
Hausberg M, Somers VK. Neural circulatory responses to carbon monoxide in healthy humans. Hypertension. 1997;29(5):1114-1118. [pmid: 9149675].
Heckerling PS, Leikin JB, Maturen A, et al. Screening hospital admissions from the emergency department for occult carbon monoxide poisoning. Am J Emerg Med. 1990;8(4):301-304. [pmid: 2094235].
*. HEI. Daily mortality and fine and ultrafine particles in Erfurt, Germany. Part I. Role of particle numbers and particle mass. 2000. Health Effects Institute. http://publs.healtheffects.org/getfile.php?u=189. September 24, 2009.
HEI. The national morbidity, mortality, and air pollution study. Part IV. Hierarchical bivariate time-series models-a combined analysis of PM_10_ effects on hospitalization and mortality. Number 94. 2005. Health Effects Institute. http://pubs.healtheffects.org/getfile.php?u=218. August 10, 2009.
Helfaer MA, Traystman RJ. Cerebrovascular effects of carbon monoxide. Penny DG, editor. Carbon monoxide poisoning. New York, NY. CRC Press. 1996:69-86.
Henrotin JB, Besancenot JP, Bejot Y, et al. Short-term effects of ozone air pollution on ischaemic stroke occurrence: A case-crossover analysis from a 10-year population-based study in Dijon, France. Occup Environ Med. 2007;64:439-445. [pmid: 17409181].
Herman GD, Shapiro AB, Leikin J. Myonecrosis in carbon monoxide poisoning. Vet Hum Toxicol. 1988;30(1):28-30. [pmid: 3354179].
Hill EP, Hill JR, Power GG, et al. Carbon monoxide exchanges between the human fetus and mother: A mathematical model. Am J Physiol. 1977;232(3):H311-H323. [pmid: 842687].
Hinderliter AL, Adams KF, Price CJ, et al. Effects of low-level carbon monoxide exposure on resting and exercise-induced ventricular arrhythmias in patients with coronary artery disease and no baseline ectopy. Arch Environ Health. 1989;44(2):89-93. [pmid: 2930250].
*. Hinwood AL, De Klerk N, Rodriguez C, et al. The relationship between changes in daily air pollution and hospitalizations in Perth, Australia 1992–1998: A case-crossover study. Int J Environ Health Res. 2006;16(1):27-46. [pmid: 16507479].
*. Hirsch T, Weiland SK, von Mutius E, et al. Inner city air pollution and respiratory health and atopy in children. Eur Respir J. 1999;14:669-677. [pmid: 10543291].
*. Hoek G, Brunekreef B, Fischer P, et al. The association between air pollution and heart failure, arrhythmia, embolism, thrombosis, and other cardiovascular causes of death in a time series study. Epidemiology. 2001;12:355-357. [pmid: 11337606].
*. Hoek G, Brunekreef B, Verhoeff A, et al. Daily mortality and air pollution in the Netherlands. J Air Waste Manage Assoc. 2000;50:1380-1389.
Hoel DG, Davis DL, Miller AB, et al. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst. 1992;84(5):313-320. [pmid: 1738181].
Holguin F, Tellez-Rojo MM, Hernandez M, et al. Air pollution and heart rate variability among the elderly in Mexico City. Epidemiology. 2003;14:521-527. [pmid: 14501266].
Hollander DI, Nagey DA, Welch R, et al. Hyperbaric oxygen therapy for the treatment of acute carbon monoxide poisoning in pregnancy. J Reprod Med. 1987;32:615-617. [pmid: 3656301].
Honda Y, Nitta H, Ono M. Low level carbon monoxide and mortality of persons aged 65 or older in Tokyo, Japan 1976–1990. J Health Sci. 2003;49:454-458.
Hong YC, Lee JT, Kim H, et al. Effects of air pollutants on acute stroke mortality. Environ Health Perspect. 2002a;110(2):187-191. [pmid: 11836148].
Hong YC, Lee JT, Kim H, et al. Air pollution: A new risk factor in ischemic stroke mortality. Stroke. 2002b;33:2165-2169. [pmid: 12215581].
Hong YC, Leem JH, Ha EH. Air pollution and daily mortality in Inchon, Korea. J Korean Med Sci. 1999a;14:239-244. [pmid: 10402164].
Hong YC, Leem JH, Ha EH, et al. PM_10_ exposure, gaseous pollutants, and daily mortality in Inchon, South Korea. Environ Health Perspect. 1999b;107(11):873-878. [pmid: 10544154].
Hopkins RO, Fearing MA, Weaver LK, et al. Basal ganglia lesions following carbon monoxide poisoning. Brain Inj. 2006;20(3):273-281. [pmid: 16537269].
Horvath SM, Bedi JF, Wagner JA, et al. Maximal aerobic capacity at several ambient concentrations of CO at several altitudes. J Appl Physiol. 1988;65(6):2696-2708. [pmid: 3215869].
Horvath SM, Raven PB, Dahms TE, et al. Maximal aerobic capacity at different levels of carboxyhemoglobin. J Appl Physiol. 1975;38(2):300-303. [pmid: 1120755].
Hosseinpoor AR, Forouzanfar MH, Yunesian M, et al. Air pollution and hospitalization due to angina pectoris in Tehran, Iran: A time-series study. Environ Res. 2005;99:126-131. [pmid: 16053936].
Houck JE, Crouch J, Huntley RH. Review of wood heater and fireplace emissions factors. 10^th^ International Emission Inventory Conference-“One Atmosphere, One Inventory, Many Challenges”. 2006. http://www.epa.gov/ttn/chief/conference/ei10/pm/houck.pdf. May 8, 2009.
HSDB. Carbon monoxide. Hazardous Substances Data Bank. 2009. National Library of Medicine. http://toxnet.nlm.nih.gov. June 9, 2009.
Hsia CC. Recruitment of lung diffusing capacity: Update of concept and application. Chest. 2002;122(5):1774-1783. [pmid: 12426283].
Hu S, Kincaid JR. Resonance Raman studies of the carbonmonoxy form of catalase. Evidence for and effects of phenolate ligation. FEBS Lett. 1992;314(3):293-296. [pmid: 1468561].
Huang SH, Chang WN, Chen SF, et al. Tc99m-sestamibi thigh SPECT/CT images for noninvasive assessment of skeletal muscle injury in carbon monoxide intoxication with clinical and pathological correlation. Clin Nucl Med. 2011;36(3):199-205. [pmid: 21285677].
Hugod C. The effect of carbon monoxide exposure on morphology of lungs and pulmonary arteries in rabbits. A light-and electron-microscopic study. Arch Toxicol. 1980;43:273-281. [pmid: 7387387].
Huynh M, Woodruff TJ, Parker JD, et al. Relationships between air pollution and preterm birth in California. Paediatr Perinat Epidemiol. 2006;20:454-461. [pmid: 17052280].
Hwang BF, Jaakkola JJ. Ozone and other air pollutants and the risk of oral clefts. Environ Health Perspect. 2008;116(10):1411-1415. [pmid: 18941587].
*. Hwang BF, Jaakkola JJ, Lee YL, et al. Relation between air pollution and allergic rhinitis in Taiwanese schoolchildren. Respir Res. 2006;7(1):23. [pmid: 16469096].
Hwang BF, Lee YL, Lin YC, et al. Traffic related air pollution as a determinant of asthma among Taiwanese school children. Thorax. 2005;60:467-476. [pmid: 15923246].
*. Hwang JS, Chan CC. Effects of air pollution on daily clinic visits for lower respiratory tract illness. Am J Epidemiol. 2002;155(1):1-10. [pmid: 11772777].
IARC. Agents Reviewed by the IARC Monographs. 2009;Volumes 1–99. Lyon, France. International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/index.php. May 19, 2009.
Ibald-Mulli A, Stieber J, Wichmann HE, et al. Effects of air pollution on blood pressure: A population-based approach. Am J Public Health. 2001;91:571-577. [pmid: 11291368].
Iheagwara KN, Thom SR, Deutschman CS, et al. Myocardial cytochrome oxidase activity is decreased following carbon monoxide exposure. Biochim Biophys Acta. 2007;1772(9):1112-1116. [pmid: 17628447].
ILSI. Physiological parameter values for PBPK models. International Life Science Institute under agreement with U.S. Environmental Protection Agency. 1994. Washington, DC. Office of Health and Environmental Assessment.
IPCS. Carbon oxide. International chemical safety cards. International Programme on Chemical Safety. 2008. Commission of the European Communities. http://www.cdc.gov/niosh/ipcsneng/neng0023.html. June 9, 2009.
IRIS. Integrated Risk Information System. 2009. Washington, DC. U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.html. May 11, 2009.
*. Ito K, Thurston GD, Silverman RA. Characterization of PM2.5, gaseous pollutants, and meteorological interactions in the context of time-series health effects models. J Expo Sci Environ Epidemiol. Suppl 2. 2007;17:S45-S60. [pmid: 18079764].
Jalaludin B, Morgan G, Lincoln D, et al. Associations between ambient air pollution and daily emergency department attendances for cardiovascular disease in the elderly (65+ years). J Expo Sci Environ Epidemiol. 2006;16:225-237. [pmid: 16118657].
Jalaludin B, Mannes T, Morgan G, et al. Impact of ambient air pollution on gestational age is modified by season in Sydney, Australia. Environ Health. 2007;6(1):16-24. [pmid: 17553174].
Jerrett M, Burnett RT, Willis A, et al. Spatial analysis of the air pollution-mortality relationship in the context of ecologic confounders. J Toxicol Environ Health Part A. 2003;66:1735-1777. [pmid: 12959842].
Johanson CE. Permeability and vascularity of the developing brain: Cerebellum vs. cerebral cortex. Brain Res. 1980;190(1):3-16. [pmid: 6769537].
Joumard R, Chiron M, Vidon R, et al. Mathematical models of the uptake of carbon monoxide on hemoglobin at low carbon monoxide levels. Environ Health Perspect. 1991;41:277-289. [pmid: 7333242].
Kalay N, Ozdogru I, Cetinkaya Y, et al. Cardiovascular effects of carbon monoxide poisoning. Am J Cardiol. 2007;99:322-324. [pmid: 17261390].
Kao LW, Nañagas KA. Toxicity associated with carbon monoxide. Clin Lab Med. 2006;26(1):99-125. [pmid: 16567227].
*. Karr C, Lumley T, Schreuder A, et al. Effects of subchronic and chronic exposure to ambient air pollutants on infant bronchiolitis. Am J Epidemiol. 2007;165(5):553-560. [pmid: 17158471].
Karr C, Lumley T, Shepherd K, et al. A case-crossover study of wintertime ambient air pollution and infant bronchiolitis. Environ Health Perspect. 2006;114(2):277-281. [pmid: 16451867].
*. Keatinge WR, Donaldson GC. Mortality related to cold and air pollution in London after allowance for effects of associated weather patterns. Environ Res. 2001;86(3):209-216. [pmid: 11453671].
*. Kettunen J, Lanki T, Tiittanen P, et al. Associations of fine and ultrafine particulate air pollution with stroke mortality in an area of low air pollution levels. Stroke. 2007;38:918-922. [pmid: 17303767].
Khalil MAK, Rasmussen RA. The global cycle of carbon monoxide: Trends and mass balance. Chemosphere. 1990;20(1–2):227-242.
Kim KM, Pae HO, Zheng M, et al. Carbon monoxide induces heme oxygenase-1 via activation of protein kinase R-like endoplasmic reticulum kinase and inhibits endothelial cell apoptosis triggered by endoplasmic reticulum stress. Circ Res. 2007;101:919-927. [pmid: 17823375].
King GM. Characteristics and significance of atmospheric carbon monoxide consumption by soils. Chemosphere Global Change Sci. 1999a;1:53-63.
King GM. Attributes of atmospheric carbon monoxide oxidation by Maine forest soils. Appl Environ Microbiol. 1999b;65(12):5257-5264. [pmid: 10583974].
Kizakevich PN, McCartney ML, Hazucha MJ, et al. Noninvasive ambulatory assessment of cardiac function in healthy men exposed to carbon monoxide during upper and lower body exercise. Eur J Appl Physiol. 2000;83:7-16. [pmid: 11072767].
Klawans HL, Stein RW, Tanner CM, et al. A pure parkinsonian syndrome following acute carbon monoxide intoxication. Arch Neurol. 1982;39(5):302-304. [pmid: 7073551].
Kleinman MT, Davidson DM, Vandagriff RB, et al. Effects of short-term exposure to carbon monoxide in subjects with coronary artery disease. Arch Environ Health. 1989;44(6):361-369. [pmid: 2692521].
Kleinman MT, Leaf DA, Kelly E, et al. Urban angina in the mountains: Effects of carbon monoxide and mild hypoxemia on subjects with chronic stable angina. Arch Environ Health. 1998;53(6):388-397. [pmid: 9886157].
*. Klemm RJ, Lipfert FW, Wyzga RE, et al. Daily mortality and air pollution in Atlanta: Two years of data from ARIES. Inhal Toxicol. Suppl 1. 2004;16:131-141. [pmid: 15204801].
Koike A, Wasserman K, Armon Y, et al. The work-rate-dependent effect of carbon monoxide on ventilatory control during exercise. Respir Physiol. 1991;85(2):169-183. [pmid: 1947457].
Koken PJ, Piver WT, Ye F, et al. Temperature, air pollution, and hospitalization for cardiovascular diseases among elderly people in Denver. Environ Health Perspect. 2003;111(10):1312-1317. [pmid: 12896852].
Komori M, Nishio K, Kitada M, et al. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry. 1990;29(18):4430-4433. [pmid: 2350547].
*. Kontos AS, Fassols SD, Deli MF. Short-term effects of air pollution on childhood respiratory illness in Piraeus, Greece, 1987–1992: Nonparametric stochastic dynamic analysis. Environ Res. 1999;81:275-296. [pmid: 10581106].
Kreck TC, Shade ED, Lamm W, et al. Isocapnic hyperventilation increases carbon monoxide elimination and oxygen delivery. Am J Respir Crit Care Med. 2001;163:458-462. [pmid: 11179122].
Krishnan K, Andersen ME. Physiologically based pharmacokinetic modeling in toxicology. Hayes AW, editor. Principles and methods of toxicology. 3rd ed. New York, NY. Raven Press, Ltd. 1994:149-188.
Krishnan K, Anderson ME, Clewell HJ, et al. Physiologically based pharmacokinetic modeling of chemical mixtures. Yang RSH, editor. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA. Academic Press. 1994:399-437.
Ku HL, Yang KC, Lee YC, et al. Predictors of carbon monoxide poisoning-induced delayed neuropsychological sequelae. Gen Hosp Psychiatry. 2010;32(3):310-314. [pmid: 20430235].
Kuska J, Kokot F, Wnuk R. Acute renal failure after exposure to carbon monoxide. Mater Med Pol. 1980;12:236-238. [pmid: 7266048].
Kwak HM, Yang YH, Lee MS. Cytogenetic effects on mouse fetus of acute and chronic transplacental in vivo exposure to carbon monoxide: Induction of micronuclei and sister chromatid exchanges. Yonsei Med J. 1986;27(3):205-212. [pmid: 3798962].
*. Kwon HJ, Cho SH, Nyberg F, et al. Effects of ambient air pollution on daily mortality in a cohort of patients with congestive heart failure. Epidemiology. 2001;12:413-419. [pmid: 11416779].
Lagorio S, Forastiere F, Pistelli R, et al. Air pollution and lung function among susceptible adult subjects: A panel study. Environ Health. 2006;5:11-22. [pmid: 16674831].
Landaw SA. The effects of cigarette smoking on total body burden and excretion rates of carbon monoxide. J Occup Med. 1973;15(3):231-235. [pmid: 4693166].
Landaw SA, Callahan EW, Schmid R. Catabolism of heme in vivo: Comparison of the simultaneous production of bilirubin and carbon monoxide. J Clin Invest. 1970;49:914-925. [pmid: 5441545].
Langston P, Gorman D, Runciman W, et al. The effect of carbon monoxide on oxygen metabolism in the brains of awake sheep. Toxicology. 1996;114:223-232. [pmid: 8980711].
Lanki T, Pekkanen J, Aalto P, et al. Associations of traffic related air pollutants with hospitalisation for first acute myocardial infarction: The HEAPSS study. Occup Environ Med. 2006;63:844-851. [pmid: 16912091].
Lavonas EJ. Carbon monoxide poisoning. Haddad and Winchester's clinical management of poisoning and drug overdose. 4th ed. Philadelphia, PA. Saunders. 2007:1297-1307.
Law MR, Morris JK, Watt HC, et al. The dose-response relationship between cigarette consumption, biochemical markers and risk of lung cancer. Br J Cancer. 1997;75(11):1690-1693. [pmid: 9184188].
*. Leaf DA, Kleinman MT. Acute exposure to carbon monoxide does not affect plasma lipids, lipoproteins, and apolipoproteins. Angiology. 1996a;47(4):337-341. [pmid: 8619505].
Leaf DA, Kleinman MT. Urban ectopy in the mountains: Carbon monoxide exposure at high altitude. Arch Environ Health. 1996b;51(4):283-290. [pmid: 8757408].
Lee BE, Ha EH, Park HS, et al. Exposure to air pollution during different gestational phases contributes to risks of low birth weight. Hum Reprod. 2003a;18(3):638-643. [pmid: 12615838].
Lee BS, Heo JH, Kim YM, et al. Carbon monoxide mediates heme oxygenase-1 induction via Nrf2 activation in hepatoma cells. Biochem Biophys Res Commun. 2006;343:965-972. [pmid: 16574070].
Lee HU, Lee HJ, Park HY, et al. Effects of heme oxygenase system on the cyclooxygenase in the primary cultured hypothalamic cells. Arch Pharm Res. 2001;24:607-612. [pmid: 11794544].
*. Lee IM, Tsai SS, Chang CC, et al. Air pollution and hospital admissions for chronic obstructive pulmonary disease in a tropical city: Kaohsiung, Taiwan. Inhal Toxicol. 2007b;19(5):393-398. [pmid: 17365044].
Lee IM, Tsai SS, Ho CK, et al. Air pollution and hospital admissions for congestive heart failure in a tropical city: Kaohsiung, Taiwan. Inhal Toxicol. 2007a;19(10):899-904. [pmid: 17687721].
Lee JT, Kim H, Cho YS, et al. Air pollution and hospital admissions for ischemic heart diseases among individuals 64+ years of age residing in Seoul, Korea. Arch Environ Health. 2003b;58(10):617-623. [pmid: 15562633].
*. Lee JT, Kim H, Song H, et al. Air pollution and asthma among children in Seoul, Korea. Epidemiology. 2002;13(4):481-484. [pmid: 12094105].
*. Lee JT, Son JY, Cho YS. A comparison of mortality related to urban air particles between periods with Asian dust days and without Asian dust days in Seoul, Korea, 2000–2004. Environ Res. 2007c;105:409-413. [pmid: 17659273].
*. Lee YL, Shaw CK, Su HJ, et al. Climate, traffic-related air pollutants and allergic rhinitis prevalence in middle-school children in Taiwan. Eur Respir J. 2003c;21(6):964-970. [pmid: 12797489].
Leeder JS, Kearns GL. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am. 1997;44(1):55-77. [pmid: 9057784].
Leem JH, Kaplan BM, Shim YK, et al. Exposures to air pollutants during pregnancy and preterm delivery. Environ Health Perspect. 2006;114(6):905-910. [pmid: 16759993].
Leikin JB. Carbon monoxide detectors and emergency physicians. J Emerg Med. 1996;14(1):90-94.
Leikin JB, Vogel S. Carbon monoxide levels in cardiac patients in an urban emergency department. Am J Emerg Med. 1986;4:126-128. [pmid: 3947439].
Leikin JB, Wills BK. Long-term psychiatric consequences from carbon monoxide exposure: Progression of endogenous cause or toxicant effect?. Crit Care Med. 2009;37(6):2116-2118. [pmid: 19448463].
Leikin JB, Kaufman D, Lipscomb JW, et al. Methylene chloride: Report of five exposures and two deaths. Am J Emerg Med. 1990;8:534-537. [pmid: 2222600].
Leung H. Physiologically-based pharmacokinetic modeling. Ballantyne B, Marrs T, Turner P, editors. General and applied toxicology. New York, NY. Stockton Press. 1993;Vol. 1:153-164.
Levasseur L, Galliot-Guilley M, Richter F, et al. Effects of mode of inhalation of carbon monoxide and of normobaric oxygen administration on carbon monoxide elimination from the blood. Hum Exp Toxicol. 1996;15(11):898-903. [pmid: 8938485].
Levy D, Sheppard L, Checkoway H, et al. A case-crossover analysis of particulate matter air pollution and out-of-hospital primary cardiac arrest. Epidemiology. 2001;12(2):193-199. [pmid: 11246580].
Lewis RJ. Hawley's condensed chemical dictionary. 15th ed. Hoboken, NJ. John Wiley & Sons, Inc. 2007:235.
Liao D, Duan Y, Whitsel EA, et al. Association of higher levels of ambient criteria pollutants with impaired cardiac autonomic control: A population-based study. Am J Epidemiol. 2004;159(8):768-777. [pmid: 15051586].
Liao D, Heiss G, Chinchilli VM, et al. Association of criteria pollutants with plasma hemostatic/inflammatory markers: A population-based study. J Expo Anal Environ Epidemiol. 2005;15(4):319-328. [pmid: 15536489].
Lide DR, editor. CRC handbook of chemistry and physics. 88th ed. New York, NY. CRC Press. 2008:4-56.
Light A, Grass C, Pursley D, et al. Carboxyhemoglobin levels in smokers vs. non-smokers in a smoking environment. 2007 Open forum abstracts. American Association for Respiratory Care’s International Respiratory Congress. 2007. Daedalus Enterprises. http://www.rcjournal.com/abstracts/2007/?id=aarc07_111. May 8, 2009.
*. Lin CA, Martins MA, Farhat SC, et al. Air pollution and respiratory illness of children in Sao Paulo, Brazil. Paediatr Perinat Epidemiol. 1999;13(4):475-488. [pmid: 10563367].
Lin CA, Pereira LA, Nishioka DC, et al. Air pollution and neonatal deaths in Sao Paulo, Brazil. Braz J Med Biol Res. 2004a;37(5):765-770. [pmid: 15107940].
Lin CM, Li CY, Yang GY, et al. Association between maternal exposure to elevated ambient sulfur dioxide during pregnancy and term low birth weight. Environ Res. 2004b;96(1):41-50. [pmid: 15261783].
Lin M, Chen Y, Burnett RT, et al. Effect of short-term exposure to gaseous pollution on asthma hospitalisation in children: A bi-directional case-crossover analysis. J Epidemiol Community Health. 2003;57:50-55. [pmid: 12490649].
*. Lin M, Chen Y, Villeneuve PJ, et al. Gaseous air pollutants and asthma hospitalization of children with low household income in Vancouver, British Columbia, Canada. Am J Epidemiol. 2004c;159(3):294-303. [pmid: 14742290].
Lin M, Stieb DM, Chen Y. Coarse particulate matter and hospitalization for respiratory infections in children younger than 15 years in Toronto: A case-crossover analysis. Pediatrics. 2005;116(2):e235-e240. [pmid: 16061576].
Linderholm H, Lundstrom P. Endogenous carbon monoxide production and blood loss at delivery. Acta Obstet Gynecol Scand. 1969;48:362-370. [pmid: 5370776].
Linn WS, Szlachcic Y, Gong H, et al. Air pollution and daily hospital admissions in metropolitan Los Angeles. Environ Health Perspect. 2000;108(5):427-434. [pmid: 10811569].
Lipfert FW, Morris SC. Temporal and spatial relations between age specific mortality and ambient air quality in the United States: Regression results for counties, 1960–97. Occup Environ Med. 2002;59(3):156-174. [pmid: 11886947].
Lipfert FW, Baty JD, Miller JP, et al. PM_2.5_ constituents and related air quality variables as predictors of survival in a cohort of U.S. military veterans. Inhal Toxicol. 2006b;18(9):645-657. [pmid: 16864555].
Lipfert FW, Morris SC, Wyzga RE. Daily mortality in the Philadelphia metropolitan area and size-classified particulate matter. J Air Waste Manag Assoc. 2000;50(8):1501-1513. [pmid: 11002610].
Lipfert FW, Wyzga RE, Baty JD, et al. Traffic density as a surrogate measure of environmental exposures in studies of air pollution health effects: Long-term mortality in a cohort of US veterans. Atmos Environ. 2006a;40:154-169.
*. Lippmann M, Ito K, Nadas A, et al. Association of particulate matter components with daily mortality and morbidity in urban populations. Res Rep Health Eff Inst. 2000;(95):5-72. discussion 73-82. [pmid: 11246487].
Liss PS, Slater PG. Flux of gases across the air-sea interface. Nature. 1974;247:181-184.
Liu S, Krewski D, Shi Y, et al. Association between gaseous ambient air pollutants and adverse pregnancy outcomes in Vancouver, Canada. Environ Health Perspect. 2003;111(14):1773-1778. [pmid: 14594630].
Liu S, Krewski D, Shi Y, et al. Association between maternal exposure to ambient air pollutants during pregnancy and fetal growth restriction. J Expo Sci Environ Epidemiol. 2007;17(5):426-432. [pmid: 16736056].
Livingston AL. Forage plant estrogens. J Toxicol Environ Health. 1978;4(2–3):301-324. [pmid: 351201].
Lo CP, Chen SY, Lee KW, et al. Brain injury after acute carbon monoxide poisoning: Early and late complications. Am J Roentgenol. 2007;189(4):W205-W211. [pmid: 17885032].
Longo LD. The biological effects of carbon monoxide on the pregnant woman, fetus, and newborn infant. Am J Obstet Gynecol. 1977;129(1):69-103. [pmid: 561541].
Longo LD, Hill EP. Carbon monoxide uptake and elimination in fetal and maternal sheep. Am J Physiol Heart Circ Physiol. 1977;232:H324-H330.
Lopez I, Acuna D, Webber DS, et al. Mild carbon monoxide exposure diminishes selectively the integrity of the cochlea of the developing rat. J Neurosci Res. 2003;74(5):666-675. [pmid: 14635218].
Lopez IA, Acuna D, Beltran-Parrazal L, et al. Oxidative stress and the deleterious consequences to the rat cochlea after prenatal chronic mild exposure to carbon monoxide in air. Neuroscience. 2008;151(3):854-867. [pmid: 18155845].
Lopez IA, Acuna D, Beltran-Parrazal L, et al. Evidence for oxidative stress in the developing cerebellum of the rat after chronic mild carbon monoxide exposure (0.0025% in air). BMC neuroscience. 2009;10:53. http://www.biomedcentral.com/content/pdf/1471-2202-10-3.pdf. December 22, 2011.
Lopez IA, Acuna D, Shahram Y, et al. Neuroglobin expression in the cochlea of rat pups exposed to chronic very mild carbon monoxide (25ppm) in air during and after the prenatal period. Brain Res. 2010;1327:56-68. [pmid: 20211612].
Lou BS, Snyder JK, Marshall P, et al. Resonance Raman studies indicate a unique heme active site in prostaglandin H synthase. Biochemistry. 2000;39:12424-12434. [pmid: 11015223].
*. Luginaah IN, Fung KY, Gorey KM, et al. Association of ambient air pollution with respiratory hospitalization in a government-designated "area of concern": The case of Windsor, Ontario. Environ Health Perspect. 2005;113(3):290-296. [pmid: 15743717].
Lundquist P, Lennart R, Sorbo B. The role of hydrogen cyanide and carbon monoxide in fire casualties: A prospective study. Forensic Sci Int. 1989;43:9-14. [pmid: 2556335].
Luomanmäki K, Coburn RF. Effects of metabolism and distribution of carbon monoxide on blood and body stores. Am J Physiol. 1969;217(2):354-363. [pmid: 5799358].
Mactutus CF, Fechter LD. Moderate prenatal carbon monoxide exposure produces persistent, and apparently permanent, memory deficits in rats. Teratology. 1985;31(1):1-12. [pmid: 4039076].
*. Maheswaran R, Haining RP, Brindley P, et al. Outdoor air pollution, mortality, and hospital admissions from coronary heart disease in Sheffield, UK: A small-area level ecological study. Eur Heart J. 2005a;26(23):2543-2549. [pmid: 16166102].
Maheswaran R, Haining RP, Brindley P, et al. Outdoor air pollution and stroke in Sheffield, United Kingdom: A small-area level geographical study. Stroke. 2005b;36(2):239-243. [pmid: 15604422].
Mahoney AM, Stimpson CL, Scott KL, et al. Noninvasive measurement of carboxyhemoglobin levels for adjustment of diffusion capacity measured during pulmonary function testing. Respir Care. 2007;52(12):1741-1743. [pmid: 18028565].
Mahoney JJ, Vreman HJ, Stevenson DK, et al. Measurement of carboxyhemoglobin and total hemoglobin by five specialized spectrophotometers (CO-oximeters) in comparison with reference methods. Clin Chem. 1993;39(8):1693-1700. [pmid: 8353959].
Maisonet M, Bush TJ, Correa A, et al. Relation between ambient air pollution and low birth weight in the Northeastern United States. Environ Health Perspect. Suppl 3. 2001;109:351-356. [pmid: 11427384].
Mancuso C, Navarra P, Preziosi P. Roles of nitric oxide, carbon monoxide, and hydrogen sulfide in the regulation of the hypothalamic-pituitary-adrenal axis. J Neurochem. 2010;113(3):563-575. [pmid: 20089135].
Mancuso C, Preziosi P, Grossman AB, et al. The role of carbon monoxide in the regulation of neuroendocrine function. Neuroimmunomodulation. 1997;4:225-229. [pmid: 9650814].
Mann JK, Tager IB, Lurmann F, et al. Air pollution and hospital admissions for ischemic heart disease in persons with congestive heart failure or arrhythmia. Environ Health Perspect. 2002;110(12):1247-1252. [pmid: 12460805].
Mannes T, Jalaludin B, Morgan G, et al. Impact of ambient air pollution on birth weight in Sydney, Australia. Occup Environ Med. 2005;62(8):524-530. [pmid: 16046604].
*. Mar TF, Norris GA, Koenig JQ, et al. Associations between air pollution and mortality in Phoenix, 1995–1997. Environ Health Perspect. 2000;108(4):347-353. [pmid: 10753094].
Margulies JL. Acute carbon monoxide poisoning during pregnancy. Am J Emerg Med. 1986;4:516-519. [pmid: 3778597].
*. Martins LC, Latorre Mdo R, Saldiva PH, et al. Air pollution and emergency room visits due to chronic lower respiratory diseases in the elderly: An ecological time-series study in Sao Paulo, Brazil. J Occup Environ Med. 2002;44(7):622-627. [pmid: 12134525].
*. Masjedi MR, Jamaati HR, Dokouhaki P, et al. The effects of air pollution on acute respiratory conditions. Respirology. 2003;8(2):213-230. [pmid: 12753539].
Materna BL, Jones JR, Sutton PM, et al. Occupational exposures in California wildland fire fighting. Am Ind Hyg Assoc J. 1992;53(1):69-76. [pmid: 1317093].
Maulik N, Engelman DT, Watanabe M, et al. Nitric oxide - a retrograde messenger for carbon monoxide signaling in ischemic heart. Mol Cell Biochem. 1996;157:75-86. [pmid: 8739231].
Mayr U, Butsch A, Schneider S. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology. 1992;74(2–3):135-149. [pmid: 1387742].
McCartney ML. Sensitivity analysis applied to Coburn-Forster-Kane models of carboxyhemoglobin formation. Am Ind Hyg Assoc J. 1990;51(3):169-177. [pmid: 2327328].
*. McGowan JA, Hider RN, Chacko E, et al. Particulate air pollution and hospital admissions in Christchurch, New Zealand. Aust N Z J Public Health. 2002;26:23-29. [pmid: 11895020].
McGrath JJ, Schreck RM, Lee PS. Carboxyhemoglobin levels in humans: Effects of altitude. Inhal Toxicol. 1993;5:241-249.
McGregor HP, Westcott K, Walker DW. The effect of prenatal exposure to carbon monoxide on breathing and growth of the newborn guinea pig. Pediatr Res. 1998;43(1):126-131. [pmid: 9432123].
Medeiros A, Gouveia N. Relationship between low birthweight and air pollution in the city of Sao Paulo, Brazil. Rev Saude Publica. 2005;39(6):965-972. [pmid: 16341408].
*. Meng YY, Wilhelm M, Rull RP, et al. Traffic and outdoor air pollution levels near residences and poorly controlled asthma in adults. Ann Allergy Asthma Immunol. 2007;98(5):455-463. [pmid: 17521030].
Mercke C, Lundh B. Erythrocyte filterability and heme catabolism during the menstrual cycle. Ann Intern Med. 1976;85:322-324. [pmid: 962222].
Metzger KB, Klein M, Flanders WD, et al. Ambient air pollution and cardiac arrhythmias in patients with implantable defibrillators. Epidemiology. 2007;18(5):585-592. [pmid: 17700247].
Metzger KB, Tolbert PE, Klein M, et al. Ambient air pollution and cardiovascular emergency department visits. Epidemiology. 2004;15(1):46-56. [pmid: 14712146].
Meyer G, Boissiere J, Tanguy S, et al. Carbon Monoxide Pollution Impairs Myocardial Perfusion Reserve: Implication of Coronary Endothelial Dysfunction. Cardiovasc Toxicol. 2011;11(4):334-340. [pmid: 21792669].
Meyer J, Prien T, Van Aken H, et al. Arterio-venous carboxyhemoglobin difference suggests carbon monoxide production by human lungs. Biochem Biophys Res Commun. 1998;244(1):230-232. [pmid: 9514911].
*. Migliaretti G, Dalmasso P, Gregori D. Air pollution effects on the respiratory health of the resident adult population in Turin, Italy. Int J Environ Health Res. 2007;17(5):369-379. [pmid: 17924265].
Miller KA, Siscovick DS, Sheppard L, et al. Long-term exposure to air pollution and incidence of cardiovascular events in women. N Engl J Med. 2007;356(5):447-458. [pmid: 17267905].
Miller SM, Matross DM, Miller ADB, et al. Sources of carbon monoxide and formaldehyde in North America determined from high-resolution atmospheric data. Atmos Chem Phys. 2008;8:7673-7696.
Mishra S, Fujita T, Lama VN, et al. Carbon monoxide rescues ischemic lungs by interrupting MAPK-driven expression of early growth response 1 gene and its downstream target genes. Proc Natl Acad Sci. 2006;103(13):5191-5196. [pmid: 16551742].
Moir D, Rickert WS, Levasseur G, et al. A comparison of mainstream and sidestream marijuana and tobacco cigarette smoke produced under two machine smoking conditions. Chem Res Toxicol. 2008;21(2):494-502. [pmid: 18062674].
Moller P, Sylven C. Myoglobin in human skeletal muscle. Scand J Clin Lab Invest. 1981;41(5):479-482. [pmid: 7313529].
Moolgavkar SH. Air pollution and daily mortality in three U.S. counties. Environ Health Perspect. 2000a;108(8):777-784. [pmid: 10964799].
*. Moolgavkar SH. Air pollution and hospital admissions for chronic obstructive pulmonary disease in three metropolitan areas in the United States. Inhal Toxicol. Suppl 4. 2000b;12:75-90. [pmid: 12881887].
*. Moolgavkar SH. Air pollution and daily mortality in two U.S. counties: Season-specific analyses and exposure-response relationships. Inhal Toxicol. 2003;15(9):877-907. [pmid: 12872178].
Moore SJ, Norris JC, Walsh DA, et al. Antidotal use of methemoglobin forming cyanide antagonists in concurrent carbon monoxide/cyanide intoxication. J Pharmacol Exp Ther. 1987;242(1):70-73. [pmid: 2886639].
Morello-Frosch R, Jesdale BM, Sadd JL, et al. Ambient air pollution exposure and full-term birth weight in California. Environ Health. 2010;9:44. http://www.ehjournal.net/content/pdf/1476-069X-9-44.pdf. February 14, 2012. [pmid: 20667084].
Morse CI, Pritchard LJ, Wust RC, et al. Carbon monoxide inhalation reduces skeletal muscle fatigue resistance. Acta Physiol (Oxf). 2008;192(3):397-401. [pmid: 17970829].
Morselli PL, Franco-Morselli R, Bossi L. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokinet. 1980;5(6):485-527. [pmid: 7002417].
Mortazavi S, Kashani MM, Khavanin A, et al. Effects of N-acetylcysteine on auditory brainstem response threshold shift in rabbits exposed to noise and carbon monoxide. Am J Appl Sci. 2010;7(2):201-207.
Mortimer K, Neugebauer R, Lurmann F, et al. Air pollution and pulmonary function in asthmatic children: Effects of prenatal and lifetime exposures. Epidemiology. 2008;19(4):550-557. [pmid: 18520616].
Myers RA, Snyder SK, Majerus TC. Cutaneous blisters and carbon monoxide poisoning. Ann Emerg Med. 1985;14(6):603-606. [pmid: 3994090].
Nakao A, Kaczorowski DJ, Sugimoto R, et al. Application of heme oxygenase-1, carbon monoxide and biliverdin for the prevention of intestinal ischemia/reperfusion injury. J Clin Biochem Nutr. 2008;42(2):78-88. [pmid: 18385824].
Nakayama M, Takahashi K, Kitamuro T, et al. Repression of heme oxygenase-1 by hypoxia in vascular endothelial cells. Biochem Biophys Res Commun. 2000;271:665-671. [pmid: 10814519].
NAS/NRC. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC. National Academy of Sciences, National Research Council, National Academy Press. 1989:15-35.
*. Neidell MJ. Air pollution, health, and socio-economic status: The effect of outdoor air quality on childhood asthma. J Health Econ. 2004;23(6):1209-1236. [pmid: 15556243].
Niden AH. The effects of low levels of carbon monoxide on the fine structure of the terminal airways. Am Rev Respir Dis. 1971;103:898.
NIOSH. Preventing carbon monoxide poisoning from small gasoline-powered engines and tools. National Institute for Occupational Safety and Health. 1996:96-118a. http://www.cdc.gov/niosh/docs/96-118a/. May 24, 2012.
NIOSH. Carbon monoxide. NIOSH pocket guide to chemical hazards. 2005. Atlanta, GA. National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/. May 19, 2009.
Norman CA, Halton DM. Is carbon monoxide a workplace teratogen? A review and evaluation of the literature. Ann Occup Hyg. 1990;34(4):335-347. [pmid: 2240988].
*. Norris G, YoungPong SN, Koenig JQ, et al. An association between fine particles and asthma emergency department visits for children in Seattle. Environ Health Perspect. 1999;107(6):489-493. [pmid: 10339450].
Norris JC, Moore SJ, Hume AS. Synergistic lethality induced by the combination of carbon monoxide and cyanide. Toxicology. 1986;40:121-129. [pmid: 3726889].
Novelli PC. CO in the atmosphere: Measurement techniques and related issues. Chemosphere Global Change Sci. 1999;1:115-126.
NRC. Medical and biologic effects of environmental pollutants. Carbon monoxide. 1977. Washington, DC. National Academy of Sciences. PB274965.
NRC. Pesticides in the diets of infants and children. 1993. Washington, DC. National Research Council. National Academy Press.
NTP. Toxicology and carcinogenesis studies of p-nitroaniline (CAS No. 100-01-6) in B6C3F1 mice (gavage studies). 1993. Research Triangle Park. National Toxicology Program. TR418.
NTP. Report on carcinogens. 2005. 11th edition. Research Triangle Park, NC. U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. May 11, 2009.
Ny L, Alm P, Ekstrom P, et al. Localization and activity of haem oxygenase and functional effects of carbon monoxide in the feline lower oesophageal sphincter. Br J Pharmacol. 1996;118:392-399. [pmid: 8735643].
Ohta K. Diurnal variations of carbon monoxide concentration in the equatorial pacific upwelling region. J Oceanogr. 1997;53:173-178.
Okeda R, Matsuo T, Kuroiwa T, et al. Regional cerebral blood flow of acute carbon monoxide poisoning in cats. Acta Neuropathol. 1987;72:389-393. [pmid: 3577693].
O'Neil MJ, Heckelman PE, Koch CB, et al. The Merck index. An encyclopedia of chemicals, drugs, and biologicals. 14th ed. Whitehouse Station, NJ. Merck & Co., Inc. 2006:294.
OSHA. Sampling and analytical methods: Carbon monoxide in workplace atmosphere, ID-210. 1991. Washington, DC. Occupational Safety & Health Administration. http://www.osha.gov/dts/sltc/methods/inorganic/id210/id210.html. May 11, 2009.
OSHA. Occupational safety and health guideline for carbon monoxide. 2000. Washington, DC. Occupational Safety & Health Administration. http://www.osha.gov/SLTC/healthguidelines/carbonmonoxide/recognition.html. May 11, 2009.
OSHA. Toxic and Hazardous Substances. Occupational safety and health standards. 2009. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000, Table Z-1. http://www.osha.gov/comp-links.html. May 19, 2009.
*. Ostro BD, Hurley S, Lipsett MJ. Air pollution and daily mortality in the Coachella Valley, California: A study of PM10 dominated by coarse particles. Environ Res. 1999;81(3):231-238. [pmid: 10585019].
Owen GM, Brozek J. Influence of age, sex and nutrition on body composition during childhood and adolescence. Falkner F, editor. Human development. Philadelphia, PA. WB Saunders. 1966:222-238.
*. Park H, Lee B, Ha EH, et al. Association of air pollution with school absenteeism due to illness. Arch Pediatr Adolesc Med. 2002;156(12):1235-1239. [pmid: 12444836].
Park JW, Lim YH, Kyung SY, et al. Effects of ambient particulate matter on peak expiratory flow rates and respiratory symptoms of asthmatics during Asian dust periods in Korea. Respirology. 2005a;10(4):470-476. [pmid: 16135170].
Park SK, O'Neill MS, Vokonas PS, et al. Effects of air pollution on heart rate variability: The VA normative aging study. Environ Health Perspect. 2005b;113(3):304-309. [pmid: 15743719].
Parker JD, Woodruff TJ, Basu R, et al. Air pollution and birth weight among term infants in California. Pediatrics. 2005;115(1):121-128. [pmid: 15629991].
Parkinson RB, Hopkins RO, Cleavinger HB, et al. White matter hyperintensities and neuropsychological outcome following carbon monoxide poisoning. Neurology. 2002;58(10):1525-1532. [pmid: 12034791].
Paulson OB, Parving HH, Olesen J, et al. Influence of carbon monoxide and of hemodilution on cerebral blood flow and blood gases in man. J Appl Physiol. 1973;35(1):111-116. [pmid: 4716144].
Peel JL, Metzger KB, Klein M, et al. Ambient air pollution and cardiovascular emergency department visits in potentially sensitive groups. Am J Epidemiol. 2007;165(6):625-633. [pmid: 17194748].
Peel JL, Tolbert PE, Klein M, et al. Ambient air pollution and respiratory emergency department visits. Epidemiology. 2005;16(2):164-174. [pmid: 15703530].
Peers C. Ion channels as target effectors for carbon monoxide. Exp Physiol. 2011;96(9):836-839. [pmid: 21551266].
Peers C, Steele DS. Carbon monoxide: A vital signalling molecule and potent toxin in the myocardium. J Mol Cell Cardiol. 2011;52(2):359-365. [pmid: 21640728].
Peers C, Dallas ML, Scragg JL. Ion channels as effectors in carbon monoxide signaling. Commun Integr Biol. 2009;2(3):241-242. [pmid: 19641743].
Pekkanen J, Brunner EJ, Anderson HR, et al. Daily concentrations of air pollution and plasma fibrinogen in London. Occup Environ Med. 2000;57(12):818-822. [pmid: 11077010].
Penney DG. Hemodynamic response to carbon monoxide. Environ Health Perspect. 1988;77:121-130. [pmid: 3289904].
Penney D, Benjamin M, Dunham E. Effect of carbon monoxide on cardiac weight as compared with altitude effects. J Appl Physiol. 1974a;37(1):80-84. [pmid: 4275771].
Penney D, Dunham E, Benjamin M. Chronic carbon monoxide exposure: Time course of hemoglobin, heart weight and lactate dehydrogenase isozyme changes. Toxicol Appl Pharmacol. 1974b;28:493-497. [pmid: 4851024].
Penney DG, Baylerian MS, Thill JE, et al. Postnatal carbon monoxide exposure: Immediate and lasting effects in the rat. Am J Physiol. 1982;243(2):H328-H339. [pmid: 6287856].
Penney DG, Baylerian MS, Thill JE, et al. Cardiac response of the fetal rat to carbon monoxide exposure. Am J Physiol. 1983;244(2):H289-H297. [pmid: 6824096].
Penney DG, Davidson SB, Gargulinski RB, et al. Heart and lung hypertrophy, changes in blood volume, hematocrit and plasma renin activity in rats chronically exposed to increasing carbon. J Appl Toxicol. 1988;8(3):171-178. [pmid: 2971710].
*. Penttinen P, Tiittanen P, Pekkanen J. Mortality and air pollution in metropolitan Helsinki, 1988–1996. Scand J Work Environ Health. Suppl 2. 2004;30:19-27. [pmid: 15487682].
Penttinen P, Timonen KL, Tiittanen P, et al. Ultrafine particles in urban air and respiratory health among adult asthmatics. Eur Respir J. 2001;17(3):428-435. [pmid: 11405521].
Perrella M, Di Cera E. CO ligation intermediates and the mechanism of hemoglobin cooperativity. J Biol Chem. 1999;274:2605-2608. [pmid: 9915786].
Peters A, Dockery DW, Muller JE, et al. Increased particulate air pollution and the triggering of myocardial infarction. Circulation. 2001;103(23):2810-2815. [pmid: 11401937].
Peters A, Liu E, Verrier RL, et al. Air pollution and incidence of cardiac arrhythmia. Epidemiology. 2000b;11:11-17. [pmid: 10615837].
Peters A, Perz S, Doring A, et al. Increases in heart rate during an air pollution episode. Am J Epidemiol. 1999;150(10):1094-1098. [pmid: 10568625].
Peters A, Skorkovsky J, Kotesovec F, et al. Associations between mortality and air pollution in central Europe. Environ Health Perspect. 2000a;108(4):283-287. [pmid: 10753084].
Peterson JE, Stewart RD. Absorption and elimination of carbon monoxide by inactive young men. Arch Environ Health. 1970;21(2):165-171. [pmid: 5430002].
Peterson JE, Stewart RD. Predicting the carboxyhemoglobin levels resulting from carbon monoxide exposures. J Appl Physiol. 1975;39(4):633-638. [pmid: 1194155].
Piantadosi CA. Biological chemistry of carbon monoxide. Antioxid Redox Signal. 2002;4:259-270. [pmid: 12006177].
Piantadosi CA, Zhang J, Demchenko IT. Production of hydroxyl radical in the hippocampus after CO hypoxia or hypoxic hypoxia in the rat. Free Radic Biol Med. 1997a;22(4):725-732. [pmid: 9013136].
Piantadosi CA, Zhang J, Levin ED, et al. Apoptosis and delayed neuronal damage after carbon monoxide poisoning in the rat. Exp Neurol. 1997b;147(1):103-114. [pmid: 9294407].
Pitt BR, Radford EP, Gurtner GH, et al. Interaction of carbon monoxide and cyanide on cerebral circulation and metabolism. Arch Environ Health. 1979;34:354-359.
Pope CA, Burnett RT, Thun MJ, et al. Lung cancer, cardiopulmonary mortality, and long-term exposure to fine particulate air pollution. JAMA. 2002;287(9):1132-1141. [pmid: 11879110].
Pope CA, Thun MJ, Namboodiri MM, et al. Particulate air pollution as a predictor of mortality in a prospective study of U.S. adults. Am J Respir Crit Care Med. 1995;151:669-674. [pmid: 7881654].
Pressman J, Warneck P. The stratosphere as a chemical sink for carbon monoxide. J Atmos Sci. 1970;27:155-163.
Prigge E, Hochrainer D. Effects of carbon monoxide inhalation on erythropoiesis and cardiac hypertrophy in fetal rats. Toxicol Appl Pharmacol. 1977;42(1):225-228. [pmid: 145041].
Rabinovitch N, Zhang L, Murphy JR, et al. Effects of wintertime ambient air pollutants on asthma exacerbations in urban minority children with moderate to severe disease. J Allergy Clin Immunol. 2004;114(5):1131-1137. [pmid: 15536421].
Radford EP, Drizd TA. Blood carbon monoxide levels in persons 3–74 years of age: United States, 1976–80. Adv Data. 1982;76:1-24. [pmid: 10257767].
*. Rainham DG, Smoyer-Tomic KE. The role of air pollution in the relationship between a heat stress index and human mortality in Toronto. Environ Res. 2003;93(1):9-19. [pmid: 12865043].
*. Ranzi A, Gambini M, Spattini A, et al. Air pollution and respiratory status in asthmatic children: Hints for a locally based preventive strategy. AIRE study. Eur J Epidemiol. 2004;19(6):567-576. [pmid: 15330130].
Rasmussen LS, Poulsen MG, Christiansen M, et al. Biochemical markers for brain damage after carbon monoxide poisoning. Acta Anaesthesiol Scand. 2004;48:469-473. [pmid: 15025610].
Raub JA, Benignus VA. Carbon monoxide and the nervous system. Neurosci Biobehav Rev. 2002;26(8):925-940. [pmid: 12667497].
Raub JA, Mathieu-Nolf M, Hampson NB, et al. Carbon monoxide poisoning--a public health perspective. Toxicology. 2000;145(1):1-14. [pmid: 10771127].
Ren X, Dorrington KL, Robbins PA. Respiratory control in humans after 8 h of lowered arterial PO2, hemodilution, or carboxyhemoglobinemia. J Appl Physiol. 2001;90(4):1189-1195. [pmid: 11247913].
Resch H, Zawinka C, Weigert G, et al. Inhaled carbon monoxide increases retinal and choroidal blood flow in healthy humans. Invest Ophthalmol Vis Sci. 2005;46(11):4275-4280. [pmid: 16249508].
Rhee JW, Leikin JB. Carbon monoxide detectors as preventive medicine. Penny DG, editor. Carbon monoxide poisoning. Boca Raton, FL. CRC Press. 2007:305-311.
Rich DQ, Kim MH, Turner JR, et al. Association of ventricular arrhythmias detected by implantable cardioverter defibrillator and ambient air pollutants in the St Louis, Missouri metropolitan area. Occup Environ Med. 2006a;63(9):591-596. [pmid: 16698809].
Rich DQ, Mittleman MA, Link MS, et al. Increased risk of paroxysmal atrial fibrillation episodes associated with acute increases in ambient air pollution. Environ Health Perspect. 2006b;114(1):120-123. [pmid: 16393668].
Rich DQ, Schwartz J, Mittleman MA, et al. Association of short-term ambient air pollution concentrations and ventricular arrhythmias. Am J Epidemiol. 2005;161(12):1123-1132. [pmid: 15937021].
Rich KE, Petkau J, Vedal S, et al. A case-crossover analysis of particulate air pollution and cardiac arrhythmia in patients with implantable cardioverter defibrillators. Inhal Toxicol. 2004;16(6–7):363-372. [pmid: 15204752].
Richardson RS, Noyszewski EA, Saltin B, et al. Effect of mild carboxy-hemoglobin on exercising skeletal muscle: Intravascular and intracellular evidence. Am J Physiol Regul Integr Comp Physiol. 2002;283:R1131-R1139. [pmid: 12376406].
Ringel SP, Klawans HL. Carbon monoxide-induced Parkinsonism. J Neurol Sci. 1972;16(3):245-251. [pmid: 5038884].
Riojas-Rodriguez H, Escamilla-Cejudo JA, Gonzalez-Hermosillo JA, et al. Personal PM2.5 and CO exposures and heart rate variability in subjects with known ischemic heart disease in Mexico City. J Expo Sci Environ Epidemiol. 2006;16(2):131-137. [pmid: 16175197].
Rissanen E, Paavilainen T, Virta J, et al. Carbon monoxide poisoning-induced nigrostriatal dopaminergic dysfunction detected using positron emission tomography (PET). Neurotoxicology. 2010;31(4):403-407. [pmid: 20346372].
Ritz B, Yu F. The effect of ambient carbon monoxide on low birth weight among children born in southern California between 1989 and 1993. Environ Health Perspect. 1999;107(1):17-25. [pmid: 9872713].
Ritz B, Wilhelm M, Hoggatt KJ, et al. Ambient air pollution and preterm birth in the environment and pregnancy outcomes study at the University of California, Los Angeles. Am J Epidemiol. 2007;166(9):1045-1052. [pmid: 17675655].
Ritz B, Wilhelm M, Zhao Y. Air pollution and infant death in southern California, 1989–2000. Pediatrics. 2006;118(2):493-502. [pmid: 16882800].
Ritz B, Yu F, Chapa G, et al. Effect of air pollution on preterm birth among children born in Southern California between 1989 and 1993. Epidemiology. 2000;11(5):502-511. [pmid: 10955401].
Ritz B, Yu F, Fruin S, et al. Ambient air pollution and risk of birth defects in Southern California. Am J Epidemiol. 2002;155(1):17-25. [pmid: 11772780].
Rodgers PA, Vreman HJ, Dennery PA, et al. Sources of carbon monoxide (CO) in biological systems and applications of CO detection technologies. Semin Perinatol. 1994;18(1):2-10. [pmid: 8209283].
Rodkey FL, Hill TA, Pitts LL, et al. Spectrophotometric measurement of carboxyhemoglobin and methemoglobin in blood. Clin Chem. 1979;25(8):1388-1393. [pmid: 455674].
Rodkey FL, O'Neal JD, Collison HA. Oxygen and carbon monoxide equilibria of human adult hemoglobin at atmospheric and elevated pressure. Blood. 1969;33(1):57-65. [pmid: 5763633].
Rodriguez C, Tonkin R, Heyworth J, et al. The relationship between outdoor air quality and respiratory symptoms in young children. Int J Environ Health Res. 2007;17(5):351-360. [pmid: 17924263].
*. Roemer WH, van Wijnen JH. Daily mortality and air pollution along busy streets in Amsterdam, 1987–1998. Epidemiology. 2001;12(6):649-653. [pmid: 11679792].
Rosenlund M, Berglind N, Pershagen G, et al. Long-term exposure to urban air pollution and myocardial infarction. Epidemiology. 2006;17(4):383-390. [pmid: 16699471].
Roughton FJ. The equilibrium of carbon monoxide with human hemoglobin in whole blood. Ann N Y Acad Sci. 1970;174(1):177-188. [pmid: 5289595].
Rucker J, Tesler J, Fedorko L, et al. Normocapnia improves cerebral oxygen delivery during conventional oxygen therapy in carbon monoxide-exposed research subjects. Ann Emerg Med. 2002;40(6):611-618. [pmid: 12447338].
Rückerl R, Greven S, Ljungman P, et al. Air pollution and inflammation (interleukin-6, C-reactive protein, fibrinogen) in myocardial infarction survivors. Environ Health Perspect. 2007;115(7):1072-1080. [pmid: 17637925].
Rückerl R, Ibald-Mulli A, Koenig W, et al. Air pollution and markers of inflammation and coagulation in patients with coronary heart disease. Am J Respir Crit Care Med. 2006;173:432-441. [pmid: 16293802].
Rudra CB, Williams MA, Sheppard L, et al. Ambient carbon monoxide and fine particulate matter in relation to preeclampsia and preterm delivery in western Washington State. Environ Health Perspect. 2011;119(6):886-892. [pmid: 21262595].
Ryter SW, Otterbein LE. Carbon monoxide in biology and medicine. BioEssays. 2004;26(3):270-280. [pmid: 14988928].
Ryter SW, Alam J, Choi AM. Heme oxygenase-1/carbon monoxide: From basic science to therapeutic applications. Physiol Rev. 2006;86(2):583-650. [pmid: 16601269].
Salam MT, Millstein J, Li YF, et al. Birth outcomes and prenatal exposure to ozone, carbon monoxide, and particulate matter results from the Children's Health Study. Environ Health Perspect. 2005;113(11):1638-1644. [pmid: 16263524].
Samet JM, Dominici F, Zeger SL, et al. The national morbidity, mortality and air pollution study. Part 1. Methods and methodologic issues. Res Rep Health Eff Inst. 2000;(94 Pt 1):5-14. discussion 75–84.
Samoli E, Touloumi G, Schwartz J, et al. Short-term effects of carbon monoxide on mortality: An analysis within the APHEA project. Environ Health Perspect. 2007;115(11):1578-1583. [pmid: 18007988].
Sanderson MG. Emission of carbon monoxide by vegetation and soils. Hadley Centre technical note 36, Met Office. 2002.
Sarnat SE, Suh HH, Coull BA, et al. Ambient particulate air pollution and cardiac arrhythmia in a panel of older adults in Steubenville, Ohio. Occup Environ Med. 2006;63:700-706. [pmid: 16757505].
Sartiani L, Cerbai E, Lonardo G, et al. Prenatal exposure to carbon monoxide affects postnatal cellular electrophysiological maturation of the rat heart: A potential substrate for arrhythmogenesis in infancy. Circulation. 2004;109:419-423. [pmid: 14718404].
Sartiani L, Stillitano F, Luceri C, et al. Prenatal exposure to carbon monoxide delays postnatal cardiac maturation. Lab Invest. 2010;90(11):1582-1593. [pmid: 20644522].
Satran D, Henry CR, Adkinson C, et al. Cardiovascular manifestations of moderate to severe carbon monoxide poisoning. J Am Coll Cardiol. 2005;45:1513-1516. [pmid: 15862427].
Sawai H, Kawada N, Yoshizato K, et al. Characterization of the heme environmental structure of cytoglobin, a fourth globin in humans. Biochemistry. 2003;42:5133-5142. [pmid: 12718557].
Schildcrout JS, Sheppard L, Lumley T, et al. Ambient air pollution and asthma exacerbations in children: An eight-city analysis. Am J Epidemiol. 2006;164(6):505-517. [pmid: 16798793].
Schwartz J, Litonjua A, Suh H, et al. Traffic related pollution and heart rate variability in a panel of elderly subjects. Thorax. 2005;60(6):455-461. [pmid: 15923244].
*. Schwartz J, Norris G, Larson T, et al. Episodes of high coarse particle concentrations are not associated with increased mortality. Environ Health Perspect. 1999;107(5):339-342. [pmid: 10210688].
Setchell BP, Waites GMH. The blood testis barrier. Creep RO, Astwood EB, Geiger SR, editors. Handbook of physiology: Endocrinology V. Washington, DC. American Physiological Society. 1975:143-172.
*. Sharovsky R, Cesar LAM, Ramires JAF. Temperature, air pollution, and mortality from myocardial infarction in Sao Paulo, Brazil. Braz J Med Biol Res. 2004;37:1651-1657. [pmid: 15517080].
*. Sheppard L, Levy D, Norris G, et al. Effects of ambient air pollution on nonelderly asthma hospital admissions in Seattle, Washington, 1987–1994. Epidemiology. 1999;10:23-30. [pmid: 9888276].
Sheps DS, Adams KF, Bromberg PA, et al. Lack of effect of low levels of carboxyhemoglobin on cardiovascular function in patients with ischemic heart disease. Arch Environ Health. 1987;42(2):108-116. [pmid: 3579364].
Sheps DS, Herbst MC, Hinderliter AL, et al. Production of arrhythmias by elevated carboxyhemoglobin in patients with coronary artery disease. Ann Intern Med. 1990;113:343-351. [pmid: 2382916].
Shibahara S, Nakayama M, Kitamuro T, et al. Repression of heme oxygenase-1 expression as a defense strategy in humans. Exp Biol Med. 2003;228:472-473.
Shimazu T, Ikeuchi H, Sugimoto H, et al. Half-life of blood carboxyhemoglobin after short-term and long-term exposure to carbon monoxide. J Trauma. 2000;49(1):126-131. [pmid: 10912868].
Shusterman D, Alexeeff G, Hargis C, et al. Predictors of carbon monoxide and hydrogen cyanide exposure in smoke inhalation patients. J Toxicol Clin Toxicol. 1996;34(1):61-71. [pmid: 8632515].
Silkoff PE, Zhang L, Dutton S, et al. Winter air pollution and disease parameters in advanced chronic obstructive pulmonary disease panels residing in Denver, Colorado. J Allergy Clin Immunol. 2005;115:337-344. [pmid: 15696092].
Silverman RK, Montano J. Hyperbaric oxygen treatment during pregnancy in acute carbon monoxide poisoning. A case report. J Reprod Med. 1997;42:309-311. [pmid: 9172124].
Silverman RA, Ito K, Freese J, et al. Association of ambient fine particles with out-of-hospital cardiac arrests in New York City. Am J Epidemiol. 2010;172(8):917-923. [pmid: 20729350].
Singh J. Early behavioral alterations in mice following prenatal carbon monoxide exposure. Neurotoxicology. 1986;7:475-481. [pmid: 3785762].
Singh J. Role of maternal protein and carbon monoxide pollution on global infant mortality - evidence from animal studies. Trends Reprod Biol. 2008;3:31-39.
*. Singh V, Khandelwal R, Gupta AB. Effect of air pollution on peak expiratory flow rate variability. J Asthma. 2003;40(1):81-86. [pmid: 12699215].
Sinha AK, Klein J, Schultze P, et al. Cerebral regional capillary perfusion and blood flow after carbon monoxide exposure. J Appl Physiol. 1991;71(4):1196-1200. [pmid: 1757341].
Slaughter JC, Kim E, Sheppard L, et al. Association between particulate matter and emergency room visits, hospital admissions and mortality in Spokane, Washington. J Expo Anal Environ Epidemiol. 2005;15(2):153-159. [pmid: 15187986].
Slaughter JC, Lumley T, Sheppard L, et al. Effects of ambient air pollution on symptom severity and medication use in children with asthma. Ann Allergy Asthma Immunol. 2003;91(4):346-353. [pmid: 14582813].
Smith MV. Comparing solutions to the linear and nonlinear CFK equations for predicting COHb formation. Math Biosci. 1990;99:251-263. [pmid: 2134522].
Smith MV, Hazucha MJ, Benignus VA, et al. Effect of regional circulation patterns on observed HbCO levels. J Appl Physiol. 1994;77(4):1659-1665. [pmid: 7836183].
Snella MC, Rylander R. Alteration in local and systemic immune capacity after exposure to bursts of CO. Environ Res. 1979;20(1):74-79. [pmid: 387409].
Snyder SH, Jaffrey SR, Zakhary R. Nitric oxide and carbon monoxide: Parallel roles as neural messengers. Brain Res Rev. 1998;26:167-175. [pmid: 9651518].
Soares MP, Seldon MP, Gregoire IP, et al. Heme oxygenase-1 modulates the expression of adhesion molecules associated with endothelial cell activation. J Immunol. 2004;172:3553-3563. [pmid: 15004156].
Solanki DL, McCurdy PR, Cuttitta FF, et al. Hemolysis in sickle cell disease as measured by endogenous carbon monoxide production. A preliminary report. Am J Clin Pathol. 1988;89(2):221-225. [pmid: 3341281].
Sørhaug S, Steinshamn S, Nilsen OG, et al. Chronic inhalation of carbon monoxide: Effects on the respiratory and cardiovascular system at doses corresponding to tobacco smoking. Toxicology. 2006;228(2–3):280-290. [pmid: 17056171].
SRI. 2008 Directory of chemical producers. Menlo Park, CA. SRI Consulting. 2008:482.
*. Steerenberg PA, Nierkens S, Fischer PH, et al. Traffic-related air pollution affects peak expiratory flow, exhaled nitric oxide, and inflammatory nasal markers. Arch Environ Health. 2001;56(2):167-174. [pmid: 11339681].
Steinvil A, Kordova-Biezuner L, Shapira I, et al. Short-term exposure to air pollution and inflammation-sensitive biomarkers. Environ Res. 2008;106(1):51-61. [pmid: 17915210].
Stevens JL, Ratnayake JH, Anders MW. Metabolism of dihalomethanes to carbon monoxide. Toxicol Appl Pharmacol. 1980;55:484-489. [pmid: 7434361].
Stewart RD, Peterson JE, Baretta ED, et al. Experimental human exposure to carbon monoxide. Arch Environ Health. 1970;21(2):154-164. [pmid: 5430001].
Stewart RD, Peterson JE, Fisher TN, et al. Experimental human exposure to high concentrations of carbon monoxide. Arch Environ Health. 1973;26(1):1-7. [pmid: 4682844].
Stieb DM, Evans GJ, Sabaliauskas K, et al. A scripted activity study of the impact of protective advice on personal exposure to ultra-fine and fine particulate matter and volatile organic compounds. J Expo Sci Environ Epidemiol. 2007;18:495-502. [pmid: 18059426].
Stieb DM, Judek S, Burnett RT. Meta-analysis of time-series studies of air pollution and mortality: Effects of gases and particles and the influence of cause of death, age, and season. J Air Waste Manag Assoc. 2002;52:470-484. [pmid: 12002192].
*. Stieb DM, Judek S, Burnett RT. Meta-analysis of time-series studies of air pollution and mortality: Update in relation to the use of generalized additive models. J Air Waste Manag Assoc. 2003;53(3):258-261. [pmid: 12661685].
Stockard-Sullivan JE, Korsak RA, Webber DS, et al. Mild carbon monoxide exposure and auditory function in the developing rat. J Neurosci Res. 2003;74(5):644-654. [pmid: 14635216].
*. Stolzel M, Breitner S, Cyrys J, et al. Daily mortality and particulate matter in different size classes in Erfurt, Germany. J Expo Sci Environ Epidemiol. 2006;17:458-467. [pmid: 17108895].
Stone JR, Marletta MA. Soluble guanylate cyclase from bovine lung: Activation with nitric oxide and carbon monoxide and spectral characterization of the ferrous and ferric states. Biochemistry. 1994;33(18):5636-5640. [pmid: 7910035].
Storm JE, Fechter LD. Alteration in the postnatal ontogeny of cerebellar norepinephrine content following chronic prenatal carbon monoxide. J Neurochem. 1985a;45(3):965-969. [pmid: 4031872].
Storm JE, Fechter LD. Prenatal carbon monoxide exposure differentially affects postnatal weight and monoamine concentration of rat brain regions. Toxicol Appl Pharmacol. 1985b;81(1):139-146. [pmid: 4049415].
Stupfel M, Bouley G. Physiological and biochemical effects on rats and mice exposed to small concentrations of carbon monoxide for long periods. Ann N Y Acad Sci. 1970;174(1):342-368. [pmid: 5289610].
Sullivan J, Ishikawa N, Sheppard L, et al. Exposure to ambient fine particulate matter and primary cardiac arrest among persons with and without clinically recognized heart disease. Am J Epidemiol. 2003;157(6):501-509. [pmid: 12631539].
*. Sun HL, Chou MC, Lue KH. The relationship of air pollution to ED visits for asthma differ between children and adults. Am J Emerg Med. 2006;24:709-713. [pmid: 16984840].
*. Sunyer J, Basagana X. Particles, and not gases, are associated with the risk of death in patients with chronic obstructive pulmonary disease. Int J Epidemiol. 2001;30(5):1138-1140. [pmid: 11689536].
*. Sunyer J, Basagana X, Belmonte J, et al. Effect of nitrogen dioxide and ozone on the risk of dying in patients with severe asthma. Thorax. 2002;57(8):687-693. [pmid: 12149528].
Symons JM, Wang L, Guallar E, et al. A case-crossover study of fine particulate matter air pollution and onset of congestive heart failure symptom exacerbation leading to hospitalization. Am J Epidemiol. 2006;164(5):421-433. [pmid: 16793862].
Szyszkowicz M. Air pollution and emergency department visits for ischemic heart disease in Montreal, Canada. Int J Occup Med Environ Health. 2007;20(2):167-174. [pmid: 17638683].
Taille C, El-Benna J, Lanone S, et al. Induction of heme oxygenase-1 inhibits NAD(P)H oxidase activity by down-regulating cytochrome b558 expression via the reduction of heme availability. J Biol Chem. 2004;279:28681-28688. [pmid: 15123630].
Takeuchi A, Vesely A, Rucker J, et al. A simple "new" method to accelerate clearance of carbon monoxide. Am J Respir Crit Care Med. 2000;161:1816-1819. [pmid: 10852750].
Tarkiainen TH, Timonen KL, Vanninen EJ, et al. Effect of acute carbon monoxide exposure on heart rate variability in patients with coronary artery disease. Clin Physiol Funct Imaging. 2003;23(2):98-102. [pmid: 12641604].
Tattoli M, Carratu MR, Cassano T, et al. Effects of early postnatal exposure to low concentrations of carbon monoxide on cognitive functions in rats. Pharmacol Res. 1999;40(3):271-274. [pmid: 10479472].
Tenías JM, Ballester F, Pérez-Hoyos S, et al. Air pollution and hospital emergency room admissions for chronic obstructive pulmonary disease in Valencia, Spain. Arch Environ Health. 2002;57(1):41-47. [pmid: 12071359].
Thom SR, Bhopale VM, Han ST, et al. Intravascular neutrophil activation due to carbon monoxide poisoning. Am J Respir Crit Care Med. 2006;174(11):1239-1248. [pmid: 16931637].
Thom SR, Fisher D, Xu YA, et al. Adaptive responses and apoptosis in endothelial cells exposed to carbon monoxide. Proc Natl Acad Sci USA. 2000;97(3):1305-1310. [pmid: 10655526].
Thom SR, Ohnishi ST, Ischiropoulos H. Nitric oxide released by platelets inhibits neutrophil B2 integrin function following acute carbon monoxide poisoning. Toxicol Appl Pharmacol. 1994;128(1):105-110. [pmid: 7521544].
Thom SR, Xu YA, Ischiropoulos H. Vascular endothelial cells generate peroxynitrite in response to carbon monoxide exposure. Chem Res Toxicol. 1997;10(9):1023-1031. [pmid: 9305585].
Thomas K, Colborn T. Organochlorine endocrine disruptors in human tissue. Colborn T, Clement C, editors. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ. Princeton Scientific Publishing. 1992:365-394.
Thompson AJ, Shields MD, Patterson CC. Acute asthma exacerbations and air pollutants in children living in Belfast, Northern Ireland. Arch Environ Health. 2001;56:234-241. [pmid: 11480499].
Thomsen HK. Carbon monoxide-induced atherosclerosis in primates. An electron-microscopic study on the coronary arteries of Macaca irus monkeys. Atherosclerosis. 1974;20(2):233-240. [pmid: 4412311].
Thorup C, Jones CL, Gross SS, et al. Carbon monoxide induces vasodilation and nitric oxide release but suppresses endothelial NOS. Am J Physiol. 1999;277(6 Pt 2):F882-F889. [pmid: 10600935].
Tikuisis P, Buick F, Kane DM. Percent carboxyhemoglobin in resting humans exposed repeatedly to 1,500 and 7,500 ppm CO. J Appl Physiol. 1987a;63(2):820-827. [pmid: 3654442].
Tikuisis P, Kane DM, McLellan TM, et al. Rate of formation of carboxyhemoglobin in exercising humans exposed to carbon monoxide. J Appl Physiol. 1992;72(4):1311-1319. [pmid: 1592720].
Tikuisis P, Madill HD, Gill BJ, et al. A critical analysis of the use of the CFK equation in predicting COHb formation. Am Ind Hyg Assoc J. 1987b;48(3):208-213. [pmid: 3578032].
Timonen KL, Pekkanen J, Tiittanen P, et al. Effects of air pollution on changes in lung function induced by exercise in children with chronic respiratory symptoms. Occup Environ Med. 2002;59(2):129-134. [pmid: 11850557].
Timonen KL, Vanninen E, de Hartog J, et al. Effects of ultrafine and fine particulate and gaseous air pollution on cardiac autonomic control in subjects with coronary artery disease: The ULTRA study. J Expo Sci Environ Epidemiol. 2006;16(4):332-341. [pmid: 16205787].
Tolbert PE, Klein M, Peel JL, et al. Multipollutant modeling issues in a study of ambient air quality and emergency department visits in Atlanta. J Expo Sci Environ Epidemiol. Suppl 2. 2007;17:S29-S35. [pmid: 18079762].
*. Tolcos M, Mallard C, McGregor H, et al. Exposure to prenatal carbon monoxide and postnatal hyperthermia: Short and long-term effects on neurochemicals and neuroglia in the developing brain. Exp Neurol. 2000a;162:235-246. [pmid: 10739630].
Tolcos M, McGregor H, Walker D, et al. Chronic prenatal exposure to carbon monoxide results in a reduction in tyrosine hydroxylase-immunoreactivity and an increase in choline acetyltransferase-immunoreactivity in the fetal medulla: Implications for Sudden Infant Death Syndrome. J Neuropathol Exp Neurol. 2000b;59(3):218-228. [pmid: 10744060].
Tolli JD, Sievert SM, Taylor CD. Unexpected diversity of bacteria capable of carbon monoxide oxidation in a coastal marine environment, and contribution of the roseobacter-associated clade to total CO oxidation. Appl Environ Microbiol. 2006;72(3):1966-1973. [pmid: 16517644].
Tomaszewski C. Carbon monoxide. Goldfrank's toxicologic emergencies. 8th ed. New York, NY. McGraw-Hill. 2006:1689-1704.
Torne R, Soyer HP, Leb G, et al. Skin lesions in carbon monoxide intoxication. Dermatologica. 1991;183:212-215. [pmid: 1743385].
*. Trapasso LM, Keith L. Relationships between selected meteorological/pollution parameters and hospital admissions for asthma in South Central Kentucky. J Ky Acad Sci. 1999;60:73-77.
Tsai S, Chen C, Hsieh H, et al. Air pollution and postneonatal mortality in a tropical city: Kaohsiung, Taiwan. Inhal Toxicol. 2006a;18:185-189. [pmid: 16399660].
*. Tsai SS, Cheng MH, Chiu HF, et al. Air pollution and hospital admissions for asthma in a tropical city: Kaohsiung, Taiwan. Inhal Toxicol. 2006b;18(8):549-554. [pmid: 16717026].
Tsai SS, Goggins WB, Chiu HF, et al. Evidence for an association between air pollution and daily stroke admissions in Kaohsiung, Taiwan. Stroke. 2003b;34(11):2612-2616. [pmid: 14551399].
Tsai SS, Huang CH, Goggins WB, et al. Relationship between air pollution and daily mortality in a tropical city: Kaohsiung, Taiwan. J Toxicol Environ Sci Health A. 2003a;66:1341-1349.
U.S. Army. Mammalian toxicity of munitions compounds. Phase III: Effects of lifetime exposure. Part I. 2,4-Dinitrotoluene. Final report no. 7. 1979. Fort Detrick, MD. U.S. Army and Medical Bioengineering Research Development Laboratory. ADA077692. http://www.dtic.mil/cgi-bin/GetTRDoc?Location=U2&doc=GetTRDoc.pdf&AD=ADA077692.
USCG. Boating safety circular 86. Boating and carbon monoxide poisoning a dangerous combination. 2008. U.S. Coast Guard. www.uscgboating.org/assets/pdf/recalls/BSC86.pdf. May 23, 2012.
*. Vedal S, Brauer M, White R, et al. Air pollution and daily mortality in a city with low levels of pollution. Environ Health Perspect. 2003;111(1):45-51. [pmid: 12515678].
Vedal S, Rich K, Brauer M, et al. Air pollution and cardiac arrhythmias in patients with implantable cardioverter defibrillators. Inhal Toxicol. 2004;16:353-362. [pmid: 15204751].
Verschueren K. Handbook of environmental data on organic chemicals. 4th ed. New York, NY. John Wiley & Sons, Inc. 2001:23-24.
Vesely AE, Somogyi RB, Sasano H, et al. The effects of carbon monoxide on respiratory chemoreflexes in humans. Environ Res. 2004;94:227-233. [pmid: 15016588].
Vieira I, Sonnier M, Cresteil T. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem. 1996;238(2):476-483. [pmid: 8681961].
*. Vigotti MA, Chiaverini F, Bagiola P, et al. Urban air pollution and emergency visits for respiratory complaints in Pisa, Italy. J Toxicol Environ Health A. 2007;70:266-269. [pmid: 17365588].
*. Villeneuve PJ, Burnett RT, Shi Y, et al. A time-series study of air pollution, socioeconomic status, and mortality in Vancouver, Canada. J Expo Anal Environ Epidemiol. 2003;13(6):427-435. [pmid: 14603343].
Villeneuve PJ, Chen L, Stieb D, et al. Associations between outdoor air pollution and emergency department visits for stroke in Edmonton, Canada. Eur J Epidemiol. 2006a;21:689-700. [pmid: 17048082].
*. Villeneuve PJ, Doiron M, Stieb D, et al. Is outdoor air pollution associated with physician visits for allergy rhinitis among the elderly in Toronto, Canada?. Allergy. 2006b;61:750-758. [pmid: 16677246].
Vogel JA, Gleser MA. Effect of carbon monoxide on oxygen transport during exercise. J Appl Physiol. 1972;32:234-239. [pmid: 4550276].
Volti GL, Vanella L, Gazzolo D, et al. Carbon monoxide: Vasoconstrictor or vasodilator? That's the question. American Journal of physiology. Renal Physiology. 2008;295:901-903.
von Klot S, Peters A, Aalto P, et al. Ambient air pollution is associated with increased risk of hospital cardiac readmissions of myocardial infarction survivors in five European cities. Circ J. 2005;112:3073-3079.
von Klot S, Wolke G, Tuch T, et al. Increased asthma medication use in association with ambient fine and ultrafine particles. Eur Respir J. 2002;20:691-702. [pmid: 12358349].
Vreman HJ, Kwong LK, Stevenson DK. Carbon monoxide in blood: An improved microliter blood-sample collection system, with rapid analysis by gas chromatography. Clin Chem. 1984;30(8):1382-1386. [pmid: 6744592].
Vreman HJ, Stevenson DK, Oh W, et al. Semiportable electrochemical instrument for determining carbon monoxide in breath. Clin Chem. 1994;40(10):1927-1933. [pmid: 7923774].
Vreman HJ, Wong RJ, Kadotani T, et al. Determination of carbon monoxide (CO) in rodent tissue: Effect of heme administration and environmental CO exposure. Anal Biochem. 2005;341:280-289. [pmid: 15907874].
Vreman HJ, Wong RJ, Stevenson DK, et al. Concentration of carbon monoxide (CO) in postmortem human tissues: Effect of environmental CO exposure. J Forensic Sci. 2006;51(5):1182-1190. [pmid: 17018107].
Wang R, Wu L. The chemical modification of KCa channels by carbon monoxide in vascular smooth muscle cells. J Biol Chem. 1997;272:8222-8226. [pmid: 9079640].
Wang R, Wang Z, Wu L. Carbon monoxide-induced vasorelaxation and the underlying mechanisms. Br J Pharmacol. 1997a;121(5):927-934. [pmid: 9222549].
Wang R, Wu L, Wang Z. The direct effect of carbon monoxide on KCa channels in vascular smooth muscle cells. Pflugers Arch. 1997b;434:285-291. [pmid: 9178628].
*. Wang T, Ko Y, Chao Y, et al. Association between indoor and outdoor air pollution and adolescent asthma from 1995 to 1996 in Taiwan. Environ Res. 1999;81:239-247. [pmid: 10585020].
Wang W, Li J, Chang Y, et al. Effects of immune reaction in rats after acute carbon monoxide poisoning. Undersea Hyperb Med. 2011;38(4):239-246. [pmid: 21877552].
Weaver LK. Clinical practice. Carbon monoxide poisoning. N Engl J Med. 2009;360(12):1217-1225. [pmid: 19297574].
Weaver LK, Howe S, Hopkins R, et al. Carboxyhemoglobin half-life in carbon monoxide-poisoned patients treated with 100% oxygen at atmospheric pressure. Chest. 2000;117(3):801-808. [pmid: 10713010].
Webber DS, Korsak RA, Sininger LK, et al. Mild carbon monoxide exposure impairs the developing auditory system of the rat. J Neurosci Res. 2003;74:655-665. [pmid: 14635217].
Wellenius GA, Bateson TF, Mittleman MA, et al. Particulate air pollution and the rate of hospitalization for congestive heart failure among Medicare beneficiaries in Pittsburgh, Pennsylvania. Am J Epidemiol. 2005a;161(11):1030-1036. [pmid: 15901623].
Wellenius GA, Schwartz J, Mittleman MA. Air pollution and hospital admissions for ischemic and hemorrhagic stroke among medicare beneficiaries. Stroke. 2005b;36:2549-2553. [pmid: 16254223].
Werner B, Lindahl J. Endogenous carbon monoxide production after bicycle exercise in healthy subjects and in patients with hereditary spherocytosis. Scand J Clin Lab Invest. 1980;40:314-324.
West JR, Smith HW, Chasis H. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr. 1948;32:10-18. [pmid: 18920567].
Wetherell HR. The occurrence of cyanide in the blood of fire victims. J Forensic Sci. 1966;11:167-173. [pmid: 5956236].
*. Wheeler A, Zanobetti A, Gold DR, et al. The relationship between ambient air pollution and heart rate variability differs for individuals with heart and pulmonary disease. Environ Health Perspect. 2006;114(4):560-566. [pmid: 16581546].
WHO. Environmental health criteria 213. Carbon monoxide. 1999. World Health Organization. http://www.inchem.org/documents/ehc/ehc/ehc213.htm. June 5, 2009.
WHO. Air quality guidelines. 2000. 2nd edition. Geneva, Switzerland. World Health Organization. http://www.euro.who.int/air/activities/20050223_4. May 11, 2009.
WHO. Guidelines for drinking-water quality. 2006. 3rd edition. Geneva, Switzerland. World Health Organization. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. May 11, 2009.
Widdowson EM, Dickerson JWT. Chemical composition of the body. Comar CL, Bronner F, editors. Mineral metabolism: An advance treatise. Volume II: The elements Part A. New York, NY. Academic Press. 1964:1-247.
Wijayanti N, Huber S, Samoylenko A, et al. Role of NF-κB and p38 MAP kinase signaling pathways in the lipopolysaccharide-dependent activation of heme oxygenase-1 gene expression. Antioxid Redox Signal. 2004;6:802-810. [pmid: 15345139].
Wilhelm M, Ritz B. Local variations in CO and particulate air pollution and adverse birth outcomes in Los Angeles County, California, USA. Environ Health Perspect. 2005;113(9):1212-1221. [pmid: 16140630].
Willis D, Tomlinson A, Frederick R, et al. Modulation of heme oxygenase activity in rat brain and spleen by inhibitors and donors of nitric oxide. Biochem Biophys Res Commun. 1995;214:1152-1156. [pmid: 7575523].
Wohlrab H, Ogunmola BG. Carbon monoxide binding studies of cytochrome α_3_ hemes in intact rat liver mitochondria. Biochemistry. 1971;10:1103-1106. [pmid: 4324202].
Wolf SJ, Lavonas EJ, Sloan EP, et al. Clinical policy: Critical issues in the management of adult patients presenting to the emergency department with acute carbon monoxide poisoning. Ann Emerg Med. 2008;51(2):138-152. [pmid: 18206551].
Wolff E. Carbon monoxide poisoning with severe myonecrosis and acute renal failure. Am J Emerg Med. 1994;12(3):347-349. [pmid: 8179748].
Woodruff TJ, Darrow LA, Parker JD. Air pollution and postneonatal infant mortality in the United States, 1999–2002. Environ Health Perspect. 2008;116(1):110-115. [pmid: 18197308].
Wu L, Wang R. Carbon monoxide: Endogenous production, physiological functions, and pharmacological applications. Pharmacol Rev. 2005;57(4):585-630. [pmid: 16382109].
*. Xirasagar S, Lin H, Liu T. Seasonality in pediatric asthma admissions: The role of climate and environmental factors. Eur J Pediatr. 2006;165:747-752. [pmid: 16718474].
Yang C, Chang C, Chuang H, et al. Relationship between air pollution and daily mortality in a subtropical city: Taipei, Taiwan. Environ Int. 2004a;30:519-523. [pmid: 15031011].
*. Yang CY, Chen CC, Chen CY, et al. Air pollution and hospital admissions for asthma in a subtropical city: Taipei, Taiwan. J Toxicol Environ Health A. 2007;70(2):111-117. [pmid: 17365571].
Yang CY, Chen YS, Yang CH, et al. Relationship between ambient air pollution and hospital admissions for cardiovascular diseases in Kaohsiung, Taiwan. J Toxicol Environ Health A. 2004b;67(6):483-493. [pmid: 14742094].
Yang CY, Hsieh HJ, Tsai SS, et al. Correlation between air pollution and postneonatal mortality in a subtropical city: Taipei, Taiwan. J Toxicol Environ Health Part A. 2006;69:2033-2040. [pmid: 17074743].
Yang Q, Chen Y, Krewski D, et al. Effect of short-term exposure to low levels of gaseous pollutants on chronic obstructive pulmonary disease hospitalizations. Environ Res. 2005;99:99-105. [pmid: 16053934].
Yang Q, Chen Y, Shi Y, et al. Association between ozone and respiratory admissions among children and the elderly in Vancouver, Canada. Inhal Toxicol. 2003;15:1297-1308. [pmid: 14569494].
Yarar C. Neurological effects of acute carbon monoxide (CO) poisoning in children. Journal of Pediatric Sciences. 2009;1:e2-e5. http://www.pediatricsciences.com/ojs/index.php?journal=jps&page=article&op=view&path%5B%5D=3&path%5B%5D=pdf_1. February 13, 2012.
Yasuda H, Sasaki T, Yamaya M, et al. Increased arteriovenous carboxyhemoglobin differences in patients with inflammatory pulmonary diseases. Chest. 2004;125(6):2160-2168. [pmid: 15189937].
Yaws CL, Hopper JR, Wang X, et al. Calculating solubility and Henry's law constants for gases in water. Chem Eng (NY). 1999;106(6):102-105.
Yildiz H, Aldemir E, Altuncu E, et al. A rare cause of perinatal asphyxia: Maternal carbon monoxide poisoning. Arch Gynecol Obstet. 2010;281(2):251-254. [pmid: 19504116].
Young LJ, Caughey WS. Oxygenation of carbon monoxide by bovine heart cytochrome c oxidase. Biochemistry. 1986;25(1):152-161. [pmid: 3006748].
Young JS, Upchurch MB, Kaufman MJ, et al. Carbon monoxide exposure potentiates high-frequency auditory threshold shifts induced by noise. Hear Res. 1987;26:37-43. [pmid: 3558142].
Yu O, Sheppard L, Lumley T, et al. Effects of ambient air pollution on symptoms of asthma in Seattle-area children enrolled in the CAMP study. Environ Health Perspect. 2000;108(12):1209-1214. [pmid: 11133403].
Zanobetti A, Schwartz J. Air pollution and emergency admissions in Boston, MA. J Epidemiol Community Health. 2006;60(10):890-895. [pmid: 16973538].
Zanobetti A, Canner MJ, Stone PH, et al. Ambient pollution and blood pressure in cardiac rehabilitation patients. Circulation. 2004b;110:2184-2189. [pmid: 15466639].
Zanobetti A, Wellenius GA, Zeka A, et al. The effect of particulate air pollution on the risk of myocardial infarction in elderly: A multi-city case-crossover analysis. Epidemiology. 2004a;15(4):S21.
Zebro T, Wright EA, Littleton RJ, et al. Bone changes in mice after prolonged continuous exposure to a high concentration of carbon monoxide. Exp Pathol. 1983;24:51-67. [pmid: 6685056].
Zevin S, Saunders S, Gourlay SG, et al. Cardiovascular effects of carbon monoxide and cigarette smoking. J Am Coll Cardiol. 2001;38(6):1633-1638. [pmid: 11704374].
Ziegler EE, Edwards BB, Jensen RL, et al. Absorption and retention of lead by infants. Pediatr Res. 1978;12(1):29-34. [pmid: 643372].
Zuckerbraun BS, Billiar TR, Otterbein SL, et al. Carbon monoxide protects against liver failure through nitric oxide-induced heme oxygenase 1. J Exp Med. 2003;198:1707-1716. [pmid: 14657222].
Zuckerbraun BS, Chin BY, Bilban M, et al. Carbon monoxide signals via inhibition of cytochrome c oxidase and generation of mitochondrial reactive oxygen species. FASEB J. 2007;21(4):1099-1106. [pmid: 17264172].