# CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

The chemical identity of carbon monoxide is shown in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Carbon monoxide is a highly poisonous, odorless, colorless, and tasteless gas. It is very flammable in air over a wide range of concentrations (George 2001) and burns in air with a bright blue flame (O’Neil et al. 2006). It becomes a liquid at 81.62 K (−191.53 °C) and is insoluble in water above 70 °C (George 2001). The physical and chemical properties of carbon monoxide are shown in Table 4-2.

Table 4-1 Chemical Identity of Carbon Monoxide

Characteristic | Carbon monoxide^a^
Synonym(s) | Carbon oxide, flue gas, monoxide
Registered trade name(s)
Chemical formula | CO^b^
Chemical structure | [image]
Identification numbers:
CAS registry | 630-08-0^b^
NIOSH RTECS | FG350000
EPA hazardous waste | No data
OHM/TADS | No data
DOT/UN/NA/IMDG shipping | 1016^c^; 9202^d,e^
HSDB | 903
NCI | No data

a All information obtained from HSDB 2009, except where noted.

b O’Neil 2006

c Compressed

d NIOSH 2005

e Cryogenic liquid

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2

Physical and Chemical Properties of Carbon Monoxide

Property | Carbon monoxide^a^
Molecular weight | 28.01
Color | Colorless
Physical state | Gas
Melting point | −205 °C
Boiling point | −191.5 °C
Density at 25 °C | 1.145 g/L at 25 °C and 1 atm^3^b
Odor | Odorless
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 20 °C | 2.3 mL/100 mL
Organic solvents | Appreciably soluble in ethyl acetate, chloroform, and acetic acid; freely absorbed by a concentrated solution of cuprous chloride in hydrochloric acid or ammonium hydroxide; solubility in methanol and ethanol about 7 times as great as in water; soluble in benzene
Partition coefficients:
Log K_ow_ | Not applicable
Log K_oc_ | Not applicable
Henry's law constant at 25 °C | 57,978.5 atm/mol fraction (~1.04 atm-m^3^/mole)^c^
Autoignition temperature | 605 °C^d^
Flashpoint | Flammable gas^d^
Flammability limits | Upper limit 74.2%; lower limit 12.5%^e^
Conversion factors | 1 ppm=1.16 mg/m^3^ at 20 °C and 1 atm
Explosive limits | No data

a All information obtained from HSDB 2009, except where noted.

c Yaws et al. 1999

b Lide 2008

d IPCS 2008

e George 2001