# 9 REFERENCES

ACGIH. 2014. 1-Bromopropane. CAS number: 106-94-5. In: Documentation of the threshold limit values and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
ACGIH. 2016. 1-Bromopropane. In: 2016 TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents & biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 15.
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
AIHA. 2014. Current ERPG values (2014). Fairfax, VA: American Industrial Hygiene Association. https://www.aiha.org/get-involved/AIHAGuidelineFoundation/EmergencyResponsePlanningGuidelines/Documents/2014%20ERPG%20Values.pdf. September 9, 2014.
Albemarle Corporation. 1997. A 13-week inhalation toxicity study of a vapor formulation of ALBTA1 in the albino rat. Document available in public docket EPA-HQ-OAR-2002-0064. Washington, DC: U.S. Environmental Protection Agency.
Alfa Aesar. 2014. MSDS. 1-Bromopropane. A10461. Alpha Aesar, A Johnson Matthey Company. http://www.alfa.com/en/GP100W.pgm?DSSTK=A10461. October 15, 2014.
Altman PL, Dittmer DS. 1974. Biology data book. 2nd ed. Bethesda, MD: Federation of American Societies of Experimental Biology.
Alwis KU, Blount BC, Britt AS, . 2012. Simultaneous analysis of 28 urinary VOC metabolites using ultra high performance liquid chromatography coupled with electrospray ionization tandem mass spectrometry (UPLC-ESI/MSMS). Anal Chim Acta 750:152–160.23062436
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, and replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87(2):185–205.3824380
Anderson SE, Munson AE, Butterworth LF, . 2010. Whole-body inhalation exposure to 1-bromopropane suppresses the IgM response to sheep red blood cells in female B6C3F1 mice and Fisher 344/N rats. Inhal Toxicol 22(2):125–132.20041805
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 2015. 1-Bromopropane. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention. http://www.atsdr.cdc.gov/SPL/resources. November 4, 2016.
Aylward LL, Kirman CR, Schoeny R, . 2013. Evaluation of biomonitoring data from the CDC National Exposure Report in a risk assessment context: Perspectives across chemicals. Environ Health Perspect 121(3):287–294.23232556
Banu S, Ichihara S, Huang F, . 2007. Reversibility of the adverse effects of 1-bromopropane exposure in rats. Toxicol Sci 100(2):504–512. 10.1093/toxsci/kfm245.17890766
Barber ED, Donish WH, Mueller KR. 1980. Quantitative measurement of the mutagenicity of volatile liquids in the Ames Salmonella/microsome assay. Environ Mutagen 2:307.
Barber ED, Donish WH, Mueller KR. 1981. A procedure for the quantitative measurement of the mutagenicity of volatile liquids in the Ames Salmonella typhimurium mammalian/microsome assay. Mutat Res 90(1):31–48.7029269
Barnsley EA, Grenby TH, Young L. 1966. Biochemical studies of toxic agents. The metabolism of 1- and 2-bromopropane in rats. Biochem J 100(1):282–288.5965256
Belkin S. 2002. Biodegradation of haloalkanes. Biodegradation 3:299–313.
Berger GS, ed. 1994. Epidemiology of endometriosis. In: Endometriosis: Modern surgical management of endometriosis. New York, NY: Springer-Verlag, 3–7.
B’Hymer C, Cheever KL. 2004. Development of a gas chromatographic test for the quantification of the biomarker 3-bromopropionic acid in human urine. J Chromatogr B Analyt Technol Biomed Life Sci 802(2):361–366.
B’Hymer C, Cheever KL. 2005. Development of a headspace gas chromatographic test for the quantification of 1- and 2-bromopropane in human urine. J Chromatogr B Analyt Technol Biomed Life Sci 814(1):185–189.
Bidleman TF. 1988. Atmospheric processes. Wet and dry deposition of organic compounds are controlled by their vapor-particle partitioning. Environ Sci Technol 22(4):361–367.
Blando JD, Schill DP, De La Cruz MP, . 2010. Preliminary study of propyl bromide exposure among New Jersey dry cleaners as a result of a pending ban on perchloroethylene. J Air Waste Manag Assoc 60(9):1049–1056.20863050
Boyle EB, Viet SM, Wright DJ, . 2016. Assessment of exposure to VOCs among pregnant women in the National Children’s Study. Int J Environ Res Public Health 13(4):376. 10.3390/ijerph13040376.27043585
Brown RP, Delp MD, Lindstedt SL, . 1997. Physiological parameter values for physiologically based pharmacokinetic models. Toxicol Ind Health 13(4):407–484.9249929
BSOC. 2001a. An inhalation two-generation reproductive toxicity study of 1-bromopropane in rats. Brominated Solvents Consortium (BSOC). EPA Office of Air and radiation. Study No. WIL-380001, Docket number: A-2001-07, OAR Box 1876, Document Number 93)11-D-10
BSOC. 2001b. A developmental toxicity study in rat via whole body inhalation exposure. Brominated Solvents Consortium (BSOC). EPA Office of Air and radiation. Study No. 98-4141, Docket number: A-2001-07, OAR Box 1882.
Burns TM, Taly A, O’Brien PC, . 2002. Clinical versus quantitative vibration assessment: Improving clinical performance. J Peripher Nerv Syst 7(2):112–117.12090297
CDC. 2005. Hematological and iron-related analytes- reference data for persons aged 1 year and over: United States, 1988-94. Vital and health statistics. Series 11, Number 247. Centers for Disease Control and Prevention. U.S. Department of Health and Human Services.
Chalupka S. 2014. Reducing workplace exposure to 1-bromopropane. Work Health Saf 62(3):128.
Cheever KL, Marlow KL, B’Hymer C, . 2009. Development of an HPLC-MS procedure for the quantification of N-acetyl-S-(n-propyl)-l-cysteine, the major urinary metabolite of 1-bromopropane in human urine. J Chromatogr B Analyt Technol Biomed Life Sci 877(8–9):827–832.
Chung MK, Yu WJ, Han SS. 2006. Lack of dominant lethality in mice following 1-bromopropane treatment. Reprod Toxicol 22(2):267.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Costa LG, Aschner M, Vitalone A, . 2004. Developmental neuropathology of environmental agents. Annu Rev Pharmacol Toxicol 44:87–110.14744240
Currance PL, Clements B, Bronstein AC. 2007. Halogenated aliphatic hydrocarbons and related compounds. In: Currance, PL, Clements B, Bronstein AC, eds. Emergency care for hazardous materials exposure. 3rd ed. St. Louis MO: Mosby Inc., 216–223.
DHHS. 2016. 1-Bromopropane. Household products database. U.S. Department of Health & Human Services, National Library of Medicine. https://householdproducts.nlm.nih.gov/. July 20, 2017.
DOE. 2012. Table 3: Protective action criteria (PAC) Rev 27 based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. February 2012. Oak Ridge, TN: U.S. Department of Energy and Subcommittee on Consequence Assessment and Protective Actions (SCAPA). http://www.atlintl.com/DOE/teels/teel/Table3.pdf. September 9, 2014.
Donaghy T, Shanahan I, Hande M, . 1993. Rate constants and atmospheric lifetimes for the reactions of OH radicals and C1 atoms with haloalkanes. Int J Chem Kinet 25:273–284.
ECHA. 2014. Environmental fate and pathways. Biodegradation in water: Screening tests. Exp key biodegradation in water: Screening tests.002. European Chemicals Agency. http://apps.echa.europa.eu/registered/data/dossiers/DISS-98761f97-d1cd-7396-e044-00144f67d031/AGGR-f65e4970-987a-4685-b5d3-574aec41e739_DISS-98761f97-d1cd-7396-e044-00144f67d031.html#AGGR-f65e4970-987a-4685-b5d3-574aec41e739. October 20, 2014.
Eckert E, Goen T. 2014. Rapid determination of four short-chain alkyl mercapturic acids in human urine by column-switching liquid chromatography-tandem mass spectrometry. J Chromatogr B Analyt Technol Biomed Life Sci 965:54–60.
Ek CJ, Dziegielewska KM, Habgood MD, . 2012. Barriers in the developing brain and neurotoxicology. Neurotoxicology 33(3):586–604.22198708
Elf Atochem S.A. 1993. Acute oral toxicity in rats: N-propyl bromide. Documents available in public docket EPA-HQ-OAR-2002-0064. Washington, DC: U.S. Environmental Protection Agency.
Elf Atochem S.A. 1995. Acute dermal toxicity in rats: N-propyl bromide. Documents available in public docket EPA-HQ-OAR-2002-0064. Washington, DC: U.S. Environmental Protection Agency.
Elf Atochem S.A. 1997. Study of acute toxicity on n-propyl bromide administered to rats by vapour inhalation. Determination of the 50% lethal concentration. Study No. 95122. Document ID Title OAR-2002-0064: Documents available in public dockets A-2001-07, OAR-2202-0064, and A-91-42. U.S. Environmental Protection Agency. Verneuill-en-Halatte, France: Laboratoire d’Etudes de Toxicologie Experimentale.
Emoto C, Murase S, Sawada Y, . 2003. In vitro inhibitory effect of 1-aminobenzotriazole on drug oxidations catalyzed by human cytochrome P450 enzymes: A comparison with SKF-525A and ketoconazole. Drug Metab Pharmacokinet 18(5):287–295.15618748
EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA600890066F.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics.
EPA. 1998a. Appendix A. Chemical substances subject to proposed or final TSCA rules or orders. Instructions for reporting for the 1998 partial updating of the TSCA chemical inventory data base. Washington, DC: U.S. Environmental Protection Agency, Office of Prevention Pesticides and Toxic Substances, A-1 to A-10. http://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=700004YF.txt. September 24, 2014.
EPA. 1998b. Notice of availability of draft RCRA waste minimization PBT chemical list. Fed Regist 63(216):60332–60343. U.S. Environmental Protection Agency. http://www.gpo.gov/fdsys/pkg/FR-1998-11-09/pdf/98-29952.pdf. September 10, 2014.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
EPA. 2006. List of lists. Consolidated list of chemicals subject to the Emergency Planning and Community Right-to-Know Act (EPCRA) and Section 112(r) of the Clean Air Act. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response. EPA550B01003. http://www.epa.gov/emergencies/docs/chem/title3_Oct_2006.pdf. September 24, 2014.
EPA. 2007a. Protection of stratospheric ozone: Listing of substitutes for ozone-depleting substances-n-propyl bromide in solvent cleaning. Fed Regist 72(103):30142–30167. U.S. Environmental Protection Agency. http://www.gpo.gov/fdsys/pkg/FR-2007-05-30/pdf/E7-9707.pdf. October 2, 2014.
EPA. 2007b. Protection of stratospheric ozone: Listing of substitutes for ozone-depleting substances-n-propyl bromide in adhesives, coatings, and aerosols. Fed Regist 72(103):30168–30207. U.S. Environmental Protection Agency. http://www.gpo.gov/fdsys/pkg/FR-2007-05-30/pdf/E7-9706.pdf. October 2, 2014.
EPA. 2007c. Q and A: 2007 final and proposed regulations for n-propyl bromide (nPB). U.S. Environmental Protection Agency. http://www.epa.gov/ozone/snap/solvents/2007nPBRegsQA.html. October 16, 2007.
EPA. 2009a. Drinking water contaminant candidate list 3-final. Fed Regist 74(194):51850–51862. U.S. Environmental Protection Agency. http://www.gpo.gov/fdsys/pkg/FR-2009-10-08/pdf/E9-24287.pdf. September 9, 2014.
EPA. 2009b. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F090004. http://water.epa.gov/drink/contaminants/upload/mcl-2.pdf. September 10, 2014.
EPA. 2012a. 2012 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822S12001. http://water.epa.gov/action/advisories/drinking/upload/dwstandards2012.pdf. September 9, 2014.
EPA. 2012b. Benchmark Dose Technical Guidance. Risk Assessment Forum. Washington, DC: U.S. Environmental Protection Agency. EPA100R12001, June 2012.
EPA. 2013a. AEGL chemical data. Final AEGLs (131). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/oppt/aegl/pubs/compiled_aegls_update_nov2013.pdf. September 9, 2014.
EPA. 2013b. List of substances. Table 1 to 68.130-List of regulated toxic substances and threshold quantities for accidental release prevention. Code of Federal Regulations. U.S. Environmental Protection Agency. 40 CFR 68.130, Subpart F. http://www.gpo.gov/fdsys/pkg/CFR-2013-title40-vol16/pdf/CFR-2013-title40-vol16-sec68-130.pdf. September 24, 2014.
EPA. 2013c. Designation of hazardous substances. Code of Federal Regulations. U.S. Environmental Protection Agency. 40 CFR 116.4, Subpart D. http://www.gpo.gov/fdsys/pkg/CFR-2013-title40-vol23/pdf/CFR-2013-title40-vol23-sec116-4.pdf. September 9, 2014.
EPA. 2013d. Determination of reportable quantities. Table 117.3. Reportable quantities of hazardous substances designated pursuant to section 311 of the Clean Water Act. Code of Federal Regulations. U.S. Environmental Protection Agency. 40 CFR 117.3, Subpart A. http://www.gpo.gov/fdsys/pkg/CFR-2013-title40-vol23/pdf/CFR-2013-title40-vol23-part117-subpartA.pdf. September 9, 2014.
EPA. 2013e. Identification and listing of hazardous waste. Appendix VIII to Part 261-Hazardous constituents. Code of Federal Regulations. U.S. Environmental Protection Agency. 40 CFR 261, Appendix VIII to Part 261. http://www.gpo.gov/fdsys/pkg/CFR-2013-title40-vol27/pdf/CFR-2013-title40-vol27-part261-appVIII.pdf. September 10, 2014.
EPA. 2013f. Groundwater monitoring list. Code of Federal Regulations. U.S. Environmental Protection Agency. 40 CFR 264, Appendix IX to Part 264. http://www.gpo.gov/fdsys/pkg/CFR-2013-title40-vol27/pdf/CFR-2013-title40-vol27-part264-appIX.pdf. September 10, 2014.
EPA. 2013g. Designation of hazardous substances. Table 302.4-List of hazardous substances and reportable quantities. Code of Federal Regulations. U.S. Environmental Protection Agency. 40 CFR 302.4. http://www.gpo.gov/fdsys/pkg/CFR-2013-title40-vol29/pdf/CFR-2013-title40-vol29-sec302-4.pdf. September 10, 2014.
EPA. 2013h. Chemicals and chemical categories to which this part applies. Code of Federal Regulations. U.S. Environmental Protection Agency. 40 CFR 372.65, Subpart D. http://www.gpo.gov/fdsys/pkg/CFR-2013-title40-vol29/pdf/CFR-2013-title40-vol29-part372.pdf. September 10, 2014.
EPA. 2013i. The list of extremely hazardous substances and their threshold planning quantities. Code of Federal Regulations. U.S. Environmental Protection Agency. 40 CFR 355, Appendix A to Part 355. http://www.gpo.gov/fdsys/pkg/CFR-2013-title40-vol29/pdf/CFR-2013-title40-vol29-part355-appA.pdf. September 10, 2014.
EPA. 2014a. The Clean Air Act amendments of 1990 list of hazardous air pollutants. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/ttn/atw/orig189.html. September 9, 2014.
EPA. 2014b. National ambient air quality standards (NAAQS). Washington, DC: U.S. Environmental Protection Agency, Office of Air and Radiation. http://www.epa.gov/air/criteria.html. January 08, 2014.
EPA. 2014c. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. http://water.epa.gov/scitech/swguidance/standards/criteria/current/index.cfm. January 08, 2014.
EPA. 2014d. Master testing list. Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/opptintr/chemtest/pubs/index1.pdf. September 10, 2014.
EPA. 2014e. Peer review plan for OPPT work plan risk assessment of 1-bromopropane (“1-BP”). Assessing and managing chemicals under TSCA. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/peer-review-plan-oppt-work-plan-risk-assessment-1. July 20, 2017.
EPA. 2015. Addition of 1-bromopropane; community right-to-know toxic chemical release reporting. Federal Register. U.S. Environmental Protection Agency. Fed Regist 80(225):72906–72914. https://www.gpo.gov/fdsys/pkg/FR-2015-11-23/pdf/2015-29799.pdf. January 3, 2016.
EPA. 2016. 1-Bromorpropane (1-BP); availability of TSCA work plan chemical risk assessment for public review and comment. U.S. Environmental Protection Agency. Fed Regist 81(45):12098–12099. https://www.gpo.gov/fdsys/pkg/FR-2016-03-08/pdf/2016-05176.pdf. April 27, 2017.
EPIWIN. 2012. CAS 106-94-5. 1-Bromopropane. Estimation Program Interface (EPI Suite) version 4.11. U.S. Environmental Protection Agency. http://www.epa.gov/oppt/exposure/pubs/episuitedl.htm. October 17, 2014.
FDA. 2013. Bottled water. Code of Federal Regulations. U.S. Food and Drug Administration. 21 CFR 165.110, Subpart B. http://www.gpo.gov/fdsys/pkg/CFR-2013-title21-vol2/pdf/CFR-2013-title21-vol2-sec165-110.pdf. October 28, 2014.
FDA. 2014. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. January 08, 2014.
Fomon SJ. 1966. Body composition of the infant: Part 1: The male reference infant. In: Faulkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35(Suppl 5):1169–1175.7081099
Frasch HF, Dotson GS, Barbero AM. 2011. In vitro human epidermal penetration of 1-bromopropane. J Toxicol Environ Health A 74(19):1249–1260.21830855
Fueta Y, Fukuda T, Ishidao T, . 2004. Electrophysiology and immunohistochemistry in the hippocampal CA1 and the dentate gyrus of rats chronically exposed to 1-bromopropane, a substitute for specific chlorofluorocarbons. Neuroscience 124(3):593–603.14980730
Fueta Y, Ishidao T, Arashidani K, . 2002. Hyperexcitability of the hippocampal CA1 and the dentate gyrus in rats subchronically exposed to a substitute for chlorofluorocarbons, 1-bromopropane vapor. J Occup Health 44(3):156–165.
Fueta Y, Ishidao T, Ueno S, . 2007. New approach to risk assessment of central neurotoxicity induced by 1-bromopropane using animal models. Neurotoxicology 28(2):270–273.16782201
Fueta Y, Kanemitsu M, Egawa S, . 2015. Prenatal exposure to 1-bromopropane suppresses kainate-induced wet dog shakes in immature rats. J UOEH 37(4):255–261. 10.7888/juoeh.37.255.26667193
Fujii T. 1992. Quadrupole mass spectrometry in combination with lithium ion attachment for sampling at atmospheric pressure: Possible coupling to supercritical fluid chromatography. Anal Chem 64(7):775–778.
Furuhashi K, Kitoh J, Tsukamura H, . 2006. Effects of exposure of rat dams to 1-bromopropane during pregnancy and lactation on growth and sexual maturation of their offspring. Toxicology 224(3):219–228.16777312
Gargas ML, Burgess RJ, Voisard DE, . 1989. Partition coefficients of low-molecular-weight volatile chemicals in various liquids and tissues. Toxicol Appl Pharmacol 98:87–99.2929023
Garner CE, Yu X. 2014. Species and sex-dependent toxicokinetics of 1-bromopropane: The role of hepatic cytochrome P450 oxidation and glutathione (GSH). Xenobiotica 44(7):644–656.24438363
Garner CE, Liang S, Yin L, . 2015. Physiologically based pharmacokinetic modeling for 1-bromopropane in F344 rats using gas uptake inhalation experiments. Toxicol Sci 145(1):23–36. 10.1093/toxsci/kfv018.25634537
Garner CE, Sloan C, Sumner SC, . 2007. CYP2E1-catalyzed oxidation contributes to the sperm toxicity of 1-bromopropane in mice. Biol Reprod 76(3):496–505.17093198
Garner CE, Sumner SC, Davis JG, . 2006. Metabolism and disposition of 1-bromopropane in rats and mice following inhalation or intravenous administration. Toxicol Appl Pharmacol 215(1):23–36.16513153
Gilman S. 2002. Joint position sense and vibration sense: Anatomical organisation and assessment. J Neurol Neurosurg Psychiatry 73:473–477.12397137
Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect 101(Supp 2):65–71.7902273
Gschwend PM, MacFarlane JK, Newman KA. 1985. Volatile halogenated organic compounds released to seawater from temperate marine macroalgae. Science 227:1033–1035.17794227
Gummin DD. 2015. Hydrocarbons. In: Hoffman RS, Lewin NA, Goldfrank LR, . eds. Goldfrank’s toxicologic emergencies. 7th ed. New York NY: McGraw-Hill Education, 1334–1345.
Guo Y, Yuan H, Jiang L, . 2015. Involvement of decreased neuroglobin protein level in cognitive dysfunction induced by 1-bromopropane in rats. Brain Res 1600:1–16. 10.1016/j.brainres.2014.12.046.25557405
Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences and Press Institute Press.
Han EH, Hwang YP, Lee KJ, . 2008. 1-Bromopropane induces macrophage activation via extracellular signal-regulated kinase 1/2 MAPK and NF-κB pathways. Cancer Lett 262(1):28–36.18164123
Han EH, Yang JH, Kim HK, . 2012. 1-Bromopropane up-regulates cyclooxygenase-2 expression via NF-κB and C/EBP activation in murine macrophages. Food Chem Toxicol 50(5):1616–1622.22353212
Hanley KW, Petersen MR, Cheever KL, . 2009. N-Acetyl-S-(n-propyl)-l-cysteine in urine from workers exposed to 1-bromopropane in foam cushion spray adhesives. Ann Occup Hyg 53(7):759–769.19706636
Hanley KW, Petersen MR, Cheever KL, . 2010. Bromide and N-acetyl-S-(n-propyl)-L-cysteine in urine from workers exposed to 1-bromopropane solvents from vapor degreasing or adhesive manufacturing. Int Arch Occup Environ Health 83(5):571–584.20229238
Hanley KW, Petersen M, Curwin BD, . 2006. Urinary bromide and breathing zone concentrations of 1-bromopropane from workers exposed to flexible foam spray adhesives. Ann Occup Hyg 50(6):599–607.16698849
Hasspieler B, Haffner D, Stelljes M, . 2006. Toxicological assessment of industrial solvents using human cell bioassays: Assessment of short-term cytotoxicity and long-term genotoxicity potential. Toxicol Ind Health 22(7):301–315.17022437
Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
Honma T, Suda M, Miyagawa M. 2003. Inhalation of 1-bromopropane causes excitation in the central nervous system of male F344 rats. Neurotoxicology 24(4–5):563–575.12900070
HSDB. 2013. 1-Bromopropane. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. October 23, 2014.
Huang Z, Ichihara S, Oikawa S, . 2015. Hippocampal phosphoproteomics of F344 rats exposed to 1-bromopropane. Toxicol Appl Pharmacol 282(2):151–160. 10.1016/j.taap.2014.10.016.25448045
Huang Z, Ichihara S, Oikawa S, . 2011. Proteomic analysis of hippocampal proteins of F344 rats exposed to 1-bromopropane. Toxicol Appl Pharmacol 257(1):93–101.21925529
Huang Z, Ichihara S, Oikawa S, . 2012. Proteomic identification of carbonylated proteins in F344 rat hippocampus after 1-bromopropane exposure. Toxicol Appl Pharmacol 263(1):44–52.22683646
Huang F, Ichihara S, Yamada Y, . 2016. Effect of 4-week inhalation exposure to 1-bromopropane on blood pressure in rats. J Appl Toxicol 10.1002/jat.3364.
IARC. 2014. Agents classified by the IARC monographs. Volumes 1–110. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/ClassificationsCASOrder.pdf. September 9, 2014.
Ichihara G, Kitoh J, Yu X, . 2000b. 1-Bromopropane, an alternative to ozone layer depleting solvents, is dose-dependently neurotoxic to rats in long-term inhalation exposure. Toxicol Sci 55(1):116–123.10788566
Ichihara G, Li W, Ding X, . 2004a. A survey on exposure level, health status, and biomarkers in workers exposed to 1-bromopropane. Am J Ind Med 45(1):63–75.14691970
Ichihara G, Li W, Shibata E, . 2004b. Neurologic abnormalities in workers of a 1-bromopropane factory. Environ Health Perspect 112(13):1319–1325.15345346
Ichihara G, Miller JK, Ziolkokwska A, . 2002. Neurological disorders in three workers exposed to 1-bromopropane. J Occup Health 44(1):1–7.
Ichihara G, Wang H, Zhang L, . 2011. Dose-dependent neurologic abnormalities in workers exposed to 1-bromopropane: Authors’ response. J Occup Environ Med 53(10):1095–1098.21915066
Ichihara G, Yu X, Kitoh J, . 2000a. Reproductive toxicity of 1-bromopropane, a newly introduced alternative to ozone layer depleting solvents, in male rats. Toxicol Sci 54(2):416–423.10774824
IRIS. 2014. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/. November 24, 2014.
Ishidao T, Fueta Y, Ueno S, . 2016. A cross-fostering analysis of bromine ion concentration in rats that inhaled 1-bromopropane vapor. J Occup Health 58(3):241–246. 10.1539/joh.15-0284-OA.27108641
Ishidao T, Kunugita N, Fueta Y, . 2002. Effects of inhaled 1-bromopropane vapor on rat metabolism. Toxicol Lett 134(1–3):237–243.12191883
Jain RB. 2015a. Distributions of selected urinary metabolites of volatile organic compounds by age, gender, race/ethnicity, and smoking status in a representative sample of U.S. adults. Environ Toxicol Pharmacol 40(2):471–479.26282484
Jain RB. 2015b. Levels of selected urinary metabolites of volatile organic compounds among children aged 6-11 years. Environ Res 142:461–470. 10.1016/j.envres.2015.07.023.26257031
Janssen DB, Jager D, Witholt B. 1987. Degradation of n-haloalkanes and α,ω-dihaloalkanes by wild-type and mutants of Acinetobacter sp. strain GJ70. Appl Environ Microbiol 53:561–566.3579270
Jones AR, Walsh DA. 1979. The oxidative metabolism of 1-bromopropane in the rat. Xenobiotica 9(12):763–772.532220
Kaneko T, Kim HY, Wang PY, . 1997. Partition coefficients and hepatic metabolism in vitro of 1- and 2-bromopropanes. J Occup Health 39(4):341–342.
Kawai T, Takeuchi A, Miyama Y, . 2001. Biological monitoring of occupational exposure to 1-bromopropane by means of urinalysis for 1-bromopropane and bromide ion. Biomarkers 6(5):303–312.23889306
Kearns GL, Abdel-Rahman SM, Alander SW, . 2003. Developmental pharmacology: Drug disposition, action, and therapy in infants and children. N Engl J Med 349(12):1157–1167.13679531
Khan S, O’Brien PJ. 1991. 1-Bromoalkanes as new potent nontoxic glutathione depletors in isolated rat hepatocytes. Biochem Biophys Res Commun 179(1):436–441.1883370
Kim HY, Chung YH, Jeong JH, . 1999. Acute and repeated inhalation toxicity of 1-bromopropane in SD rats. J Occup Health 41(2):121–128.
Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29(18):4430–4433.2350547
Krause RJ, Glocke SC, Elfarra AA. 2002. Sulfoxides as urinary metabolites of S-allyl-L-cysteine in rats: Evidence for the involvement of flavin-containing monooxygenases. Drug Metab Dispos 30(10):1137–1142.12228191
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Lee SK, Jeon TW, Kim YB, . 2007. Role of glutathione conjugation in the hepatotoxicity and immunotoxicity induced by 1-bromopropane in female BALB/c mice. J Appl Toxicol 27(4):358–367.17265426
Lee SK, Kang MJ, Jeon TW, . 2010. Role of metabolism in 1-bromopropane-induced hepatotoxicity in mice. J Toxicol Environ Health A 73(21–22):1431–1440. 10.1080/15287394.2010.511546.
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Lehman-McKeeman L. 2013. Absorption, distribution, and excretion of toxicants. In: Klaassen CD, ed. Casarett & Doull’s toxicology. The basic science of poisons. 8th ed. New York, NY: McGraw Hill Medical, 153–183.
Leung H. 1993. Physiologically-based pharmacokinetic modelling. In: Ballantyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York NY: Stockton Press, 153–164.
Levy A. 2010. Preliminary data on VibraTip, a new source of standardised vibration for bedside assessment of peripheral neuropathy. Br J Diabetes Vasc Dis 10:284–286. 10.1177/1474651410390741.
Li W, Shibata E, Zhou Z, . 2010. Dose-dependent neurologic abnormalities in workers exposed to 1-bromopropane. J Occup Environ Med 52(8):769–777.20657306
Liu F, Ichihara S, Mohideen SS, . 2009. Comparative study on susceptibility to 1-bromopropane in three mice strains. Toxicol Sci 112(1):100–110.19638432
Liu F, Ichihara S, Valentine WM, . 2010. Increased susceptibility of Nrf2-null mice to 1-bromopropane-induced hepatotoxicity. Toxicol Sci 115(2):596–606.20211940
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4(2–3):301–324.351201
Lyman WJ, Reehl WF, Rosenblatt DH. 1990. 1-Bromopropane. In: Handbook of chemical property estimation methods. Environmental behavior of organic compounds. Washington, DC: American Chemical Society, 4–9; 7–4; 8–9 to 8–29; 15–21 to 15–29.
Mabey W, Mill T. 1978. Critical review of hydrolysis of organic compounds in water under environmental conditions. J Phys Chem Ref Data 7(2):383–415.
Majersik JJ, Caravati EM, Steffens JD. 2007. Severe neurotoxicity associated with exposure to the solvent 1-bromopropane (n-propyl bromide). Clin Toxicol 45(3):270–276.
Mathias PI, Cheever KL, Hanley KW, . 2012. Comparison and evaluation of urinary biomarkers for occupational exposure to spray adhesives containing 1-bromopropane. Toxicol Mech Methods 22(7):526–532.22519856
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74(2–3):135–149.1387742
Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(12):2293–2299.
MMWR. 2008. Neurologic illness associated with occupational exposure to the solvent 1-bromopropane-New Jersey and Pennsylvania, 2007-2008. MMWR Morb Mortal Wkly Rep 57(48):1300–1302.19052528
Mohideen SS, Ichihara S, Banu S, . 2009. Changes in neurotransmitter receptor expression levels in rat brain after 4-week exposure to 1-bromopropane. Neurotoxicology 30(6):1078–1083.19576243
Mohideen SS, Ichihara G, Ichihara S, . 2011. Exposure to 1-bromopropane causes degeneration of noradrenergic axons in the rat brain. Toxicology 285(1–2):67–71.21527306
Mohideen SS, Ichihara S, Subramanian K, . 2013. Effects of exposure to 1-bromopropane on astrocytes and oligodendrocytes in rat brain. J Occup Health 55(1):29–38.23183024
Morgan DL, Nyska A, Harbo SJ, . 2011. Multisite carcinogenicity and respiratory toxicity of inhaled 1-bromopropane in rats and mice. Toxicol Pathol 39(6):938–948.21859883
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokinet 5(6):485–527.7002417
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
NIOSH. 2001. Health Hazard Evaluation Report: HETA 2000-0233-2845, Trilithic, Inc. Indianapolis, Indiana. National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention.
NIOSH. 2002. NIOSH health hazard evaluation report: HETA No. 98-0153-2883, Custom Products, Inc., Mooresville, NC. National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention.
NIOSH. 2003a. NIOSH health hazard evaluation report: HETA No. 99-0260-2906, Marx Industries, Inc., Sawmills, North Carolina. National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention, 68.
NIOSH. 2003b. NIOSH manual of analytical methods. Method 1025. 1- and 2-Bromopropane. 4th edition. National Institute of Occupational Safety and Health.
NIOSH. 2010. Health Hazard Evaluation Report: HETA-2008-0175-3111, New Jersey Department of Health and Senior Services, July 2010. Evaluation of 1-bromopropane use in four New Jersey commercial dry cleaning facilities. National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention.
NIOSH. 2014. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/npgdcas.html. September 9, 2014.
NITE. 2010. 1-Bromoprane. J-Check (Japan CHEmicals Collaborative Knowledge Database). National Institute of Technology and Evaluation. http://www.safe.nite.go.jp/jcheck/template.action?ano=2854&mno=2-0073&cno=106-94-5&request_locale=en. October 17, 2014.
Nizar H, Munro N, Nightingale P, . 2014. Diagnostic accuracy of the VibraTip in detection of diabetic peripheral neuropathy. Br J Diabetes Vasc Dis 14:26–29. 10.15277/bjdvd.2014.005.
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Research Council. National Academy Press.
NTP. 2003. NTP-CERHR monograph on the potential human reproductive and developmental effects of 1-Bromopropane (1-BP). National Toxicology Program. Center for the Evaluation of Risks to Human Reproduction.
NTP. 2011. NTP technical report on the toxicology and carcinogenesis studies of 1-bromopropane (CAS No. 106-94-5) in F344/N rats and B6C3F1 mice (inhalation studies). National Toxicology Program, Technical report series TR-564.
NTP. 2013. Report on carcinogens. Monograph on 1-bromopropane. National Toxicology Program, U.S. Department of Health and Human Services. http://ntp.niehs.nih.gov/ntp/roc/thirteenth/monographs_final/1bromopropane_508.pdf. November 4, 2014.
NTP. 2016. 1-Bromopropane. 14th report on carcinogens. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/bromopropane.pdf. April 27, 2017.
NTP-CERHR. 2004. NTP-CERHR Expert Panel report on the reproductive and developmental toxicity of 1-bromopropane. Reprod Toxicol 18(2):157–187.15019718
OSHA. 1999. Method number PV2061. 1-Bromopropane. Sampling and analytical methods. Occupational Safety and Health Administration. https://www.osha.gov/dts/sltc/methods/partial/pv2061.html. October 20, 2014.
OSHA. 2013a. Air contaminants. Table Z-1-limits for air contaminants. Code of Federal Regulations. Occupational Safety And Health Standards. 29 CFR 1910.1000, Subpart Z. http://www.gpo.gov/fdsys/pkg/CFR-2013-title29-vol6/pdf/CFR-2013-title29-vol6-sec1910-1000.pdf. September 9, 2014.
OSHA. 2013b. Process safety management of highly hazardous chemicals. Appendix A to 1910.119-List of highly hazardous chemicals, toxics and reactives (mandatory). Code of Federal Regulations. Occupational Safety And Health Standards. 29 CFR 1910.119, Subpart H. http://www.gpo.gov/fdsys/pkg/CFR-2013-title29-vol5/pdf/CFR-2013-title29-vol5-sec1910-119.pdf. September 9, 2014.
OSHA. 2014. OSHA/NIOSH Hazard Alert: 1-Bromopropane. Occupational safety and health standards. DHHS (NIOSH) Publication 2013-150 OSHA - HA-3676-2013. https://www.osha.gov/dts/hazardalerts/1bromopropane_hazard_alert.html. April 27, 2017.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Pestronk A, Florence J, Levine T, . 2004. Sensory exam with a quantitative tuning fork: Rapid, sensitive and predictive of SNAP amplitude. Neurology 62(3):461–464.14872031
Raymond LW, Ford MD. 2007. Severe illness in furniture makers using a new glue: 1-Bromopropane toxicity confounded by arsenic. J Occup Environ Med 49(9):1009–1019.17848857
RePORTER. 2014. 1-Bromopropane. NTP database summarization and evaluation. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. October 27, 2014.
RTECS. 2009. Propane, 1-bromo. Registry of Toxic Effects on Chemical Substances. National Institute for Occupational Safety and Health. MDL Information Systems, Inc. October 15, 2014.
Saito-Suzuki R, Teramoto S, Shirasu Y. 1982. Dominant-lethal studies in rats with 1,2-dibromo-3-chloropropane and its structurally related compounds. Mutat Res 101(4):321–327.7110159
Samukawa M, Ichihara G, Oka N, . 2012. A case of severe neurotoxicity associated with exposure to 1-bromopropane, an alternative to ozone-depleting or global-warming solvents. Arch Intern Med 172(16):1257–1260.22893012
Saunders NR, Ek CJ, Habgood MD, . 2008. Barriers in the brain: A renaissance? Trends Neurosci 31(6):279–286.18471905
Saunders NR, Liddelow SA, Dziegielewska KM. 2012. Barrier mechanisms in the developing brain. Front Pharmacol 3(10.3389/fphar.2012.00046):Article 46.
Scheuplein R, Charnley G, Dourson M. 2002. Differential sensitivity of children and adults to chemical toxicity. I. Biological basis. Regul Toxicol Pharmacol 35(3):429–447.12202057
Scholtz R, Schmuckle A, Cook AM, . 1987. Degradation of eighteen 1-monohaloalkanes by Arthrobacter sp. strain HA1. J Gen Microbiol 133:267–274.
Schwarzenbach RP, Giger W, Schaffner C, . 1985. Groundwater contamination by volatile halogenated alkanes abiotic formation of volatile sulfur compounds under anaerobic conditions. Environ Sci Technol 19(4):322–327.22283343
Sclar G. 1999. Encephalomyeloradiculoneuropathy following exposure to an industrial solvent. Clin Neurol Neurosurg 101(3):199–202.10536908
Sekiguchi S, Suda M, Zhai YL, . 2002. Effects of 1-bromopropane, 2-bromopropane, and 1,2-dichloropropane on the estrous cycle and ovulation in F344 rats. Toxicol Lett 126(1):41–49.11738269
Shochat E, Hermoni I, Cohen Z, . 1993. Bromoalkane-degrading Pseudomonas strains. Appl Environ Microbiol 59(5):1403–1409.8517736
Smith CJ, Johnson GT, Harbison RD, . 2011. Dose-dependent neurologic abnormalities in workers exposed to 1-bromopropane. J Occup Environ Med 53(7):707–708.21738016
Sohn YK, Suh JS, Kim JW, . 2002. A histopathologic study of the nervous system after inhalation exposure of 1-bromopropane in rat. Toxicol Lett 131(3):195–201.11992739
Subramanian K, Mohideen SS, Suzumura A, . 2012. Exposure to 1-bromopropane induces microglial changes and oxidative stress in the rat cerebellum. Toxicology 302(1):18–24.22824114
Suda M, Honma T, Miyagawa M, . 2008. Alteration of brain levels of neurotransmitters and amino acids in male F344 rats induced by three-week repeated inhalation exposure to 1-bromopropane. Ind Health 46(4):348–359.18716383
Swann RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Residue Rev 85:17–28.
Tachizawa H, Macdonald TL, Neal RA. 1982. Rat liver microsomal metabolism of propyl halides. Mol Pharmacol 22(3):745–751.7155131
Thapa P, Kim EK, Nepal MR, . 2016. Identification of a N-7-guanine adduct of 1-bromopropane in calf thymus DNA by mass spectrometry. Mol Cell Toxicol 12(1):7–14.
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton NJ: Princeton Scientific Publishing, 365–394.
Thompson TM. 2014. Chapter 126: Hydrocarbons. In: Schafermeyer R, Tenenbein M, Macias CG, eds. Strange and Schafermeyer’s pediatric emergency medicine. New York NY: McGraw-Hill. http://accessemergencymedicine.mhmedical.com/content.aspx?bookid=1345&sectionid=72128140. April 13, 2017.
Toraason M, Lynch DW, DeBord DG, . 2006. DNA damage in leukocytes of workers occupationally exposed to 1-bromopropane. Mutat Res 603(1):1–14.16412685
Ueno S, Yoshida Y, Fueta Y, . 2007. Changes in the function of the inhibitory neurotransmitter system in the rat brain following subchronic inhalation exposure to 1-bromopropane. Neurotoxicology 28(2):415–420.16647755
UNEP. 2001. Montreal protocol on substances that deplete the ozone layer. UNEP report on the geographical market potential and estimated emissions of n-propyl bromide. United Nations Environment Programme.
USAPHC. 2014. Information regarding 1-bromopropane and the adopted notice of intended change (threshold limit value decrease from 10 ppm to 0.1 ppm). Technical information paper no. 55-022-1014. U.S. Army Public Health Command. https://phc.amedd.army.mil/PHC%20Resource%20Library/BP_and_the_Adopted_TLV_Decrease.pdf. April 27, 2017.
Valentine H, Amarnath K, Amarnath V, . 2007. Globin s-propyl cysteine and urinary N-acetyl-S-propylcysteine as internal biomarkers of 1-bromopropane exposure. Toxicol Sci 98(2):427–435.17517825
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483.8681961
Wang H, Ichihara G, Ito H, . 2002. Biochemical changes in the central nervous system of rats exposed to 1-bromopropane for seven days. Toxicol Sci 67(1):114–120.11961224
Wang H, Ichihara G, Ito H, . 2003. Dose-dependent biochemical changes in rat central nervous system after 12-week exposure to 1-bromopropane. Neurotoxicology 24(2):199–206.12606292
Wang QH, Zhong ZX, Chen JJ, . 2012. [1-Bromopropane peripheral nervous system toxicity]. Zhonghua Lao Dong Wei Sheng Zhi Ye Bing Za Zhi 30(10):751–755. (Chinese).23257000
Wang TH, Wu ML, Wu YH, . 2015. Neurotoxicity associated with exposure to 1-bromopropane in golf-club cleansing workers. Clin Toxicol (Phila) 53(8):823–826. 10.3109/15563650.2015.1064939.26161839
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. September 9, 2014.
WHO. 2011. In: Guidelines for drinking-water quality. 4th ed. Geneva, Switzerland: World Health Organization. http://whqlibdoc.who.int/publications/2011/9789241548151_eng.pdf?ua=1. September 9, 2014.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advance treatise. Volume II: The elements Part A. New York NY: Academic Press, 1–247.
Willits I, Cole H, Jones R, . 2015. VibraTip™ for testing vibration perception to detect diabetic peripheral neuropathy: A NICE medical technology guidance. Appl Health Econ Health Policy 13:315–324.26093645
Wuebbles DJ, Jain AK, Patten KO, . 1998. Evaluation of ozone depletion potentials for chlorobromomethane (CH2ClBr) and 1-bromo-propane (CH2BrCH2CH3). Atmos Environ 32(2):107–113.
Xu Y, Wang S, Jiang L, . 2016. Identify melatonin as a novel therapeutic reagent in the treatment of 1-bromopropane (1-BP) intoxication. Medicine 95(3):e2203. 10.1097/md.0000000000002203.26817862
Yamada T, Ichihara G, Wang H, . 2003. Exposure to 1-bromopropane causes ovarian dysfunction in rats. Toxicol Sci 71(1):96–103.12520079
Yoshida Y, Nakano Y, Ueno S, . 2009. Effects of 1-bromopropane, a substitute for chlorofluorocarbons, on BDNF expression. Int Immunopharmacol 9(4):433–438.19189864
Yu X, Ichihara G, Kitoh J, . 1998. Preliminary report on the neurotoxicity of 1-bromopropane, an alternative solvent for chlorofluorocarbons. J Occup Health 40:234–235.
Yu X, Ichihara G, Kitoh J, . 2001. Neurotoxicity of 2-bromopropane and 1-bromopropane, alternative solvents for chlorofluorocarbons. Environ Res 85(1):48–52.11161652
Yu WJ, Kim JC, Chung MK. 2008. Lack of dominant lethality in mice following 1-bromopropane treatment. Mutat Res 652(1):81–87.18291709
Zhang L, Nagai T, Yamada K, . 2013. Effects of sub-acute and sub-chronic inhalation of 1-bromopropane on neurogenesis in adult rats. Toxicology 304:76–82.23266320
Zhong Z, Zeng T, Xie K, . 2013. Elevation of 4-hydroxynonenal and malondialdehyde modified protein levels in cerebral cortex with cognitive dysfunction in rats exposed to 1-bromopropane. Toxicology 306:16–23.23395825
Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12(1):29–34.643372
Zong C, Garner CE, Huang C, . 2016. Preliminary characterization of a murine model for 1-bromopropane neurotoxicity: Role of cytochrome P450. Toxicol Lett 258:249–258. 10.1016/j.toxlet.2016.07.006.27421776