# 8 REGULATIONS, ADVISORIES, AND GUIDELINES

MRLs are substance specific estimates that are intended to serve as screening levels. They are used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

ATSDR has derived an acute-duration inhalation MRL of 1 ppm for 1-bromopropane based on a BMCL_1SD_ of 97.4 ppm for reduced forelimb strength in male rats exposed for 14 days (Honma et al. 2003). The BMCL_1SD_ was duration adjusted (8/24 hours) to a BMCL_(HEC)_ of 32.3 ppm and an uncertainty factor of 30 was used (3 for dosimetric adjustment and 10 for human variability).

ATSDR has derived an intermediate-duration inhalation MRL of 0.1 ppm for 1-bromopropane based on a NOAEL of 10 ppm for increased spontaneous locomotor activity in rats (Honma et al. 2003). The NOAEL was duration adjusted (8/24 hours) to a NOAEL_(HEC)_ of 3.33 ppm and an uncertainty factor of 30 was used (3 for extrapolation from animals to humans with dosimetric adjustment and 10 for human variability).

ATSDR has derived a chronic-duration inhalation MRL of 0.02 ppm for 1-bromopropane based on a minimal LOAEL of 1.28 ppm for a mild neurological impairment (decreased vibration sense as measured by increased vibration sense threshold) in female 1-bromopropane production workers (Li et al. 2010). The LOAEL was adjusted for continuous exposure (5/7 days × 12/24 hours) to a LOAEL of 0.46 ppm and an uncertainty factor of 30 was used (3 for use of a minimal LOAEL and 10 for human variability).

ATSDR has derived an acute oral MRL of 0.2 mg/kg/day for 1-bromopropane based on a BMDL_1SD_ of 19.75 mg 1-bromopropane/kg/day for impaired learning and memory in rats exposed via gavage for 12 days (Zhong et al. 2013). An uncertainty factor of 100 was used (10 for extrapolation from animals to humans and 10 for human variability).

IARC and the EPA have not evaluated the carcinogenicity of 1-bromopropane (IARC 2014; IRIS 2014). However, ACGIH has assigned 1-bromopropane a classification of “A3 – Confirmed animal carcinogen with unknown relevance to humans” (ACGIH 2014, 2016) and the Department of Health and Human Services has classified 1-bromopropane as “reasonably anticipated to be a human carcinogen” (NTP 2016).

OSHA has not set permissible exposure limits (PELs) to protect workers against adverse health effects resulting from exposure to 1-bromopropane (OSHA 2013a, 2013b). ACGIH has recommended a TLV-TWA of 0.1 ppm 1-bromopropane for workers (ACGIH 2014, 2016). No guidelines for worker exposure limits have been recommended by NIOSH (2014). The EPA has not derived RfDs or RfCs for 1-bromopropane.

The World Health Organization (WHO) has not established any air quality guidelines for 1-bromopropane (WHO 2010). 1-Bromopropane is not designated as a hazardous air pollutant, and no acute exposure guidelines (AEGLs) have been derived (EPA 2013a, 2014a). The Department of Energy (DOE) has established values for responding to potential releases of airborne 1-bromopropane for use in community emergency planning. The values established by the DOE (2012) are the Protective Active Criteria (PAC-1, -2, and -3). The PAC-1, -2, and -3 values are 18, 18, and 700 ppm, respectively, represent increasing severity of effects (mild, irreversible, and life threatening, respectively) for a 1-hour exposure (DOE 2012). The American Industrial Hygiene Association (AIHA) has not established Emergency Response Planning Guidelines (ERPGs-1, -2, -3) for 1-bromopropane (AIHA 2014).

WHO has not established any drinking water guidelines for 1-bromopropane (WHO 2011) and the EPA has not set drinking water standards for 1-bromopropane (EPA 2009a, 2009b, 2012, 2013c, 2013d, 2014c). The FDA has not set allowable levels for 1-bromopropane in bottled water (FDA 2013).

The international and national regulations, advisories, and guidelines regarding 1-bromopropane in air, water, and other media are summarized in Table 8-1.

Table 8-1 Regulations, Advisories, and Guidelines Applicable to 1-Bromopropane

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | No data | IARC 2014
WHO | Air quality guidelines | No data | WHO 2010
WHO | Drinking water quality guidelines | No data | WHO 2011
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV-TWA | 0.1 ppm | ACGIH 2014, 2016
AIHA | ERPGs | No data | AIHA 2014
DOE | PACs | | DOE 2012
DOE | PAC-1 | 18 ppm
DOE | PAC-2 | 18 ppm
DOE | PAC-3 | 700 ppm
EPA | AEGLs | No data | EPA 2013a
EPA | Regulated toxic and flammable substances under Section 112(r) of the Clean Air Act | No data | EPA 2013b; 40 CFR 68.130
EPA | Hazardous Air Pollutants | No data | EPA 2014a
EPA | NAAQS | No data | EPA 2014b
EPA | Protection of stratospheric ozone – listing of substitutes for ozone-depleting substances
EPA | In solvent cleaning | Acceptable (final rule) | EPA 2007a; 72 FR 30142
EPA | In adhesives and aerosols | Unacceptable (proposed rule) | EPA 2007b; 72 FR 30168
EPA | In coatings | Acceptable subject to use conditions (proposed rule)
NIOSH | REL | No data | NIOSH 2014
NIOSH | IDLH | No data
OSHA | PEL (8-hour TWA) for general industry | No data | OSHA 2013a; 29 CFR 1910.1000, Table Z-1
OSHA | Highly hazardous chemicals | No data | OSHA 2013b; 29 CFR 1910.119, Appendix A
b. Water
EPA | Designated as hazardous substances in accordance with Section 311 (b)(2)(A) of the Clean Water Act | No datai | EPA 2013c; 40 CFR 116.4
EPA | Drinking water contaminant candidate list | No data | EPA 2009a; 74 FR 51850
EPA | Drinking water standards and health advisories | No data | EPA 2012a
EPA | National primary drinking water standards | No data | EPA 2009b
EPA | National recommended water quality criteria | No data | EPA 2014c
EPA | Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | No data | EPA 2013d; 40 CFR 117.3
c. Food
FDA | Allowable levels for contaminants in bottled water | No data | FDA 2013; 21 CFR 165.110
FDA | EAFLJS^a^ | No data | FDA 2014
d. Other
ACGIH | Carcinogenicity classification | A3^b^ | ACGIH 2014, 2016
EPA | Carcinogenicity classification | No data | IRIS 2014
EPA | RfC | No data
EPA | RfD | No data
EPA | Chemical substances subject to proposed or final TSCA rules or orders | No data | EPA 1998a
EPA | TSCA Work Plan Chemical Risk Assessment | No data | EPA 2016
EPA | Chemicals subject to EPCRA and Section 112(r) of the Clean Air Act | No data | EPA 2006
EPA | Identification and listing of hazardous waste | No data | EPA 2013e; 40 CFR 261, Appendix VIII
EPA | Master Testing List | No data | EPA 2014d
EPA | RCRA waste minimization PBT priority chemical list | No data | EPA 1998b; 63 FR 60332
EPA | Standards for owners and operators of hazardous waste TSD facilities; groundwater monitoring list | No data | EPA 2013f; 40 CFR 264, Appendix IX
EPA | Superfund, emergency planning, and community right-to-know
EPA | Designated CERCLA hazardous substance and reportable quantity | No data | EPA 2013g; 40 CFR 302.4
EPA | Effective date of toxic chemical release reporting | July 1, 2017 | EPA 2013h; 40 CFR 372.65; EPA 2015
EPA | Extremely hazardous substances and its threshold planning quantity | No data | EPA 2013i; 40 CFR 355, Appendix A
DHHS | Carcinogenicity classification | Reasonably anticipated to be a human carcinogen | NTP 2016

a The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

b A3: Confirmed animal carcinogen with unknown relevance to humans.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AEL = acceptable exposure limit; AIHA = American Industrial Hygiene Association; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DHHS = Department of Health and Human Services; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; EPCRA = Emergency Planning and Community Right-To-Know Act; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; FR = Federal Register; GRAS = generally recognized as safe; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; NAAQS = National Ambient Air Quality Standards; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PBT = persistent, bioaccumulative, and toxic; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TSCA = Toxic Substances Control Act; TSD = treatment, storage, and disposal; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization