# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of 1-bromopropane is provided in Table 4-1.

Commercial 1-bromopropane has been reported to be 99% pure (ACGIH 2014). 1-Bromopropane used as a commercial solvent blend is formulated to improve performance and inhibit decomposition, including stabilization to prevent hydrolysis (NTP 2011) and is between 85 and 99% pure (UNEP 2001). 2-Bromopropane is present as a contaminant at 0.1–0.2% (OSHA 1999).

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of 1-bromopropane is provided in Table 4-2.

Table 4-1 Chemical Identity of 1-Bromopropane^a^

Characteristic | Information
Chemical name | 1-Bromopropane
Synonym(s) | Propane, 1-bromo-; propyl bromide; n-propyl bromide; 1-BP
Registered trade name(s) | Abzol; Ensolv; Solvon; Ensolv-NDI; Whisper Spray; Soft Seam^b^
Chemical formula | C_3_H_7_Br
Chemical structure | [image]
Identification numbers:
CAS Registry | 106-94-5
NIOSH RTECS | TX4110000^c^
EPA Hazardous Waste | No data
OHM/TADS | No data
DOT/UN/NA/IMDG | UN 2344; IMO 3
HSDB | 1068
NCI | No data

a AII information obtained from HSDB (2013), unless otherwise noted.

b EPA 2007c.

c RTECS 2009.

CAS = Chemical Abstracts Services; CIS = Chemical Information System; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of 1-Bromopropane^a^

Property
Molecular weight (g/mol) | 122.99
Color | Colorless
Physical state | Liquid
Melting point | −110°C
Boiling point | 71°C
Density:
at 20°C/20°C | 1.353
Odor | Sweet
Odor threshold:
Water | No data
Air | No data
Taste | No data
Solubility:
Water at 20°C | 2.45×10^3^ mg/L
Other solvents | Soluble in acetone, ethanol, ether, benzene, chloroform, carbon tetrachloride
Partition coefficients:
Log K_ow_ | 2.10
Log K_oc_ | 40 (estimated)
Vapor pressure at 20°C | 110.8 mm Hg
OH radical rate constant at 25°C | 1.18×10^−12^ cm^3^/molecules-second^b^
Henry’s law constant at 20°C | 7.3×10^−3^ atm-m^3^/mol (estimated)
Autoignition temperature | 490°C
Flashpoint | 21°C^c^
Flammability limits at 25°C | No data
Incompatibilities | Strong oxidants; strong bases
Conversion factors (25°C and 1 atm) | 1 mg/L=198.8 ppm; 1 ppm=5.03 mg/m^3^
Explosive limits | LEL=4.6%

a AII information obtained from HSDB (2013), unless otherwise noted.

b Donaghy et al. (1993)

c Alfa Aesar (2014)