# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## 1-Bromopropane Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1-Bromopropane
CAS Number: | 106-94-5
Date: | August 2017
Profile Status: | Final
Route: | [X] Inhalation [ ] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 10
Species: | Rat

[underlined: Minimal Risk Level]: 1 [ ] mg/kg/day [X] ppm

[underlined: Reference]: Honma T, Suda M, Miyagawa M. 2003. Inhalation of 1-bromopropane causes excitation in the central nervous system of male F344 rats. Neurotoxicology 24(4–5):563–575.12900070

[underlined: Experimental design]: The study examined the effects of 1-bromopropane on several neurobehavioral tests conducted in male F-344 rats. Groups of rats were exposed whole-body to 0, 10, 50, 200, or 1,000 ppm 1-bromopropane vapors 8 hours/day, 7 days/week for 3 weeks. All tests were conducted at various times after the 3-week exposure period except for a traction test that was also conducted on exposure days 1, 7, and 14. In the traction test, rats are forced to hang from a horizontal bar with the forelimbs and the time until the rat falls from the bar is recorded. The traction test is used to measure forelimb grip strength. Five rats per group were used in this test.

[underlined: Effect noted in study and corresponding doses]: No statistically significant differences in grip strength were observed between exposed rats and controls on days 1 or 7. On day 14, however, rats exposed to 1,000 ppm 1-bromopropane showed a statistically significant decrease in grip strength compared to lower exposure groups and controls, thus defining NOAEL and LOAEL values of 200 and 1,000 ppm, respectively, for neurological effects in an acute-duration inhalation study. Because all data were presented graphically, the means and standard error (SDs were subsequently calculated) for traction time (assessed on day 14) were extracted digitally using GrabIt! Software (version XP2) (see Table A-1).

Table A-1 Digitized Dataset for Traction Time in Male F-344 Rats Exposed to Vaporized 1-Bromopropane for 14 Days^a^

Exposure concentration (ppm) | Number of rats | Traction time (seconds) | Standard deviation
0 | 5 | 15.158 | 9.644
10 | 5 | 13.433 | 6.339
50 | 5 | 11.338 | 3.582
200 | 5 | 8.627 | 5.787
1,000 | 5 | 3.204^b^ | 2.480

a Data extracted from Figure 11 in Honma et al. (2003).

b p<0.05.

[underlined: Dose and end point used for MRL derivation:] BMCL_1SD_ of 97.50 ppm for neurological effects in male rats.

[ ] NOAEL [ ] LOAEL [ X ] BMCL_1 SD_

The traction time data were fit to all available continuous models in EPA’s Benchmark Dose Software (BMDS, version 2.4.0) using a benchmark response of 1 SD change from control. The following procedure for fitting continuous data was used. The simplest model (linear) was first applied to the data while assuming constant variance. If the data were consistent with the assumption of constant variance (p≥0.1), then the fit of the linear model to the means was evaluated and the polynomial, power, exponential, and Hill models were fit to the data while assuming constant variance. Adequate model fit was judged by three criteria: goodness-of-fit p-value (p>0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined benchmark response. Among all of the models providing adequate fit to the data, the lowest BMDL (95% lower confidence limit on the BMD) was selected as the POD when the difference between the BMCLs estimated from these models were >3-fold; otherwise, the BMDL from the model with the lowest Akaike’s Information Criterion (AIC) was chosen. If the test for constant variance was negative, the linear model was run again while applying the power model integrated into the BMDS to account for nonhomogenous variance. If the nonhomogenous variance model provided an adequate fit (p≥0.1) to the variance data, then the fit of the linear model to the means was evaluated and the polynomial, power, exponential, and Hill models were fit to the data and evaluated while the variance model was applied. Model fit and POD selection proceeded as described earlier. If the test for constant variance was negative and the nonhomogenous variance model did not provide an adequate fit to the variance data, then the data set was considered unsuitable for modeling.

All but two BMD models provided adequate and nearly equivalent fits (see Table A-2) by the various statistical criteria. Because the BMCL estimates are not sufficiently close, the model with the lowest BMCL (Exponential model 4) was selected. The Exponential model calculates BMC_1SD_ and BMCL_1SD_ values of 259.23 and 97.40 ppm, respectively, for decreased traction time (reduced grip strength) on day 14 (see Figure A-1).

Table A-2 Model Predictions for Traction Time in Male F-344 Rats Exposed to Vaporized 1-Bromopropane for 14 Days (Honma et al. 2003)

Model | Test for significant difference p-value^a^ | Variance p-value^b^ | Means p-value^b^ | Scaled residuals^c^ | | | AIC | BMC_1SD_ (ppm) | BMCL_1SD_ (ppm)
Model | Test for significant difference p-value^a^ | Variance p-value^b^ | Means p-value^b^ | Dose below BMC | Dose above BMC | Overall largest | AIC | BMC_1SD_ (ppm) | BMCL_1SD_ (ppm)
Constant variance
Linear^d^ | 0.01 | 0.04 | 0.59 | −0.89 | 0.20 | −0.89 | 117.70 | ND | ND
Nonconstant variance
Exponential (model 2)^e^ | 0.01 | 0.46 | 0.51 | −0.54 | 0.17 | 0.64 | 112.84 | 452.29 | 211.80
Exponential (model 3)^e^ | 0.01 | 0.46 | 0.51 | −0.54 | 0.17 | 0.64 | 112.84 | 452.29 | 211.80
Exponential (model 4)^e,f^ | 0.01 | 0.46 | 0.45 | 0.08 | 0.01 | 0.36 | 114.10 | 259.23 | 97.40
Exponential (model 5)^e^ | 0.01 | 0.46 | 0.45 | 0.08 | 0.01 | 0.36 | 114.10 | 259.22 | 97.40
Hill^e^ | | | | | | | | | ND
Linear^d^ | | | | | | | | | ND
Polynomial (2-degree)^d^ | 0.01 | 0.46 | 0.34 | −0.86 | 0.06 | −0.86 | 113.85 | 673.69 | 461.93
Polynomial (3-degree)^d^ | 0.01 | 0.46 | 0.34 | −0.86 | 0.06 | −0.86 | 113.85 | 673.69 | 461.93
Polynomial (4-degree)^d^ | 0.01 | 0.46 | 0.34 | −0.86 | 0.06 | −0.86 | 113.85 | 673.69 | 461.93
Power^e^ | 0.01 | 0.46 | 0.34 | −0.86 | 0.06 | −0.86 | 113.85 | 673.69 | 461.93

a Values >0.05 fail to meet conventional goodness-of-fit criteria.

b Values <0.10 fail to meet conventional goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the benchmark dose; also the largest residual at any dose.

d Coefficients restricted to be negative.

e Power restricted to ≥1.

f Selected model. Constant variance model did not fit variance data, but non-constant variance model did. With non-constant variance model applied all models, except for the Hill and the Linear (BMCL computation failed), provided adequate fit to the variance data. BMCLs for models providing adequate fit were not sufficiently close (differed by >2–3-fold), so the model with the lowest BMCL was selected (Exponential 4 model; the Exponential 5 converged onto the Exponential 4).

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL_1SD_ = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _1SD_ = exposure concentration associated to a change in the mean response equal to one control standard deviation from the control mean); ND = not determined (BMCL computation failed or the BMC was higher than the highest dose tested)

Figure A-1 Selected Model (Exponential Model 4) for Decreased Grip Strength Following Exposure to 1-Bromopropane (Honma et al. 2003)

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 3 for extrapolation from animals to humans with dosimetric adjustment
- [X] 10 for human variability

MRL = BMCL_[ HEC ]_ / 30 ( UF ) MRL = 32.3 ppm / 30 = 1 ppm

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]:

BMCL_1 SD [ HEC ]_ = BMCL_1 SD [ ADJ ]_ × ( H_b/g_ A / H_b/g_ H )

where:

- BMCL_1SD[ADJ]_ = 97.40 ppm × 8 hours/24 hours = 32.3 ppm
- H_b/g_A = animal blood:air partition coefficient = 11.7 (NTP-CERHR 2004)
- H_b/g_H = human blood:air partition coefficient = 7.08 (NTP-CERHR 2004)

( H_b/g_ A / H_b/g_ H ) = 11.7 / 7.08 = 1.653

Because the ratio of the partition coefficients is >1, a default value of 1 was used.

BMCL_[ HEC ]_ = 32.3 ppm × 1 = 32.3 ppm

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes, see above.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Limited information from a few case studies showed that workers exposed to 1-bromopropane for a few weeks reported subjective symptoms including respiratory irritation, headache, nausea, and lower extremity numbness, pain, and weakness; the geometric mean air concentration was 107 ppm for glue sprayers (range 58–254 ppm) (Raymond and Ford 2007). An acute-inhalation study in rats reported decreased activity and ataxia after single exposures to ≥1,800 ppm, but not 300 ppm; however, only qualitative data were provided (Kim et al. 1999). Intermediate-duration inhalation studies have shown that concentrations as low as 50 ppm can induce changes in neurobehavior, muscle strength, electrophysiology, morphology, and biochemistry (Fueta et al. 2002; Honma et al. 2003; Ichihara et al. 2000b; Kim et al. 1999; Mohideen et al. 2011, 2013; Subramanian et al. 2012; Ueno et al. 2007; Wang et al. 2002, 2003; Yu et al. 2001).

[underlined: Agency Contact (Chemical Manager)]: Nickolette Roney

## 1-Bromopropane Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1-Bromopropane
CAS Number: | 106-94-5
Date: | August 2017
Profile Status: | Final
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 55
Species: | Rat

[underlined: Minimal Risk Level]: 0.1 [ ] mg/kg/day [X] ppm

[underlined: Reference]: Honma T, Suda M, Miyagawa M. 2003. Inhalation of 1-bromopropane causes excitation in the central nervous system of male F344 rats. Neurotoxicology 24(4–5):563–575.12900070

[underlined: Experimental design]: The study examined the effects of 1-bromopropane on several neurobehavioral tests conducted in rats. Tests included locomotor activity, open field behavior, passive avoidance test, water maze test, traction test and rota-rod tests. Body weight and temperature were also monitored. Groups of male F-344 rats (4 per group) were exposed whole-body to 0, 10, 50, 200, or 1,000 ppm 1-bromopropane vapors 8 hours/day, 7 days/week for 3 weeks. All tests were conducted at various times after a 3-week exposure period except for a traction test that was also conducted on exposure days 1, 7, and 14.

[underlined: Effect noted in study and corresponding doses]: Rats in the 1,000 ppm lost weight during the 3-week exposure period. At termination of exposure, body weight in the 1,000 ppm group was about 12% lower than in controls. However, it recovered over the next 25 days. Body temperature also was significantly reduced in 1,000 ppm group, especially during exposure days 1–7, but recovered when exposure ceased. Spontaneous locomotor activity was significantly increased in rats exposed to 50 ppm 1-bromopropane on post-exposure days 1, 2, and 3 and in the group exposed to 200 ppm on post-exposure days 1, 2, 3, and 4 (locomotor activity was not tested in rats exposed to 1,000 ppm 1-bromopropane). The open field test showed that exposure to 1-bromopropane reduced freezing time (all doses, but not significantly), significantly increased ambulation and rearing at 200 ppm, had no significant effect on preening, and significantly reduced defecation/urination at 1,000 ppm. Exposure to 1-bromopropane did not affect passive avoidance behavior. 1-Bromopropane increased latency time in the water maze test in the 1,000 ppm group. In addition, 1-bromopropane at 200 and 1,000 ppm decreased traction performance indicating decreased muscle strength. Performance in the rota-rod test (motor coordination) was not significantly affected. Of all the parameters examined, locomotor activity appeared to be the most sensitive and a NOAEL and LOAEL of 10 ppm and 50 ppm, respectively can be defined based on this test.

[underlined: Dose and end point used for MRL derivation:] NOAEL of 10 ppm for neurological effects in male rats.

[ X ] NOAEL [ ] LOAEL

The spontaneous locomotor activity results were presented graphically; however, the data were not amenable for extraction using GrabIt! Software (version XP2). Thus, the NOAEL/LOAEL approach was used to identify the POD for the MRL. The data (Figure 3 in the study) are presented as changes in spontaneous locomotor activity relative to pre-exposure levels (assigned as 100% activity) for each day post-exposure that the test was performed (up to 6 days post-exposure). The selection of which post-exposure day (1–6) to model to compare treated and controls would have been entirely arbitrary.

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 3 for extrapolation from animals to humans with dosimetric adjustment
- [X] 10 for human variability

MRL = 3.33 ppm / 30 ( UF ) = 0.1 ppm

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]:

NOAEL_[ HEC ]_ = NOAEL_[ ADJ ]_ × ( H_b/g_ A / H_b/g_ H )

where:

- NOAEL_[ADJ]_ = 10 ppm × 8 hours/24 hours = 3.33 ppm
- H_b/g_A = animal blood:air partition coefficient = 11.7 (NTP-CERHR 2004)
- H_b/g_H = human blood:air partition coefficient = 7.08 (NTP-CERHR 2004)

( H_b/g_ A / H_b/g_ H ) = 11.7 / 7.08 = 1.653

Because the ratio of the partition coefficients is >1, a default value of 1 was used.

NOAEL_HEC]_ = 3.33 ppm × 1 = 3.33 ppm

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes, see above.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: No human data suitable for MRL derivation. However, the human data available suggests that the nervous system is a target for 1-bromopropane toxicity. There are two publications of human cases exposed for intermediate durations (from weeks to months) that provide exposure levels. A case discussed by Ichihara et al. (2002) (case 3) was a woman who showed signs of staggering and numbness and paresthesias in the feet, thighs, lower back, and hips, and complained of headaches after 2 months of using 1-bromopropane as a solvent with a spray gun. Estimates of the exposure levels using a passive sampler indicated that the daily TWA concentration ranged from 60 to 261 ppm with an average of 133±67 ppm (SD). Raymond and Ford (2007) reported that four workers developed severe ataxia, sensory motor, and cognitive impairments soon after the introduction of 1-bromopropane into their workplace as a furniture adhesive. A survey conducted by NIOSH 9 months after the four workers became ill showed that the workers could have been exposed to a mean concentration of 1-bromopropane of 107 ppm (range 58–254 ppm).

[underlined: Agency Contact (Chemical Manager)]: Nickolette Roney

## 1-Bromopropane Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1-Bromopropane
CAS Number: | 106-94-5
Date: | August 2017
Profile Status: | Final
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 89
Species: | Human

[underlined: Minimal Risk Level]: 0.02 [ ] mg/kg/day [X] ppm

[underlined: Reference]: Li W, Shibata, E, Zhou Z, 2010. Dose-dependent neurologic abnormalities in workers exposed to 1-bromopropane. J Occup Environ Med 52(8):769–777.20657306

[underlined: Experimental design]: The study examined the exposure-dependent effects of 1-bromopropane in a population of workers and age-, sex-, and region-matched controls in three 1-bromopropane production plants in China. The purity of the 1-bromopropane manufactured was >96% in one factory and ≥99% in the other two factories. The factories were evaluated at different times, but within the 2001–2005 year period. The final analysis comprised 120 women (60 exposed, 60 referents) and 52 men (26 exposed, 26 referents). The referents were randomly recruited from various factories not involved with 1-bromo propane; however, no monitoring data were available in the control factories. Workers from 1-bromopropane production plants could potentially be exposed to 1-bromopropane during: adding the chemical into the reaction pots; sitting close to the reaction pots to observe and record the temperature; taking out the crude product; adding hydroxy carbonate and stirring; or pouring the product into drums. No protective masks were worn in any of the factories studied, but in one of the factories investigated in 2001, the workers wore plastic gloves. The exposure periods ranged from 35.9 to 47.0 months. Workers were asked to fill out a questionnaire that included age, sex, smoking or drinking habits, education, past or present illnesses, and previous exposure to other chemicals and duration of exposure to 1-bromopropane. Electrophysiological studies measured motor nerve conduction velocity, distal latency, F-wave conduction velocity in the tibial nerve, sensory nerve conduction velocity in the sural nerve, and amplitude of the electromyography (EMG) elicited by stimulation of the motor nerve, and F-wave and potential of sensory nerve. Vibration sense was measured in the big toe, and reflexes and muscle strength were scored in four limbs. Various neurobehavioral tests, including Santa Ana, simple reaction time, digit symbol, Benton test, digit span, and pursuit aiming tests, were conducted. The report, however, does not indicate how often the tests were conducted. Comprehensive hematological and clinical tests were also conducted in addition to measuring serum TSH, LH, FSH, estradiol (females), and testosterone (males). Assessment of individual exposure to 1- and 2-bromopropane was done by analyzing the content of passive samplers attached to each worker during one 8- or 12-hour shift. This was done twice for two shifts and the average exposure level was used as the representative exposure level. Individual TWA exposure to 1-bromopropane ranged from 0.07 to 106.4 (median ± interquartile range, 6.6±16.3) ppm for females and from 0.06 to 114.8 (median ± interquartile range, 4.6±11.6) ppm for males. Females were classified into low-, mid-, and high-exposure groups (median exposures of 1.28, 6.6, and 22.58 ppm, respectively) and males into low- and high-exposure groups (median exposures of 1.05 and 12.5 ppm, respectively). Data were analyzed in three different ways. Continuous variables were analyzed with ANOVA followed by Dunnett’s multiple comparison and scores of reflex and muscle strength were compared using nonparametric Wilcoxon test. Linear regression analysis was performed to confirm the trend with the exposure level or the product of exposure level and period of exposure (cumulative exposure). The median value of each exposure group (rather than individual exposures) was used for regression analysis or analysis of covariance (ANCOVA) on the exposure level.

[underlined: Effect noted in study and corresponding doses]: Dunnett’s multiple comparison following ANOVA showed significant differences between controls and exposed female groups for tibial distal latency (increase), sural sensory nerve conduction velocity (decrease), vibration sense threshold (increase), fatigue, serum LDH (increase), serum TSH (increase), serum FSH (increase), estradiol (decrease), white blood cell (decrease), red blood cells (decrease), and hemoglobin and hematocrit (decrease). The most sensitive effect was increased vibration sense threshold, which showed significant effects in all exposure groups. No differences between controls and exposed men were seen except for increased BUN in exposed men. Regression analysis adjusting for alcohol exposure and pair-matching for age, sex, and region in selecting controls showed significant trends in tibial distal latency, vibration sense in toes, Benton test (test for visual perception and memory), BUN, LDH, TSH, red blood cells, hematocrit, and platelets in females. In males, only BUN showed a significant trend. The same regression analysis on the product of exposure levels and duration of exposure (cumulative exposure) showed significant increases in tibial distal latency, vibration sense threshold, BUN, LDH, CK, TSH, MCV, MCH, red blood cells, and hematocrit in female workers and in BUN and Santa Ana non-preferred hand in male workers. Because estimation of vibration loss is influenced by the examining neurologist and body weight, which were not controlled for in the regression analysis, an ANCOVA analysis on 1-bromopropane exposure level (or 1-bromopropane cumulative exposure level), neurologist, age, height, body weight, and alcohol consumption was conducted in female workers (n=60/group; body weight data was unavailable for five age-matched pairs, so these pairs were assigned the average body weight of the group). The results showed that the effect of 1-bromopropane and cumulative 1-bromopropane were significant; however, the effect of examining neurologist was also significant.

This study has a number of limitations, some of which were identified by the investigators or pointed out by others (Smith et al. 2011). Of particular concern for the chronic inhalation MRL derivation are the following limitations: (1) the cross-sectional study design; (2) potential selection bias for the control group; (3) potential underestimation of 1-bromopropane exposure levels; (4) lack of biomonitoring data for controls; and (5) concerns regarding the vibration sense measurement method utilized in the study.

1. ATSDR acknowledges that use of a cross-sectional study design limits the ability to identify a cause-effect relationship between 1-bromopropane and observed effects. However, supporting evidence from two other cross-sectional studies and several case-reports supported an association between neurotoxic effects and exposure to 1-bromopropane (Ichihara et al. 2002; Majersik et al. 2007; NIOSH 2002, 2003a; Raymond and Ford 2007; Samukawa et al. 2012; Sclar 1999; Wang et al. 2015).
2. ATSDR acknowledges that there may be selection bias in the identification of the age-, sex-, and region-matched controls. While the investigators stated that controls were “randomly” selected from adjacent factories, it is unclear what methods were used to randomly select controls.
3. ATSDR acknowledges that estimated 1-bromopropane exposures provided by the study investigators may be lower than actual exposures. The study authors indicated that windows and doors were wide open during the working hours, but it is reasonable to assume that windows and/or doors may have been closed during rainy or cold weather. If monitoring was conducted with windows and doors open, the exposure levels would be greater if windows and doors were closed. Study authors also indicate uncertainties in the cumulative exposure assessment, as measurements were taken over a 1–3-day period and presumed to be the same level for entire duration of employment. Additionally, no details for the sampling rate on personal monitors was provided and indoor air temperature during monitoring was not reported (temperature is essential to convert the mass concentration in mg/m^3^ to ppm). Furthermore, exposure levels were not reported by factory or job description, which would have led to a more meaningful evaluation of results. Also, potential dermal exposure from lack of wearing gloves and oral exposure if hands were not properly washed prior to eating may have contributed to exposure levels beyond measured air levels (Smith et al. 2011). In response, the study investigators clarified that plastic gloves were worn in at least one of the factories, decreasing the potential for dermal/oral exposure (Ichihara et al. 2011), but it does not appear that gloves were worn in other factories.
4. Smith et al. (2011) raised concerns regarding lack of biomonitoring data for controls from nearby factories not using 1-bromopropane, particularly the lack of exposure data for other potentially neurotoxic chemicals. However, ATSDR agrees with the study investigators, who proposed that if neurotoxic chemical exposure did occur at control factories it would only serve to underestimate the neurotoxic effects in the bromopropane-exposed group of workers (Ichihara et al. 2011).
5. ATSDR acknowledges that the 128 Hz tuning fork is not the best choice for quantitative analysis of vibration sense between individuals, as more specialized equipment is available that would have produced more quantitatively accurate results (such as the quantitative Rydel-Seiffer 64 Hz tuning fork, bio/neurothesiometer, or Computer Assisted Sensation Examination IV [CASE IV]) (Burns et al. 2002; Levy 2010; Nizar et al. 2014; Pestronk et al. 2004; Willits et al. 2015). Identification of clinical vibration impairment using a tuning fork has been shown to overestimate the quantitative vibration threshold (identified by the CASE IV system), and the discordance was associated with age, height, and body surface area of the subject (Burns et al. 2002). However, the study authors acknowledged that clinical assessment of vibration threshold using a tuning fork is inherently inaccurate due to examiner bias and subject characteristics (age, weight, height), and reported that findings remained significant after statistical adjustment for examiner and subject characteristics. A follow-up letter to the editor by the study investigators clarified that examiners were blinded to the exposure group (Ichihara et al. 2011), which was an initial concern raised by Smith et al. (2011). Other studies evaluating the 128 Hz tuning for the ability to accurately detect loss of vibration sense in patients with diabetic neuropathy reported a sensitivity (ability to diagnose condition if present) of 40–69% and a specificity (ability to diagnose lack of condition) of 90–100%, compared with detection using the neurothesiometer (which is considered the diagnostic tool of choice) (Nizar et al. 2014; Willits et al. 2015). These values indicate that use of a 128 Hz tuning fork to clinically identify loss of vibration sense will most likely underestimate (rather than overestimate) the presence of dysfunction. Additionally, by placing the tuning fork on the examiner’s foot (once subjects indicated they could no longer feel vibration), the study investigators deviated from the standard protocol (as described by Gilman 2002), which involves removing the tuning fork from the subject and placing it on the examiner’s fingers (which are much more sensitive). This deviation would also most likely underestimate (rather than overestimate) the presence of dysfunction. Taking into consideration all available evidence, while the 128 Hz tuning fork is not the most sensitive or quantitative assessment tool, it was able to detect statistically significant differences between control and exposed groups after adjusting for examiner and subject characteristics (age, weight, height). Therefore, ATSDR considered data obtained using this method adequate for the derivation of the chronic inhalation MRL.

Other limitations of the study identified by Smith et al. (2011) or the study authors include: (1) lack of control of the temperature of the skin of the legs may have impacted measurements of nerve conduction velocity; (2) abnormally high control values for tibial nerve distal latency; (3) co-exposure to low levels of 2-bromopropane in the exposed group of workers (which has been shown to have reproductive and hematopoietic effects on workers and animals); and (4) no data on menstrual cycle of females (which could have influenced some hematology and some clinical chemistry results). While these limitations are acknowledged by ATSDR, they do not directly impact end points used in the MRL derivation because they relate either to neurological end points not selected as the basis for the MRL (limitations 1 and 2) or to non-neurological end points (limitations 3 and 4).

Despite the limitations of this study, ATSDR still considers the study by Li et la. (2010) as the most appropriate study for deriving the chronic inhalation MRL (see further discussion in [underlined: Other additional studies or pertinent information that lend support to this MRL] section below). However, it is noted that the confidence in this MRL is low due to the acknowledged limitations.

The results of the study by Li et al. (2010) suggest a minimal LOAEL of 1.28 ppm based on a statistically significant increase in the vibration sense threshold in female workers. Women in this exposure group also showed significantly slower sural nerve conduction velocity; however, this effect was not selected as the critical effect as it was not observed consistently in higher exposure groups and was not significant based on regression analysis. Other neurological effects observed in this study at higher exposures (≥6.6 ppm) in female workers included increased tibial nerve distal latency. Effects observed in hematology and clinical chemistry are not considered by ATSDR to be biologically relevant because they were small in magnitude and were generally within human reference ranges. No NOAEL was identified for this study.

[underlined: Dose and end point used for MRL derivation]: 1.28 ppm

[ ] NOAEL [ X ] LOAEL

A minimal LOAEL of 1.28 ppm was identified for mild neurological impairment in females (increased vibration sense threshold). No NOAEL was identified. BMD modeling was conducted on this end point; however, no models provided an adequate fit.

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 3 for use of a minimal LOAEL
- [ ] 10 for extrapolation from animals to humans
- [X] 10 for human variability

MRL = 1.28 × 5 days / 7 days × 12 hours / 24 hours = 0.46 ppm MRL = 0.46 ppm / 30 ( UF ) = 0.02 ppm

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? The exposure concentration was adjusted to continuous exposure basis as shown above. Although Li et al. (2010) report median exposure levels based on TWA concentrations for 8- or 12-hour work shifts, the majority of workers (65%) had 12-hour work shifts.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Candidate principal studies considered for deriving the chronic inhalation MRL are shown in Table A-3. Of the candidate human studies, only the Li et al. (2010) study was adequate for consideration. The NIOSH occupational health surveys (2002, 2003a) did not contain a reference group. Among the candidate animal studies, the lowest LOAEL was for various histological alterations in the respiratory tract of mice (Morgan et al. 2011; NTP 2011); LOAELs from other available studies occur at much higher concentrations. Therefore, both the Li et al. (2010) study in humans and the Morgan et al. (2011) study in mice were further evaluated as potential principal studies. The critical effects, PODs, uncertainty factors, and candidate MRL for each option are presented in Table A-4. Candidate MRLs based on the key human and animal studies are almost the same (0.02 and 0.03 ppm, respectively); rationale for selection of the human study over the animal study as the critical study is discussed below.

Table A-3 Studies Considered for Deriving the Chronic-Duration Inhalation MRL

Study | End point(s) evaluated | Significant effects at LOAEL | NOAEL (ppm) | LOAEL (ppm)
Human studies
Li et al. (2010); Cross-sectional occupational exposure study; average exposure duration ~40 months | Hematology, clinical chemistry (including thyroid and reproductive hormones), neurological evaluation (nerve conduction velocity, vibration sense, neurobehavioral testing) | Increased vibration threshold | ND | 1.28
NIOSH (2003a); Cross-sectional occupational health survey; average exposure duration ~29 months | Hematology, clinical chemistry, questionnaire for neurological deficits, nerve conduction velocity | Subjective complaints of neurotoxicity | ND | 45.7
NIOSH (2002); Cross-sectional occupational health survey; exposure duration 4–9 years | Hematology, questionnaire for neurological and reproductive deficits | Subjective complaints of neurotoxicity | ND | 117.1
Animal studies
Morgan et al. (2011); NTP (2011); B6C3F1 mice, 105 weeks | Comprehensive 2-year bioassay; neurological function not assessed | Various histological alterations in the nasal respiratory epithelium, larynx, trachea, and bronchioles | ND | 62.5
Morgan et al. (2011); NTP (2011); F-344 rats, 105 weeks | Comprehensive 2-year bioassay; neurological function not assessed | Glandular hyperplasia in the nose (both sexes), chronic active nasal inflammation (females) | ND | 125
BSOC (2001a); Sprague-Dawley rats, 2 generations (~16–18 weeks per generation) | Comprehensive 2-generation reproductive toxicity study; neurological function not assessed | Hepatocellular vacuolization in F0 and F1 males, reduced prostate weight in F0 males | 100 | 250

LOAEL = lowest-observed-adverse-effect level; MRL = Minimal Risk Level; ND = not determined; NOAEL = no-observed-ad verse-effect level

Table A-4 Options for Derivation of Chronic-Duration Inhalation MRL Based on Principal Chronic Human and Animal Studies

Study | Critical effect | POD (ppm) | UF | MRL (ppm)
Human study Li et al. (2010) | Decreased vibration sense | 0.46 ppm; (LOAEL_CONV_) | 30; 10 for human variability; 3 for use of minimal LOAEL | 0.02
Mouse study Morgan et al. (2011); NTP (2011) | Respiratory lesions | 0.78; (BMCL_10HEC_) | 30; 10 for human variability; 3 for dosimetric adjustment | 0.03

BMCL = lower limit on the benchmark concentration; CONV = converted to continuous exposure; HEC = human equivalent concentration; LOAEL = lowest-observed-adverse-effect level; MRL = Minimal Risk Level; POD = point of departure; UF = uncertainty factor

Decreased vibration sense was identified as the most sensitive effect in the human occupational study by Li et al. (2010). As discussed above, there are numerous limitations to this study; however, the identification of neurological impairment as the critical effect is supported by the NIOSH occupational surveys and several human case reports of workers exposed to 1-bromopropane at workplace air concentrations >45 ppm for weeks to years. No other available study evaluated the reportedly low exposure levels (median exposures of 4.6 ppm in men and 6.6 ppm in women) reported in the Li et al. (2010) study. Reported neurological effects in workers in these other studies ranged from mild neurological impairments and complaints, such as numbness and tremors, to frank neurotoxic effects requiring hospitalization, such as ataxia, spastic paraparesis, and symmetric demyelinating polyneuropathy (Ichihara et al. 2002; Majersik et al. 2007; NIOSH 2002, 2003a; Raymond and Ford 2007; Samukawa et al. 2012; Sclar 1999; Wang et al. 2015). Several of the case studies reported decreased vibration sense, particularly in the lower extremities (Ichihara et al. 2002; Majersik et al. 2007; Raymond and Ford 2007; Samukawa et al. 2012; Sclar 1999), supporting the selection of increased vibration sense threshold in the toe from the Li et al. (2010) study as the critical effect.

Animal studies provide supporting evidence that exposure to 1-bromopropane can result in neurotoxicity. Although neurological function has not been evaluated in animals following chronic exposure, observed effects in acute- and intermediate-duration inhalation rat studies at concentrations as low as 50 ppm included changes in neurobehavior, muscle strength, electrophysiology, morphology, and biochemistry (Fueta et al. 2002; Honma et al. 2003; Ichihara et al. 2000b; Kim et al. 1999; Mohideen et al. 2011, 2013; Subramanian et al. 2012; Ueno et al. 2007; Wang et al. 2002, 2003; Yu et al. 2001).

In the chronic mouse study, lesions in the lung and nasal epithelium were the most sensitive effects occurring at the lowest tested concentration, 62.5 ppm (Morgan et al. 2011; NTP 2011). Lesions in the lung and nasal epithelium were also found in F-344 rats at the lowest tested concentration, 125 ppm (Morgan et al. 2011; NTP 2011). In intermediate-duration animal studies, respiratory tract lesions were found in mice exposed to concentrations as low as 125 ppm for 2–14 weeks (NTP 2011), but were not found in F-344 rats at concentrations up to 1000 ppm for 14 weeks (NTP 2011), Sprague-Dawley rats at concentrations up to 1,800 ppm for 8–13 weeks (Albemarle Corporation 1997; Kim et al. 1999), or Wistar rats at concentrations up to 800 ppm for 12 weeks (Ichihara et al. 2000a). These results suggest that mice are more sensitive to respiratory effects than rats following intermediate-duration inhalation exposure. Several acute and intermediate-duration rat studies found neurological effects at concentrations lower than those causing respiratory effects (as low as 50 ppm, see previous paragraph), providing support for neurological effects as the critical effects following acute and intermediate-duration exposure. In humans, the only evidence for respiratory effects was mild respiratory irritation reported in case studies of workers experiencing frank neurotoxicity following exposure to >100 ppm 1-bromopropane (Ichihara et al. 2002; Raymond and Ford 2007). The relative severities of the respiratory and neurotoxic effects in these cases suggest that humans are more susceptible to neurotoxic effects from 1-bromopropane than respiratory effects.

Based on available data, neurological effects appear to be the most sensitive effect for workers repeatedly exposed to 1-bromopropane and in animals exposed to 1-bromopropane for acute and intermediate durations. Neurological effects in chronically exposed animals, however, have not been adequately studied to characterize the relative sensitivity of neurological effects versus respiratory effects. In the absence of this information, a comparison was made of MRLs based on the minimal LOAEL for neurological effects in workers in the Li et al. (2010) study and the LOAEL for respiratory tract lesions in mice exposed for 2 years (Morgan et al. 2011; NTP 2011). The resultant MRLs were numerically equivalent (Table 3). Despite the limitations in the principal human study, ATSDR still considers Li et al. (2010) the best available study on which to base the MRL, principally because it is based on human data. ACGIH (2014) also used the same study to recommend a TLV-TWA of 0.1 ppm based on the LOAEL of 1.28 ppm for decreased vibration sense in toes from female workers in the Li et al. (2010) study. The TLV-TWA is TWA concentration for a conventional 8-hour workday and a 40-hour workweek, to which it is believed that nearly all workers may be repeatedly exposed, day after day, for a working lifetime without adverse effect (AGCIH 2016). Confidence in the chronic MRL is low because of the limitations of the principal study, but could be improved with additional and better-designed neurological evaluations (cross-sectional or prospective) of workers exposed to 1-bromopropane in workplace air.

[underlined: Agency Contact (Chemical Manager)]: Nickolette Roney

## 1-Bromopropane Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1-Bromopropane
CAS Number: | 106-94-5
Date: | August 2017
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 7
Species: | Rat

[underlined: Minimal Risk Level]: 0.2 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Zhong Z, Zeng T, Xie K, 2013. Elevation of 4-hydroxynonenal and malondialdehyde modified protein levels in cerebral cortex with cognitive dysfunction in rats exposed to 1-bromopropane. Toxicology 306:16–23.23395825

[underlined: Experimental design]: The study examined the effects of 1-bromopropane on cognitive function in male Wistar rats and the possible role of oxidative stress. Groups of rats (10/group) were administered 0, 200, 400, or 800 mg 1-bromopropane/kg/day by gavage in corn oil for 12 consecutive days. On days 8–12, cognitive function (spatial learning and memory) was assessed with the Morris water maze test. Twenty-four hours after the last dose, the rats were killed, and the cerebral cortex was removed. The following were measured in cerebral cortex homogenates: GSH, oxidized glutathione (GSSG), total thiol (total -SH) content, GSH reductase and GSH peroxide (GSH-Px) activities, and MDA level, as well as 4-HNE and MDA modified proteins.

[underlined: Effect noted in study and corresponding doses]: Some rats in the 400 and 800 mg 1-bromopropane/kg/day groups showed irritability at the start of dosing. After 1 week of dosing, rats in the 800 mg 1-bromopropane/kg/day group showed slow response and sluggishness. Final body weight was reduced about 13% in the high-dose group; no data on food consumption were provided. Dose-related impairments were observed in learning and memory measures of the Morris water maze. During the 4-day learning phase, the escape latency was significantly increased in the 800 mg 1-bromopropane/kg/day group and the total swimming distance was increased at ≥200 mg 1-bromopropane/kg/day. Time spent in different swimming “search” patterns (direct finding, approaching target, random searching, and thigmotaxis) differed significantly in all exposed groups, compared with controls, with exposed animals showing increased thigmotaxis (time spent in periphery of tank). On day 5, when the escape platform was removed to assess memory, all exposure groups showed a significant decrease in the number of times they crossed the former location of the target platform; rats exposed to 800 mg 1-bromopropane/kg/day also showed a significant decrease in time spent in the target quadrant. Assessment of biochemical indices showed an increase in oxidative stress (increased MDA and GSSG, decreased GSH, and decreased GSH reductase activities), mostly observed in the mid- and high-dose groups. Tests with specific monoclonal antibodies also showed increased total levels of reactive aldehyde modified proteins in the cerebral cortex.

A LOAEL of 200 mg/kg/day was identified for this study based on impaired spatial learning and memory (increased swimming distance, altered search pattern, decreased number of crossings of the escape platform); no NOAEL was identified. All data were presented graphically. The SDs could not be extracted from day 1–4 figures either because they overlapped between dose-groups (total swimming distance) or they were not reported (distribution of search patterns); therefore, these data could not be used for BMD analysis. However, the means and SDs for the number of crossing of the escape platform (assessed on day 5) were extracted digitally using GrabIt! software (version XP2) for BMD analysis (Table A-5). Alternate data extraction of the means and SDs using DigitizeIt software resulted in BMDLs that differed by <17% on average, which would yield the same MRL.

Table A-5 Digitized Dataset for Number of Crossings of Escape Platform Location on Day 5^a^

Dose (mg/kg/day) | Animal number | Mean (number) | Standard deviation
0 | 10 | 7.2 | 2.8
200 | 10 | 4.3^b^ | 2.6
400 | 10 | 3.7^c^ | 2
800 | 10 | 2.4^c^ | 2

a Data extracted from Figure 3B in Zhong et al. (2013).

b p<0.05.

c p<0.01.

[underlined: Dose and end point used for MRL derivation]: 19.75 mg/kg/day

[ ] NOAEL [ ] LOAEL [ X ] BMDL_1 SD_

All models provided an adequate and nearly equivalent fits (see Table A-6) by the various statistical criteria, but the BMDLs had a 15.4-fold range, indicating some model dependence of the BMDL estimates. The range of results is judged to be reasonable, because the range of the absolute differences between the individual BMDs and their corresponding BMDLs was comparable, ranging from about 111 to 130 mg/kg/day. Because the BMDL estimates are not sufficiently close, selecting the model with the lowest BMDL is recommended (EPA 2012b). Thus, the BMDL of 19.75 mg/kg/day from the Hill model is a reasonable conservative estimate. The Hill model calculates BMD_1SD_ and BMDL_1SD_ values of 148.37 and 19.75 mg/kg/day, respectively, for decreased spatial memory in rats on day 5 of the Morris water test (see Figure A-2).

Table A-6 Model Predictions for Effects of 1-Bromopropane on the Spatial Memory Ability of Rats

Model | Test for significant difference p-value^a^ | Variance p-value^b^ | Means p-value^b^ | Scaled residuals^c^ | | | AIC | BMD_1SD_ (mg/kg/day) | BMDL_1SD_ (mg/kg/day)
Model | Test for significant difference p-value^a^ | Variance p-value^b^ | Means p-value^b^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_1SD_ (mg/kg/day) | BMDL_1SD_ (mg/kg/day)
All doses
Constant variance
Exponential (model 2)^d^ | 0.002 | 0.61 | 0.45 | −0.9692 | 0.0365 | 0.579 | 112.63 | 266.03 | 154.01
Exponential (model 3)^d^ | 0.002 | 0.61 | 0.45 | −0.9692 | 0.0365 | 0.579 | 112.63 | 266.04 | 154.01
Exponential (model 4)^d^ | 0.002 | 0.61 | 0.52 | 0.0777 | −0.3698 | 0.4757 | 113.46 | 165.96 | 55.12
Exponential (model 5)^d^ | 0.002 | 0.61 | 0.52 | 0.0777 | −0.3698 | 0.4757 | 113.46 | 165.96 | 55.12
Hill^d,e^ | 0.002 | 0.61 | 0.63 | 0.0291 | −0.247 | 0.384 | 113.29 | 148.37 | 19.75
Linear^f^ | 0.002 | 0.61 | 0.15 | −1.22 | −0.573 | 1.2 | 114.85 | 435.59 | 305.49
Polynomial (2-degree)^f^ | 0.002 | 0.61 | 0.15 | −1.22 | −0.573 | 1.2 | 114.85 | 435.59 | 305.49
Polynomial (3-degree)^f^ | 0.002 | 0.61 | 0.15 | −1.22 | −0.573 | 1.2 | 114.85 | 435.59 | 305.49
Power^d^ | 0.002 | 0.61 | 0.15 | −1.22 | −0.573 | 1.2 | 114.85 | 435.59 | 305.49

a Values >0.05 fail to meet conventional goodness-of-fit criteria.

b Values <0.10 fail to meet conventional goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the benchmark dose; also the largest residual at any dose.

d Power restricted to ≥1.

e Selected model. With constant variance applied, all the models provided an adequate fit to means. BMDLs for models providing adequate fit differed by >threefold, so the model with the lowest BMDL (Hill) was selected. The Hill model also provided the best fit in the low-dose range (based on scaled residuals).

f Coefficients restricted to be negative.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure concentration associated to a change in the mean response equal to one control standard deviation from the control mean)

Figure A-2 Selected Model (Hill) for Impaired Spatial Memory Following Exposure to 1-Bromopropane (Zhong et al. 2013)

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

MRL = 19.75 mg/kg/day ÷ 100 = 0.2 mg/kg/day

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? [underlined: Not applicable.]

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Marked decreases in spontaneous activity (sedation), piloerection, and dyspnea were reported in rats exposed once to 2,000 mg 1-bromopropane/kg in a lethality study by Elf Atochem S.A. (1993). Clinical signs were observed within 4 hours of dosing; surviving animals (9/10) fully recovered by day 2 of the 14-day observation period. Of direct relevance to the results of Zhong et al. (2013) are the results of a recent study by the same groups of investigators, which confirmed the previous results and reported that treatment of male Wistar rats with ≥200 mg 1-bromopropane/kg/day for 12 days impaired spatial memory and spatial learning ability (Guo et al. 2015). In this study, rats exposed to ≥200 mg 1-bromopropane/kg/day tested in the Morris Water Maze showed a significantly dose-related decreased percent of time at the target platform; the NOAEL was 100 mg 1-bromopropane/kg/day. Modeling these data yielded a BMDL_1SD_ (POD) of 77.94 mg 1-bromopropane/kg/day, which is higher than the BMDL_1SD_ of 19.75 mg 1-bromopropane/kg/day used to derive the current MRL. Therefore, it is still more appropriate (more protective) to use data from Zhong et al. (2013) to derive an acute-duration oral MRL for 1-bromopropane. Also relevant is another study from the same group of investigators that reported motor abnormalities in rats administered ≥200 mg 1-bromopropane/kg/day for up to 16 weeks (Wang et al. 2012). Only limited data from this study were available for review.

While evidence for neurotoxicity following oral exposure is limited, human and animal evidence from inhalation studies indicate that the nervous system is a target for 1-bromopropane toxicity. Mild neurological symptoms have been reported in humans at median TWA workplace air levels as low as 1.28 ppm (Li et al. 2010), and two NIOSH health surveys and several case reports of workers exposed for months to years indicate that higher exposure levels (>45 ppm) can lead to more severe, even permanent, effects (Ichihara et al. 2002; Majersik et al. 2007; NIOSH 2002; Raymond and Ford 2007; Samukawa et al. 2012; Sclar 1999). Neurological effects ranged from mild neurological impairments and complaints with acute exposure, such as headache, numbness and weakness, to frank neurotoxic effects requiring hospitalization following exposure for months or years, such as ataxia, spastic paraparesis, and symmetric demyelinating polyneuropathy. Evidence from animal studies supports that exposure to 1-bromopropane can result in neurotoxic effects. Observed effects in acute and intermediate-duration inhalation studies at concentrations as low as 50 ppm included changes in neurobehavior, muscle strength, electrophysiology, morphology, and biochemistry (Fueta et al. 2002; Honma et al. 2003; Ichihara et al. 2002; Kim et al. 1999; Mohideen et al. 2011, 2013; Subramanian et al. 2012; Suda et al. 2008; Ueno et al. 2007; Wang et al. 2002, 2003; Yu et al. 2001; Zhang et al. 2013).

All other effects observed in acute studies occurred at or above the LOAEL of 200 mg 1-bromopropane/kg/day identified in the neurobehavioral study by Zhong et al. (2013). Observed effects included reduced antibody responses to the T-dependent SRBC antigen at ≥200 mg 1-bromopropane/kg/day (Lee et al. 2007); congestion, hemorrhage, cellular swelling and vacuolization of hepatocytes in mouse liver at ≥500 mg 1-bromopropane/kg/day, but not 200 mg 1-bromopropane/kg/day (Lee et al. 2007); degeneration of spermatocytes in mouse testes at 600 mg 1-bromopropane/kg/day (only dose tested) (Yu et al. 2008); and a 13% decrease in body weight at 800 mg 1-bromopropane/kg/day, but not ≤400 mg 1-bromopropane/kg/day (Zhong et al. 2013). While the LOAEL of 200 mg 1-bromopropane/kg/day for immune effects was considered as the basis of the MRL, the evidence supporting that 1-bromopropane is an immunosuppressant (Anderson et al. 2010; Lee et al. 2007) is far less than the evidence indicating that 1-bromopropane is a neurotoxicant (discussed above).

[underlined: Agency Contact (Chemical Manager)]: Nickolette Roney