# PEER REVIEW

A peer review panel was assembled for 1,4-dioxane. The panel consisted of the following members:

1. Dr. George Alexeeff, Deputy Director for Scientific Affairs, Office of Environmental Health Hazard Assessment, CAL/EPA, Oakland, California;
2. Dr. Phillip Leber, Consultant in Toxicology, Akron, Ohio;
3. Dr. Raghubir Sharma, Emeritus Fred C. Davison Distinguished Chair in Toxicology, Department of Physiology and Pharmacology, University of Georgia College of Veterinary Medicine, Athens, Georgia; and
4. Dr. Alan Stern, Chief, Bureau for Risk Analysis, Division of Science and Research, Bureau for Risk Assessment, New Jersey Department of Environmental Protection, Trenton, New Jersey.

These experts collectively have knowledge of 1,4-dioxane’s physical and chemical properties, toxicokinetics, key health end points, mechanisms of action, human and animal exposure, and quantification of risk to humans. All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers' comments and determined which comments will be included in the profile. A listing of the peer reviewers' comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound.

The citation of the peer review panel should not be understood to imply its approval of the profile's final content. The responsibility for the content of this profile lies with the ATSDR.