# REFERENCES

* Not cited in text

Abe A. Distribution of 1,4-dioxane in relation to possible sources in the water environment. Sci Total Environ. 1999;227:41-47. [pmid: 10209880].
ACGIH. 1,4-Dioxane. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH. American Conference of Governmental Industrial Hygienists. 2011:27.
Adinolfi M. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol. 1985;27:532-537. [pmid: 4029526].
Adlercreutz H. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl. 1995;103(7):103-112.
Agency for Toxic Substances and Disease Registry. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry, Division of Toxicology. Fed Regist. 1989;54(174):37618-37634.
Agency for Toxic Substances and Disease Registry. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Subcommittee on Biomarkers of Organ Damage and Dysfunction. Atlanta, GA. Agency for Toxic Substances and Disease Registry. 1990.
Alexander M. Biotechnology report. Nonbiodegradable and other recalcitrant molecules. Biotechnol Bioengineer. 1973;15:611-647.
Altman PL, Dittmer DS. Biological handbooks: Biology data book. 2nd ed. Bethesda, MD. Federation of American Societies for Experimental Biology. 1974;Vol. III:1987-2008. 2041.
Anbar M, Neta P. A compilation of specific bimolecular rate constants for the reactions of hydrated electrons, hydrogen atoms and hydroxyl radicals with inorganic and organic compounds in aqueous solution. Int J Appl Radiat Isot. 1967;18:493-523.
Andersen ME, Krishnan K. Salem H, editor. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. Animal test alternatives: Refinement, reduction, replacement. New York. Marcel Dekker, Inc. 1994:9-25.
Andersen ME, Clewell HJ III, Gargas ML, et al. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol. 1987;87:185-205. [pmid: 3824380].
Andersen ME, Green T, Frederick CB, et al. Physiologically based pharmacokinetic (PBPK) models for nasal tissue dosimetry of organic esters: Assessing the state-of-knowledge and risk assessment applications with methyl methacrylate and vinyl acetate. Regul Toxicol Pharmacol. 2002;36(3):234-245. [pmid: 12473408].
Argus MF, Arcos JC, Hoch-ligeti C. Studies on the carcinogenic activity of protein-denaturing agents: Hepatocarcinogenicity of dioxane. J Natl Cancer Inst. 1965;35:949-958. [pmid: 4285466].
Argus MF, Sohal RS, Bryant GM, et al. Dose-response and ultrastructural alterations in dioxane carcinogenesis: Influence of methylcholanthrene on acute toxicity. Eur J Cancer. 1973;9:237-243. [pmid: 4778367].
Atkinson R. 1,4-Dioxane. Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds. New York, NY. American Chemical Society. 1989.
Barber H. Hemorrhagic nephritis and necrosis of the liver from dioxane poisoning. Guys Hosp Rep. 1934;84:267-280.
Barnes DG, Dourson M. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol. 1988;8:471-486. [pmid: 3222488].
Berger GS. Berger GS, editor. Epidemiology of endometriosis. Endometriosis: Advanced management and surgical techniques. New York, NY. Springer-Verlag. 1994.
Birkel TJ, Warner CR, Fazio T. Gas chromatographic determination of 1,4-dioxane in polysorbate 60 and polysorbate 80. J Assoc Off Anal Chem. 1979;62:931-936.
Black RE, Hurley FJ, Havery DC. Occurrence of 1,4-dioxane in cosmetic raw materials and finished cosmetic products. J AOAC Int. 2001;84:666-670. [pmid: 11417628].
Blake BW. Written communication to Moiz Mumtaz, Division of Toxicology, Agency for Toxic Substances and Disease Registry, Public Health Service, Atlanta, GA, regarding SAR assessment of 1,4-dioxane using TOPKAT programs. Rochester, NY. Health Designs Inc. 1995. As cited in De Rosa et al. 1996.
Bozzelli JW, Kemp J, Horgan L, et al. Analysis of ambient air at New Jersey locations for selected volatile organic compounds. Proc APCA Annu Meet. 1980;74:1-22.
Braun WH, Young JD. Identification of β-hydroxyethoxyacetic acid as the major urinary metabolite of 1,4-dioxane in the rat. Toxicol Appl Pharmacol. 1977;39:33-38. [pmid: 841572].
Bronaugh RL. Frost P, Horwitz SN, editors. Percutaneous absorption of cosmetic ingredients. Principles of cosmetics for the dermatologist. Minneapolis, MN. University of Minnesota Press. 1982:277-284.
Brown RP, Delp MD, Lindstedt SL, et al. Physiological parameter values for physiologically based pharmacokinetic models. Toxicol Ind Health. 1997;13(4):407-484. [pmid: 9249929].
Brown SK, Sim MR, Abramson M, et al. Concentrations of volatile organic compounds in indoor air- A review. Indoor Air. 1994;4:123-134.
BUA. GDCh-Advisory committee on existing chemicals of environmental relevance (BUA): 1,4-Dioxane: BUA Report 80. Beratergremium fur Umweltrelevante Altsoffe S. Hirzel-Wissenchaftliche Verlagsgesellschaft Stuttgart. 1994.
Buffler PA, Wood SM, Suarez L, et al. Mortality follow-up of workers exposed to 1,4-dioxane. J Occup Med. 1978;20:255-259. [pmid: 641607].
Bull RJ, Robinson M, Laurie RD. Association of carcinoma yield with early papilloma development in SENCAR mice. Environ Health Perspect. 1986;68:11-17. [pmid: 3780623].
Burmaster DE. The new pollution-groundwater contamination. Environment. 1982;24:6-13. 33. 36.
*. Burmistrov SO, Arutyunyan AV, Stepanov MG, et al. Effect of chronic inhalation of toluene and dioxane on activity of free radical processes in rat ovaries and brain. Bull Exp Biol Med. 2001;132:832-836. [pmid: 11740571].
California ARB. California Air Resources Board. 1997. http://www.arb.ca.gov/toxics/tac/factshts/1-4-diox.pdf. June 06, 2004.
Campaign for Safe Cosmetics. Cancer-causing chemical found in children's bath products. 2007. http://www.safecosmetics.org/newsroom/press.cfm?pressReleaseID=21. August 22, 2007.
Campaign for Safe Cosmetics. No more toxic tub. Getting contaminants out of children's bath and personal care products. 2009. http://www.safecosmetics.org/downloads/NoMoreToxicTub_Mar09Report.pdf. March 24, 2009.
Canter LW, Sabatini DA. Contamination of public ground water supplies by Superfund Sites. Int J Environ Stud. 1994;46:35-57.
Chang SS, Peterson RJ, Ho C. Chemical reactions involved in the deep-fat frying of foods. J Am Oil Chem Soc. 1978;1:718-727. [pmid: 730972].
ChemChannels. Chemical directories. 1,4-dioxane. 2004. http://www.chemchannels.com. June 16, 2004.
Choi SH, Kobayashi A, Yamanisnhi T. Odor of cooked small shrimp, Acetes japonicus Kishinouye: Difference between raw material and fermented product. Agric Biol Chem. 1983;47(2):337-342.
Chung T, Hayase F, Kato H. Volatile components of ripe tomatoes and their juices, purees and pastes. Agric Biol Chem. 1983;47:343-351.
City of Ann Arbor. 1,4-Dioxane and Pall Life Sciences (Gelman). City of Ann Arbor, Michigan. 2003. http://www.ci.ann-arbor.mi.us/EnvironmentalCoordination/Pall.html. July 28, 2004.
Clark B, Furlong JW, Ladner A, et al. Dermal toxicity of dimethyl acetylene dicarboxylate, n-methyl pyrrolidone, triethyleneglycol dimethy ether, dioxane and tetralin in the rat. IRCS J Med Sci. 1984;12:296-297.
Clewell HJ III, Andersen ME. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health. 1985;1(4):111-131. [pmid: 3843496].
Colborn T, Clement C. Chemically induced alterations in sexual and functional development. The wildlife/human connection. Advances in modern environmental toxicology. Princeton, NJ. Princeton Scientific Publishing Co. 1992;Vol. XXI.
Committee on Food Chemicals Codex. Food chemicals index. Food and Nutritional Board Institute of Medicine. Washington, DC. National Academy Press. 1996.
Conkle JP, Camp BJ, Welch BE. Trace composition of human respiratory gas. Arch Environ Health. 1975;30(6):290-295. [pmid: 1137435].
Conolly RB, Kimbell JS, Janszen D, et al. Human respiratory tract cancer risks of inhaled formaldehyde: Dose-response predictions derived from biologically-motivated computational modeling of a combined rodent and human dataset. Toxicol Sci. 2004;82(1):279-296. [pmid: 15254341].
Daniels DH, Warner CR, Birkel TJ. Use of closed-system vacuum distillation for isolation of moderately volatile compounds. J Assoc Off Anal Chem. 1981;64:769-771.
Daubert TE, Danner RP. 1,4-Dioxane. Physical and thermodynamic properties of pure chemicals. New York, NY. Taylor & Francis. 1985.
de Navasquez S. Experimental tubular necrosis of the kidneys accompanied by liver changes due to dioxane poisoning. J Hyg. 1935;35:540-548. [pmid: 20475302].
DeRosa CT, Wilbur S, Holler J, et al. Health evaluation of 1,4-dioxane. Toxicol Ind Health. 1996;12:1-43. [pmid: 8713712].
Dewalle FB, Chian ESK. Detection of trace organics in well water near a solid waste landfill. J Am Water Works Assoc. 1981;73:206-211.
Dietrich AM, Millington DS, Seq Y. Specific identification of synthetic organic chemicals in river water using liquid-liquid extraction and resin adsorption coupled with electron impact, chemical ionization and accurate mass measurement gas chromatography-mass spectrometry analyses. J Chromatogr. 1988;436:229-241.
Dmitriev MT, Rastiannikov EG, Mal'ysheva AG. Identification of specific micro-components of human feces. Lab Delo. 1985;10:608-614. (Russian). [pmid: 2416998].
Dow Chemical Co. Assessment of health and environmental effects of 1,4-dioxane and publications concerning 1,4-dioxane. Submitted to U.S. Environmental Protection Agency under TSCA Section 8E. OTS05166244. 1989.
Draper WM, Dhoot JS, Remoy JW, et al. Trace-level determination of 1,4-dioxane in water by isotopic dilution GC and GC-MS. Analyst. 2000;125:1403-1408. [pmid: 11002923].
Drew RT, Patel JM, Lin F. Changes in serum enzymes in rats after inhalation of organic solvents singly and in combination. Toxicol Appl Pharmacol. 1978;45:809-819. [pmid: 214898].
EC. European Union risk assessment report: CAS No. 123-91-1: EINECS No. 204-661-8: 1,4-Dioxane. Luxembourg. European Communities, Institute for Health and Consumer Protection, European Chemicals Bureau. 2002. http://ecb.jrc.it/Documents/Existing-Chemicals/RISK_ASSESSMENT/REPORT/dioxanereport038.pdf. July 09, 2004.
EPA. Project summary: Indoor air pollutants from household product sources. Las Vegas, NV. U.S. Environmental Protection Agency. 1992. EPA600S491025.
EPA. Final report on ambient concentration summaries for clean air act Title III hazardous air pollutants. Research Triangle Park, NC. U.S. Environmental Protection Agency. 1993. EPA600R94090.
EPA. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC. U.S. Environmental Protection Agency, Office of Research and Development. 1994. EPA600890066F.
EPA. Toxic chemical release inventory. Reporting form R and instructions. Washington, DC. U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. 1995. EPA745K95-051.
EPA. Method 8015B: Nonhalogenated organics using GC/FID. U.S. Environmental Protection Agency. 1996a:1-28.
EPA. Method 8260B. Volatile organic compounds by gas chromatography/mass spectrometry (CG/MS). U.S. Environmental Protection Agency. 1996b.
EPA. Automated Form R for Windows: User’s guide (RY97). Washington, DC. U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. 1997a.
EPA. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC. U.S. Environmental Protection Agency, Risk Assessment Forum. 1997b. EPA630R96012.
EPA. Benchmark dose technical guidance document. Washington, DC. U.S. Environmental Protection Agency. 2000a. EPA630R00001.
EPA. EPIWIN Suite. Estimation Program Interface for Windows. Version 3.11. U.S. Environmental Protection Agency. 2000b.
EPA. Method 1624. Code of Federal Regulations. 40 CFR (Pt 136). 2001:274-287.
EPA. Designation, reportable quantities, and notification: Designation of hazardous substance. U.S. Environmental Protection Agency. 2004a. Code of Federal Regulations. 40 CFR 302.4. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
EPA. 2004 Edition of the drinking water standards and health advisories. U.S. Environmental Protection Agency Office of Water. 2004b. EPA822R04005. http://www.epa.gov/waterscience/drinking/standards/dwstandards. June 16, 2004.
EPA. Identification and listing of hazardous waste: Hazardous constituents. U.S. Environmental Protection Agency. 2004c. Code of Federal Regulations. 40 CFR 261, Appendix VIII. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
EPA. Programs and activities: Hazardous air pollutants. U.S. Environmental Protection Agency. 2004d. United States Code. 42 USC 7412. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
EPA. Toxic chemical release reporting: Community right-to-know: Chemicals and chemical categories to which this part applies. U.S. Environmental Protection Agency. 2004e. Code of Federal Regulations. 40 CFR 372.65. http://www.epa.gov/epahome/cfr40.htm. June 06, 2004.
EPA. Guidelines for carcinogen risk assessment. Washington, DC. U.S. Environmental Protection Agency. 2005a. EPA630/P-03/001B.
EPA. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. 2005b. Office of Environmental Information. EPA260B05001.
Epstein PS, Mauer T, Wagner M, et al. Determination of parts-per-billion concentrations of dioxane in water and soil by purge and trap gas chromatography/mass spectrometry or charcoal tube enrichment gas chromatography. Anal Chem. 1987;59:1987-1990.
Ernstgård L, Iregren A, Sjogren B, et al. Acute effects of exposure to vapours of dioxane in humans. Human Exp Toxicol. 2006;25:723-729.
Fairley A, Linton EC, Ford-Moore AH. The toxicity to animals of 1,4-dioxane. J Hyg. 1934;34:486-501. [pmid: 20475249].
FDA. Cosmetic product warning statements: Establishment of effective date for label caution requirement on children's foaming detergent bath products; response to comments. U.S. Food and Drug Administration. Fed Regist. 1986;51(108):20471-20475.
FDA. Cosmetic handbook. U.S. Food and Drug Administration, Center for Food Safety and Applied Nutrition. 1992.
FDA. Letter to Dr. Lione and Ms. Braiman Re: Docket No. 83P-0187/CP1 & CP2. U.S. Food and Drug Administration. 1997. http://www.fda.gov/ohrms/dockets/ac/00/backgrd/3630b1e_83p_0187_pdn1.pdf. February 09, 2010.
FDA. Indirect food additives: Adhesives and components of coatings. Food and Drug Administration. Fed Regist. 1998;63(205):56786-56789.
FDA. Part 175– Indirect food additives– adhesives and components of coatings: Adhesives. Food and Drug Administration. 2003. Code of Federal Regulations. 21 CFR 175.105. http://www.access.gpo.gov/cgi-bin/cfrassemble.cgi?title=200321. June 06, 2004.
FDA. Food additives permitted for direct addition to food for human consumption; glycerides and polyglycides. Food and Drug Administration. 2006. Code of Federal Regulations. 21 CFR 172.736. http://edocket.access.gpo.gov/cfr_2006/aprqtr/pdf/21cfr172.736.pdf. February 10, 2010.
FDA. 1,4-dioxane. U.S. Food and Drug Administration. Center for Food Safety and Applied Nutrition. 2009. http://www.cfsan.fda.gov/~dms/cosdiox.html. March 24, 2009.
FEDRIP. 1,4-Dioxane. Federal Research in Progress database. Springfield, VA. National Technical Information Service. 2009.
Fincher EL, Payne WJ. Bacterial utilization of ether glycols. Appl Microbiol. 1962;10:542-547. [pmid: 13945208].
Fisher J, Mahle D, Bangston L, et al. Lactational transfer of volatile chemicals in breast milk. Am Ind Hyg Assoc J. 1997;58:425-431. [pmid: 9183837].
Fomon SJ. Falkner F, editor. Body composition of the infant: Part I: The male reference infant. Human development. Philadelphia, PA. WB Saunders. 1966:239-246.
Fomon SJ, Haschke F, Ziegler EE, et al. Body composition of reference children from birth to age 10 years. Am J Clin Nutr. 1982;35:1169-1175. [pmid: 7081099].
Fowlie AJ, Grasso P, Benford DJ. The short-term effects of carcinogens and sulphur dioxide on the nuclear size of rat nasal epithelial cells. J Appl Toxicol. 1990;10(1):29-38. [pmid: 2335709].
Francis AJ, Iden CR, Nine, BJ, et al. Characterization of organics in leachates from low-level radioactive waste disposal sites. Nucl Technol. 1980;50:158-163.
Francis GJ, Langford VS, Milligan DB, et al. Real-time monitoring of hazardous air pollutants. Anal Chem. 2009;81(4):1595-1599. [pmid: 19159214].
Franke C, Studinger G, Berger G, et al. The assessment of bioaccumulation. Chemosphere. 1994;29(7):1501-1514.
Frantik R, Hornychova M, Horvath M. Relative acute neurotoxicity of solvents: Isoeffective air concentrations of 48 compounds evaluated in rats and mice. Environ Res. 1994;66:173-185. [pmid: 8055839].
Galloway SM, Armstrong MJ, Reuben C, et al. Chromosome aberrations and sister chromatid exchanges in Chinese hamster ovary cells: Evaluations of 108 chemicals. Environ Mol Mutagen. 1987;10(supp 10):1. 10. 21. 67. [pmid: 3319609].
Gelman Sciences. Information on the dioxane content of polyethylene glycol, raw materials and consumer products with cover letter dated 011789. Submitted to U.S. Environmental Protection Agency under TSCA Section 8E. 1989a. OTS0516624-1.
Gelman Sciences. Reports on 1,4-dioxane and polyethylene glycol in products with cover letter dated 011489. Submitted to U.S. Environmental Protection Agency under TSCA Section 8E. 1989b. OTS0516624-1.
Gelman Sciences. Letter from Gelman Sciences to USEPA regarding contamination of 1,4-dioxane at rest stops with attachments. Submitted to U.S. Environmental Protection Agency under TSCA Section 8E. 1989c. OTS0516624.
Gelman Sciences. Concentrations of 1,4-dioxane in consumer materials. List of materials containing 1,4-dioxane and a bibliography containing references for sources of 1,4-dioxane. Submitted to U.S. Environmental Protection Agency under TSCA Section 8E. 1996. OTS05166244.
Ghassempour A, Arshadi MR, Adimi B. Modified GC-MS for determination of 1,4-dioxane in cosmetic products. Orient J Chem. 1998;14:287-291.
Giavini E, Vismara C, Broccia ML. Teratogenesis study of dioxane in rats. Toxicol Lett. 1985;26:85-88. [pmid: 4024160].
Giwercman A, Carlsen E, Keiding N, et al. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl. 1993;101(2):65-71.
Gold LS, Slone TH, Stern BR, et al. Comparison of target organs of carcinogenicity for mutagenic and non-mutagenic chemicals. Mutat Res. 1993;286:75-100. [pmid: 7678909].
Goldberg ME, Johnson HE, Pozzani UC, et al. Effect of repeated inhalation of vapors of industrial solvents on animal behavior I. Evaluation of nine solvent vapors on pole-climb performance in rats. Am Ind Hyg Assoc J. 1964;25:369-375. [pmid: 14194199].
Goldsworthy TL, Monticello TM, Morgan KT, et al. Examination of potential mechanisms of carcinogenicity of 1,4-dioxane in rat nasal epithelial cells and hepatocytes. Arch Toxicol. 1991;65:1-9. [pmid: 2043044].
Gombar V. Written communication (March 16) to Moiz Mumtaz, Division of Toxicology, Agency for Toxic Substances and Disease Registry, Public Health Service, Atlanta, GA, regarding SAR assessments of β-hydroxyethoxyacetic acid and 1,4-dioxane-2 using TOPKAT programs. Rochester, NY. Health Designs Inc. 1995.
Grant D, Grasso P. Suppression of HeLa cell growth and increase in nuclear size by chemical carcinogens: A possible screening method. Mutat Res. 1978;57:369-380. [pmid: 353551].
Grosjean D. Atmospheric chemistry of toxic contaminants 2. Saturated aliphatics: Acetaldehyde, dioxane, ethylene glycol ethers, propylene oxide. J Air Waste Mgmt Assoc. 1990;40:1522-1531.
Groves WA, Frye GC, Zellers ET. Analyzing organic vapors in exhaled breath using a saw sensor array with preconcentration. Symposium on chemical and biological sensors and analytical electrochemical methods. 1997:179-190.
Guzelian PS, Henry CJ, Olin SS, editors. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC. International Life Sciences Institute Press. 1992.
Hansch C, Leo A, Hoekman D. Exploring QSAR: Hydrophobic, electronic, and steric constants. Washington, DC. American Chemical Society. 1995.
Harkov R, Gianti SJ, Bozzelli JW, et al. Monitoring volatile compounds at hazardous and sanitary landfills in New Jersey. J Environ Sci Health Part A. 1985;20:491-501.
Harkov R, Kebbekus B, Bozzelli JW, et al. Measurement of selected volatile organic compound at three locations in New Jersey during the summer season. J Air Pollut Control Assoc. 1983;33:1177-1183.
Harkov R, Kebbekus B, Bozzelli JW, et al. Comparison of selected volatile organic compounds during the summer and winter at urban sites in New Jersey. Sci Total Environ. 1984;38:259-274.
Hartung R. Health and environmental effects assessment for 1,4-dioxane. Ann Arbor, Michigan. Gelman Sciences. 1989.
Haworth S, Lawlor T, Mortelmans K, et al. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen Supp. 1983;1:1-10.
HazDat. 1,4-Dioxane. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA. Agency for Toxic Substances and Disease Registry. 2007. http://www.atsdr.cdc.gov/hazdat.html. May 10, 2007.
Hellmer L, Bolcsfoldi G. An evaluation of the E. coli K-12 uvrB/recA DNA repair host-mediated assay. I. In vitro sensitivity of the bacteria to 61 compounds. Mutat Res. 1992;272:145-160. [pmid: 1383747].
Heukelekian H, Rand MC. Biochemical oxygen demand of pure organic compounds. Sewage Ind. Waste. 1955;27:1040-1053.
Hoch-Ligeti C, Argus MF. Nettesheim P, Hanna MG, Deatherage JW, editors. Effect of carcinogens on the lung of guinea pigs. Morphology of experimental respiratory carcinogenesis. AEC Symp Ser 21. National Cancer Institute and U.S. Atomic Energy Commission. 1970:267-279. CONF700501.
Hoch-Ligeti C, Argus MF, Arcos JC. Induction of carcinomas in the nasal cavity of rats by dioxane. Br J Cancer. 1970;24:164-167. [pmid: 4316974].
Hoel DG, Davis DL, Miller AB, et al. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst. 1992;84(5):313-320. [pmid: 1738181].
Howard JA, Ingold KU. Absolute rate constants for hydrocarbon autoxidation XVII. The oxidation of some cyclic ethers. Can J Chem. 1969;47:3809-3815.
HSDB. 1,4-Dioxane. Hazardous Substances Data Bank. 2010. http://toxnet.nlm.nih.gov. May 20, 2010.
IARC. 1,4-Dioxane. IARC Monogr Eval Carcinog Risks Hum. 1976;11:247-256.
IARC. Some chemicals that cause tumours of the kidney or urinary bladder in rodents and some other substances- 1,4-Dioxane (group 2B). IARC Monogr Eval Carcinog Risks Hum. 1999;71:589. http://www-cie.iarc.fr/htdocs/monographs/vol71/019-dioxane.html. June 06, 2004.
IRIS. 1,4-Dioxane. Integrated risk information system. Washington, DC. U.S. Environmental Protection Agency. 2011. http://www.epa.gov/iris/subst/0326.htm. August 13, 2011.
JBRC. Two-week studies of 1,4-dioxane in F344 rats and BDF1 mice (drinking water studies). Kanagawa, Japan. Japan Bioassay Research Center. 1998.
Jewett D, Lawless JG. Formate esters of 1,2-ethanediol: Major decomposition products of p-dioxane during storage. Bull Environ Contam Toxicol. 1980;25:118-121. [pmid: 7459474].
Johanson CE. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res. 1980;190:3-16. [pmid: 6769537].
Johnstone RT. Death due to dioxane?. AMA Arch Ind Health. 1959;20:445-447. [pmid: 14407583].
Kadokami K, Koga M, Otsuki A. Gas chromatography/mass spectrometric determination of traces of hydrophilic and volatile organic compounds in water after preconcentration with activated carbon. Anal Sci. 1990;6:843-849.
Kanada M, Miyagawa M, Sato M, et al. Neurochemical profile of effects of 28 neurotoxic chemicals on the central nervous system in rats (1). Effects of oral administration on brain contents of biogenic amines and metabolites. Ind Health. 1994;32:145-164. [pmid: 7698903].
Kano H, Umeda Y, Saito M, et al. Thirteen-week oral toxicity of 1,4-dioxane in rats and mice. J Toxicol Sci. 2008;33:141-153. [pmid: 18544906].
Kano H, Umeda Y, Kasai T, et al. Carcinogenicity studies of 1,4-dioxane in drinking water to rats and mice for 2 years. Food Chem Toxicol. 2009;47:2776-2784. [pmid: 19703511].
Kasai T, Saito M, Senoh H, et al. Thirteen-week inhalation toxicity of 1,4-dioxane in rats. Inhal Toxicol. 2008;20:961-971. [pmid: 18668411].
Kasai T, Kano H, Umeda Y, et al. Two-year inhalation study of carcinogenicity and chronic toxicity of 1,4-dioxane in male rats. Inhal Toxicol. 2009;21:889-897. [pmid: 19681729].
Kawasaki M. Experiences with the test scheme under the chemical control law of Japan: An approach to structure-activity correlations. Ecotoxicol Environ Saf. 1980;4:444-454. [pmid: 7472248].
Kawata K, Ibaraki T, Tanabe A, et al. Gas chromatographic-mass spectrometric determination of hydrophilic compounds in environmental water by solid-phase extraction with activated carbon fiber felt. J Chromatogr A. 2001;911:75-83. [pmid: 11269598].
Kawata K, Ibaraki T, Tanabe A, et al. Distribution of 1,4-dioxane and n,n-dimethylformamide in river water from Nigata, Japan. Bull Environ Contam Toxicol. 2003;70:876-882. [pmid: 12719810].
Kelley SL, Aitchison EW, Deshpande M, et al. Biodegradation of 1,4-dioxane in planted and unplanted soil: Effect of bioaugmentation with amycolata sp. CB1190. Water Res. 2001;35:3791-3800. [pmid: 12230161].
Kesten HD, Mulinos MG, Pomerantz L. Pathologic effects of certain glycols and related compounds. Arch Pathol. 1939;27:447-465.
Khudoley VV, Mizgireuv I, Pliss GB. The study of mutagenic activity of carcinogens and other chemical agents with Salmonella typhimurium assays: Testing of 126 compounds. Arch Geschwulstforsch. 1987;57:453-462. [pmid: 3435224].
Kimbell JS, Subramaniam RP, Gross EA, et al. Dosimetry modeling of inhaled formaldehyde: comparisons of local flux predictions in the rat, monkey, and human nasal passages. Toxicol Sci. 2001;64(1):100-110. [pmid: 11606806].
King ME, Shefner AM, Bates RR. Carcinogenesis bioassay of chlorinated dibenzodioxins and related chemicals. Environ Health Perspect. 1973;5:163-170. [pmid: 4752902].
Kitchin KT, Brown JL. Is 1,4-dioxane a genotoxic carcinogen?. Cancer Lett. 1990;53:67-71. [pmid: 2397485].
Kitchin KT, Brown JL. Dose-response relationship for rat liver DNA damage caused by 49 rodent carcinogens. Toxicology. 1994;88:31-49. [pmid: 8160204].
Klecka GM, Gonsior SJ. Removal of 1,4-dioxane from wastewater. J Hazard Mater. 1986;13:161-168.
Knoefel PK. Narcotic potency of some cyclic acetals. J Pharmacol Exp Ther. 1935;53:440-444.
Kociba RJ, McCollister SB, Park C, et al. 1,4-Dioxane. I. Results of a 2-year ingestion study in rats. Toxicol Appl Pharmacol. 1974;30:275-286.
Kociba RJ, Torkelson TR, Young D, et al. 1,4-Dioxane: Correlation of the results of chronic ingestion and inhalation studies with its dose-dependent fate in rats. Toxicity of high density jet fuel components. Wright-Patterson Air Force Base, OH. Air Force Aerospace Medical Research Laboratory. 1975. AMRL-TR-75-125.
Komori M, Nishio K, Kitada M, et al. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry. 1990;29:4430-4433. [pmid: 2350547].
Konasewich D, Traversy W, Zar H. Great Lakes Water Quality: Status report on heavy metal contaminants in the Lakes Erie, Michigan, Huron, and Superior Basins. 1978.
Kraybill HF. Carcinogenesis induced by contaminants in potable water. Bull NY Acad Med. 1978;54:413-427.
Krishnan K, Andersen ME. Hayes AW, editor. Physiologically based pharmacokinetic modeling in toxicology. Principles and methods of toxicology. 3rd ed. New York, NY. Raven Press, Ltd. 1994:149-188.
Krishnan K, Andersen ME, Clewell HJ III, et al. Yang RSH, editor. Physiologically based pharmacokinetic modeling of chemical mixtures. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA. Academic Press. 1994:399-437.
Krotoszynski BK, Bruneau GM, O'Neill HJ. Measurement of chemical inhalation exposure in urban population in the presence of endogenous effluents. J Anal Toxicol. 1979;3:225-234.
Kuwabara K, Andoh K, Nishimune T. Daily intake of volatile halogenated hydrocarbons from diet. Osaka-furitsu Koshu Eisei Kenyyusho Kenkyo Hokuku, Shokuhin Eisei Hen. 1994;25:1-6.
Kwan KK, Dutka BJ, Rao SS, et al. Mutatox test: a new test for monitoring environmental genotoxic agents. Environ Pollut. 1990;65:323-332. [pmid: 15092256].
Kwon K, Jo W, Lim H, et al. Characterization of emissions composition for selected household products available in Korea. J Hazard Mater. 2007;148:192-198. [pmid: 17376591].
Laug EP, Calvery HO, Morris HJ, et al. The toxicity of some glycols and derivatives. J Ind Hyg Toxicol. 1939;21:173-201.
Leeder JS, Kearns GL. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am. 1997;44(1):55-77. [pmid: 9057784].
Lesage S, Jackson RE, Priddle MW, et al. Occurrence and fate of organic solvent residues in anoxic groundwater at the Gloucester Landfill, Canada. Environ Sci Technol. 1990;24:559-565.
Leung H. Ballentyne B, Marrs T, Turner P, editors. Physiologically-based pharmacokinetic modelling. General and applied toxicology. New York, NY. Stockton Press. 1993;Vol. 1:153-164.
Leung H, Paustenbach DJ. Cancer risk assessment for dioxane based upon a physiologically-based pharmacokinetic approach. Toxicol Lett. 1990;51:147-162. [pmid: 2158678].
Livingston AL. Forage plant estrogens. J Toxicol Environ Health. 1978;4:301-324. [pmid: 351201].
Lundberg I, Ekdahl M, Kronevi T, et al. Relative hepatotoxicity of some industrial solvents after intraperitoneal injection or inhalation exposure in rats. Environ Res. 1986;40:411-420. [pmid: 3732212].
Lundberg I, Hogberg J, Kronevi T, et al. Three industrial solvents investigated for tumor promoting activity in the rat liver. Cancer Lett. 1987;36:29-33. [pmid: 2884030].
Lyman WJ, Reehl WF, Rosenblatt DH. Handbook of chemical property estimation methods: Environmental behavior of organic compounds. New York. McGraw-Hill Book Company. 1982:9-64.
Marzulli F, Anjo DM, Maibach HI. In vivo skin penetration studies of 2,4-toluenediamine, 2,4-diaminoanisole, 2-nitro-p-phenylenediamine, p-dioxane and N-nitrosodiethanolamine in cosmetics. Food Cosmet Toxicol. 1981;19:743-747. [pmid: 7327475].
Mayr U, Butsch A, Schneider S. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology. 1992;74:135-149. [pmid: 1387742].
McCarty PL. In situ bioremediation of chlorinated solvents. Curr Opin Biotechnol. 1993;4:323-330.
McElroy NR, Thompson ED, Jurs PC. Classification of diverse organic compounds that induce chromosomal aberrations in Chinese hamster cells. J Chem Inf Comput Sci. 2003;43(6):2111-2119. [pmid: 14632463].
McFee AF, Abbott MG, Gulati DK, et al. Results of mouse bone marrow micronucleus studies on 1,4-dioxane. Mutat Res. 1994;322:141-150. [pmid: 7519321].
McGregor DB, Brown AG, Howgate S, et al. Responses of the L5178Y mouse lymphoma cell forward mutation assay. V. 27 coded chemicals. Environ Mol Mutagen. 1991;17(3):196-219. [pmid: 1902415].
Meylan WM, Howard PH, Boethling RS, et al. Improved method for estimating bioconcentration/bioaccumulation factor from octanol/water from partition coefficient. Environ Toxicol Chem. 1999;18:664-672.
Michigan DEQ. Contamination investigation report. Michigan Department of Environmental Quality. 2004.
Mikheev MI, Gorlinskaya YE P, Solovyova TV. The body distribution and biological action of xenobiotics. J Hyg Epidemiol Microbiol Immunol. 1990;34:329-336.
Mills EJ, Stack VT. Measurement of pesticides in air during application to lawns, trees, and shrubs in urban environments. Eng Ext Ser (Purdue Univ). 1954;83:492-517.
Mirkova ET. Activity of the rodent carcinogen 1,4-dioxane in the mouse bone marrow micronucleus assay. Mutat Res. 1994;322:141-150. [pmid: 7519321].
Miyagawa M, Shirotori T, Tsuchitani M, et al. Repeat-assessment of 1,4-dioxane in a rat-hepatocyte replicative DNA synthesis (RDS) test: evidence for stimulus of hepatocyte proliferation. Exp Toxicol Pathol. 1999;51:555-558. [pmid: 10661815].
Mohr T. GRA's 1,4-Dioxane Conference Profiles: National challenge of emerging and unregulated contaminants. Sacramento, CA. Groundwater Resources Association of California. 2004. http://www.grac.org/dioxanemain.html. June 24, 2004.
Mori K, Nakamura Y, Kaneko M, et al. Determination of 1,1,1-Trichloroethane and 1,4-dioxane in household aerosol products. Jpn J Toxicol Environ Health (Eisei Kagaku). 1992;38:511-516.
Morita T, Hayashi M. 1,4-dioxane is not mutagenic in five in vitro assays and mouse peripheral blood micronucleus assay, but is in mouse liver micronucleus assay. Environ Mol Mutagen. 1998;32:269-280. [pmid: 9814442].
Morselli PL, Franco-Morselli R, Bossi L. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin. 1980;5:485-527.
MSU. Gelman Sciences dioxane project. Ann Arbor, Michigan. Midwest Hazardous Substance Research Center, Michigan State University. 2001. http://www.egr.msu.edu/tosc/gelman/. July 28, 2004.
Mungikar AM, Pawar SS. Induction of the hepatic microsomal mixed function oxidase system in mice by p-dioxane. Bull Environ Contam Toxicol. 1978;20:797-804. [pmid: 749978].
Munoz ER, Barnett BM. The rodent carcinogens 1,4-dioxane and thiourea induce meiotic non-disjunction in Drosophila melanogaster females. Mutat Res. 2002;517:231-238. [pmid: 12034324].
Nannelli A, De Rubertis A, Longo V, et al. Effects of dioxane on cytochrome P450 enzymes in liver, kidney, lung and nasal mucosa of rat. Arch Toxicol. 2005;79(2):74-82. [pmid: 15490126].
NAS/NRC. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC. National Academy of Sciences, National Research Council, National Academy Press. 1989.
NAS. Polysorbate 20. Food chemicals codex. 5th ed. Washington, DC. National Academy of Sciences. 2003:346-347.
NCI. Bioassay of 1,4-dioxane for possible carcinogenicity. Bethesda, MD. National Cancer Institute. 1978. NIH Pub. No. 78-1330. NCICGTR-80.
NCI. Monograph on human exposure to chemicals in the workplace. Bethesda, MD. National Cancer Institute, Division of Cancer Etiology. 1985. 86131414.
Nestmann ER, Otson R, Kowbel DJ, et al. Mutagenicity in a modified Salmonella assay of fabric-protecting products containing 1,1,1-trichloroethane. Environ Mutagen. 1984;6:71-80. [pmid: 6692801].
NICNAS. 1-4, Dioxane priority existing chemical no. 7. Full public report. National Industrial Chemicals Notification and Assessment Scheme. 1998. http://www.nicnas.gov.au/publications/car/pec/pec7/pec7_full_report_pdf.pdf. June 05, 2007.
NIH. Household products database. National Institutes of Health. National Library of Medicine. 2004. http://hpd.nlm.nih.gov/cgi-bin/household/search. June 24, 2004.
NIOSH. National occupational hazard survey. Cincinnati, OH. Department of Health and Human Services. National Institute for Occupational Safety and Health. 1976.
NIOSH. Criteria for a recommended standard. Occupational exposure to dioxane. Washington, DC. National Institute for Occupational Safety and Health. 1977. http://www.cdc.gov/niosh/77-226.html. June 23, 2004.
NIOSH. HHE Report No. HETA-86-051-1911. National Cover of Atlanta, Inc., Lawrenceville, Georgia. National Institute for Occupational Safety and Health. 1988. http://www.cdc.gov/niosh/hhe/reports/pdfs/1986-0051-1911.pdf. June 05, 2007.
NIOSH. Dioxane. NIOSH manual of analytical methods. Washington, DC. National Institute for Occupational Safety and Health. 1994.
NIOSH. NIOSH pocket guide to chemical hazards and other databases. Department of Health and Human Services, National Institute for Occupational Safety and Health. 2001. DHHS Publication No. 2001-145. http://www.cdc.gov/niosh/npg/npgd0237.html. July 29, 2004.
NIOSH. Dioxane. NIOSH pocket guide to chemical hazards. Washington, DC. National Institute for Occupational Safety and Health. 2004. http://www.cdc.gov/niosh/npg/npgd0237.html. June 06, 2004.
Nishihara T, Nishikawa J-I, Kanayama T, et al. Estrogenic activities of 517 chemicals by yeast two-hybrid assay. J Health Sci. 2000;46:282-298.
Nishimura T, Iizuka S, Kibune N, et al. Study of 1,4-dioxane intake in the total diet using the market-basket method. J Health Sci. 2004;50(1):101-107.
NRC. Pesticides in the diets of infants and children. Washington, DC. National Academy Press. National Research Council. 1993.
NTP. 1,4-Dioxane. Report on carcinogens, Twelfth edition National Toxicology Program. 2011:176-178. http://ntp.niehs.nih.gov/ntp/roc/twelfth/roc12.pdf. August 1, 2011.
O’Neil MJ. Dioxane. The Merck index. An encyclopedia of chemicals, drugs, and biologicals. Whitehouse Station NJ. Merck & Co., Inc. 2001:3332.
OSHA. Air contaminants. Occupational safety and health standards for shipyard employment. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. 2004a. http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10286. June 06, 2004.
OSHA. Appendix A. Safety and health regulations for construction: Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55, Appendix A. 2004b. http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=10629. June 06, 2004.
OSHA. Table Z-1: Limits for air contaminants. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. 2004c. http://www.osha.gov/pls/oshaweb/owadisp.show_document?p_table=STANDARDS&p_id=9992. June 06, 2004.
Owen GM, Brozek J. Falkner F. Influence of age, sex and nutrition on body composition during childhood and adolescence. Human development. Philadelphia, PA. WB Saunders. 1966:222-238.
Parales RE, Adamus JE, White N, et al. Degradation of 1,4-dioxane by an actinomycete in pure culture. Appl Environ Microbiol. 1994;60:4527-4530. [pmid: 7811088].
Park JH, Hussam A, Couasnon P, et al. Experimental reexamination of selected partition coefficients from Rohrschneider's data set. Anal Chem. 1987;59:1970-1976.
*. Pawar SS, Mungikar AM. Dioxane-induced changes in mouse liver microsomal mixed function oxidase system. Bull Environ Contam Toxicol. 1976;15:762-767. [pmid: 7331].
Paxéus N. Organic compounds in municipal landfill leachates. Water Sci Technol. 2000;4:323-333.
Pellizzari ED, Hartwell TD, Perritt RL, et al. Comparison of indoor and outdoor residential levels of volatile organic chemicals in five USA geographical areas. Environ Int. 1986;12(6):619-624.
Pereira MA, Herren SL, Britt AL, et al. Initiation/promotion bioassay in rat liver: Use of gamma glutamyltranspeptidase-positive foci to indicate carcinogenic activity. Toxicol Pathol. 1982;10(2):11-18.
Platz J, Megelberg T, Nielson OJ, et al. Atmospheric chemistry of 1,4-dioxane. J Chem Soc Faraday Trans. 1997;93:2855-2863.
Pozzani UC, Weil CS, Carpenter CP. The toxicological basis of threshold limit values: 5: The experimental inhalation of vapor mixtures by rats, with notes upon the relationship between single dose inhalation and single dose oral data. J Ind Hyg. 1959;20:364-369.
Priddle MW, Jackson RE. Laboratory column measurement of VOC retardation factors and comparison with field values. Ground Water. 1991;29:260-266.
Ramsey JC, Andersen ME. A physiologically based description of the inhalation pharmacokinetics of styrene in rats and humans. Toxicol Appl Pharmacol. 1984;73:159-175. [pmid: 6710512].
Rastogi SC. Headspace analysis of 1,4-dioxane in products containing polyethoxylated surfactants by GC-MS. Chromatographia. 1990;29:441-445.
Reitz RH, McCroskey PS, Park CN, et al. Development of a physiologically based pharmacokinetic model for risk assessment with 1,4-dioxane. Toxicol Appl Pharmacol. 1990;105:37-54. [pmid: 2392805].
Riddick JA, Bunger WB, Sakano TK. 1,4-Dioxane. Organic solvents. Physical properties and methods of purification. New York, NY. John Wiley & Sons. 1986:312. 938.
Romero J, Ventura F, Caixach J. Identification of 1,3-dioxanes and 1,3 dioxolanes as malodorous compounds at trace levels in river water, groundwater, and tap water. Environ Sci Technol. 1998;32:206-216.
Rosenkranz HS, Klopman G. 1,4-Dioxane: Prediction of in vivo clastogenicity. Mutat Res. 1992;280:245-251. [pmid: 1382225].
Roy D, Anagnostu G, Chaphalkar P. Biodegradation of dioxane and diglyme in industrial waste. J Environ Sci Health Part A. 1994;A29:129-147.
Roy D, Anagnostu G, Chaphalkar P. Analysis of respirometric data to obtain kinetic coefficients for biodegradation of 1,4-dioxane. J Environ Sci Health, Part A. 1995;30:1775-1790.
Roy SK, Thilagar AK, Eastmond DA. Chromosome breakage is primarily responsible for the micronuclei induced by 1,4-dioxane in the bone marrow and liver of young CD-1 mice. Mutat Res. 2005;586(1):28-37. [pmid: 16023405].
Royal Society of Chemistry. 1,4-Dioxane. Solvents in common use: Health risks to workers. 1988;EUR 11553:105-134.
RTECS. Registry of Toxic Effects of Chemical Substances. Bethesda, MD. National Library of Medicine, National Toxicology Information Program. 2004.
Sanceda NG, Kurata T, Arakawa N. Fractionation and identification of volatile compounds in Patis, a Philippine fish sauce. Agric Biol Chem. 1984;48:3047-3052.
Scalia S, Guarneri M, Menegatti E. Determination of 1,4-dioxane in cosmetic products by high-performance liquid chromatography. Analyst. 1990;115:929-931. [pmid: 2221400].
Schrenk HH, Yant WP. Toxicity of dioxane. J Ind Hyg Toxicol. 1936;18:448-460.
ScienceLab. Material safety data sheet: p-dioxane. ScienceLab.com: Chemicals and Laboratory Equipment. 2005. http://www.sciencelab.com/xMSDS-p_Dioxane-9923847. August 22, 2007.
Setchell BP, Waites GMH. Creep RO, Astwood EB, Geiger SR, editors. The blood-testis barrier. Handbook of physiology: Endocrinology. V. Washington, DC. American Physiological Society. 1975.
Shah J, Singh HB. Distribution of volatile organic chemicals in outdoor and indoor air. Environ Sci Technol. 1988;22:1381-1388. [pmid: 22200458].
Shahidi F, Rubin LJ, D'Souza LA. Meat flavor volatiles: a review of the composition, techniques of analysis, and sensory evaluation. CRC Crit Rev Food Sci Nutr. 1986;24:141-243.
Shell Oil Co. Letter to U.S. Environmental Protection Agency regarding information developed on the presence of 1,4-dioxane in two specific products, the sodium and ammonium salts of alcohol ethoxysulfates (sanitized). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. 1988:OTS0200615.
Sheu CW, Moreland FM, Lee JK, et al. In vitro BALB/3T3 cell transformation assay of nonoxynol-9 and 1,4-dioxane. Environ Mol Mutagen. 1988;11:41-48. [pmid: 2828043].
Silverman L, Schulte HF, First MW. Further studies of sensory response to certain industrial solvent vapors. J Ind Hyg Toxicol. 1946;28:262-266. [pmid: 21002364].
Sina JF, Bean CL, Dysart GR, et al. Evaluation of the alkaline elution/rat hepatocyte assay as a predictor of carcinogenic/mutagenic potential. Mutat Res. 1983;113:357-391. [pmid: 6877265].
Sivadier G, Ratel J, Bouvier F, et al. Authentication of meat products: determination of animal feeding by parallel GC-MS analysis of three adipose tissues. J Agric Food Chem. 2008;56(21):9803-9812. [pmid: 18837504].
Smyth HFJ, Seaton J, Fischer L. The single dose toxicity of some glycols and derivatives. J Ind Hyg Toxicol. 1941;23(6):259-268.
Song D, Zhang S. Rapid determination of 1,4-dioxane in water by solid-phase extraction and gas chromatography-mass spectrometry. J Chromatogr A. 1997;787:283-287. [pmid: 9409003].
SRI. 1,4-Dioxane. 2003 Directory of chemical producers. Menlo Park, CA. SRI International. 2003.
Stafford ML, Guin KF, Johnson GA, et al. Analysis of 1,4-dioxane in ethoxylated surfactants. J Soc Cosmet Chem. 1980;31:281-287.
Stickney JA, Sager SL, Clarkson JR, et al. An updated evaluation of the carcinogenic potential of 1,4-dioxane. Regul Toxicol Pharmacol. 2003;38:183-195. [pmid: 14550759].
Stott WT, Quast JF, Watanabe PG. Differentiation of the mechanisms of oncogenicity of 1,4-dioxane and 1,3-hexachlorobutadiene in the rat. Toxicol Appl Pharmacol. 1981;60:287-300. [pmid: 7281189].
Surprenant KS. Gerhartz W, Yamamoto YS, Campbell FT, et al., editors. Dioxane. Ullman's encyclopedia of industrial chemistry. A3 Weinham, Germany. VCH Verlagsgesellschaft. 2002:545-550.
Swann RL, Laskowski DA, McCall PJ, et al. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Res Rev. 1983;85:17-28.
Sweeney LM, Andersen ME, Gargas ML. Ethyl acrylate risk assessment with a hybrid computational fluid dynamics and physiologically based nasal dosimetry model. Toxicol Sci. 2004;79(2):394-403. [pmid: 15056811].
Sweeney LM, Thrall KD, Poet TS, et al. Physiologically based pharmacokinetic modeling of 1,4-dioxane in rats, mice, and humans. Toxicol Sci. 2008;101(1):32-50. [pmid: 17897969].
Swope HG, Kenna M. Effect of organic compounds or biochemical oxygen demand. Wastes Eng. 1950;21:467-468.
Takano R, Murayama N, Horiuchi K, et al. Blood concentrations of 1,4-dioxane in humans after oral administration extrapolated from in vivo rat pharmacokinetics, in vitro human metabolism, and physiologically based pharmacokinetic modeling. J Health Sci. 2010;56:557-565.
Tang J, Jin QZ, Shen G-H, et al. Isolation and identification of volatile compounds from fried chicken. J Agric Food Chem. 1983;31:1287-1292.
Thiess AM, Tress E, Fleig I. Industrial-medical investigation results in the case of workers exposed to dioxane. Arbeitsmed Sozialmed Pravent. 1976;11:35-46. (German).
Thomas RG. Lyman WJ, Reehl WF, editors. Volatilization from water. Handbook of chemical property estimation methods: Environmental behavior of organic compounds. Washington, DC. American Chemical Society. 1990:1-34.
Thomas K, Colborn T. Thomas K, Colborn T, Clement C, editors. Organochlorine endocrine disruptors in human tissue. Chemically induced alterations in sexual and functional development: the wildlife/human connection. Princeton, NJ. Princeton Scientific Publishing. 1992:365-394.
Tinwell H, Ashby J. Activity of 1,4-dioxane in mouse bone marrow micronucleus assays. Mutat Res. 1994;322:148-150. [pmid: 7519324].
Torkelson R, Leong BKJ, Kociba RJ, et al. 1,4-Dioxane. II. Results of a 2-year inhalation study in rats. Toxicol Appl Pharmacol. 1974;30:287-298.
TRI07. TRI explorer: Providing access to EPA’s toxic release inventory data. Washington, DC. Office of Information Analysis and Access, Offices of Environmental Information, U.S. Environmental Protection Agency. Toxic Release Inventory. 2009. http://www.epa.gov/triexplorer/. March 12, 2007.
United Nations. Treatment and disposal methods for waste chemicals. Geneva, Switzerland. United Nations Environmental Programs. 1985.
Uno Y, Takaswas H, Miyagawa M, et al. An in vivo-in vitro replications DNA synthesis (RDS) test using rat hepatocytes as an early prediction assay for nongenotoxic heptacarcinogens: Screening of 22 known positives and 25 noncarcinogens. Mutat Res. 1994;320(3):189-205. [pmid: 7508085].
U.S. Army. Studies on metabolism of 1,4-dioxane. Aberdeen Proving Ground, MD. Army Center for Health Promotion and Preventive Medicine. 2010. Toxicology report No. 87-XE-08WR-09. ADA528633. http://www.clu-in.org/download/contaminantfocus/dioxane/Dioxane-Tox-ADA528633.pdf. July 29, 2011.
USGS. Geohydrology, water quality, and simulation of ground-water flow in the vicinity of a former waste-oil refinery near Westville, Indiana, 1997–2000. U.S. Department of the Interior. U.S. Geological Survey. 2002. http://in.water.usgs.gov/newreports/camor.pdf. March 24, 2009.
Vieira I, Sonnier M, Cresteil T. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem. 1996;238:476-483. [pmid: 8681961].
Wallace L, Nelson W, Ziegenfus R, et al. The Los Angeles TEAM Study: Personal exposures, indoor-outdoor air concentrations, and breath concentrations of 25 volatile organic compounds. J Expo Anal Environ Epidemiol. 1991;1:157-192. [pmid: 1824315].
Wang RY, Blount BC, Chambers DM, et al. Measuring 1,4-dioxane in blood as a biomarker of exposure [abstract]. Toxicologist. 2009;108(1):336.
West JR, Smith HW, Chasis H. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr. 1948;32:10-18. [pmid: 18920567].
Widdowson EM, Dickerson JWT. Comar CL, Bronner F, editors. Chemical composition of the body. Mineral metabolism: An advanced treatise. Vol. II: The elements Part A. New York. Academic Press. 1964.
Wirth W, Klimmer O. On the toxicology of organic solvents. 1,4-Dioxane (diethylene dioxide.). Arch Gewerbepathol Gewerbehyg. 1936;17:192-206. (German).
Wolfe NL, Jeffers PM. Boethling RS, Mackay D, editors. Hydrolysis. Handbook of property estimation methods for chemicals: Environmental and health sciences. Boca Raton, FL. Lewis Publishers. 2000.
Woo YT, Arcos JC, Argus MF, et al. Structural identification of p-dioxane-2-one as the major urinary metabolite of p-dioxane. Naunyn-Schmiedebergs Arch Pharmacol. 1977a;299:283-287. [pmid: 927555].
Woo YT, Argus MF, Arcos JC. Tissue and subcellular distribution of 3H-dioxane in the rat and apparent lack of microsome-catalyzed covalent binding in the target tissue. Life Sci. 1977b;21:1447-1456. [pmid: 927007].
Woo Y, Argus MF, Arcos JC. Metabolism in vivo of dioxane: Effect of inducers and inhibitors of hepatic mixed-function oxidases. Biochem Pharmacol. 1977c;25:1539-1542. [pmid: 901573].
Woo Y, Arcos JC, Argus MF. Metabolism in vivo of dioxane: Identification of p-dioxane-2-one as the major urinary metabolite. Biochem Pharmacol. 1977d;26:1535-1538. [pmid: 901572].
Woo YT, Argus MF, Arcos JC. Effect of mixed-function oxidase modifiers on metabolism and toxicity of the oncogen dioxane. Cancer Res. 1978;38:1621-1625. [pmid: 417804].
Woo YT, Neuburger BJ, Arcos JC, et al. Enhancement of toxicity and enzyme-repressing activity of p-dioxane by chlorination: Stereoselective effects. Toxicol Lett. 1980;5:69-75. [pmid: 7376202].
*. Yamazaki K, Ohno H, Asakura M, et al. Sumino K, Sato S, editors. Two-year toxicological and carcinogenesis studies of 1,4-dioxane in F344 rats and BDF1 mice -- drinking studies. Second Asia-Pacific Symposium on Environmental and Occupational Health. 22–24 July, 1993. Kobe: proceedings. Kobe. International Center for Medical Research Kobe, University School of Medicine. 1994:193-198.
Yant WP, Schrenk HH, Waite CP, et al. Acute response of guinea pigs to vapors of some new commercial organic compounds—VI. Dioxane. Public Health Rep. 1930;45:2023-2032.
Yasugi T, Endo G, Monna T, et al. Types of organic solvent used in workplaces and work environment conditions with special references to reproducibility of work environment classification. Ind Health. 1998;36:223-233. [pmid: 9701900].
Yasuhara A, Shiraishi H, Nishikawa M, et al. Determination of organic components in leachates from hazardous waste disposal sites in Japan by gas chromatography-mass spectrometry. J Chromatogr A. 1997;774:321-332.
Yasuhara A, Tanaka Y, Tanabe A, et al. Elution of 1,4-dioxane from waste landfill sites. Bull Environ Contam Toxicol. 2003;71:641-647. [pmid: 14567593].
Yoo LJ, Fitzsimmons S, Wehner M. Simultaneous determination of 1,4-dioxane and n-nitrodimethylamine from drinking water by GC/MS using positive chemical ionization. American Water Works Association. WQTC Proceedings. 2001.
Yoo LJ, Fitzsimmons S, Wehner M. Improved purge-trap and GC/MS/MS techniques for the trace-level determination of 1,4-dioxane in water. Fountain Valley, CA. American Water Works Association. 2002. Water Quality Technology Conference.
Yoon JS, Mason JM, Nalencia R, et al. Chemical mutagenesis testing in Drosophila. IV. Results of 45 coded compounds tested for the national toxicology program. Environ Mutagen. 1985;7:349-367. [pmid: 3930235].
Young JD, Braun WH, Gehring PJ, et al. Short Communication. 1,4-dioxane and beta-hydroxyoxyacetic acid excretion in urine of humans exposed to dioxane vapors. Toxicol Appl Pharmacol. 1976;38:643-646. [pmid: 1014018].
Young JD, Braun WH, Gehring PJ. Dose-dependent fate of 1,4-dioxane in rats. J Toxicol Environ Health. 1978a;4:709-726. [pmid: 731724].
Young JD, Braun WH, Gehring PJ. The dose-dependent fate of 1,4-dioxane in rats. J Environ Pathol Toxicol. 1978b;2:263-282. [pmid: 739213].
Young JD, Braun WH, Rampy LW. Pharmacokinetics of 1,4-dioxane in humans. J Toxicol Environ Health. 1977;3:507-520. [pmid: 926203].
Zenker MJ, Borden RC, Barlaz MA. Alleman BC, Leeson A, editors. Investigation of the intrinsic biodegradation of alkyl and cyclic ethers. The Fifth International In Situ and On-site Bioremediation Symposium. April 19–22, 1999. San Diego. Calif. Columbus. Battelle Press. 1999:165-170.
Zenker MJ, Borden RC, Barlaz MA. Mineralization of 1,4-dioxane in the presence of a structural analog. Biodegradation. 2000;11:239-246. [pmid: 11432582].
Zhang ZZ, Low PF, Cushman JH, et al. Adsorption and heat of adsorption of organic compounds on montmorillonite from aqueous solutions. Soil Sci Soc Am J. 1990;54:59-66.
Ziegler EE, Edwards BB, Jensen RL, et al. Absorption and retention of lead by infants. Pediatr Res. 1978;12:29-34. [pmid: 643372].
Zimmermann FK, Mayer VW, Scheel I, et al. Acetone, methyl ethyl ketone, ethyl acetate, acetonitrile and other polar aprotic solvents are strong inducers of aneuploidy in Saccharomyces cerevisiae. Mutat Res. 1985;149:339-351. [pmid: 3887145].