# GLOSSARY

Absorption: The taking up of liquids by solids, or of gases by solids or liquids.
Acute Exposure: Exposure to a chemical for a duration of 14 days or less, as specified in the Toxicological Profiles.
Adsorption: The adhesion in an extremely thin layer of molecules (as of gases, solutes, or liquids) to the surfaces of solid bodies or liquids with which they are in contact.
Adsorption Coefficient (K_oc_): The ratio of the amount of a chemical adsorbed per unit weight of organic carbon in the soil or sediment to the concentration of the chemical in solution at equilibrium.
Adsorption Ratio (Kd): The amount of a chemical adsorbed by sediment or soil (i.e., the solid phase) divided by the amount of chemical in the solution phase, which is in equilibrium with the solid phase, at a fixed solid/solution ratio. It is generally expressed in micrograms of chemical sorbed per gram of soil or sediment.
Benchmark Dose (BMD): Usually defined as the lower confidence limit on the dose that produces a specified magnitude of changes in a specified adverse response. For example, a BMD_10_ would be the dose at the 95% lower confidence limit on a 10% response, and the benchmark response (BMR) would be 10%. The BMD is determined by modeling the dose response curve in the region of the dose response relationship where biologically observable data are feasible.
Benchmark Dose Model: A statistical dose-response model applied to either experimental toxicological or epidemiological data to calculate a BMD.
Bioconcentration Factor (BCF): The quotient of the concentration of a chemical in aquatic organisms at a specific time or during a discrete time period of exposure divided by the concentration in the surrounding water at the same time or during the same period.
Biomarkers: Broadly defined as indicators signaling events in biologic systems or samples. They have been classified as markers of exposure, markers of effect, and markers of susceptibility.
Cancer Effect Level (CEL): The lowest dose of chemical in a study, or group of studies, that produces significant increases in the incidence of cancer (or tumors) between the exposed population and its appropriate control.
Carcinogen: A chemical capable of inducing cancer.
Case-Control Study: A type of epidemiological study that examines the relationship between a particular outcome (disease or condition) and a variety of potential causative agents (such as toxic chemicals). In a case-controlled study, a group of people with a specified and well-defined outcome is identified and compared to a similar group of people without outcome.
Case Report: Describes a single individual with a particular disease or exposure. These may suggest some potential topics for scientific research, but are not actual research studies.
Case Series: Describes the experience of a small number of individuals with the same disease or exposure. These may suggest potential topics for scientific research, but are not actual research studies.
Ceiling Value: A concentration of a substance that should not be exceeded, even instantaneously.
Chronic Exposure: Exposure to a chemical for 365 days or more, as specified in the Toxicological Profiles.
Cohort Study: A type of epidemiological study of a specific group or groups of people who have had a common insult (e.g., exposure to an agent suspected of causing disease or a common disease) and are followed forward from exposure to outcome. At least one exposed group is compared to one unexposed group.
Cross-sectional Study: A type of epidemiological study of a group or groups of people that examines the relationship between exposure and outcome to a chemical or to chemicals at one point in time.
Data Needs: Substance-specific informational needs that if met would reduce the uncertainties of human health assessment.
Developmental Toxicity: The occurrence of adverse effects on the developing organism that may result from exposure to a chemical prior to conception (either parent), during prenatal development, or postnatally to the time of sexual maturation. Adverse developmental effects may be detected at any point in the life span of the organism.
Dose-Response Relationship: The quantitative relationship between the amount of exposure to a toxicant and the incidence of the adverse effects.
Embryotoxicity and Fetotoxicity: Any toxic effect on the conceptus as a result of prenatal exposure to a chemical; the distinguishing feature between the two terms is the stage of development during which the insult occurs. The terms, as used here, include malformations and variations, altered growth, and in utero death.
Environmental Protection Agency (EPA) Health Advisory: An estimate of acceptable drinking water levels for a chemical substance based on health effects information. A health advisory is not a legally enforceable federal standard, but serves as technical guidance to assist federal, state, and local officials.
Epidemiology: Refers to the investigation of factors that determine the frequency and distribution of disease or other health-related conditions within a defined human population during a specified period.
Genotoxicity: A specific adverse effect on the genome of living cells that, upon the duplication of affected cells, can be expressed as a mutagenic, clastogenic, or carcinogenic event because of specific alteration of the molecular structure of the genome.
Half-life: A measure of rate for the time required to eliminate one half of a quantity of a chemical from the body or environmental media.
Immediately Dangerous to Life or Health (IDLH): The maximum environmental concentration of a contaminant from which one could escape within 30 minutes without any escape-impairing symptoms or irreversible health effects.
Immunologic Toxicity: The occurrence of adverse effects on the immune system that may result from exposure to environmental agents such as chemicals.
Immunological Effects: Functional changes in the immune response.
Incidence: The ratio of individuals in a population who develop a specified condition to the total number of individuals in that population who could have developed that condition in a specified time period.
Intermediate Exposure: Exposure to a chemical for a duration of 15–364 days, as specified in the Toxicological Profiles.
In Vitro: Isolated from the living organism and artificially maintained, as in a test tube.
In Vivo: Occurring within the living organism.
Lethal Concentration_(LO)_ (LC_LO_): The lowest concentration of a chemical in air that has been reported to have caused death in humans or animals.
Lethal Concentration_(50)_ (LC_50_): A calculated concentration of a chemical in air to which exposure for a specific length of time is expected to cause death in 50% of a defined experimental animal population.
Lethal Dose_(LO)_ (LD_Lo_): The lowest dose of a chemical introduced by a route other than inhalation that has been reported to have caused death in humans or animals.
Lethal Dose_(50)_ (LD_50_): The dose of a chemical that has been calculated to cause death in 50% of a defined experimental animal population.
Lethal Time_(50)_ (LT_50_): A calculated period of time within which a specific concentration of a chemical is expected to cause death in 50% of a defined experimental animal population.
Lowest-Observed-Adverse-Effect Level (LOAEL): The lowest exposure level of chemical in a study, or group of studies, that produces statistically or biologically significant increases in frequency or severity of adverse effects between the exposed population and its appropriate control.
Lymphoreticular Effects: Represent morphological effects involving lymphatic tissues such as the lymph nodes, spleen, and thymus.
Malformations: Permanent structural changes that may adversely affect survival, development, or function.
Minimal Risk Level (MRL): An estimate of daily human exposure to a hazardous substance that is likely to be without an appreciable risk of adverse noncancer health effects over a specified route and duration of exposure.
Modifying Factor (MF): A value (greater than zero) that is applied to the derivation of a Minimal Risk Level (MRL) to reflect additional concerns about the database that are not covered by the uncertainty factors. The default value for a MF is 1.
Morbidity: State of being diseased; morbidity rate is the incidence or prevalence of disease in a specific population.
Mortality: Death; mortality rate is a measure of the number of deaths in a population during a specified interval of time.
Mutagen: A substance that causes mutations. A mutation is a change in the DNA sequence of a cell’s DNA. Mutations can lead to birth defects, miscarriages, or cancer.
Necropsy: The gross examination of the organs and tissues of a dead body to determine the cause of death or pathological conditions.
Neurotoxicity: The occurrence of adverse effects on the nervous system following exposure to a chemical.
No-Observed-Adverse-Effect Level (NOAEL): The dose of a chemical at which there were no statistically or biologically significant increases in frequency or severity of adverse effects seen between the exposed population and its appropriate control. Effects may be produced at this dose, but they are not considered to be adverse.
Octanol-Water Partition Coefficient (K_ow_): The equilibrium ratio of the concentrations of a chemical in n-octanol and water, in dilute solution.
Odds Ratio (OR): A means of measuring the association between an exposure (such as toxic substances and a disease or condition) that represents the best estimate of relative risk (risk as a ratio of the incidence among subjects exposed to a particular risk factor divided by the incidence among subjects who were not exposed to the risk factor). An OR of greater than 1 is considered to indicate greater risk of disease in the exposed group compared to the unexposed group.
Organophosphate or Organophosphorus Compound: A phosphorus-containing organic compound and especially a pesticide that acts by inhibiting cholinesterase.
Permissible Exposure Limit (PEL): An Occupational Safety and Health Administration (OSHA) allowable exposure level in workplace air averaged over an 8-hour shift of a 40-hour workweek.
Pesticide: General classification of chemicals specifically developed and produced for use in the control of agricultural and public health pests.
Pharmacokinetics: The dynamic behavior of a material in the body, used to predict the fate (disposition) of an exogenous substance in an organism. Utilizing computational techniques, it provides the means of studying the absorption, distribution, metabolism, and excretion of chemicals by the body.
Pharmacokinetic Model: A set of equations that can be used to describe the time course of a parent chemical or metabolite in an animal system. There are two types of pharmacokinetic models: data-based and physiologically-based. A data-based model divides the animal system into a series of compartments, which, in general, do not represent real, identifiable anatomic regions of the body, whereas the physiologically-based model compartments represent real anatomic regions of the body.
Physiologically Based Pharmacodynamic (PBPD) Model: A type of physiologically based dose-response model that quantitatively describes the relationship between target tissue dose and toxic end points. These models advance the importance of physiologically based models in that they clearly describe the biological effect (response) produced by the system following exposure to an exogenous substance.
Physiologically Based Pharmacokinetic (PBPK) Model: Comprised of a series of compartments representing organs or tissue groups with realistic weights and blood flows. These models require a variety of physiological information: tissue volumes, blood flow rates to tissues, cardiac output, alveolar ventilation rates, and possibly membrane permeabilities. The models also utilize biochemical information, such as air/blood partition coefficients, and metabolic parameters. PBPK models are also called biologically based tissue dosimetry models.
Prevalence: The number of cases of a disease or condition in a population at one point in time.
Prospective Study: A type of cohort study in which the pertinent observations are made on events occurring after the start of the study. A group is followed over time.
q_1_⁎: The upper-bound estimate of the low-dose slope of the dose-response curve as determined by the multistage procedure. The q_1_^*^ can be used to calculate an estimate of carcinogenic potency, the incremental excess cancer risk per unit of exposure (usually μg/L for water, mg/kg/day for food, and μg/m^3^ for air).
Recommended Exposure Limit (REL): A National Institute for Occupational Safety and Health (NIOSH) time-weighted average (TWA) concentration for up to a 10-hour workday during a 40-hour workweek.
Reference Concentration (RfC): An estimate (with uncertainty spanning perhaps an order of magnitude) of a continuous inhalation exposure to the human population (including sensitive subgroups) that is likely to be without an appreciable risk of deleterious noncancer health effects during a lifetime. The inhalation reference concentration is for continuous inhalation exposures and is appropriately expressed in units of mg/m^3^ or ppm.
Reference Dose (RfD): An estimate (with uncertainty spanning perhaps an order of magnitude) of the daily exposure of the human population to a potential hazard that is likely to be without risk of deleterious effects during a lifetime. The RfD is operationally derived from the no-observed-adverse-effect level (NOAEL, from animal and human studies) by a consistent application of uncertainty factors that reflect various types of data used to estimate RfDs and an additional modifying factor, which is based on a professional judgment of the entire database on the chemical. The RfDs are not applicable to nonthreshold effects such as cancer.
Reportable Quantity (RQ): The quantity of a hazardous substance that is considered reportable under the Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA). Reportable quantities are (1) 1 pound or greater or (2) for selected substances, an amount established by regulation either under CERCLA or under Section 311 of the Clean Water Act. Quantities are measured over a 24-hour period.
Reproductive Toxicity: The occurrence of adverse effects on the reproductive system that may result from exposure to a chemical. The toxicity may be directed to the reproductive organs and/or the related endocrine system. The manifestation of such toxicity may be noted as alterations in sexual behavior, fertility, pregnancy outcomes, or modifications in other functions that are dependent on the integrity of this system.
Retrospective Study: A type of cohort study based on a group of persons known to have been exposed at some time in the past. Data are collected from routinely recorded events, up to the time the study is undertaken. Retrospective studies are limited to causal factors that can be ascertained from existing records and/or examining survivors of the cohort.
Risk: The possibility or chance that some adverse effect will result from a given exposure to a chemical.
Risk Factor: An aspect of personal behavior or lifestyle, an environmental exposure, or an inborn or inherited characteristic that is associated with an increased occurrence of disease or other health-related event or condition.
Risk Ratio: The ratio of the risk among persons with specific risk factors compared to the risk among persons without risk factors. A risk ratio greater than 1 indicates greater risk of disease in the exposed group compared to the unexposed group.
Short-Term Exposure Limit (STEL): The American Conference of Governmental Industrial Hygienists (ACGIH) maximum concentration to which workers can be exposed for up to 15 minutes continually. No more than four excursions are allowed per day, and there must be at least 60 minutes between exposure periods. The daily Threshold Limit Value-Time Weighted Average (TLV-TWA) may not be exceeded.
Standardized Mortality Ratio (SMR): A ratio of the observed number of deaths and the expected number of deaths in a specific standard population.
Target Organ Toxicity: This term covers a broad range of adverse effects on target organs or physiological systems (e.g., renal, cardiovascular) extending from those arising through a single limited exposure to those assumed over a lifetime of exposure to a chemical.
Teratogen: A chemical that causes structural defects that affect the development of an organism.
Threshold Limit Value (TLV): An American Conference of Governmental Industrial Hygienists (ACGIH) concentration of a substance to which most workers can be exposed without adverse effect. The TLV may be expressed as a Time Weighted Average (TWA), as a Short-Term Exposure Limit (STEL), or as a ceiling limit (CL).
Time-Weighted Average (TWA): An allowable exposure concentration averaged over a normal 8-hour workday or 40-hour workweek.
Toxic Dose_(50)_ (TD_50_): A calculated dose of a chemical, introduced by a route other than inhalation, which is expected to cause a specific toxic effect in 50% of a defined experimental animal population.
Toxicokinetic: The absorption, distribution, and elimination of toxic compounds in the living organism.
Uncertainty Factor (UF): A factor used in operationally deriving the Minimal Risk Level (MRL) or Reference Dose (RfD) or Reference Concentration (RfC) from experimental data. UFs are intended to account for (1) the variation in sensitivity among the members of the human population, (2) the uncertainty in extrapolating animal data to the case of human, (3) the uncertainty in extrapolating from data obtained in a study that is of less than lifetime exposure, and (4) the uncertainty in using lowestobserved-adverse-effect level (LOAEL) data rather than no-observed-adverse-effect level (NOAEL) data. A default for each individual UF is 10; if complete certainty in data exists, a value of 1 can be used; however, a reduced UF of 3 may be used on a case-by-case basis, 3 being the approximate logarithmic average of 10 and 1.
Xenobiotic: Any chemical that is foreign to the biological system.