# CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

1,4-Dioxane or para-dioxane is also commonly referred to as simply ‘dioxane’. However, 1,4-dioxane should not be confused with dioxin (or dioxins), which are a different class of chemical compounds. Information regarding the chemical identity of 1,4-dioxane is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

1,4-Dioxane is a colorless liquid. 1,4-Dioxane is also completely miscible in water and organic solvents. The technical-grade product is >99.9% pure, but may contain bis(2-chloroethyl) ether as an impurity (DeRosa et al. 1996). Information regarding the physical and chemical properties of 1,4-dioxane is located in Table 4-2.

Table 4-1 Chemical Identity of 1,4-Dioxane

Characteristic | Information
Chemical name | 1,4-Dioxane
Synonym(s) | 1,4-diethylenedioxide; 1,4-dioxacyclohexane; 1,4-dioxanne (French); di(ethylene oxide); diethylene dioxide; diethylene ether; dioksan (Polish); diossano-1,4 (Italian); dioxaan-1,4 (Dutch); dioxan; dioxan-1,4 (German); dioxane; dioxane-1,4; dioxanne (French); dioxyethylene ether; glycol ethylene ether; para-dioxane; p-dioxan (Czech); p-dioxane; p-dioxin, tetrahydro-; tetrahydro-1,4-dioxin; tetrahydro-para-dioxin; tetrahydro-p-dioxin
Registered trade name(s) | No data
Chemical formula | C_4_H_8_O_2_
Chemical structure
Identification numbers:
CAS Registry | 123-91-1
NIOSH RTECS | JG8225000
EPA Hazardous Waste | U108; A toxic waste when a discarded commercial chemical product or manufacturing chemical intermediate or an off-specification commercial chemical product or a manufacturing chemical intermediate
OHM/TADS | No data
DOT/UN/NA/IMDG | UN 1165; IMDG 3.2
HSDB | 81
NCI | No data

CAS = Chemical Abstracts Services; CIS = Chemical Information System; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of 1,4-Dioxane

Property
Molecular weight (g/mol) | 88.11^a^
Color | Clear^b^
Physical state | Liquid^a^
Melting point | 11.8 °C^a^
Boiling point | 101.1 °C^a^
Density | 1.0329^a^
Odor | Faint pleasant odor^a^
Odor threshold:
Water | 230 ppm w/v^b^
Air | 24 ppm v/v^b^
Taste | No data
Solubility:
Water | Miscible^c^
Other solvents | Soluble in organic solvents^a^
Partition coefficients:
Log K_ow_ | −0.27^d^
Log K_oc_ | 1.23^b^
Vapor pressure at 25 °C | 38.1 mm Hg^e^
OH radical rate constant | 1.09×10^−11^ cm^3^/molecule-sec^f^
Henry's law constant at 25 °C | 4.80×10^−6^ atm-cm^3^/mole^g^
Autoignition temperature | 356 °F (180 °C)^h^
Flashpoint | 5–18 °C^a^
Flammability limits at 25 °C | Lower: 2.0%; Upper: 22%^b^
Incompatibilities | Strong oxidizers, decaborane, triethynyl aluminum^h^
Conversion factors (25 °C and 1 atm) | 1 ppm = 3.6 mg/m^3^; 1 mg/m^3^ = 0.278 ppm^b^
Explosive limits | Vapor forms explosive mixtures with air over wide range^i^

a O’Neil et al. 2001.

b EC 2002.

c Riddick et al. 1986.

d Hansch et al. 1995.

e Daubert and Danner 1985.

f Atkinson 1989.

g Park et al. 1987.

h NIOSH 2001.

i ScienceLab 2005.