# PEER REVIEW

A peer review panel was assembled for manganese. The panel consisted of the following members:

1. David Dorman, D.V.M., Ph.D., Associate Dean for Research and Graduate Studies, College of Veterinary Medicine, Professor of Toxicology, Department of Molecular Biomedical Sciences, North Carolina State University, Raleigh, North Carolina 27606,
2. Donald Smith, Ph.D., Professor of Environmental Toxicology, University of California, Santa Cruz, California 95064, and
3. Wei Zheng, Ph.D., Director of Graduate Studies, School of Health Sciences, Purdue University, West Lafayette, Indiana 47907.

These experts collectively have knowledge of manganese’s physical and chemical properties, toxicokinetics, key health end points, mechanisms of action, human and animal exposure, and quantification of risk to humans. All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers' comments and determined which comments will be included in the profile. A listing of the peer reviewers' comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound.

The citation of the peer review panel should not be understood to imply its approval of the profile's final content. The responsibility for the content of this profile lies with the ATSDR.