# CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Table 4-1 lists common synonyms, trade names, and other relevant information regarding the chemical identity of manganese and several of its most important compounds.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of manganese is located in Table 4-2.

Table 4-1 Chemical Identity of Manganese and Compounds^a^

Characteristic | Information
Chemical name | Manganese | Mn(II) chloride | Manganese sulfate
Synonym(s) | Elemental manganese^b^; collodial manganese^b^; cutaval^b^ | Manganese chloride^b^; manganese dichloride | Manganese sulfate
Registered trade name(s) | Cutaval^b^; Mangan^b^ | No data | Sorba-spray manganese^b^
Chemical formula | Mn | MnCl_2_ | MnSO_4_
Chemical structure | Mn
Identification numbers:
CAS registry | 7439-96-5 | 7773-01-5 | 7785-87-7
NIOSH RTECS | 009275000^b^ | 009625000^b^ | OP1050000^b^
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMDG shipping | No data | No data | No data
HSDB | 00550^b^ | 02154^b^ | 02187^b^
NCI | No data | No data | No data
Chemical name | Manganese (II, III) oxide | Manganese dioxide | Potassium permanganate
Synonym(s) | Manganese tetroxide; mangano-manganic oxide^c^ | Manganese peroxide; manganese binoxide; manganese black; battery manganese | Permanganic acid; potassium salt; chameleon mineral^c^
Registered trade name(s) | No data | No data | No data
Chemical formula | Mn_3_O_4_ | MnO_2_ | KMnO_4_
Chemical structure
Identification numbers:
CAS registry | 1317-35-7 | 1313-13-9 | 7722-64-7
NIOSH RTECS | OP0900000^b^ | No data | SD6475000^b^
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMDG shipping | No data | No data | UN1490^b^, IMDG 5.1^b^
HSDB | No data | No data | 01218^b^
NCI | No data | No data | No data
Chemical name | Mn(II) carbonate | Mangafodipir | Methylcyclopentadienyl manganese tricarbonyl (MMT)
Synonym(s) | Carbonic acid; manganese (2+) salt; manganous carbonate^b^; natural rhodochrosite^b^ | Mangafodipir trisodium^d^; MnDPDP^d^ | MMT; manganese, tricarbonyl ([1,2,3,4,5-eta]-1-methyl-2,4-cyclopentadien-1yl)-; methylcymantrene; tricarbonyl (2-methylcyclopentadientyl) manganese^b^
Registered trade name(s) | No data | Teslascan^d^; Win 59010^d^ | AK-33X; Antiknock-33; CI-2; Combustion Improver-2^b^
Chemical formula | MnCO_3_ | C_22_H_24_MnN_4_O_14_P_2_H_3_Na_3_ | C_9_H_7_MnO_3_
Chemical structure | | No data
Identification numbers:
CAS registry | 598-62-9 | 140678-14-4 | 12108-13-3
NIOSH RTECS | No data | OO9163250 | 48184
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMDG shipping | No data | No data | No data
HSDB | 00790^b^ | No data | 2014
NCI | No data | No data | No data

a All information obtained from Sax and Lewis 1987, except where noted.

b HSDB 2008.

c O’Neil et al. 2006.

d RTECS 2007.

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Material Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Manganese and Compounds^a^

Property | Manganese | Mn(II) chloride | Manganese sulfate
Molecular weight | 54.94^b^ | 125.85^b^ | 151.00^b^
Color | Steel-gray^b^ | Pink | Pale rose-red
Physical state | Solid | Solid | Solid
Melting point | 1,244 °C^c^ | 650 °C | 700 °C
Boiling point | 2,095 °C^b^ | 1,412 °C^b^ | 850 °C (decomposes)
Density at 20 °C | 7.26 g/cm^3^ b at 20 °C | 2.325 g/cm^3^ at 25 °C b | 3.25 g/cm^3^ d
Odor | No data | No data | Odorless
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water at 20 °C | Decomposes | No data | No data
Acids | Reacts with diluted mineral acids with evolution of hydrogen and formation of divalent manganous salts^b^ | No data | No data
Organic solvents | No data | Soluble in alcohol, insoluble in ether | Soluble in alcohol, insoluble in ether
Partition coefficients:
Log K_ow_ | No data | No data | Not applicable
Log K_oc_ | No data | No data | Not applicable
Vapor pressure at 20 °C | 1 Pa at 955 °C^c^ | 1,000 Pa at 760 °C^c^ | No data
Henry's law constant at 25 °C | No data | Not applicable | Not applicable
Autoignition temperature | No data | Noncombustible | No data
Flashpoint | No data | No data | No data
Flammability limits | Flammable and moderately explosive in dust form when exposed to flame^d^ | No data | No data
Conversion factors | Not applicable | Not applicable | Not applicable
Explosive limits | Mixture of aluminum and manganese dust may explode in air. Mixtures with ammonium nitrate may explode when heated^d^ | No data | No data
Reactivity | Hydrogen^d^; when heated above 200 °C in presence of nitrogen, forms nitrode; violent reaction with NO_2_ and oxidants; incandescent reaction with phosphorous, nitryl fluoride, nitric acid^d^ | No data | No data
Molecular weight | 228.81^b^ | 86.94^b^ | 158.03^b^
Color | Brownish-black^b^ | Black | Purple
Physical state | Solid | Solid | Solid
Melting point | 1,564 °C Loses oxygen at | 535 °C^d^ | <240 °C (decomposes)
Boiling point | No data | No data | No data
Density at 20 °C | No data | 5.0 g/cm^3^ d | 2.703 g/cm^3^
Odor | No data | No data | Odorless
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water at 20 °C | Insoluble | Insoluble | No data
Acids | Soluble in hydrochloric acid | Soluble in hydrochloric acid | Soluble in sulfuric acid
Organic solvents | No data | No data | Soluble in acetone
Partition coefficients:
Log K_ow_ | Not applicable | No data | No data
Log K_oc_ | Not applicable | No data | No data
Vapor pressure at 20 °C | No data | No data | No data
Henry's law constant at 25 °C | Not applicable | No data | No data
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | No data | No data | No data
Conversion factors | Not applicable | Not applicable | Not applicable
Explosive limits | No data | No data | No data
Reactivity | No data | No data | Spontaneously flammable on contact with ethylene glycol
Molecular weight | 114.95 | 757.4^e^ | 218.1
Color | Pink^c^ | No data | Yellow to dark orange
Physical state | hexagonal, crystals^c^ | Liquid (solution for infusion) | Liquid, solid below 2 °C
Melting point | Decomposes | No data | 1.5 °C^d^
Boiling point | No data | No data | 232 °C
Density at 20 °C | 3.70 g/cm^3^ c | 1.537 g/cm^3^ b | 1.39 g/cm^3^
Odor | No data | No data | Faint, pleasant
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water at 20 °C | Insoluble | 459.6 g/L^b^ | Insoluble
Acids | Soluble in dilute acid^c^ | No data | No data
Organic solvents | No data | 23 g/L (methanol); 0.8 g/L (ethanol); 0.6 g/L (acetone); 1.1 g/L (chloroform)^b^ | Readily soluble in hydrocarbons and the usual organic solvents including hexane, alcohols, ethers, acetone, ethylene glycol, lubricating oils, gasoline and diesel fuel^b^
Partition coefficients:
Log K_ow_ | No data | −5.62^b^ | No data
Log K_oc_ | No data | No data | No data
Vapor pressure at 20 °C | No data | No data | Ranges from 8 mm Hg at 100 °C to 360.6 mm Hg at 200 °C^b^
Henry's law constant at 25 °C | No data | No data | No data
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | 110 °C
Flammability limits | No data | No data | No data
Conversion factors | Not applicable | No data | No data
Explosive limits | No data | No data | No data
Reactivity | No data | No data | Light (decomposes)

a All information obtained from Sax and Lewis 1987, except where noted.

b O’Neil et al. 2006.

c Lide 2000.

d Lewis 2000.

e RTECS 2007.

f Data for MMT from NIOSH 2005 unless otherwise noted.