# REFERENCES

Abbasi SA. Atomic absorption spectrometric and spectrophotometric trace analysis of uranium in environmental samples with N-p-methoxyphenyl-2-furylacrylohydroxamic acid and 4-(2-pyridylazo) resorcinol. Int J Environ Anal Chem. 1989;36:163-172.
ABMS. Non-ferrous metal data 1993. American Bureau of Metal Statistics Inc. 1994.
ACE. Formerly utilized sites remedial action program. U.S. Army Corps of Engineers. 2013. http://www.usace.army.mil/Media/FactSheets/FactSheetArticleView/tabid/219/Article/816/formerly-utilized-sites-remedial-action-program.aspx. February 21, 2013.
ACGIH. Uranium. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH. American Conference of Governmental Industrial Hygienists. 2012:59. 111.
Adams N, Spoor NL. Kidney and bone retention functions in the human metabolism of uranium. Phys Med Biol. 1974;19:460-471. [pmid: 4445220].
Adinolfi M. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol. 1985;27(4):532-537. [pmid: 4029526].
Adlercreutz H. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl. 1995;103(7):103-112.
AEC. The excretion of hexavalent uranium following intravenous administration. II. Studies on human subjects. Rochester, NY. U.S. Atomic Energy Commission. 1948. UR-37. http://www.osti.gov/bridge/purl.cover.jsp?purl=/122006-Q20zHP/webviewable/. November 23, 2010.
AEC. A study of the distribution and excretion of uranium in man. Oak Ridge, TN. U.S. Atomic Energy Commission. 1957. DE86013703.
AEC. Environmental survey of the uranium fuel cycle. U.S. Atomic Energy Commission. 1974. USAEC Report WASH-1248.
Agency for Toxic Substances and Disease Registry. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry, Division of Toxicology. Fed Regist. 1989;54(174):37618-37634.
Agency for Toxic Substances and Disease Registry. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Subcommittee on Biomarkers of Organ Damage and Dysfunction. Atlanta, GA. Agency for Toxic Substances and Disease Registry. 1990c.
Agency for Toxic Substances and Disease Registry. Public health assessment. Monticello Mill tailings (DOE) and Monticello radioactively contaminated properties (aka Monticello vicinity properties). Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. 1997. http://www.atsdr.cdc.gov/HAC/pha/PHA.asp?docid=802&pg=0. November 15, 2010.
Agency for Toxic Substances and Disease Registry. Health consultation. Depleted uranium at Hawaiian military sites; Schofield Barracks Impact Area; Makua Military Reservation, Pohakuloa Training Area on Islands of Oahu and Hawaii. Agency for Toxic Substances and Disease Registry. 2008. http://www.atsdr.cdc.gov/HAC/pha//DepletedUraniumHawaiianMilitarySites/Depleted_Uranium_At_Ha waiian_Military_Sites%20(HC%208-25-2008)%20.pdf. February 21, 2013.
Agency for Toxic Substances and Disease Registry. Toxicological profile for plutonium. Atlanta, GA. Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. 2010. http://www.atsdr.cdc.gov/ToxProfiles/tp143.pdf. December 16, 2010.
Agency for Toxic Substances and Disease Registry. Toxicological profile for radon. Atlanta, GA. Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. 2012. http://www.atsdr.cdc.gov/ToxProfiles/tp145.pdf. July 24, 2012.
Ahsanullah M, Williams AR. Kinetics of uranium uptake by the crab Pachygrapsus laevimanus and the zebra winkle Austrocochlea constricta. Mar Biol. 1989;101:323-327.
Aieta EM, Singley JE, Trussell AR, et al. Radionuclides in drinking water: An overview. J Am Water Works Assoc. 1987;79:144-152.
AIHA. Emergency response planning guidelines (ERPG). Fairfax, VA. American Industrial Hygiene Association. 2011. http://www.aiha.org/insideaiha/GuidelineDevelopment/ERPG/Documents/2011erpgweelhandbook_table-only.pdf. April 25, 2012.
Aldstadt JH, Kuo JM, Smith LL, et al. Determination of uranium by flow injection inductively coupled plasma mass spectrometry. Anal Chim Acta. 1996;319(1–2):135-143.
Allard B, Kipatsi H, Torstenfelt B, et al. McCarthy GJ, editor. Nuclide transport by groundwater in Swedish bedrock. Scientific Basis for Nuclear Waste Management. NY. Plenum Press. 1979:403-410.
Allard B, Olofsson U, Torstenfelt B, et al. Lutze W, editor. Sorption of actinides in well-defined oxidation states on geologic media. Scientific basis for radioactive waste management - V. Elsevier. 1982:775-782.
Altman PL, Dittmer DS. Biological handbooks: Biology data book. 2nd ed. Bethesda, MD. Federation of American Societies for Experimental Biology. 1974;Vol. III. 1987–2008, 2041.
Ames LL, McGarrah JE, Walker BA. Sorption of uranium and cesium by Hanford basalts and associated secondary smectite. Chem Geol. 1982;35:205-225.
Amethyst Galleries. The mineral tyuyamunite. 1995. http://mineral.galleries.com/minerals/phosphat/tyuyamun/tyuyanum.htm.
Andersen ME, MacNaughton MG, Clewell HJ, et al. Adjusting exposure limits for long and short exposure periods using a physiological pharmacokinetic model. Am Ind Hyg Assoc J. 1987;48(4):335-343. [pmid: 3591649].
Andersen ME, Krishnan K. Salem H, editor. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. Animal test alternatives: Refinement, reduction, replacement. New York, NY. Marcel Dekker, Inc. 1994:9-25.
Anderson RF, Fleer AP. Determination of natural actinides and plutonium in marine particulate material. Anal Chem. 1982;54:1142-1147.
Andre S, Metivier H, Auget D, et al. Lung dissolution of uranium tetrafluoride in rats and baboons. Comparison with dissolution by alveolar macrophages in culture and chemical dissolution. Hum Toxicol. 1989;8:111-119. [pmid: 2744773].
ANL. Depleted UF6 storage. Depleted UF6 inventory and storage locations. Argonne National Laboratory. 2011. http://web.ead.anl.gov/uranium/mgmtuses/storage/index.cfm. January 21, 2011.
ANSI. American national standard radiation protection instrumentation test and calibration. American National Standard Institute, ANSI N323. New York, NY. Institute of Electrical and Electronics Engineers, Inc. 1978.
Anthony ML, Gartland KPR, Beddell CR, et al. Studies of the biochemical toxicology of uranyl nitrate in the rat. Arch Toxicol. 1994;68(1):43-53. [pmid: 8166604].
Archer VE, Wagoner JK, Lundin FE. Lung cancer among uranium miners in the United States. Health Phys. 1973a;25:351-371. [pmid: 4361970].
Archer VE, Wagoner JK, Lundin FE. Cancer mortality among uranium mill workers. J Occup Med. 1973b;15:11-14. [pmid: 4684721].
Arfsten DP, Schaeffer DJ, Johnson EW, et al. Evaluation of the effect of implanted depleted uranium on male reproductive success, sperm concentration, and sperm velocity. Environ Res. 2006;100(2):205-215. [pmid: 15939419].
Arfsten DP, Still KR, Wilfong ER, et al. Two-generation reproductive toxicity study of implanted depleted uranium (DU) in CD rats. J Toxicol Environ Health A. 2009;72(6):410-427. [pmid: 19199148].
Arfsten DP, Wilfong ER, Bekkedal MY, et al. Evaluation of the effect of implanted depleted uranium (DU) on adult rat behavior and toxicological endpoints. J Toxicol Environ Health A. 2007;70(23):1995-2010. [pmid: 17966071].
Argonne National Laboratory. Natural decay series: Uranium, radium, and thorium. Human health fact sheet. 2005. http://www.ead.anl.gov/pub/doc/natural-decay-series.pdf. April 28, 2011.
Arnault E, Doussau M, Pesty A, et al. Natural uranium disturbs mouse folliculogenesis in vivo and oocyte meiosis in vitro. Toxicology. 2008;247(2–3):80-87. [pmid: 18407394].
Arruda-Neto JD, Guevara MV, Nogueira GP, et al. Long-term accumulation of uranium in bones of Wistar rats as a function of intake dosages. Radiat Prot Dosimetry. 2004a;112(3):385-393. [pmid: 15466919].
Arruda-Neto JD, Likhachev VP, Nogueira GP, et al. Transfer coefficient measurements of uranium to the organs of Wistar rats, as a function of the uranium content in the food. Appl Radiat Isot. 2001;54(6):947-956. [pmid: 11300409].
Arruda-Neto JD, Manso Guevara MV, Nogueira GP, et al. Long-term accumulation and microdistribution of uranium in the bone and marrow of beagle dog. Int J Radiat Biol. 2004b;80(8):567-575. [pmid: 15370968].
ASTM. Annual books of ASTM standards. Water and environmental technology, Section 11, Vol. 11.02 (water 11). Philadelphia, PA. American Society for Testing of Materials. 1986:511-515. 516. 521. 523. 528.
ASTM. Annual books of ASTM standards. Water and environmental technology. Philadelphia, PA. American Society for Testing of Materials. 1994:449-452.
Au WW, Lane RG, Legator MS, et al. Biomarker monitoring of a population residing near uranium mining activities. Environ Health Perspect. 1995;103(5):466-470. [pmid: 7656876].
Auerbach O, Saccomanno G, Kuschner M, et al. Histologic findings in the tracheobronchial tree of uranium miners and non-miners with lung cancer. Cancer. 1978;42:483-489. [pmid: 679150].
Avasthi PS, Evan AP, Hay D. Glomerular endothelial cells in uranyl nitrate-induced acute renal failure in rats. J Clin Invest. 1980;65:121-127. [pmid: 7350192].
Bakhmutsky MV, Oliver MS, McDiarmid MA, et al. Long term depleted uranium exposure in Gulf War I veterans does not cause elevated numbers of micronuclei in peripheral blood lymphocytes. Mutat Res. 2011;720(1–2):53-57. [pmid: 21167307].
Ballou JE, Gies RA, Case AC, et al. Deposition and early disposition of inhaled uranium-233 uranyl nitrate and uranium-232 uranyl nitrate in the rat. Health Phys. 1986;51:755-772. [pmid: 2946648].
Band P, Feldstein M, Saccomanno G, et al. Potentiation of cigarette smoking and radiation: Evidence from a sputum cytology survey among uranium miners and controls. Cancer. 1980;45:1273-1277. [pmid: 7357519].
Band P, Feldstein M, Watson L, et al. Lung cancer screening programs in Canadian uranium mines. Recent Results Cancer Res. 1982;82:153-158. [pmid: 6287544].
Barber DS, Hancock SK, McNally AM, et al. Neurological effects of acute uranium exposure with and without stress. Neurotoxicology. 2007;28(6):1110-1119. [pmid: 17669499].
Barnes CE, Cochran JK. Uranium geochemistry in estuarine sediments controls on removal and release processes. Geochim Cosmochim Acta. 1993;57:555-569.
Barnes DG, Dourson M. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol. 1988;8(4):471-486. [pmid: 3222488].
Bearman PJ. A review of the environmental problems associated with the disposal of uranium tailings. Miner Environ. 1979;1:64-74.
Bednar AJ, Medina VF, Ulmer-Scholle DS, et al. Effects of organic matter on the distribution of uranium in soil and plant matrices. Chemosphere. 2007;70(2):237-247. [pmid: 17709130].
Began D. Goldfrank LR, Flomenbaum NE, Lewin NA, et al., editors. Dermatologic principles. Goldfrank’s toxicologic emergencies. 7th ed. New York, NY. McGraw-Hill. 2002:432-440.
BEIR III. The effects on populations of exposure to low levels of ionizing radiation. Committee on the Biological Effects of Ionizing Radiations, National Research Council. Washington, DC. National Academy Press. 1980.
BEIR IV. Uranium. Health risk of radon and other internally deposited alpha-emitters. Washington, DC. National Academy Press. Biological Effects of Ionizing Radiations. 1988:276-302.
BEIR V. Health effects of exposure to low levels of ionizing radiation. Committee on the Biological Effects of Ionizing Radiations, National Research Council. Washington, DC. National Academy Press. 1990.
Beiter H, Gibb FR, Morrow PE. Intramuscular retention of UO_3_ and UO_2_. Health Phys. 1975;29:273-277. [pmid: 1193838].
Belles M, Albina ML, Linares V, et al. Combined action of uranium and stress in the ratIBehavioral effects. Toxicol Lett. 2005;158(3):176-185. [pmid: 16061148].
Belles M, Linares V, Luisa Albina M, et al. Melatonin reduces uranium-induced nephrotoxicity in rats. J Pineal Res. 2007;43(1):87-95. [pmid: 17614840].
Bensoussan H, Grancolas L, Dhieux-Lestaevel B, et al. Heavy metal uranium affects the brain cholinergic system in rat following sub-chronic and chronic exposure. Toxicology. 2009;261(1–2):59-67. [pmid: 19409444].
Bentley KW, Stockwell DR, Britt KA, et al. Transient proteinuria and aminoaciduria in rodents following uranium intoxication. Bull Environ Contam Toxicol. 1985;34:407-416. [pmid: 3978278].
Berard P, Quesne B, Auriol B, et al. Cutaneous contamination after a uranyl nitrate skin burn: Incident report. Radiat Prot Dosim. 1994;53(1–4):269-272.
Berger GS, editor. Epidemiology of endometriosis. Endometriosis: Modern surgical management of endometriosis. New York, NY. Springer-Verlag. 1994:3-7.
Berradi H, Bertho JM, Dudoignon N, et al. Renal anemia induced by chronic ingestion of depleted uranium in rats. Toxicol Sci. 2008;103(2):397-408. [pmid: 18375546].
Bhattacharyya RP, Larsen P, Cohen N, et al. Gastrointestinal absorption of plutonium and uranium in fed and fasted adult baboons and mice: Application to humans. Radiat Prot Dosimetry. 1989;26:159-165.
Bigu J, Duport P. Characterization of long-lived radioactive dust in uranium mill operations. Am Ind Hyg Assoc. 1992;53:588-595.
Bigu J, Grenier NK, Dave TP, et al. Study of radon gas concentration surface radon flux and other radiation variables from uranium mine tailings areas. Uranium. 1984;1:257-277.
Birkenfeld HP, Kathren RL, Hedaya MA. A sensitive method for the determination of uranium in biological samples utilizing kinetic phosphorescence analysis (KPA). Pharm Res. 1995;12(9 Suppl):S48.
Blantz RC. The mechanism of acute renal failure after uranyl nitrate. J Clin Invest. 1975;55:621-635. [pmid: 1090637].
Boice JD, Cohen SS, Mumma MT, et al. A cohort study of uranium millers and miners of Grants, New Mexico, 1979–2005. J Radiol Prot. 2008;28(3):303-325. [pmid: 18714128].
Boice JD, Cohen SS, Mumma MT, et al. Mortality among residents of Uravan, Colorado who lived near a uranium mill, 1936–84. J Radiol Prot. 2007a;27(3):299-319. [pmid: 17768330].
Boice JD, Mumma MT, Blot WJ. Cancer and noncancer mortality in populations living near uranium and vanadium mining and milling operations in Montrose County, Colorado, 1950–2000. Radiat Res. 2007b;167(6):711-726. [pmid: 17523851].
Boice JD, Mumma MT, Blot WJ. Cancer incidence and mortality in populations living near uranium milling and mining operations in Grants, New Mexico, 1950–2004. Radiat Res. 2010;175(5):624-636. [pmid: 20954862].
Boice JD, Mumma M, Schweitzer S, et al. Cancer mortality in a Texas county with prior uranium mining and milling activities, 1950–2001. J Radiol Prot. 2003;23(3):247-262. [pmid: 14582717].
Boniforti R. Lanthanides, uranium, and thorium as possible simulators of the behavior of transuranics in the aquatic environment. Sci Total Environ. 1987;64:181-189.
Boomer DW, Powell MJ. Determination of uranium in environmental samples using inductively coupled plasma mass spectrometry. Anal Chem. 1987;59:2810-2813. [pmid: 3434809].
Boothe GF. The need for radiation controls in the phosphate and related industries. Health Phys. 1977;32:285. [pmid: 881315].
Bosque MA, Domingo JL, Llobet JM, et al. Embryotoxicity and teratogenicity of uranium in mice following subcutaneous administration of uranyl acetate. Biol Trace Elem Res. 1993;36(2):109-118. [pmid: 7681302].
Bostick WD, McCulla WH, Pickrell PW. Sampling, characterization, and remote sensing of aerosols formed in the atmospheric hydrolysis of uranium hexafluoride. J Environ Sci Health A. 1985;20:369-393.
Bozal CB, Martinez AB, Cabrini RL, et al. Effect of ethane-1-hydroxy-1,1-bisphosphonate (EHBP) on endochondral ossification lesions induced by a lethal oral dose of uranyl nitrate. Arch Toxicol. 2005;79(8):475-481. [pmid: 15798912].
Bradford GR, Bakhtar D, Westcot D. Uranium vanadium and molybdenum in saline waters of California. J Environ Qual. 1990;19:105-108.
Brady HR, Kone CB, Brenner RM, et al. Early effects of uranyl nitrate on respiration and K transport in rabbit proximal tubule. Kidney Int. 1989;36:27-34. [pmid: 2811055].
Brandvold LL, Brendvold DK, Popp CJ. Effects of uranium mining and milling on surface water in New Mexico. Environmental and economic considerations in energy utilization. Proceedings of the Seventh Conference on Energy and the Environment. Phoenix, Arizona. Canton, NY. Ann Arbor Science Publishers. 1981:467-476.
Braunlich H, Fleck C. Urinary enzyme excretion as a indicator of nephrotoxicity in dependence on age. Exp Pathol. 1981;20(3):182-187. [pmid: 7338279].
Briner W. Effects of depleted uranium on mouse midbrain catecholamines and related behavior. Internet Journal of Toxicology. 2009;7(1). No pp. http://www.ispub.com/journal/the_internet_journal_of_toxicology/volume_7_number_2_29/article/effects-of-depleted-uranium-on-mouse-midbraincatecholamines-and-related-behavior.html. November 5, 2010.
Briner W, Byrd K. Collery P, Centeno JA, et al., editors. Effects of depleted uranium on development of the mouse. Metal ions in biology and medicine. Proceedings of the sixth International symposium on metal ions in biology and medicine, held in San Juan, Puerto Rico, USA, on May 7–10, 2000. Vol. 6. Montrouge, France. John Libbey Eurotext. 2000:459-461.
Briner W, Murray J. Effects of short-term and long-term depleted uranium exposure on open-field behavior and brain lipid oxidation in rats. Neurotoxicol Teratol. 2005;27(1):135-144. [pmid: 15681127].
Broadway JA, Strong AB. Radionuclides in human bone samples. Health Phys. 1983;45:765-768. [pmid: 6885482].
Brookins DG, Thomson BM, Longmire PA, et al. Geochemical behavior of uranium mill tailings leachate in the subsurface. Radioactive waste management and the nuclear fuel cycle. Malaysia. Harwood Academic Publishers. 1993;Vol. 17(3–4):269-287.
Brunskill GJ, Wilkinson P. Annual supply of uranium-238, uranium-234, thorium-230, radium-226, lead-210, polonium-210 and thorium-232 to lake 239 (Experimental Lakes Area, Ontario, Canada) from terrestrial and atmospheric sources. Can J Fish Aquat Sci. Suppl 1. 1987;44:215-230.
Busby C, Hamdan M, Ariabi E. Cancer, infant mortality and birth sex-ratio in Fallujah, Iraq 2005–2009. Int J Environ Res Public Health. 2010;7(7):2828-2837. [pmid: 20717542].
Bushaw BA. Advanced analytical techniques. Biokinetics and analysis of uranium in man. Proceedings of a colloquium held at Richland, WA. August 8–9, 1984. Prepared by the Hanford Environmental Health Foundation for the Department of Energy. 1984:K-1-K-36.
Bussy C, Lestaevel P, Dhieux B, et al. Chronic ingestion of uranyl nitrate perturbs acetylcholinesterase activity and monoamine metabolism in male rat brain. Neurotoxicology (Amsterdam). 2006;27(2):245-252.
Butterworth A. The significance and value of uranium in urine analysis. Trans Assoc Ind Med Offrs. 1955;5:36-43.
Byerley JJ, Scharer JM, Atkinson GF. Determination of uranium(VI) in process liquors by ion chromatography. Analyst. 1987;112:41-44.
Caldwell KL, Hartel J, Jarrett J, et al. Inductively coupled plasma mass spectrometry to measure multiple toxic elements in urine in NHANES 1999–2000. Atom Spectrosc. 2005;26(1):1-7.
Canu IG, Ellis ED, Tirmarche M. Cancer risk in nuclear workers occupationally exposed to uranium-emphasis on internal exposure. Health Phys. 2008;94:1-17. [pmid: 18091147].
Carpenter AV, Flanders WD, Frome EL, et al. Chemical exposures and central nervous system cancers: A case-control study among workers at two nuclear facilities. Am J Ind Med. 1988;13:351-362. [pmid: 3354584].
Carvalho FP, Oliveira JM. Uranium isotopes in the Balkan's environment and foods following the use of depleted uranium in the war. Environ Int. 2010;36(4):352-360. [pmid: 20303178].
CDC. Fourth national report on human exposure to environmental chemicals and updated tables, February 2012. Atlanta, GA. Centers for Disease Control and Prevention. 2012. http://www.cdc.gov/exposurereport/. May 30, 2012.
Chan C, Hughes TS, Muldoon S, et al. Mortality patterns among Paducah Gaseous Diffusion Plant workers. J Occup Environ Med. 2010;52(7):725-732. [pmid: 20595915].
Chang X, Luo X, Zhan G, et al. Performance for PAN-3 chelate fiber for adsorbing and separating trace uranium. Mikrochim Acta. 1990:101-105.
Chase GR. Correlation between airborne uranium exposure and uranium urinalysis results at Bear Creek Uranium. Health Phys. 1989;56(2):195-199. [pmid: 2917847].
*. Checkoway H, Crawford-Brown D. Metabolic modeling of organ-specific doses to carcinogens as illustrated with alpha-radiation emitting radionuclides. J Chronic Dis. 1987;40(2):191S-200S. [pmid: 3667866].
Checkoway H, Pearce N, Crawford-Brown DJ, et al. Radiation doses and cause-specific mortality among workers at a nuclear materials fabrication plant. Am J Epidemiol. 1988;127(2):255-266. [pmid: 3337081].
Chen J, Lariviere D, Timmins R, et al. Estimation of uranium GI absorption fractions for children and adults. Radiat Prot Dosimetry. 2011;144(1–4):379-383. [pmid: 21123245].
Chen J, Meyerhof DP, Tracy BL. Model results of kidney burdens from uranium intakes. Health Phys. 2004;86(1):3-11. [pmid: 14695003].
Chovil A, Chir B. The epidemiology of primary lung cancer in uranium miners in Ontario. J Occup Med. 1981;23(6):417-421. [pmid: 7241255].
Clark DL, Neu MP, Runde W, et al. Uranium and uranium compounds. Kirk-Othmer encyclopedia of chemical technology. 2006. http://onlinelibrary.wiley.com/doi/10.1002/0471238961.2118011403120118.a01.pub3/pdf. January 26, 2011.
Clarke R. Control of low-level radiation exposure: Time for a change?. J Radiol Prot. 1999;19(2):107-115. [pmid: 10400149].
Clayton GD, Clayton FE. Patty's industrial hygiene and toxicology. Toxicology. 3rd ed. New York. John Wiley & Sons. 1981;Vol. 2A:1995-2013.
Clewell HJ, Andersen ME. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health. 1985;1(4):111-131. [pmid: 3843496].
Cookfair DL, Beck WL, Shy C, et al. Lung cancer among workers at a uranium processing plant. Epidemiology applied to health physics. Proceedings of the sixteenth midyear topical meeting of the Health Physics society. January 9–13, 1983. Albuquerque, New Mexico. U.S. Department of Energy. Health Physics Society. 1983:398-406. DE83014383.
Cooper JR, Stradling GN, Smith H, et al. The behavior of uranium-233 oxide and uranyl-233 nitrate in rats. Int J Radiat Biol Relat Stud Phys Chem Med. 1982;41(4):421-433. [pmid: 6978863].
Coryell VH, Stearns DM. Molecular analysis of hprt mutations generated in Chinese hamster ovary EM9 cells by uranyl acetate, by hydrogen peroxide, and spontaneously. Mol Carcinog. 2006;45(1):60-72. [pmid: 16299811].
Cothern CR. Graves B, editor. Development of regulations for radionuclides in drinking water. Radon in ground water, radon, radium and other radioactivity in ground water: Hydrogeologic impact and application to indoor airborne contamination. Proceedings of the National Water Well Association conference. April 7–9, 1987. Somerset, NJ. Chelsea, MI. Lewis Publishers, Inc. 1987:1-11.
Cothern CR, Lappenbusch WL. Occurrence of uranium in drinking water in the U.S. Health Phys. 1983;45:89-99. [pmid: 6874353].
Cowart JB, Burnett WC. The distribution of uranium and thorium decay-series radionuclides in the environment-A review. J Environ Qual. 1994;23:651-662.
Cragle DL, McLain RW, Qualters JR, et al. Mortality among workers at a nuclear fuels production facility. Am J Ind Med. 1988;14:379-401. [pmid: 3189355].
Crancon P, Pili E, Charlet L. Uranium facilitated transport by water-dispersible colloids in field and soil columns. Sci Total Environ. 2010;408(9):2118-2128. [pmid: 20178885].
Cross FT, Filipy RE, Loscutoff SM, et al. Histopathologic, morphometric and physiologic investigation of lungs of dogs exposed to uranium ore dust. International conference: Hazards Min Control Meas Med Aspects. 1981a:228-235.
Cross FT, Palmer RF, Busch RH, et al. Development of lesions in Syrian golden hamsters following exposure to radon daughters and uranium ore dust. Health Phys. 1981b;41:135-153. [pmid: 7275591].
Cross FT, Palmer RF, Filipy RE, et al. Carcinogenic effects of radon daughters, uranium ore dust and cigarette smoke in Beagle dogs. Health Phys. 1982;42(1):33-52. [pmid: 7056646].
Damon EG, Eidson AF, Hahn FF, et al. Comparison of early lung clearance of yellowcake aerosols in rats with in vitro dissolution and IR analysis. Health Phys. 1984;46:859-866. [pmid: 6706593].
Darolles C, Broggio D, Feugier A, et al. Different genotoxic profiles between depleted and enriched uranium. Toxicol Lett. 2010;192(3):337-348. [pmid: 19914362].
Davesne E, Chojnacki E, Paquet F, et al. Modeling the imprecision in prospective dosimetry of internal exposure to uranium. Health Phys. 2009;96(2):144-154. [pmid: 19131736].
de Rey BM, Lanfranchi HE, Cabrini RL. Percutaneous absorption of uranium compounds. Environ Res. 1983;30:480-491. [pmid: 6832127].
de Siloniz MI, Lorenzo P, Perera J. Distribution of oxidizing bacterial activities and characterization of bioleaching-related microorganisms in a uranium mineral heap. Microbiologia. 1991;7(2):82-89. [pmid: 1760138].
*. Diamond GL. Clarkson TW, Friberg L, Nordberg GF, et al., editors. Biological monitoring of urine for exposure to toxic metals. Biological monitoring of toxic metals. New York, NY. Plenum Press. 1988:515-529.
Diamond GL, Morrow PE, Panner BJ, et al. Reversible uranyl nephrotoxicity in the Long Evans rat. Govt Rep Announce Ind. 1989;(Issue 01). NTIS/NUREG/CR-4951.
Dias da Cunha KM, Lima C, Barros Leite CV, et al. Case study. Uranium oxide solubility in simulated lung fluids. J Occup Environ Hyg. 2011;8(6):D51-D56. [pmid: 21667368].
Diaz Sylvester PL, Lopez R, Ubios AM, et al. Exposure to subcutaneously implanted uranium dioxide impairs bone formation. Arch Environ Health. 2002;57(4):320-325. [pmid: 12530598].
Dockery DW, Arden P, Xu X. An association between air pollution and mortality in six US cities. N Engl J Med. 1993;329(24):1753-1759. [pmid: 8179653].
Dodge CJ, Francis AJ. Photodegradation of uranium-citrate complex with uranium recovery. Environ Sci Technol. 1994;28:1300-1306. [pmid: 22176322].
Dodge CJ, Francis AJ. Biotransformation of binary and ternary citric acid complexes of iron and uranium. Environ Sci Technol. 1997;31(11):3062-3067.
DOE. Environmental monitoring report. Paducah gaseous diffusion plant. Calendar year 1980. U.S. Department of Energy. 1981a. DE81023308.
DOE. Uranium in U.S. surface, ground, and domestic waters. U.S. Department of Commerce. National Technical Information Services. 1981b;Volume 1.
DOE. Radiological survey of the Shpack Landfill, Norton, Massachusetts. Washington, DC. U.S. Department of Energy. 1981c. DE82004939.
DOE. Geochemical information for sites contaminated with low-level radioactive wastes: II-St. Louis airport storage site. U.S. Department of Energy. 1985. DE85004955.
*. DOE. Results of radiological measurements taken in the Niagara Falls, NY area. Oak Ridge National Lab, TN. U.S. Department of Energy. 1986a. DE87002963.
DOE. The elimination rate of uranium from the kidney of the dog. Research in radiobiology. Annual report of work in progress in the Internal Irradiation Program. U.S. Department of Energy. 1986b. DEAC0276EV00119.
DOE. Health physics manual of good practices for uranium facilities. U.S. Department of Energy, Idaho National Engineering Laboratory. 1988. EGG-2530 UC-41.
DOE. Behavior of mercury, lead, cesium, and uranyl ions on four SRS soils (U). Aiken, SC. U.S. Department of Energy. 1992. DE93003378.
*. DOE. Radiological control manual. U.S. Department of Energy. 1994a. DOE/EH-0256T, Revision 1, April 1994.
DOE. U.S. Department of Energy. Management of depleted uranium hexafluoride (UF6); request for recommendations. Fed Regist 56324. Washington, D.C. 1994b. November 1994.
DOE. Environment monitoring report for the former Middlesex Sampling Plant and Middlesex Municipal Landfill sites, calendar year 1984. U.S. Department of Energy. 1984c. DOE/OR20722-56. DE85017886.
DOE. Uranium Industry Annual 1994. Energy Information Administration, Office of Coal, Nuclear, Electric and Alternate Fuels. Washington DC. U.S. Department of Energy. 1995.
DOE. Uranium industry annual 1995. Energy Information Administration, Office of Coal, Nuclear, Electric and Alternate Fuels. Washington DC. U.S. Department of Energy. 1996a.
*. DOE. Annual limits on intake (ALIs) and derived air concentrations (DACs) of radionuclides for occupational exposure; effluent concentrations; concentrations for release to sewerage. 10CFR20 Appendix B. Washington, DC. U.S. Department of Energy. 1996b.
DOE. Uranium industry annual 1996. Energy Information Administration, Office of Coal, Nuclear, Electric and Alternate Fuels. Washington, DC. U.S. Department of Energy. 1997b. April 1997, DOE/EIA-0478(96), Distribution Category UC-950.
DOE. EML procedures manual, HASL-300. 28th edition. New York. Environmental Measurements Laboratory, U.S. Department of Energy. 1997a.
DOE. Total production of uranium concentrate in the United States. U.S. Department of Energy. 1999a. http://www.eia.doe.gov/cneaf/nuclear/page/at_a_glance/qtr_upd/qupd.html.
DOE. Uranium industry annual 1998. Washington, DC. U.S. Department of Energy, Energy Information Administration, Office of Coal, Nuclear, and Alternate Fuels. 1999b. DOE/EIA0478(98).
DOE. Isotopic uranium in biological and environmental materials. Washington, DC. U.S. Department of Energy, Environmental Measurements Laboratory. 2000. http://www.caslab.com/Test-Methods-Search/PDF/DOE-Method-U-02-RC.pdf. March 23, 2011.
DOE. Excess uranium inventory management plan. U.S. Department of Energy. 2008. www.ne.doe.gov/pdfFiles/inventory_plan_unclassified.pdf. August 3, 2012.
DOE. DOE Standard: Guide of good practices for occupational radiological protection in uranium facilities. Washington, DC. U.S. Department of Energy. 2009. DOE-STD-1136-2004.
DOE. Quality assurance program document. Carlsbad, New Mexico. U.S. Department of Energy, Carlsbad Field Office. 2010. DOE/CBFO-94-1012. www.wipp.energy.gov/library/qapd/qapd.pdf. March 23, 2011.
DOE. Depleted UF6 Storage. U.S. Department of Energy. Office of Environmental Management. 2011a. http://web.ead.anl.gov/uranium/mgmtuses/storage/index.cfm. March 24, 2011.
DOE. Certified reference materials price list (CRM listing, prices and certificates). Chicago, IL. U.S. Department of Energy. 2011b. http://www.nbl.doe.gov/htm/lists/certified_reference_materials_price_list.htm. March 23, 2011.
DOE. Legacy management 2011–2020 strategic plan. U.S. Department of Energy. 2011c. http://www.lm.doe.gov/WorkArea/linkit.aspx?LinkIdentifier=id&ItemID=7624. February 22, 2013.
DOE. Protective action criteria (PAC). Oak Ridge, TN. U.S. Department of Energy and Subcommittee on Consequence Assessment and Protective Actions (SCAPA). 2012. http://orise.orau.gov/emi/scapa/chem-pacs-teels/default.htm. April 25, 2012.
DOE. Formerly Utilized Sites Remedial Action Program (FUSRAP). LM and U.S. Army Corps of Engineers Sites. U.S. Department of Energy. 2013. http://www.lm.doe.gov/default.aspx?id=2126. February 22, 2013.
DOI. Exclusion of certain noncoal reclamation sites. U.S. Department of the Interior. Code of Federal Regulations 30 CFR 875.16. 2010. http://edocket.access.gpo.gov/cfr_2010/julqtr/pdf/30cfr875.16.pdf. January 27, 2011.
Domingo JL, Colomina MT, Llobet JM, et al. The action of chelating agents in experimental uranium intoxication in mice: Variations with structure and time of administration. Fundam Appl Toxicol. 1992;19:350-357. [pmid: 1459366].
Domingo JL, de la Torre A, Belles M, et al. Comparative effects of the chelators sodium 4,5-dihydroxybenzene-1,3-disulfonate (Tiron) and diethylenetriaminepentaacetic acid (DTPA) on acute uranium nephrotoxicity in rats. Toxicology. 1997;118(1):49-59. [pmid: 9074653].
Domingo JL, Llobet JM, Tomas JM, et al. Acute toxicity of uranium in rats and mice. Bull Environ Contam Toxicol. 1987;39:168-174. [pmid: 3607315].
Domingo JL, Ortega A, Llobet JM, et al. The effects of repeated parenteral administration of chelating agents on the distribution and excretion of uranium. Res Commun Chem Pathol Pharmacol. 1989a;64(1):161-164. [pmid: 2748997].
Domingo JL, Ortega A, Paternain JL, et al. Evaluation of the perinatal and postnatal effects of uranium in mice upon oral administration. Arch Environ Health. 1989b;44(6):395-398. [pmid: 2610529].
Domingo JL, Paternain JL, Llobet JM, et al. The developmental toxicity of uranium in mice. Toxicology. 1989c;55(1–2):143-152. [pmid: 2711400].
Dounce AL, Flagg JF. Voegtlin C, Hodge HC, editors. The chemistry of uranium compounds. Pharmacology and toxicology of uranium compounds with a section on the pharmacology and toxicology of fluorine and hydrogen fluoride. New York, NY. McGraw-Hill Book Co., Inc. 1949;55:83-84.
Downs WL, Wilson HB, Sylvester GE, et al. Excretion of uranium by rats following inhalation of uranium dioxide. Health Phys. 1967;13:445-453. [pmid: 6033014].
Dreesen DR, Williams MJ, Marple ML, et al. Mobility and bioavailability of uranium mill tailings contaminants. Environ Sci Technol. 1982;16:702-709.
Dublineau I, Grison S, Baudelin C, et al. Absorption of uranium through the entire gastrointestinal tract of the rat. Int J Radiat Biol. 2005;81(6):473-482. [pmid: 16249162].
Dublineau I, Grison S, Grandcolas L, et al. Absorption, accumulation and biological effects of depleted uranium in Peyer's patches of rats. Toxicology. 2006;227(3):227-239. [pmid: 16978755].
Dungworth DL. McClellan RO, Henderson RF, editors. Noncarcinogenic responses of the respiratory tract to inhaled toxicants. Concepts in inhalation toxicology. New York, NY. Hemisphere Publishing Corporation. 1989:273-298.
Dupree EA, Cragle DL, McLain RW, et al. Mortality among workers at a uranium processing facility, the Linde Air Products Company Ceramics Plant, 1943–1949. Scand J Work Environ Health. 1987;13(2):100-107. [pmid: 3602963].
du Preez JGH. A review of the industrial process involving uranium from the ore to the reactor. Radiat Prot Dosimetry. 1989;26:7-13.
Dupzyk IA, Dupzyk RJ. Separation of uranium from urine for measurement by fluorimetry of isotope-dilution mass spectrometry. Health Phys. 1979;36:526-529. [pmid: 478890].
Durbin PW, Wrenn ME. Wrenn ME, editor. Metabolism and effects of uranium in animals. Conference: Occupational health experience with uranium. Arlington VA. April, 1975. Washington, DC. U.S. Energy Research and Development Administration. 1975:67-129. ERDA-93.
Dygert HP. Voegtlin C, Hodge HC, editors. Uranium tetrafluoride. Pharmacology and toxicology of uranium compounds. New York, NY. McGraw-Hill Book Inc. 1949a:603-614.
Dygert HP. Voegtlin C, Hodge HC, editors. Ammonium diuranate. Pharmacology and toxicology of uranium compounds. New York, NY. McGraw-Hill Book Inc. 1949b:666-672.
Dygert HP. Voegtlin C, Hodge HC, editors. Uranium tritaoctoxide. Pharmacology and toxicology of uranium compounds. New York, NY. McGraw-Hill Book Inc. 1949c:673-676.
Dygert HP. Voegtlin C, Hodge HC, editors. Uranium peroxide. Pharmacology and toxicology of uranium compounds. New York, NY. McGraw-Hill Book Inc. 1949d:647-652.
Dygert HP. Voegtlin C, Hodge HC, editors. Tests of respiratory protective devices in atmospheres containing uranium dust. Pharmacology and toxicology of uranium compounds. New York, NY. McGraw-Hill Book Inc. 1949e:676-700.
Eadie GG, Kaufmann RF. Radiological evaluation of the effects of uranium mining and milling operations on selected ground water supplies in the Grants Mineral Belt, New Mexico. Health Phys. 1977;32:231-241. [pmid: 881310].
EIA. Uranium marketing annual report. U.S. Energy Information Administration. 2010a. http://www.eia.doe.gov/cneaf/nuclear/umar/umar.html. January 26, 2011.
EIA. Domestic uranium production report - annual. U.S. Energy Information Administration. 2010b. http://www.eia.doe.gov/cneaf/nuclear/dupr/dupr.html. January 26, 2011.
*. EIA. Domestic uranium production report - quarterly. U.S. Energy Information Administration. 2010c. http://www.eia.doe.gov/cneaf/nuclear/dupr/qupd.html. January 26, 2011.
EIA. 2010d. U.S. uranium reserves estimates. U.S. Energy Information Administration. http://www.eia.doe.gov/cneaf/nuclear/page/reserves/ures.html. January 26, 2011.
EIA. Domestic uranium production report - quarterly. 2010e. 4th quarter. Washington, DC. U.S. Energy Information Administration. 2010. http://eia.doe.gov/cneaf/nuclear/dupr/qupd.pdf. March 23, 2011.
Eidson AF. The effect of solubility on inhaled uranium compound clearance. Health Phys. 1994;67(1):1-14. [pmid: 8200796].
Eidson AF, Griffith WC Jr, Hahn FF, et al. A model for scaling the results of U excretion rate studies in Beagle dogs to man. Health Phys. 1989;57:199-210. [pmid: 2606682].
Eisenbud M, Quigley JA. Industrial hygiene of uranium processing. AMA Arch Ind Health. 1956;14:12-22. [pmid: 13325976].
Ejnik JW, Todorov TI, Mullick FG, et al. Uranium analysis in urine by inductively coupled plasma dynamic reaction cell mass spectrometry. Anal Bioanal Chem. 2005;382(1):73-79. [pmid: 15900454].
El-Didamony H, Gado HS, Awwade NS, et al. Treatment of phosphogypsum waste produced from phosphate ore processing. J Hazard Mater. 2013;244–245:596-602.
*. Ellender M. The clearance of uranium after deposition of the nitrate and bicarbonate in different regions of the rat lung. Human Toxicol. 1987;6:479-482.
Ellender M, Haines JW, Harrison JD. The distribution and retention of plutonium, americium and uranium in cba/h mice. Hum Exp Toxicol. 1995;14(1):38-48. [pmid: 7748615].
Elliston JT, Glover SE, Filby RH. The determination of natural uranium in human tissues by recovery corrected kinetic phosphorescence analysis. J Radioanal Nucl Chem. 2001;248(2):487-491.
Elliston JT, Glover SE, Filby RH. Comparison of direct kinetic phosphorescence analysis and recovery corrected kinetic phosphorescence analysis and recovery corrected kinetic phosphorescence analysis for the determination of natural uranium in human tissues. J Radioanal Nucl Chem. 2005;263(2):301-306.
EPA. Ambient airborne radioactivity measurements in the vicinity of the jackpile open pit uranium mine New Mexico. Las Vegas, NV. U.S. Environmental Protection Agency. 1979a. ISS ORP/LV-79/2. PB292379.
*. EPA. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 125. 1979b.
EPA. A combined methodology for estimating Dose Rates and health effects for exposure to radioactive pollutants. Oak Ridge, TN. U.S. Environmental Protection Agency. 1980a. EPA78DX0231. ORNL/RM-7105.
EPA. Source category survey: Uranium refining industry. Research Triangle Park, NC. U.S. Environmental Protection Agency. 1980b. EPA450380010. PB80192867.
EPA. Prescribed procedures for measurement of radioactivity in drinking water. Cincinnati, OH. U.S. Environmental Protection Agency. 1980c. EPA600480032. PB80224744.
*. EPA. U.S. Environmental Protection Agency Code of Federal Regulations. 40 CFR 60 Subpart LL. 1984a.
EPA. U.S. Environmental Protection Agency. Radionuclides: Background information document for final rules. Washington, DC. U.S. Environmental Protection Agency, Office of Radiation Program. 1984b;Vol 1. EPA 520/1-84-022-1. NTIS PB85-165751.
EPA. Determination of uranium in drinking water by laser induced fluorometry. EPA Method 908.2. Cincinnati, OH. Environmental Monitoring and Support Laboratory, Physical and Chemical Methods Branch, U.S. Environmental Protection Agency. 1984e.
EPA. U.S. Environmental Protection Agency Code of Federal Regulations. 40 CFR 302.3. 1985a.
EPA. U.S. Environmental Protection Agency Code of Federal Regulation CFR 421, Subpart AD. 1985b.
EPA. Drinking water criteria document for uranium. Washington, DC. U.S. Environmental Protection Agency. 1985c. PB86241049.
*. EPA. U.S. Environmental Protection Agency. Analysis of clean water act effluent guidelines pollutants: Summary of the chemicals regulated by industrial point source category. Prepared by the Industrial technology Division (WH 552). Washington, DC. Office of Water Regulations and Standards, Office of Water. 1988a. 40 CFR Parts 400-475.
EPA. U.S. Environmental Protection Agency. Limiting values of radionuclide intake and air concentration and dose conversion factors for inhalation, submersion, and ingestion. EPA-520/1-88-020. Washington, DC. U.S. Environmental Protection Agency. 1988b.
*. EPA. U.S. Environmental Protection Agency. Environmental radiation protection standards for nuclear power operations. 40 CFR 190. 1988c.
EPA. Gastrointestinal absorption of soluble uranium from drinking water. Research Triangle Park, NC. U.S. Environmental Protection Agency. 1988d. EPA600D88G78. PB8201231.
EPA. Interim methods for development of inhalation reference concentrations. Washington, DC. U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. 1990. EPA600890066A.
EPA. U.S. Environmental Protection Agency. Radionuclides in drinking water fact sheet. National Primary Drinking Water Regulations for Radionuclides, Proposed Rule. Washington, DC. 1991b. June, 1991. EPA570991700.
EPA. Method 200.8: Determination of trace elements in waters and wastes by inductively coupled plasma-mass spectrometry (revision 4.4). Cincinnati, OH. Environmental Monitoring Systems Laboratory, Office of Research and Development, U.S. Environmental Protection Agency. 1991a.
EPA. Environmental radiation data. Report number 74. April-June 1993. U.S. Environmental Protection Agency. 1994a. http://www.epa.gov/narel/radnet/erd/erd74.pdf. July 5, 2012.
EPA. U.S. Environmental Protection Agency. EPA requirements for quality assurance project plans for environmental data operations. EPA QA/R-5, draft interim final. Washington, D.C. Quality Assurance Management Staff. 1994b.
EPA. U.S. Environmental Protection Agency. Technical resource document, extraction and beneficiation of ores and minerals. 1995. EPA 530-R-94-032, NTIS PB94-2008987.
*. EPA. U.S. Environmental Protection Agency. Guidance for data quality assessment: Practical methods for data analysis. Washington, D.C. Quality Assurance Management Staff. 1996a. EPA QA/G-9 QA96 Version, EPA/600/R-96/084.
EPA. Environmental radiation data. Report 86. U.S. Environmental Protection Agency. 1996b. http://www.epa.gov/narel/radnet/erd/erd86.pdf. January 28, 2011.
EPA. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC. U.S. Environmental Protection Agency, Risk Assessment Forum. 1997a. EPA630R96012.
Endocrine section EPA. Environmental radiation data. Report 92. U.S. Environmental Protection Agency. 1997b. http://www.epa.gov/narel/radnet/erd/erd92.pdf. January 28, 2011.
EPA. Automated Form R for Windows: User’s guide (RY97). Washington, DC. U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. 1998a.
EPA. The drinking water contaminant candidate list. U.S. Environmental Protection Agency. Federal Register 63 FR 10274. 1998b. http://www.gpo.gov/fdsys. April 25, 2012.
EPA. Data quality objectives process for hazardous waste site investigations. Washington, DC. U.S. Environmental Protection Agency, Office of Environmental Information. 2000. EPA600R00007. www.epa.gov/quality/qs-docs/g4hw-final.pdf. March 23, 2011.
EPA. Environmental radiation data. Report 124. U.S. Environmental Protection Agency. 2005a. http://www.epa.gov/narel/radnet/erd/erd124.pdf. January 28, 2011.
EPA. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. 2005b. EPA260B05001.
EPA. Data quality assessment: A reviewer's guide. Washington, DC. U.S. Environmental Protection Agency, Office of Environmental Information. 2006a. EPA240B06002.www.epa.gov/QUALITY/qs-docs/g9r-final.pdf. March 23, 2011.
EPA. Data quality assessment: Statistical methods for practitioners. Washington, DC. U.S. Environmental Protection Agency, Office of Environmental Information. 2006b. EPA240B06003.www.epa.gov/quality/qs-docs/g9s-final.pdf. March 23, 2011.
EPA. Environmental radiation data. Report 128 October-December 2006. U.S. Environmental Protection Agency. 2006c. http://www.epa.gov/narel/radnet/erd/erd128.pdf. March 22, 2011.
EPA. Environmental radiation data. Report 132. U.S. Environmental Protection Agency. 2007. http://www.epa.gov/narel/radnet/erd/erd132.pdf. January 28, 2011.
EPA. Public health and environmental radiation protection standards for Yucca Mountain, Nevada. U.S. Environmental Protection Agency. Fed Regist. 2008;73(200):61256-61289. http://www.epa.gov/radiation/docs/yucca/yucca_mtn_rule_fed_reg_version.pdf. August 3, 2012.
EPA. National primary drinking water regulations. Washington, DC. Office of Ground Water and Drinking Water. U.S. Environmental Protection Agency. 2009a. EPA816F090004. http://water.epa.gov/drink/contaminants/upload/mcl-2.pdf. April 25, 2012.
EPA. National recommended water quality criteria. Washington, DC. Office of Water, Office of Science and Technology. U.S. Environmental Protection Agency. 2009b. http://water.epa.gov/scitech/swguidance/standards/current/upload/nrwqc-2009.pdf. April 25, 2012.
EPA. National ambient air quality standards (NAAQS). Washington, DC. Office of Air and Radiation. U.S. Environmental Protection Agency. 2010a. http://www.epa.gov/air/criteria.html. April 25, 2012.
EPA. RadNet-tracking environmental radiation nationwide. U.S. Environmental Protection Agency. 2010b. http://www.epa.gov/narel/radnet/aboutus.html. January 28, 2011.
EPA. Acute exposure guideline levels (AEGLs). Washington, DC. Office of Pollution Prevention and Toxics. U.S. Environmental Protection Agency. 2011a. http://www.epa.gov/oppt/aegl/pubs/compiled_aegls_nov072011.pdf. April 25, 2012.
EPA. Designated as hazardous substances in accordance with section 311(b)(2)(a) of the clean water act. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 116.4. 2011b. http://www.gpo.gov/fdsys. April 25, 2012.
EPA. Drinking water standards and health advisories. Washington, DC. Office of Water. U.S. Environmental Protection Agency. 2011c. http://water.epa.gov/action/advisories/drinking/upload/dwstandards2011.pdf. April 25, 2012.
EPA. Environmental radiation protection standards for management and disposal of spent nuclear fuel, high-level and transuranic radioactive wastes. Code of Federal Regulations 40 CFR 191, Appendix A. U.S. Environmental Protection Agency. 2011d. http://www.gpo.gov/fdsys. June 15, 2012.
EPA. Environmental standards for the uranium fuel cycle. Code of Federal Regulations 40 CFR 190.10, Subpart B. U.S. Environmental Protection Agency. 2011e. http://www.gpo.gov/fdsys. June 15, 2012.
EPA. Exclusion from Identification and listing of hazardous waste. Code of Federal Regulations 40 CFR 261.4. U.S. Environmental Protection Agency. 2011f. http://www.gpo.gov/fdsys. June 15, 2012.
EPA. Identification and listing of hazardous waste. Hazardous constituents. Code of Federal Regulations 40 CFR 261, Appendix VIII. U.S. Environmental Protection Agency. 2011g. http://www.gpo.gov/fdsys. April 25, 2012.
EPA. Inert ingredients permitted for use in nonfood pesticide products. Washington, DC. U.S. Environmental Protection Agency. 2011h. http://www.epa.gov/opprd001/inerts/inert_nonfooduse.pdf. April 25, 2012.
EPA. National emission standards for radon-222 emissions from operating mill tailings. Code of Federal Regulations 40 CFR 61.252, Subpart W. U.S. Environmental Protection Agency. 2011i. http://www.gpo.gov/fdsys. June 15, 2012.
EPA. National emission standards for radon-222 emissions from the disposal of uranium mill tailings that are no longer operational. U.S. Environmental Protection Agency. 2011j. http://www.gpo.gov/fdsys. June 15, 2012.
EPA. National emission standards for radon-222 emissions from underground uranium mines. Code of Federal Regulations 40 CFR 61.22, Subpart B. U.S. Environmental Protection Agency. 2011k. http://www.gpo.gov/fdsys. June 15, 2012.
EPA. National emission standards for radionuclide emissions from federal facilities other than NRC licensees and not covered by Subpart H. Code of Federal Regulations 40 CFR 61.102, Subpart I. U.S. Environmental Protection Agency. 2011l. http://www.gpo.gov/fdsys. June 15, 2012.
EPA. National oil and hazardous substances pollution contingency plan. Hazard ranking system. Code of Federal Regulations 40 CFR 300, Appendix A. U.S. Environmental Protection Agency. 2011m. http://www.gpo.gov/fdsys. June 15, 2012.
EPA. National oil and hazardous substances pollution contingency plan. National priorities list. Code of Federal Regulations 40 CFR 300, Appendix B. U.S. Environmental Protection Agency. 2011n. http://www.gpo.gov/fdsys. June 15, 2012.
EPA. NPDES permit application testing requirements. Code of Federal Regulations 40 CFR 122, Appendix D. U.S. Environmental Protection Agency. 2011o. http://www.gpo.gov/fdsys. June 15, 2012.
EPA. Reportable quantities of hazardous substances designated pursuant to section 311 of the clean water act. Code of Federal Regulations 40 CFR 117.3. U.S. Environmental Protection Agency. 2011p. http://www.gpo.gov/fdsys. April 25, 2012.
EPA. Standards for cleanup of land and buildings contaminated with residual radioactive materials from inactive uranium processing sites; listed constituents. Code of Federal Regulations 40 CFR 192, Subpart B. U.S. Environmental Protection Agency. 2011q. http://www.gpo.gov/fdsys. June 15, 2012.
EPA. Standards for management of uranium byproduct materials pursuant to Section 84 of the Atomic Energy Act of 1954, as amended. Code of Federal Regulations 40 CFR 192, Subpart D. U.S. Environmental Protection Agency. 2011r. http://www.gpo.gov/fdsys. June 15, 2012.
EPA. Standards for owners and operators of hazardous waste TSD facilities. Groundwater monitoring list. Code of Federal Regulations 40 CFR 264, Appendix IX. U.S. Environmental Protection Agency. 2011s. http://www.gpo.gov/fdsys. April 25, 2012.
EPA. Standards for the control of residual radioactive materials from inactive uranium processing sites. Code of Federal Regulations 40 CFR 192, Subpart A. U.S. Environmental Protection Agency. 2011t. http://www.gpo.gov/fdsys. June 15, 2012.
EPA. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notifications. Code of Federal Regulations 40 CFR 302.4. U.S. Environmental Protection Agency. 2011u. http://www.gpo.gov/fdsys. April 25, 2012.
EPA. Superfund, emergency planning, and community right-to-know programs. Extremely hazardous substances and their threshold planning quantities. Code of Federal Regulations 40 CFR 355, Appendix A. U.S. Environmental Protection Agency. 2011v. http://www.gpo.gov/fdsys. April 25, 2012.
EPA. Superfund, emergency planning, and community right-to-know programs. Toxic chemical release reporting. Code of Federal Regulations 40 CFR 372.65. U.S. Environmental Protection Agency. 2011w. http://www.gpo.gov/fdsys. April 25, 2012.
EPA. Toxic substances control act. Chemical lists and reporting periods. Code of Federal Regulations 40 CFR 712.30. U.S. Environmental Protection Agency. 2011x. http://www.gpo.gov/fdsys. April 25, 2012.
EPA. Toxic substances control act. Health and safety data reporting. Code of Federal Regulations 40 CFR 716.120. U.S. Environmental Protection Agency. 2011y. http://www.gpo.gov/fdsys. April 25, 2012.
EPA. Uranium mill tailings. U.S. Environmental Protection Agency. 2011z. http://www.epa.gov/radiation/docs/radwaste/402-k-94-001-umt.html. April 28, 2011.
EPA. Hazardous air pollutants. Clean air act. United States Code 42 USC 7412. U.S. Environmental Protection Agency. 2012a. http://www.epa.gov/ttn/atw/orig189.html. April 25, 2012.
EPA. Master testing list. Washington, DC. Office of Pollution Prevention and Toxics, U.S. Environmental Protection Agency. 2012b. http://www.epa.gov/oppt/chemtest/pubs/index1.pdf. April 25, 2012.
EPA. Benchmark dose technical guidance. U.S. Environmental Protection Agency. U.S. Environmental Protection Agency. 2012c. EPA100R12001. http://www.epa.gov/raf/publications/pdfs/benchmark_dose_guidance.pdf. July 5, 2012.
EPA. Federal actions to address impacts of uranium contamination in the Navajo Nation: Five-year plan summary report. U.S. Environmental Protection Agency. 2013a. http://www.epa.gov/region9/superfund/navajo-nation/pdf/NavajoUraniumReport2013.pdf. February 21, 2013.
EPA. Fertilzer and fertilizer production wastes. U.S. Environmental Protection Agency. 2013b. http://www.epa.gov/rpdweb00/tenorm/fertilizer.html. February 21, 2013.
Eral M. Chemical determination of uranium in natural waters with DBM by the adsorption of U(VI) on Fe(OH)_3_. Spectrosc Lett. 1989;22(4):431-440.
Erdal BR, Daniels WR, Hoffman DC, et al. J MG, editor. Sorption and migration of radionuclides in geologic media. Scientific basis for nuclear waste management. New York. Plenum Press. 1979;Vol 1:423-425.
Essien IO, Sandoval DN, Kuroda PK. Deposition of excess amount of natural U from the atmosphere. Health phys. 1985;48(3):325-331. [pmid: 3980219].
Fabrikant JI. The health effects of radon and other alpha emitting radionuclides: The National Academy of Sciences BEIR IV report. Elsevier Science Publishers. 1990:9-13.
Fajgelj A, Horvat D, Pucelj B. Chromosome aberrations induced in human lymphocytes by U-235 fission neutrons. Part II: Evaluation of the effect of the induced Na-24 activity on the chromosomal aberration yield. Strahlenther Onkol. 1992;168(7):406-411. [pmid: 1496451].
*. Fajgelj A, Lakoski D, Horvat I, et al. Chromosome aberrations induced in human lymphocytes by U-235 fission neutrons: 1. Irradiation of human blood samples in the “dry cell” of the TRIGA Mark II nuclear reactor. Strahlenther. Onkol. 1991;167:661-666. [pmid: 1962281].
Farfan EB, Huston TE, Bolch WE, et al. Influences of parameter uncertainties within the ICRP-66 respiratory tract model: Regional tissue doses for 239PuO2 and 238UO2/238U3O8. Health Phys. 2003;84(4):436-450. [pmid: 12705442].
FDA. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations 21 CFR 165.110. 2012a. http://www.gpo.gov/fdsys. June 15, 2012.
FDA. Everything added to food in the United States (EAFUS). Washington, DC. U.S. Food and Drug Administration. 2012b. http://www.fda.gov/food/foodingredientspackaging/ucm115326.htm. April 25, 2012.
FDA. Uranium in dental porcelain. Rockville, MD. U.S. Food and Drug Administration. 1976. PB259624.
Feeney CM, Anderson JW, Tindall FM. Determination of uranium in tailings by inductively coupled plasma optical emission spectrometry. At Spectrosc. 1983;4:108-110.
Feugier A, Frelon S, Gourmelon P, et al. Alteration of mouse oocyte quality after a subchronic exposure to depleted uranium. Reprod Toxicol. 2008;26(3–4):273-277. [pmid: 18926898].
Filippova LG, Nifativ AP, Lyubchanskii ER. Some of the long-term sequelae of giving rats enriched uranium. Radiobiologiia. 1978;18(3):94-100.
Fisenne IM. Uranium in humans. Radiat Prot Dosimetry. 1988;24:127-131.
Fisenne IM, Perry PM. Isotopic U concentration in human blood from New York City donors. Health Phys. 1985;49:1272-1275. [pmid: 4077531].
Fisenne IM, Welford GA. Natural U concentrations in soft tissues and bone of New York City residents. Health Phys. 1986;50:739-746. [pmid: 3710782].
Fisenne IM, Perry PM, Welford GA. Determination of uranium (isotopes) in human bone ash. Anal Chem. 1980;52:777-779. [pmid: 7396206].
Fisher DR, Jackson PO. Reply to Singh and Wrenn regarding levels of uranium-234, -238 and thorium-230 in excreta of uranium mill crushermen. Health Phys. 1986;50:302-303.
Fisher DR, Jackson PO, Brodaczynski GG, et al. Levels of ^234^U, ^238^U and ^230^Th in excreta of uranium mill crushermen. Health Phys. 1983;45:617. [pmid: 6885471].
Fisher DR, Kathern RL, Swint MJ. Modified biokinetic model for uranium from analysis of acute exposure of UF_6_. Health Phys. 1991;60(3):335-342. [pmid: 1995506].
Fomon SJ. Falkner F, editor. Body composition of the infant: Part I: The male reference infant. Human development. Philadelphia, PA. WB Saunders. 1966:239-246. Child health section.
Fomon SJ, Haschke F, Ziegler EE, et al. Body composition of reference children from birth to age 10 years. Am J Clin Nutr. Suppl 5. 1982;35:1169-1175. Child health section. [pmid: 7081099].
Forte M, Rusconi R, Margini C, et al. Determination of uranium isotopes in food and environmental samples by different techniques: A comparison. Radiat Prot Dosimetry. 2001;97(4):325-328. [pmid: 11878412].
Francis AJ, Dodge CJ, Gillow JB, et al. Microbial transformation of uranium in wastes. 2nd International conference on chemistry and migration behavior of actinides and fission products in the geosphere held in Monterey. California, November. 6–10, 1989. Washington, DC. U.S. Department of Energy. 1989. DE90004191. BNL43483.
Frome EL, Cragle DL, McLain RW. Poisson regression analysis of the mortality among a cohort of World War II. Radiat Res. 1990;123:138-152. [pmid: 2389000].
Fruchter JS, Robertson DE, Evans JC, et al. Reports-Mount St. Helens ash from the 18 May 1980 eruption: Chemical, physical, mineralogical, and biological properties. Science. 1980;209(5):1116-1125. [pmid: 17841472].
Fujino O, Umetani S, Matsui M. Determination of uranium in apatite minerals by inductively coupled plasma atomic emission spectrometry after solvent extraction and separation with 3-phenyl-4-benzoyl-5-isoxazolone into diisobutyl ketone. Anal Chim Acta. 1994;296:63-68.
Fukuda S, Iida H, Ikeda M, et al. Toxicity of uranium and the removal effects of CBMIDA and EHBP in simulated wounds of rats. Health Phys. 2005;89(1):81-88. [pmid: 15951694].
Fukuda S, Ikeda M, Anzai K, et al. Radiation protection by deferiprone in animal models. Hemoglobin. 2006;30(2):201-208. [pmid: 16798644].
Fukuda S, Ikeda M, Nakamura M, et al. The effects of bicarbonate and its combination with chelating agents used for the removal of depleted uranium in rats. Hemoglobin. 2008;32(1–2):191-198. [pmid: 18274996].
Fukuda S, Ikeda M, Nakamura M, et al. Efficacy of oral and intraperitoneal administration of CBMIDA for removing uranium in rats after parenteral injections of depleted uranium. Radiat Prot Dosimetry. 2009;133(1):12-19. [pmid: 19168864].
Galle P, Berry JP, Galle C. Role of alveolar macrophages in precipitation of mineral elements inhaled as soluble aerosols. Environ Health Perspect. 1992;97:145-147. [pmid: 1396450].
Galletti M, D'Annibale L, Pinto V, et al. Uranium daily intake and urinary excretion: A preliminary study in Italy. Health Phys. 2003;85(2):228-235. [pmid: 12938971].
Garten CT. A review of parameter values used to assess the transport of plutonium, uranium, and thorium in terrestrial food chains. Environ Res. 1978;17(3):437-452. [pmid: 400973].
Gavrilescu M, Pavel LV, Cretescu I. Characterization and remediation of soils contaminated with uranium. J Hazard Mater. 2009;163(2–3):475-510. [pmid: 18771850].
*. Giglio MJ, Brandan N, Leal TL, et al. The mechanism of the transient depression of the erythropoietic rate induced in the rat by a single injection of uranyl nitrate. Toxicol Appl Pharmacol. 1989;99(2):260-265. [pmid: 2734790].
Gilkeson RH, Cowart JB. Graves B, editor. Radium radon and uranium isotopes in groundwater from Cambrian-Ordovician sandstone aquifers in Illinois USA. Radon in ground water, radon, radium and other radioactivity in ground water: Hydrogeologic impact and application to indoor airborne contamination: Proceedings of the National Water Well Association conference. Somerset, NJ. April 7–9, 1987. Chelsea, MI. Lewis Publishers, Inc. 1987:403-422.
Gilman AP, Moss MA, Villeneuve DC, et al. Uranyl nitrate: 91-day exposure and recovery studies in the male New Zealand white rabbit. Toxicol Sci. 1998c;41(1):138-151. [pmid: 9520348].
Gilman AP, Villeneuve DC, Secours VE, et al. Uranyl nitrate: 28-day and 91-day toxicity studies in the Sprague-Dawley rat. Toxicol Sci. 1998a;41(1):117-128. [pmid: 9520346].
Gilman AP, Villeneuve DC, Secours VE, et al. Uranyl nitrate: 91-day toxicity studies in the New Zealand white rabbit. Toxicol Sci. 1998b;41(1):129-137. [pmid: 9520347].
Gindler JE. Hodge HC, et al., editors. Physical and chemical properties of uranium. Uranium, plutonium transplutonic elements. New York, NY. Springer-Verlag. 1973:69-164.
Giwercman A, Carlsen E, Keiding N, et al. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl. 1993;101(2):65-71.
Gladney ES, Peters RJ, Perrin DR. Determination of uranium-235/uranium-238 ratio in natural waters by Chelex-100 ion exchange and neutron-activation analysis. Anal Chem. 1983;55:976-977.
Goans RE. Shannon MW, Borron SW, Burns MJ, editors. Medical management of radiation incidents. Haddad and Winchester's clinical management of poisoning and drug overdose. 4th ed. Philadelphia, PA. Saunders. 2007:1467-1485.
Goel KA, Garg VK, Garg V. Histopathology of kidney of albino rat poisoned with uranyl nitrate. Bull Environ Contam Toxicol. 1980;24:9-12. [pmid: 7357115].
Gogolak CV. The radiological impact of atmospheric emissions from oil shale retorts. Environ Int. 1985;11:57-64.
Golchert NW, Iwami FS, Sedlet J. Lyon WS, editor. Determination of actinides in soil. Radioelement analysis: Progress and problems. 23rd Conference: Analytical chemistry in energy technology. Gatlinburg, TN. Oct, 9–11, 1979. Ann Arbor, MI. Ann Arbor Science Publishers, Inc. 1980:215-222.
Gonzales ER, Gladney ES, Boyd HA, et al. Determination of U in human tissues by delayed neutron activation analysis. Health Phys. 1988;55(6):927-932. [pmid: 3198401].
Goode DJ, Wilder RJ. Ground-water contamination near a uranium tailings disposal site in Colorado. Ground Water. 1987;27:545-554.
Goodman DR. Williams PL, Burson JL, editors. Nephrotoxicity. Toxic effects in the kidneys. Industrial toxicology safety and health applications in the workplace. New York, NY. Van Nostrand Reinhold Company. 1985:106-122.
Gottlieb LS, Husen LA. Lung cancer among Navajo uranium miners. Chest. 1982;81:449-452. [pmid: 6279361].
Grace M, Larson M, Hanson J. Bronchogenic carcinoma among former uranium mine workers at Port Radium, Canada. Health Phys. 1980;38:657-661. [pmid: 7410083].
Greene B, Uranga A, Sneddon J. Observations on the determination of uranium in waters by direct current argon plasma emission spectrometry. Spectrosc Lett. 1985;18(6):425-436.
Grey C. Uranium: From ore to concentrate. The Nuclear Engineer. 1993;34(1):3-9.
Grignard E, Gueguen Y, Grison S, et al. Contamination with depleted or enriched uranium differently affects steroidogenesis metabolism in rat. Int J Toxicol. 2008;27(4):323-328. [pmid: 18821396].
Guglielmotti MB, Ubios AM, Larumbe J, et al. Tetracycline in uranyl nitrate intoxication: Its action on renal damage and U retention in bone. Heath Physics. 1989;57:403-405.
Guilmette RA, Parkhurst MA. Dose assessment for inhalation intakes in complex, energetic environments: Experience from the US Capstone study. Radiat Prot Dosimetry. 2007;127(1–4):516-520. [pmid: 17766261].
Guilmette RA, Miller G, Parkhurst MA. Capstone depleted uranium aerosol biokinetics, concentrations, and doses. Health Phys. 2009;96(3):328-342. [pmid: 19204489].
Guzelian PS, Henry CJ, Olin SS, editors. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC. International Life Sciences Institute Press. 1992.
Hadjimichael CC, Ostfeld AM, D'Atri DA, et al. Mortality and cancer incidence experience of employees in a nuclear fuels fabrication plant. J Occup Med. 1983;25:48-61. [pmid: 6827389].
Hahn FF. McClellan RO, Henderson RF, editors. Carcinogenic responses of the lung to inhaled materials. Concepts in inhalation toxicology. New York, NY. Hemisphere Publishing Corporation. 1989:313-346.
Hahn FF, Guilmette RA, Hoover MD. Implanted depleted uranium fragments cause soft tissue sarcomas in the muscles of rats. Environ Health Perspect. 2002;110(1):51-59. [pmid: 11781165].
Hakonson-Hayes AC, Fresquez PR, Whicker FW. Assessing potential risks from exposure to natural uranium in well water. J Environ Radioact. 2002;59(1):29-40. [pmid: 11848150].
Haley DP. Morphologic changes in uranyl nitrate-induced acute renal failure in saline- and water-drinking rats. Lab Invest. 1982;46:196-208. [pmid: 7062722].
Haley DP, Bulger RE, Dobyan DC. The long-term effects of uranyl nitrate on the structure and function of the rat kidney. Virchows Arch B. 1982;41:181-192. [pmid: 6190305].
Handley-Sidhu S, Worsfold PJ, Livens FR, et al. Biogeochemical controls on the corrosion of depleted uranium alloy in subsurface soils. Environ Sci Technol. 2009;43(16):6177-6182. [pmid: 19746710].
Hans J, Burris E, Gorsuch T. Radioactive waste management at the former Shiprock Uranium Mill Site New-Mexico, USA. Health Phys. 1979;37:811.
Hao Y, Li R, Leng Y, et al. A study assessing the genotoxicity in rats after chronic oral exposure to a low dose of depleted uranium. J Radiat Res (Tokyo). 2009;50(6):521-528. [pmid: 19801891].
Harduin JC, Cogema LH, Beaumont-Hague FP. Uptake and urinary excretion of uranium after oral administration in man. Radiat Prot Dosimetry. 1994;53(1–4):245-248.
*. Harley NH, Fisenne IS. Distribution and radiation dose from naturally occurring, U, Th and Ra in the human skeleton. Health Phys. 1990;58(4):515-518. [pmid: 2323933].
*. Harley NH, Pasternack BS. A model for predicting lung cancer risks induced by environmental levels of radon daughters. Health Phys. 1981;40:307-316. [pmid: 7228679].
Harms TF, Ward FN, Erdman JA. Laser fluorometric analysis of plants for uranium exploration. J Geochem Explor. 1981;15:617-623.
Harrison JD, Stather JW. The gastrointestinal absorption of proactinium, uranium and neptunium in the hamster. Radiat Res. 1981;88:47-55. [pmid: 7302131].
Hart DR, McKee PM, Burt AJ, et al. Benthic community and sediment quality assessment of Port Hope Harbour, Lake Ontario. J Great Lakes Res. 1986;12:206-220.
HazDat. Uranium. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA. Agency for Toxic Substances and Disease Registry. 2007.
*. Heid KR, Fuqua PA. Review of uranium inhalation case. Health Phys. 1974;26:399-403. [pmid: 4836719].
*. Henge-Napoli MH, Archimbaud M, Ansoborlo E, et al. Efficacy of 3,4,3-LIHOPO for reducing the retention of uranium in rat after acute administration. Int J Radiat Biol. 1995;68(4):389-393. [pmid: 7594963].
Herczeg AL, Simpson HJ, Anderson RF, et al. Uranium and radium mobility in groundwaters and brines within the Delaware basin, southeastern New Mexico, U.S.A. Chem Geol. 1988;72:181-196.
Hindin R, Brugge D, Panikkar B. Teratogenicity of depleted uranium aerosols: a review from an epidemiological perspective. Environ Health. 2005;4:17. [pmid: 16124873].
Hindman FD. Neodymium fluoride mounting for alpha spectrometric determination of uranium, plutonium, and americium. Anal Chem. 1983;55:2460-2461.
Hinton ER. Development of a multi-purpose alpha-detection procedure for enriched uranium in urine. Anal Lett. 1983;16:367-380.
Hinton ER, White LE. Applications of laser-induced fluorimetry to analysis of ultra-trace levels of uranium in an industrial environment. Anal Lett. 1981;14:947-958.
Ho CH, Doern DC. The sorption of uranyl species on a hematite sol. Can J Chem. 1985;63:1100-1104.
*. Hobbs CH, McClellan RO. Doull J, Klaassen CD, Amdur MO, editors. Toxic effects of radiation and radioactive materials. Casarett and Doull's Toxicology, the basic science of poisons. 3rd ed. New York, NY. Macmillan Publishing Co Inc. 1986:669-705.
Hoel DG, Davis DL, Miller AB, et al. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst. 1992;84(5):313-320. [pmid: 1738181].
Holzbecher J, Ryan DE. Determination of uranium by thermal- and epithermal-neutron activation in natural waters and in human urine. Anal Chim Acta. 1980;119:405-408.
Hooper FJ, Squibb KS, Siegel EL, et al. Elevated urine uranium excretion by soldiers with retained uranium shrapnel. Health Phys. 1999;77(5):512-519. [pmid: 10524504].
*. Horikoshi T, Nakajima A, Sakaguchi T. Studies on the accumulation of heavy metal elements in biological systems. XIX. Accumulation of uranium by microorganisms. Eur J Appl Microbiol Biotechnol. 1981;12:90-96.
Hornung RW, Meinhardt TJ. Quantitative risk assessment of lung cancer in USA uranium miners. Health Phys. 1987;52:417-430. [pmid: 3032855].
Hornung RW, Deddens JA, Roscoe RJ. Modifiers of lung cancer risk in uranium miners from the Colorado Plateau. Health Phys. 1998;74(1):12-21. [pmid: 9415577].
Houpert P, Bizot JC, Bussy C, et al. Comparison of the effects of enriched uranium and 137-cesium on the behaviour of rats after chronic exposure. Int J Radiat Biol. 2007b;83(2):99-104. [pmid: 17357431].
Houpert P, Chazel V, Paquet F, et al. The effects of the initial lung deposit on uranium biokinetics after administration as UF4 and UO4. Int J Radiat Biol. 1999;75(3):373-377. [pmid: 10203187].
Houpert P, Chazel V, Paquet F, et al. Reduction of uranium transfer by local chelation in simulated wounds in rats. Hum Exp Toxicol. 2001;20(5):237-241. [pmid: 11476155].
Houpert P, Chazel V, Paquet F. A local approach to reduce industrial uranium wound contamination in rats. Can J Physiol Pharmacol. 2004;82(2):73-78. [pmid: 15052287].
Houpert P, Frelon S, Lestaevel P, et al. Parental exposure to enriched uranium induced delayed hyperactivity in rat offspring. Neurotoxicology. 2007a;28(1):108-113. [pmid: 16965816].
Houpert P, Frelon S, Monleau M, et al. Heterogeneous accumulation of uranium in the brain of rats. Radiat Protect Dosimetry. 2007c;127:86-89.
Houpert P, Lestaevel P, Bussy C, et al. Enriched but not depleted uranium affects central nervous system in long-term exposed rat. Neurotoxicology. 2005;26(6):1015-1020. [pmid: 15996736].
Howe GR, Stager RH. Risk of lung cancer mortality after exposure to radon decay products in the Beaverlodge cohort based on revised exposure estimates. Radiat Res. 1996;146(1):37-42. [pmid: 8677296].
Howe GR, Nair RC, Newcombe HB, et al. Lung cancer mortality (1950–1980) in relation to radon daughter exposure in a cohort of workers at the Eldorado Beaverlodge Uranium Mine (Saskatchewan, Canada). J Natl Cancer Inst. 1986;77:357-362. [pmid: 3461198].
Howe GR, Nair RC, Newcombe HB, et al. Lung cancer mortality (1950–1980) in relation to radon daughter exposure in a cohort of workers at the Eldorado Port Radium Uranium Mine: Possible modification of risk by exposure rate. J Natl Cancer Inst. 1987;79:1255-1260. [pmid: 3480377].
HPS. Health Physics Society Standard no. N13.30-1996. Performance criteria for radiobioassay published by the Health Physics Society in 1996. 1996.
HPS. HPS laboratory accreditation program. Atlanta, GA. Health Physics Society. 2011. http://www.hps.org/labs/. March 23, 2011.
HSDB. Hazardous Substances Data Bank. Bethesda, MD. National Library of Medicine, National Toxicology Program (via TOXNET). 1995. January 1995.
HSDB. Uranium and uranium compounds. Hazardous Substances Data Bank. National Library of Medicine. 2011. http://toxnet.nlm.nih.gov. June 21, 2011.
Hsi CKD, Langmuir D. Adsorption of uranyl onto ferric oxyhydroxides: Application of the surface complexation site-binding model. Geochim Cosmochim Acta. 1985;49:1931-1942.
Hu QY, Zhu SP. Detection of DNA damage in spermiogenic stages of mice and treated with enriched uranyl fluoride by alkaline elution. Radiat Environ Biophys. 1990;29(3):161-167. [pmid: 2396006].
Hueper WC, Zuefle JH, Link AM, et al. Experimental studies in metal carcinogenesis. II. Experimental uranium cancers in rats. J Natl Cancer Inst. 1952;13:291-305. [pmid: 12991041].
Hughes LD, Powell BA, Soreefan AM, et al. Anomalously high levels of uranium and other naturally occurring radionuclides in private wells in the piedmont region of South Carolina. Health Phys. 2005;88(3):248-252. [pmid: 15706145].
Hursh JB, Spoor NL. Hodge HC, Stannard JN, Hursh JB, editors. Data on man. Uraniumplutonium transplutonic elements. New York, NY. Springer-Verlag. 1973:197-239.
Hursh JB, Neuman WF, Toribara T, et al. Oral ingestion of uranium by man. Health Phys. 1969;17:619-621. [pmid: 5344473].
IARC. IARC monographs on the evaluation of carcinogenic risks to humans. Volume 100. A review of human carcinogens. Part D: Radiation. Lyon, France. International Agency for Research on Cancer. 2012. http://monographs.iarc.fr/ENG/Monographs/vol100D/index.php. June 15, 2012.
Ibrahim SA, Wicker FW. Comparative uptake of U and Th by native plants at a U production site. Health phys. 1988;54(4):413-419. [pmid: 3350662].
*. ICRP. Depositions and retention models for internal dosimetry of the human respiratory tract. Task group on lung dynamics. International Commission for Radiation Protection. Health Phys. 1966;21:173-207.
*. ICRP. The metabolism of compounds of plutonium and other actinides. ICRP Publication No. 19. New York, NY. Pergamon Press. International Commission for Radiation Protection. 1972.
ICRP. Report of the task group on reference man. ICRP Publication No. 23. New York, NY. Pergamon Press. International Commission for Radiation Protection. 1975.
ICRP. Limits for intakes of radionuclides by workers. Supplement to Part 1. Publication 30. Pergamon Press. International Commission on Radiological Protection. 1979.
*. ICRP. A compilation of the major concepts and quantities in use by ICRP. ICRP Publication 42. Oxford. Pergamon Press. International Commission for Radiation Protection. 1984.
ICRP. 1990 Recommendations of the International Commission on Radiological Protection. ICRP Publication 60. Oxford. International Commission on Radiological Protection. 1991.
ICRP. Appendix A: Age-specific biokinetic models for the alkaline earth elements and lead. Age-dependent doses to members of the public from intake of radionuclides: Part 2 ingestion dose coefficients. ICRP publication 67. Tarrytown, NY. The International Commission on Radiological Protection. 1994a:95-120.
ICRP. Human respiratory tract model for radiological protection. International Commission on Radiological Protection. Oxford. Pergamon Press. 1994b.
ICRP. Age-dependent doses to members of the public from intake of radionuclides: Part 3, Ingestion dose coefficients. ICRP Publication 69. Oxford. Pergamon Press. International Commission for Radiation Protection. 1995.
ICRP. Age-dependent doses to members of the public from intake of radionuclides: Part 4, Inhalation dose coefficients. ICRP Publication 71. Oxford. Pergamon Press. International Commission for Radiation Protection. 1996.
ICRP. Description of the model. 5.1 Overview. International Commission on Radiological Protection. 2006a;36(1–2):69-76.
ICRP. Draft recommendations of the International Commission on Radiological Protection. International Commission on Radiological Protection. 2006b. http://www.icrp.org/docs/ICRP_Recs_02_276_06_web_cons_5_June.pdf. January 28, 2011.
*. Ingersoll JG. A survey of radionuclide contents and radon emanation rates in building materials used in the U.S. Health Phys. 1983;45:363-368. [pmid: 6885435].
Inn KGW. The National Bureau of Standards fresh water lake sediment environmental-level radioactivity standard reference material. J Radioanal Nucl Chem. 1987;115:91-112.
IRIS. Uranium, natural and uranium, soluble salts. Integrated Risk Information System. Washington, DC. U.S. Environmental Protection Agency. 2011. http://cfpub.epa.gov/ncea/iris/index.cfm?fuseaction=iris.showSubstanceList. January 28, 2011.
IRIS. Uranium. Integrated risk information system. Washington, DC. U.S. Environmental Protection Agency. 2012. http://www.epa.gov/iris/. June 15, 2012.
*. James RC. Williams PL, Burson JL, editors. Hematotoxicity: Toxic effects in the blood. Industrial toxicology. Safety and health applications in the workplace. New York. Van Nostrand Reinhold Company. 1985:59-78.
Jaworowski Z, Grzybowska D. Natural radionuclides in industrial and rural soils. Sci Total Environ. 1977;7:45-52. [pmid: 835001].
Jefferson CW, Thomas DJ, Gandhi SS, et al. Goodfellow WD, editor. Unconformity-associated uranium deposits of the Athabasca basin, Saskatchewan and Alberta. Mineral deposits of Canada: A synthesis of major deposit-types, District Metallogeny, the evolution of geological provinces, and exploration methods. Special Publication No. 5. Geological Association of Canada, Mineral Deposits Division. 2007:273-305.
Jia G, Belli M, Sansone U, et al. Concentration and characteristics of depleted uranium in biological and water samples collected in Bosnia and Herzegovina. J Environ Radioact. 2006;89(2):172-187. [pmid: 16806612].
Jiang FS, Lee SC, Bakhitiar SN, et al. Determination of thorium, uranium and plutonium isotopes in atmospheric samples. J Radioanal Nucl Chem. 1986;100:65-72.
Johanson CE. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res. 1980;190(1):3-16. [pmid: 6769537].
Jurgens BC, Fram MS, Belitz K, et al. Effects of groundwater development on uranium: Central Valley, California, USA. Ground Water. 2010;48(6):913-928. [pmid: 19788559].
Kamata E, Nakashima R, Furukawa M. Determination of trace amounts of thorium and uranium in coal ash by inductively coupled plasma atomic emission spectrometry after extraction with 2-thenoyltrifluoroacetone and back-extraction with dilute nitric acid. J Anal Atom Spectrom. 1987;2:321-324.
Karpas Z. Uranium bioassay-beyond urinalysis. Health Phys. 2001;81(4):460-463. [pmid: 11569642].
Karpas Z, Halicz L, Roiz J, et al. Inductively coupled plasma mass spectrometry as a simple, rapid, and inexpensive method for determination of uranium in urine and fresh water: Comparison with LIF. Health Phys. 1996;71(6):879-885. [pmid: 8919071].
Karpas Z, Lorber A, Elish E, et al. Uptake of ingested uranium after low "acute intake". Health Phys. 1998;74(3):337-345. [pmid: 9482599].
Karpas Z, Lorber A, Sela H, et al. Measurement of the 234U/238U ratio by MC-ICPMS in drinking water, hair, nails, and urine as an indicator of uranium exposure source. Health Phys. 2005a;89(4):315-321. [pmid: 16155452].
Karpas Z, Paz-Tal O, Lorber A, et al. Urine, hair, and nails as indicators for ingestion of uranium in drinking water. Health Phys. 2005b;88(3):229-242. [pmid: 15706143].
Kathren RL. Radioactivity in the environment: Sources, distribution and surveillance. New York, NY. Harwood Academic Publishers. 1984:75.
Kathren RL. Uranium in the tissues of two whole body donations to the USTUR. United States Transuranium and Uranium Registries. Richland, WA. Washington State University. 1997. Annual report October 1, 1995-September 30, 1996. USTUR-0072-97.
Kathren RL, Moore RH. Acute accidental inhalation of uranium: A 38-year follow-up. Health Phys. 1986;51:609-620. [pmid: 3771222].
Keane AT, Polednak AP. Retention of uranium in the chest: Implications of findings in vivo and postmortem. Health Phys. Suppl 1. 1983;44:391-402. [pmid: 6862916].
Kelly WR, Fassett JD. Determination of picogram quantities of uranium in biological tissues by isotope-dilution thermal-ionization mass spectrometry with ion-counting detection. Anal Chem. 1983;55:1040-1044. [pmid: 6349417].
Kelly WR, Fassett JD, Hotes SA. Determining picogram quantities of uranium in human urine by thermal ionization mass spectrometry. Health Phys. 1987;52:331-336. [pmid: 3818298].
Kerr A, Kupferschmidt W, Atlas M. Determination of uranium in natural groundwaters using high-performance liquid chromatography. Anal Chem. 1988;60:2729-2733.
Kirk WS. Depleted uranium. Mineral facts and problems. 1980 edition. Washington, DC. U.S. Department of the Interior, Bureau of Mines. 1980:1-7. Bulletin 671.
Kobayashi S, Nagase M, Honda N, et al. Glomerular alterations in uranyl acetate-induced acute renal failure in rabbits. Kidney Int. 1984;26:808-815. [pmid: 6533394].
Komori M, Nishio K, Kitada M, et al. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry. 1990;29(18):4430-4433. [pmid: 2350547].
Kressin IK. Spectrophotometric method for the determination of uranium in urine. Anal Chem. 1984;56:2269-2227. [pmid: 6507874].
Krishnan K, Andersen ME. Hayes AW, editor. Physiologically based pharmacokinetic modeling in toxicology. Principles and methods of toxicology. 3rd ed. New York, NY. Raven Press, Ltd. 1994:149-188.
Krishnan K, Andersen ME, Clewell HJ, et al. Yang RSH, editor. Physiologically based pharmacokinetic modeling of chemical mixtures. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA. Academic Press. 1994:399-437.
Krunić A, Haverić S, Ibrulj S. Micronuclei frequencies in peripheral blood lymphocytes of individuals exposed to depleted uranium. Arh Hig Rada Toksikol. 2005;56(3):227-232. [pmid: 16180607].
Kundt MS, Martinez-Taibo C, Muhlmann MC, et al. Uranium in drinking water: Effects on mouse oocyte quality. Health Phys. 2009;96(5):568-574. [pmid: 19359850].
Kuroda PK, Essien IO, Sandoval DN. Fallout of uranium isotopes from the 1980 eruption of Mount St. Helens. J Radioanal Nucl Chem. 1984;84:23-32.
Kurttio P, Auvinen A, Salonen L, et al. Renal effects of uranium in drinking water. Environ Health Perspect. 2002;110(4):337-342. [pmid: 11940450].
Kurttio P, Harmoinen A, Saha H, et al. Kidney toxicity of ingested uranium from drinking water. Am J Kidney Dis. 2006a;47(6):972-982. [pmid: 16731292].
Kurttio P, Komulainen H, Leino A, et al. Bone as a possible target of chemical toxicity of natural uranium in drinking water. Environ Health Perspect. 2005;113(1):68-72. [pmid: 15626650].
*. Kurttio P, Salonen L, Ilus T, et al. Well water radioactivity and risk of cancers of the urinary organs. Environ Res. 2006b;102(3):333-338. [pmid: 16448644].
Kusiak RA, Ritchie AC, Muller J, et al. Mortality from lung cancer in Ontario uranium miners. Br J Ind Med. 1993;50:920-928. [pmid: 8217852].
Labrecque JJ, Rosales PA, Mejias G. Instrumental neutron-activation analysis of river sediments from Rio Tigre (Venezuela) employing a planar germanium detector. Appl Spectrosc. 1986;40:1232-1235.
LaCerte C, Xie H, Aboueissa AM, et al. Particulate depleted uranium is cytotoxic and clastogenic to human lung epithelial cells. Mutat Res. 2010;697(1–2):33-37. [pmid: 20172046].
*. Land CE, Shimosato Y, Saccomanno G, et al. Radiation-associated lung cancer. A comparison of the histology of lung: Cancers in uranium miners and survivors of the atomic bombings on Hiroshima and Nagasaki. Radiat Res. 1993;134(2):234-243. [pmid: 8387679].
Landa ER, Councell TB. Leaching of uranium from glass and ceramic foodware and decorative items. Health Phys. 1992:343-348. [pmid: 1322875].
Landsberger S, Wu D. Improvement of analytical sensitivities for the determination of antimony, arsenic, cadmium, indium, iodine, molybdenum, silicon and uranium in airborne particulate matter by epithermal neutron activation analysis. J Radioanal Nucl Chem. 1993;167(2):219-225.
*. Lang S, Raunemaa T. Behavior of neutro-activated uranium dioxide dust particles in the gastrointestinal tract of the rat. Radiat Res. 1991;26:273-279. [pmid: 2034784].
*. Lang S, Kosma VM, Kumlin T, et al. Distribution and short-term effects of intratracheally instilled neutron-irradiation UO2 particles in the rat. Environ Res. 1994;65:119-131. [pmid: 8162878].
Lapham SC, Millard JB, Samet JM. Health implications of radionuclide levels in cattle raised near U mining and milling facilities in Ambrosia Lake, New Mexico. Health Phys. 1989;36(3):327-340. [pmid: 2917862].
Larsen RP, Bhattachyaryya MH, Oldham RD, et al. Gastrointestinal absorption and retention of plutonium and uranium in the baboon. Division of Biological and Medical Research. Tuxedo, New York. Institute of Environmental Medicine, New York University Medical Center. 1984:51-60.
La Touche YD, Willis DL, Dawydiak OI. Absorption and biokinetics of U in rats following an oral administration of uranyl nitrate solution. Health Phys. 1987;53(2):147-162. [pmid: 3610641].
Laul JC. U-234/U-238 ratio: Qualitative estimate of groundwater flow in Rocky Flats monitoring wells. Golden, CO. Environmental Technologies. 1994.
Lazo EN, Roessler GS, Berven BA. Determination of uranium and thorium concentrations in unprocessed soil samples. Health phys. 1991;61(2):231-243. [pmid: 1856084].
Leach LJ, Gelein RM, Panner BJ, et al. The acute toxicity of the hydrolysis products of uranium hexafluoride (UF6) when inhaled by the rat and guinea pig. Final report. 1984. ISS K/SUB-81-9039-3. DE84011539.
Leach LJ, Maynard EA, Hodge CH, et al. A five-year inhalation study with natural uranium dioxide dust. Health Phys. 1970;18:599-612. [pmid: 5514668].
Leach LJ, Yuile CL, Hodge HC, et al. A five-year inhalation study with natural uranium dioxide (UO_2_) dust. II. Postexposure retention and biologic effects in the monkey, dog and rat. Health Phys. 1973;25:239-258. [pmid: 4206489].
Leeder JS, Kearns GL. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am. 1997;44(1):55-77. [pmid: 9057784].
Leggett RW, Harrison JD. Fractional absorption of ingested uranium in humans. Health Phys. 1995;68(4):484-498. [pmid: 7883560].
Leggett RW, Pellmar TC. The biokinetics of uranium migrating from embedded DU fragments. J Environ Radioact. 2002;64(2–3):205-225. [pmid: 12500806].
*. Leifer R, Juzdan ZR, Kelly WR, et al. Detection of uranium from Cosmos-1402 in the stratosphere. Science. 1987;238:512-514. [pmid: 17809615].
Lestaevel P, Bussy C, Paquet F, et al. Changes in sleep-wake cycle after chronic exposure to uranium in rats. Neurotoxicol Teratol. 2005b;27(6):835-840. [pmid: 16099620].
*. Lestaevel P, Houpert P, Bussy C, et al. The brain is a target organ after acute exposure to depleted uranium. Toxicology. 2005a;212(2–3):219-226. [pmid: 15951092].
Leung HW. Ballentyne B, Marrs T, Turner P, editors. Physiologically-based pharmacokinetic modelling. General and applied toxicology. New York, NY. Stockton Press. 1993;Vol. 1:153-164.
Li WB, Gerstmann UC, Hollriegl V, et al. Radiation dose assessment of exposure to depleted uranium. J Expo Sci Environ Epidemiol. 2009b;19(5):502-514. [pmid: 18596688].
Li WB, Karpas Z, Salonen L, et al. A compartmental model of uranium in human hair for protracted ingestion of natural uranium in drinking water. Health Phys. 2009a;96(6):636-645. [pmid: 19430216].
Li WB, Roth P, Wahl W, et al. Biokinetic modeling of uranium in man after injection and ingestion. Radiat Environ Biophys. 2005;44(1):29-40. [pmid: 15830205].
Li WB, Salonen L, Muikku M, et al. Internal dose assessment of natural uranium from drinking water based on biokinetic modeling and individual bioassay monitoring: A study of a Finnish family. Health Phys. 2006;90(6):533-543. [pmid: 16691101].
Lide DR, Frederikse HPR. CRC Handbook of chemistry and physics. Boca Raton, FL. CRC Press. 1994. 4-31 to 4-32; 11-131 to 11-31; 4-109 to 4-110.
Limson Zamora M, Tracy BL, Zielinski JM, et al. Chronic ingestion of uranium in drinking water: A study of kidney bioeffects in humans. Toxicol Sci. 1998;43(1):68-77. [pmid: 9629621].
Limson Zamora M, Zielinski JM, Meyerhof DP, et al. Gastrointestinal absorption of uranium in humans. Health Phys. 2002;83(1):35-45. [pmid: 12075682].
Limson Zamora M, Zielinski JM, Meyerhof D, et al. Uranium gastrointestinal absorption: The f_1_ factor in humans. Radiat Prot Dosimetry. 2003;105(1–4):55-60. [pmid: 14526927].
Limson Zamora M, Zielinski JM, Moodie GB, et al. Uranium in drinking water: Renal effects of long-term ingestion by an aboriginal community. Arch Environ Occup Health. 2009;64(4):228-241. [pmid: 20007119].
Lin RH, Wu LJ, Lee CH, et al. Cytogenetic toxicity of uranyl nitrate in Chinese hamster ovary cells. Mutat Res. 1993;319:197-203. [pmid: 7694141].
Linares V, Albina ML, Belles M, et al. Combined action of uranium and stress in the rat. II. Effects on male reproduction. Toxicol Lett. 2005;158(3):186-195. [pmid: 15905049].
Linares V, Sanchez DJ, Belles M, et al. Pro-oxidant effects in the brain of rats concurrently exposed to uranium and stress. Toxicology. 2007;236(1–2):82-91. [pmid: 17493736].
Linsalata P. Uranium and thorium decay series radionuclides in human and animal foodchains. J Environ Qual. 1994;23:633-642.
*. Lippmann M, Ong LDY, Harris WB. The significance of urine uranium excretion data. Ind Hyg J. 1964;25:43-54.
Little TT, Miller G, Guilmette R. Internal dosimetry of uranium isotopes using Bayesian inference methods. Radiat Prot Dosimetry. 2003;105(1–4):413-416. [pmid: 14526999].
Little T, Miller G, Guilmette R, et al. Uranium dose assessment: A Bayesian approach to the problem of dietary background. Radiat Prot Dosimetry. 2007;127(1–4):333-338. [pmid: 17623684].
Livingston AL. Forage plant estrogens. J Toxicol Environ Health. 1978;4(2–3):301-324. [pmid: 351201].
Llobet JM, Sirvent JJ, Ortega A, et al. Influence of chronic exposure to uranium on male reproduction in mice. Fundam Appl Toxicol. 1991;16:821-829. [pmid: 1884918].
Longtin JP. Occurrence of radon, radium, and uranium in groundwater. Am Water Works Assoc J. 1988;80:84-93.
*. Loomis DP, Shy CM, Allen JW, et al. Micronuclei in epithelial cells from sputum of uranium workers. Scand J Work Environ Health. 1990;16:355-362. [pmid: 2255876].
Lopez R, Diaz Sylvester PL, Ubios AM, et al. Percutaneous toxicity of uranyl nitrate: Its effect in terms of exposure area and time. Health Phys. 2000;78(4):434-437. [pmid: 10749526].
Lowry JD, Hoxie DC, Moreau E. Graves B, editor. Extreme levels of radon-222 and uranium in a private water supply. Radon in ground water, radon, radium and other radioactivity in ground water: Hydrogeologic impact and application to indoor airborne contamination. Proceedings of the National Water Well Association Conference. Somerset, NJ. April 7–9, 1987. Chelsea, MI. Lewis Publishers, Inc. 1987:363-376.
Lu S, Zhao F. Nephrotoxic limit and annual limit on intake for natural U. Health Phys. 1990;58(5):619-623. [pmid: 2341251].
*. Lubin JH, Boice JD Jr, Edling C, et al. Lung cancer in radon-exposed miners and estimation of risk from indoor exposure. J Natl Cancer Inst. 1995;87(11):817-827. [pmid: 7791231].
Luessenhop AJ, Gallimore JC, Sweet WH, et al. The toxicity in man of hexavalent uranium following intravenous administration. Am J Roentgenol. 1958;79:83-100.
Lundin FE, Lloyd W, Smith EM, et al. Mortality of uranium miners in relation to radiation exposure, hard rock mining and cigarette smoking 1950 through September 1967. Health Phys. 1969;16:571-578. [pmid: 5795875].
*. MacNider WDB. A study of the acquired resistance of fixed tissue cells morphologically altered through processes of repair. I. The liver injury induced by uranium nitrate. A consideration of the type of epithelial repair which imparts to the liver resistance against subsequent uranium intoxications. J Pharmacol Exp Ther. 1936a;56(3):359-372.
*. MacNider WDB. A study of the acquired resistance of fixed tissue cells morphologically altered through processes of repair. II. The resistance of liver epithelium altered morphologically as the result of an injury from uranium, followed by repair, to the hepatoxic action of chloroform. J Pharmacol Exp Ther. 1936b;56(3):373-381.
MacFarlane GJ, Hotopf M, Maconochie N, et al. Long-term mortality amongst Gulf War Veterans: Is there a relationship with experiences during deployment and subsequent morbidity?. Int J Epidemiol. 2005;34(6):1403-1408. [pmid: 16251257].
Magdo HS, Forman J, Graber N, et al. Grand rounds: nephrotoxicity in a young child exposed to uranium from contaminated well water. Environ Health Perspect. 2007;115(8):1237-1241. [pmid: 17687453].
Magnoni M, Bertino S, Bellotto B, et al. Variations of the isotopic ratios of uranium in environmental samples containing traces of depleted uranium: Theoretical and experimental aspects. Radiat Prot Dosimetry. 2001;97(4):337-340. [pmid: 11878415].
Mahon DC. Uptake and translocation of naturally-occurring radionuclides of the uranium series. Bull Environ Cont Toxicol. 1982;29:697-703.
Malard V, Gaillard JC, Berenguer F, et al. Urine proteomic profiling of uranium nephrotoxicity. Biochim Biophys Acta. 2009;1794(6):882-891. [pmid: 19336034].
Malenchenko AF, Barkun NA, Guseva GF. Effect of uranium on the induction and course of experimental autoimmune orchitis and thyroiditis. J Hyg Epidemiol Microbiol Immunol. 1978;22:268-277.
Mao Y, Desmeules M, Schaubel D, et al. Inorganic components of drinking water and microalbuminuria. Environ Res. 1995;71(2):135-140. [pmid: 8977622].
Marco R, Katorza E, Gonen R, et al. Normalisation of spot urine samples to 24-h collection for assessment of exposure to uranium. Radiat Prot Dosimetry. 2008;130(2):213-223. [pmid: 18337294].
MARLAP. Multi-agency radiological laboratory analytical protocols manual. Washington, DC. Multi-Agency Radiological Laboratory Analytical Protocols. 2004. NUREG-1576, EPA402b04001A. PB2004105421. http://www.nrc.gov/reading-rm/doc-collections/nuregs/staff/sr1576/initial/. March 23, 2011.
MARSSIM. Multi-agency radiation survey and site investigation manual (MARSSIM). Washington, DC. Multi-agency radiation survey and site investigation manual. 2000. NUREG-1575, EPA402R97016, DOE/EH-0624. http://www.epa.gov/rpdweb00/marssim/obtain.html. March 23, 2011.
Martin F, Earl R, Tawn EJ. A cytogenetic study of men occupationally exposed to uranium. Br J Ind Med. 1991;48:98-102. [pmid: 1998615].
Martinez AB, Cabrini RL, Ubios AM. Orally administered ethane-1-hydroxy-1,1-biphosphonate reduces the lethal effect of oral uranium poisoning. Health Phys. 2000;78(6):668-671. [pmid: 10832926].
Martinez AB, Mandalunis PM, Bozal CB, et al. Renal function in mice poisoned with oral uranium and treated with ethane-1-hydroxy-1,1-bisphosphonate (EHBP). Health Phys. 2003;85(3):343-347. [pmid: 12938724].
Masuda K. Intake and urinary excretion of uranium in non-occupationally exposed persons. III. Urinary excretion of uranium. Nippon Eiseigaku Zasshi (Japan). 1971;26:442-446.
Maynard EA, Hodge HC. Voegtlin IC, Hodge HC, editors. Studies of the toxicity of various uranium compounds when fed to experimental animals. Pharmacology and toxicology of uranium compounds, National Nuclear Energy Series (VI). New York, NY. McGraw-Hill. 1949:309-376.
Maynard EA, Down WL, Hodge HC. Voegtlin C, Hodge HC, editors. Oral toxicity of uranium compounds. Pharmacology and toxicology of uranium compounds. New York, NY. McGraw-Hill. 1953:1221-1369.
Mayr U, Butsch A, Schneider S. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology. 1992;74(2–3):135-149. [pmid: 1387742].
Mays CW, Rowland RE, Stehaney AF, et al. Cancer risk from the lifetime intake of Ra and U isotopes. Health Phys. 1985;48(5):635-647. [pmid: 3921492].
McDiarmid MA, Albertini RJ, Tucker JD, et al. Measures of genotoxicity in Gulf War I veterans exposed to depleted uranium. Environ Mol Mutagen. 2011a;52(7):569-581. [pmid: 21728185].
McDiarmid MA, Engelhardt SM, Dorsey CD, et al. Surveillance results of depleted uranium-exposed Gulf War I veterans: Sixteen years of follow-up. J Toxicol Environ Health A. 2009;72(1):14-29. [pmid: 18979351].
McDiarmid MA, Engelhardt SM, Dorsey CD, et al. Longitudinal health surveillance in a cohort of Gulf War veterans 18 years after first exposure to depleted uranium. J Toxicol Environ Health A. 2011b;74(10):678-691. [pmid: 21432717].
McDiarmid MA, Engelhardt S, Oliver M, et al. Health effects of depleted uranium on exposed Gulf War veterans: A 10-year follow-up. J Toxicol Environ Health A. 2004b;67(4):277-296. [pmid: 14713562].
McDiarmid MA, Engelhardt SM, Oliver M, et al. Biological monitoring and surveillance results of Gulf War I veterans exposed to depleted uranium. Int Arch Occup Environ Health. 2006;79(1):11-21. [pmid: 16075297].
McDiarmid MA, Engelhardt SM, Oliver M, et al. Health surveillance of Gulf War I veterans exposed to depleted uranium: Updating the cohort. Health Phys. 2007;93(1):60-73. [pmid: 17563493].
McDiarmid MA, Engelhardt SM, Oliver M. Urinary uranium concentrations in an enlarged Gulf War veteran cohort. Health Phys. 2001b;80(3):270-273. [pmid: 11219540].
McDiarmid MA, Hooper FJ, Squibb K, et al. The utility of spot collection for urinary uranium determinations in depleted uranium exposed Gulf War veterans. Health Phys. 1999b;77(3):261-264. [pmid: 10456496].
*. McDiarmid MA, Keough JP, Hooper FJ, et al. Health effects of depleted uranium on exposed Gulf War veterans. J Int Neuropsychol Soc. 1999a;82(2):168-180.
McDiarmid MA, Keogh JP, Hooper FJ, et al. Health effects of depleted uranium on exposed Gulf War veterans. Environ Res. 2000;82(2):168-180. [pmid: 10662531].
McDiarmid MA, Squibb K, Engelhardt S, et al. Surveillance of depleted uranium exposed Gulf War veterans: Health effects observed in an enlarged"friendly fire" cohort. J Occup Environ Med. 2001a;43(12):991-1000. [pmid: 11765683].
McDiarmid MA, Squibb K, Engelhardt SM. Biologic monitoring for urinary uranium in Gulf War I veterans. Health Phys. 2004a;87(1):51-56. [pmid: 15194922].
McDonald-Taylor CK, Bhatnagar MK, Gilman A, et al. Uranyl nitrate-induced glomerular basement membrane alterations in rabbits: A quantitative analysis. Bull Environ Contam Toxicol. 1992;48(3):367-373. [pmid: 1627910].
McDonald-Taylor C, Singh A, Gilman A, et al. Uranyl nitrate-induced proximal tubule alterations in rabbits: A quantitive analysis. Toxicol Pathol. 1997;25(4):381-389. [pmid: 9280121].
Meditext. Medical management (uranium). Micromedex Inc. 1998. Vol. 34 (expires 10-31-97), copyright 1987–1997.
Melgard R. Kathren RL, Weber JR, editors. Proceedings of the meeting on ultrasensitive techniques for measurement of uranium in biological samples and the nephrotoxicity of uranium. Washington, DC. U.S. Nuclear Regulatory Commission. 1988:1-9.
Melville CM, Wai CM, Collopy M, et al. Uranium dispersion along roads paved with phosphate slag. Bull Environ Cont Toxicol. 1981;27:470-473.
Meriwether JR, Beck JN, Keeley DF, et al. Radionuclides in Louisiana soils. J Environ Qual. 1988;17:562-568.
Milačić S. Health investigations of depleted-uranium clean-up workers. Med Lav. 2008;99(5):366-370. [pmid: 18828536].
Milačić S, Simic J. Identification of health risks in workers staying and working on the terrains contaminated with depleted uranium. J Radiat Res (Tokyo). 2009;50(3):213-222. [pmid: 19531923].
Milacic S, Petrovic D, Jovicic D, et al. Examination of the health status of populations from depleted-uranium-contaminated regions. Environ Res. 2004;95(1):2-10. [pmid: 15068925].
Miller HT. Radiation exposures associated with surface mining for uranium. Health Phys. 1977;32:523-527. [pmid: 881351].
Miller AC, Blakely WF, Livengood D, et al. Transformation of human osteoblast cells to the tumorigenic phenotype by depleted uranium-uranyl chloride. Environ Health Perspect. 1998b;106:465-471. [pmid: 9681973].
Miller AC, Bonait-Pellie C, Merlot RF, et al. Leukemic transformation of hematopoietic cells in mice internally exposed to depleted uranium. Mol Cell Biochem. 2005;279(1–2):97-104. [pmid: 16283518].
Miller AC, Brooks K, Stewart M, et al. Genomic instability in human osteoblast cells after exposure to depleted uranium: Delayed lethality and micronuclei formation. J Environ Radioact. 2003;64(2–3):247-259. [pmid: 12500809].
Miller AC, Fuciarelli AF, Jackson WE, et al. Urinary and serum mutagenicity studies with rats implanted with depleted uranium or tantalum pellets. Mutagenesis. 1998a;13:643-648. [pmid: 9862198].
Miller AC, Stewart M, Brooks K, et al. Depleted uranium-catalyzed oxidative DNA damage: Absence of significant alpha particle decay. J Inorg Biochem. 2002a;91(1):246-252. [pmid: 12121782].
Miller AC, Stewart M, Rivas R. Preconceptional paternal exposure to depleted uranium: Transmission of genetic damage to offspring. Health Phys. 2010;99(3):371-379. [pmid: 20699700].
Miller AC, Xu J, Stewart M, et al. Potential late health effects of depleted uranium and tungsten used in armor-piercing munitions: Comparison of neoplastic transformation and genotoxicity with the known carcinogen nickel. Mil Med. 2 Suppl. 2002b;167:120-122. [pmid: 11873492].
Miller AC, Xu J, Stewart M, et al. Observation of radiation-specific damage in human cells exposed to depleted uranium: dicentric frequency and neoplastic transformation as endpoints. Radiat Prot Dosimetry. 2002c;99(1–4):275-278. [pmid: 12194305].
Miller BG, Colvin AP, Hutchison PA, et al. A normative study of levels of uranium in the urine of British Forces personnel. Occup Environ Med. 2008;65(6):398-403. [pmid: 17933886].
Miller KM, Shebell P, Kemic A. In situ gamma-ray spectrometry for the measurement of uranium in surface soils. Health Phys. 1994;67(2):140-150. [pmid: 8026967].
Mindat. Ralph J, Chau I, editors. Thucholite. Mindat.org. 2011. http://www.mindat.org/min-3954.html. April 28, 2011.
Mitchel RE, Jackson JS, Heinmiller B. Inhaled uranium ore dust and lung cancer risk in rats. Health Phys. 1999;76(2):145-155. [pmid: 9929125].
Mlakar M, Branica M. Stripping voltammetric determination of trace levels of uranium by synergic adsorption. Anal Chim Acta. 1989;221:279-287.
MMES. United States Department of Energy Paducah Gaseous Diffusion Plant: Environmental monitoring report, 1984. Report ISS KY-747. Martin Marietta Energy Systems, Inc. 1985. DE85014027.
Moffett D, Tellier M. Uptake of radioisotopes by vegetation growing on uranium tailings. Can J Soil Sci. 1977;57:417-424.
Monleau M, Bussy C, Lestaevel P, et al. Bioaccumulation and behavioural effects of depleted uranium in rats exposed to repeated inhalations. Neurosci Lett. 2005;390(1):31-36. [pmid: 16115730].
Monleau M, De Meo M, Frelon S, et al. Distribution and genotoxic effects after successive exposure to different uranium oxide particles inhaled by rats. Inhal Toxicol. 2006b;18(11):885-894. [pmid: 16864406].
Monleau M, De Meo M, Paquet F, et al. Genotoxic and inflammatory effects of depleted uranium particles inhaled by rats. Toxicol Sci. 2006a;89(1):287-295. [pmid: 16221956].
Moolgavkar SH, Luebeck EG, Krewski D, et al. Radon, cigarette smoke, and lung cancer a re-analysis of the Colorado Plateau Uranium Miners Data. Epidemiology. 1993;4:204-217. [pmid: 8512985].
Moon JW, Roh Y, Phelps TJ, et al. Physicochemical and mineralogical characterization of soil-saprolite cores from a field research site, Tennessee. J Environ Qual. 2006;35(5):1731-1741. [pmid: 16899744].
Moore RH, Kathren RL. A World War II uranium hexafluoride inhalation event with pulmonary implications for today. J Occup Med. 1985;27:753-756. [pmid: 4067678].
Morishima H, Koga T, Kawai H, et al. Studies on the movement of distribution of uranium in the environments-distribution of uranium in agricultural products. J Radiat Res. 1977;18:139-150. [pmid: 886523].
Morris KJ, Barker CL, Batchelor AL, et al. Dosimetric implications of pulmonary macrophage clusters observed within lungs of rats that have inhaled enriched UO2 particles. Environ Health Perspect. 1992;97:201-208. [pmid: 1396459].
Morris KJ, Khanna P, Batchelor AL. Long-term clearance of inhaled UO_2_particles from the pulmonary region of the rat. Health Phys. 1990;58(4):477-485. [pmid: 2323929].
Morris KJ, Townsend KMS, Batchelor AL. Studies of alveolar cell morphometry and mass clearance in the rat lung following inhalation of an enriched uranium dioxide aerosol. Radiat Environ Biophys. 1989;28:141-154. [pmid: 2727252].
Morrison HI, Semenciw RM, Mao Y, et al. Cancer mortality among a group of fluorspar miners exposed to radon progeny. Am J Epidemiol. 1988;128(6):1266-1275. [pmid: 3195567].
Morrow PE, Gelein R, Beiter H. Inhalation and intravenous studies of UF6/UO2F2 in dogs. Health Phys. 1982a;43:859-873. [pmid: 7152950].
Morrow PE, Gibb FR, Beiter HD. Inhalation studies of uranium trioxide. Health Phys. 1972;23:273-280. [pmid: 4642950].
Morrow PE, Leach LJ, Smith FA, et al. Metabolic fate and evaluation of injury in rats and dogs following exposure to the hydrolysis products of uranium hexafluoride. Implications for a bioassay program related to potential releases of uranium hexafluoride. 1982b. Govt Rep Announce Ind, Issue 11. NTIS/NUREG/CR-2268.
Morselli PL, Franco-Morselli R, Bossi L. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin. 1980;5(6):485-527.
Mortvedt JJ. Plant and soil relationships of uranium and thorium decay series radionuclides. J Environ Qual. 1994;23:643-650.
MSA. Uranium ores. The Mineralogical Society of America. 2011. http://www.handbookofmineralogy.org/search.html?p=all. April 27, 2011.
Muikku M, Puhakainen M, Heikkinen T, et al. The mean concentration of uranium in drinking water, urine, and hair of the occupationally unexposed Finnish working population. Health Phys. 2009;96(6):646-654. [pmid: 19430217].
Muller C, Rozicka L, Bakstein J. The sex ratio in the offsprings of uranium miners. Acta Univ Carol Med. 1967;13(7):599-603.
Murray RL. Understanding radioactive waste. 1994. 4th edition. Battelle Pacific Northwest Laboratories, Battelle Press.
Nagj M, Makjanic J, Orlic I, et al. Determination of uranium in sea-water by X-ray fluorescence spectroscopy. J Radioanal Nucl Chem. 1986;97:373-380.
NAS/NRC. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC. National Academy of Sciences, National Research Council, National Academy Press. 1989:15-35.
NCRP. National Council on Radiation Protection and Measurements. Natural background radiation in the United States. NCRP Report No. 45. Bethesda, MD. 1975:4-6.
NCRP. National Council on Radiation Protection and Measurements. Instrumentation and monitoring methods for radiation protection. NCRP Report No. 57. Washington, DC. 1978.
NCRP. National Council on Radiation Protection and Measurements. Exposures from the uranium series with emphasis on radon and its daughter. NCRP Report No. 77. Bethesda, MD. 1984a.
NCRP. National Council on Radiation Protection and Measurements. Radiological assessment: Predicting the transport, bioaccumulation and uptake by man of radionuclides released to the environment. NCRP Report No. 76. 1984b.
NCRP. National Council on Radiation Protection and Measurements. Limitation of exposure to ionizing radiation. Report No. 116. Bethesda, MD. 1993.
NCRP. Deposition, retention and dosimetry of inhaled radioactive substances. National Council on Radiation Protection and Measurement. NCRP Report No. 125. Bethesda, MD. 1997.
NCRP. NCRP Report no. 156. Development of a biokinetic model for radionuclidecontaminated wounds and procedures for their assessment, dosimetry and treatment. Bethesda, MD. National Council on Radiation Protection and Measurements. 2008. http://www.ncrppublications.org/Reports/156. July 5, 2012.
NCRP. Management of persons contaminated with radionuclided: Handbook. NCRP Report No. 161. National Council on Radiation Protection and Measurements. 2010:128-137. 176. 236. http://www.ncrponline.org/Publications/161press.html. February 11, 2010.
NEDH. Nebraska Department of Health. Domestic well water sampling in Nebraska, 1987 laboratory findings and their implications. Division of Environmental Health and Housing Surveillance. Lincoln, NE. 1989.
NIOSH. Health hazard evaluation: Cotter Corporation; Canon City, Colorado; September 1981. Cincinnati, OH. U.S. National Institute for Occupational Safety and Health. 1981. PB83127407.
NIOSH. Mortality among uranium enrichment workers. Washington, DC. National Institute of Occupational Safety and Health. 1987. PB87188991.
NIOSH. NIOSH pocket guide to chemical hazards. U.S. Department of Health and Human Services. Public Health Services. Centers for Disease Control and Prevention. National Institute for Occupational Safety and Health. 1997.
NIOSH. Uranium (insoluble compounds, as U). NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. 2010a. http://www.cdc.gov/niosh/npg/npgd0650.html. January 28, 2011.
NIOSH. Uranium (soluble compounds, as U). NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. 2010b. http://www.cdc.gov/niosh/npg/npgd0651.html. January 28, 2011.
NIOSH. Uranium. NIOSH pocket guide to chemical hazards. Atlanta, GA. National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. 2012. http://www.cdc.gov/niosh/npg/. June 15, 2012.
NIST. Standard reference materials catalog, special publication 260. Washington, DC. National Institute for Standards and Technology. U.S. Department of Commerce. 1995.
NIST. Standard reference materials. National Institute of Standards and Technology. 2011. http://www.nist.gov/srm/. April 29, 2011.
NMHED. Summary report on the Church Rock uranium mill tailings spill: A health and environment assessment. Santa Fe NM. New Mexico Health and Environment Department. 1989.
NNDC. Chart of Nuclides. Upton, NY. National Nuclear Data Center, Brookhaven National Laboratory. 2011. http://www.nndc.bnl.gov/chart/. April 28, 2011.
NNSA. Environmental assessment for increased depleted uranium use on Target 63-10, Nevada Test and Training Range. National Nuclear Security Administration. 2006. http://nnsa.energy.gov/sites/default/files/nnsa/inlinefiles/usaf%202006d.pdf. February 21, 2013.
Norman JD, Stumpe LA, Trimm J, et al. Argon-plasma emission spectrometry of uranium in phosphatic materials (e.g. fertilizers). J Assoc Off Anal Chem. 1983;66:949-951.
NRC. Pesticides in the diets of infants and children. National Research Council. Washington DC. National Academy Press. 1993.
NTP. Substances nominated to the report on carcinogens. U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. Federal Register 77 FR 2728. 2012. http://ntp.niehs.nih.gov/?objectid=C3213BD9-F807-E389-916C16858403102B. June 15, 2012.
Oeh U, Li WB, Hollriegl V, et al. Daily uranium excretion in German peacekeeping personnel serving on the Balkans compared to ICRP model prediction. Radiat Prot Dosimetry. 2007a;127(1–4):329-332. [pmid: 17567762].
Oeh U, Priest ND, Roth P, et al. Measurements of daily urinary uranium excretion in German peacekeeping personnel and residents of the Kosovo region to assess potential intakes of depleted uranium (DU). Sci Total Environ. 2007b;381(1–3):77-87. [pmid: 17459457].
Ohanian EV. National primary drinking water regulations for radionuclides. Safe Drinking Water Act: Amendments, Regulations and Standards. Lewis Publishers. 1989:45-55.
Oliver IW, Graham MC, MacKenzie AB, et al. Assessing depleted uranium (DU) contamination of soil, plants and earthworms at UK weapons testing sites. J Environ Monit. 2007;9(7):740-748. [pmid: 17607395].
Oliver IW, Graham MC, MacKenzie AB, et al. Depleted uranium mobility across a weapons testing site: Isotopic investigation of porewater, earthworms, and soils. Environ Sci Technol. 2008a;42(24):9158-9164. [pmid: 19174886].
Oliver IW, Graham MC, Mackenzie AB, et al. Distribution and partitioning of depleted uranium (DU) in soils at weapons test ranges-investigations combining the BCR extraction scheme and isotopic analysis. Chemosphere. 2008b;72(6):932-939. [pmid: 18457863].
Orcutt JA. Voegtlin C, Hodge HC, editors. The toxicology of compounds of uranium following application to the skin. Pharmacology and toxicology of uranium compounds. New York, NY. McGraw Hill Book Co. 1949;Vols 3 and 4:377-414.
Orloff KG, Mistry K, Charp P, et al. Human exposure to uranium in groundwater. Environ Res. 2004;94(3):319-326. [pmid: 15016600].
ORNL. Oak Ridge Reservation annual site environmental report for 1995. Oak Ridge, TN. Oak Ridge National Laboratory. 2011. http://www.ornl.gov/sci/env_rpt/aser95/aser.htm. March 23, 2011.
*. Ortega A, Domingo JL, Gomez M, et al. Treatment of experimental acute uranium poisoning by chelating agents. Pharmacol Toxicol. 1989b;64:247-251. [pmid: 2726688].
Ortega A, Domingo JL, Lloket JM, et al. Evaluation of the oral toxicity of uranium in a 4-week drinking water study in rats. Bull Environ Contam Tox. 1989a;42:935-941.
OSHA. Each area or room in which natural uranium is used or stored shall be conspicuously posted with a sign or signs bearing the radiation caution symbol. Occupational Safety and Health Administration. Code of Federal Regulations 29 CFR 1910.1096. 2012a. http://www.gpo.gov/fdsys. June 15, 2012.
OSHA. Each container in which natural uranium is transported, stored, or used shall bear a durable, clearly visible label bearing the radiation caution symbol. Occupational Safety and Health Administration. Code of Federal Regulations 29 CFR 1910.1096. 2012b. http://www.gpo.gov/fdsys. June 15, 2012.
OSHA. Toxic and hazardous substances. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations 29 CFR 1910.1000, Table Z-1. 2012c. http://www.osha.gov/law-regs.html. April 25, 2012.
Otake M, Schull W. Mental retardation in children exposed in utero to the atomic bombs: A reassessment. Technical Report RERF TR 1-83. Japan. Radiation Effects Research Foundation. 1984.
Ough EA, Lewis BJ, Andrews WS, et al. Determination of natural and depleted uranium in urine at the ppt level: An interlaboratory analytical exercise. Health Phys. 2006;90:494-499. [pmid: 16607181].
Owen GM, Brozek J. Falkner F, editor. Influence of age, sex and nutrition on body composition during childhood and adolescence. Human development. Philadelphia, PA. WB Saunders. 1966:222-238.
Ozmen M, Yurekli M. Subacute toxicity of uranyl acetate in Swiss-Albino mice. Environ Toxicol Pharmacol. 1998;6(2):111-115. [pmid: 21781887].
Paquet F, Houpert P, Blanchardon E, et al. Accumulation and distribution of uranium in rats after chronic exposure by ingestion. Health Phys. 2006;90(2):139-147. [pmid: 16404171].
Parkhurst MA, Guilmette RA. Overview of the Capstone depleted uranium study of aerosols from impact with armored vehicles: Test setup and aerosol generation, characterization, and application in assessing dose and risk. Health Phys. 2009a;96(3):207-220. [pmid: 19204481].
Parkhurst MA, Guilmette RA. Conclusions of the Capstone depleted uranium aerosol characterization and risk assessment study. Health Phys. 2009b;96(3):393-409. [pmid: 19204494].
Parkhurst MA, Cheng YS, Kenoyer JL, et al. Physicochemical characterization of Capstone depleted uranium aerosols I: Uranium concentration in aerosols as a function of time and particle size. Health Phys. 2009;96(3):251-265. [pmid: 19204484].
Parrington JR, Knox H, Breneman SL, et al. Nuclides and isotopes. San Jose, CA. General Electric Co. and KAPL Inc. 1996.
Parrish RR, Horstwood M, Arnason JG, et al. Depleted uranium contamination by inhalation exposure and its detection after approximately 20 years: Implications for human health assessment. Sci Total Environ. 2008;390(1):58-68. [pmid: 17976690].
*. Paschoa AS, Cholewa M, Jones KW, et al. PIXE-RBS (Rutherford Back-Scattering) combination to measure uranium and thorium in environmental and biological samples. J Radioanal Nucl Chem. 1987;115:231-240.
Paternain JL, Domingo JL, Ortega A, et al. The effects of uranium on reproduction, gestation, and postnatal survival in mice. Ecotoxicol Environ Saf. 1989;17:291-296. [pmid: 2743917].
Paunescu N. Determination of uranium and thorium concentration in natural waters. J Radioanal Nucl Chem. 1986;104:209-216.
Pavlakis N, Pollock CA, McLean G, et al. Deliberate overdose of uranium: Toxicity and treatment. Nephron. 1996;72(2):313-317. [pmid: 8684547].
Peehs M, Walter T, Walter S, et al. Uranium, uranium alloys, and uranium compounds. Ullmann's encyclopedia of industrial chemistry. 2007. http://onlinelibrary.wiley.com/doi/10.1002/14356007.a27_281.pub2/pdf. January 26, 2011.
Pellmar TC, Fuciarelli AF, Ejnik JW, et al. Distribution of uranium in rats implanted with depleted uranium pellets. Toxicol Sci. 1999a;49:29-39. [pmid: 10367339].
Pellmar TC, Keyser DO, Emery C, et al. Electrophysiological changes in hippocampal slices isolated from rats embedded with depleted uranium fragments. Neurotoxicology. 1999b;20(5):785-792. [pmid: 10591514].
*. Pelayo JC, Andrews PM, Coffey AK, et al. The influence of age on acute renal toxicity of uranyl nitrate in the dog. Pediatr Res. 1983;17(12):985-992. [pmid: 6657329].
Perez JLP, Cordero BM, Garcia ER, et al. Determination of uranium using a flow system with reagent injection. Application to the determination of uranium in ore leachates. Anal Chim Acta. 1990;230:217-220.
Petitot F, Frelon S, Moreels AM, et al. Incorporation and distribution of uranium in rats after a contamination on intact or wounded skin. Health Phys. 2007a;92(5):464-474. [pmid: 17429305].
Petitot F, Gautier C, Moreels AM, et al. Percutaneous penetration of uranium in rats after a contamination on intact or wounded skin. Radiat Prot Dosimetry. 2007b;127(1–4):125-130. [pmid: 17553861].
Petitot F, Moreels AM, Paquet F. In vitro evaluation of percutaneous diffusion of uranyl nitrate through intact or excoriated skin of rat and pig. Can J Physiol Pharmacol. 2004;82(2):133-139. [pmid: 15052294].
Pinkerton LE, Bloom TF, Hein MJ, et al. Mortality among a cohort of uranium mill workers: An update. Occup Environ Med. 2004;61(1):57-64. [pmid: 14691274].
Pleskach SD. Determination of uranium and thorium in urine by neutron activation. Health Phys. 1985;48:303-307. [pmid: 3980216].
PNL. Occupational exposures to uranium: Processes, hazards and regulations. Pacific Northwest Laboratory and Hanford Environmental Health Foundation. 1981. PNL-3341 USUR-01 UC-41.
Polednak AP, Frome EL. Mortality among men employed between 1943 and 1947 at a uranium-processing plant. J Occup Med. 1981;23:169-178. [pmid: 6985520].
Polednak AP, Keane AT, Beck WL. Estimation of radiation doses to the lungs of early uranium processing plant workers. Environ Res. 1982;28:313-328. [pmid: 7117220].
Poston TM. The bioaccumulation potential of thorium and uranium in rainbow trout ( Salmo gairdneri ). Bull Environ Cont Toxicol. 1982;28:682-690.
Pozzani UC. High-grade ore. Pharmacology and toxicology of uranium compounds. New York, NY. McGraw-Hill, Inc. 1949:622-634.
Prat O, Ansoborlo E, Sage N, et al. From cell to man: Evaluation of osteopontin as a possible biomarker of uranium exposure. Environ Int. 2011;37(4):657-662. [pmid: 21324525].
Prat O, Berenguer F, Malard V, et al. Transcriptomic and proteomic responses of human renal HEK293 cells to uranium toxicity. Proteomics. 2005;5(1):297-306. [pmid: 15672453].
Premuzic ET, Francis AJ, Lin M, et al. Induced formation of chelating agents by Pseudomonas aeruginosa grown in presence of thorium and uranium. Arch Environ Contam Toxicol. 1995;14:759-768. [pmid: 3935054].
Price KR, Kinnison RR. Uranium and other heavy metals in soil and vegetation from the Hanford environs. Report: ISS PNL-4466-DE83003313. 1982.
*. Priest ND, Howells GR, Green D, et al. Uranium in bone: Metabolic and autoradiographic studies in the rat. Hum Toxicol. 1982;1:97-114. [pmid: 7173898].
Pujadas-Bigi MM, Lemlich L, Mandalunis PM, et al. Exposure to oral uranyl nitrate delays tooth eruption and development. Health Phys. 2003;84(2):163-169. [pmid: 12553645].
Pujadas Bigi MM, Ubios AM. Catch-up of delayed tooth eruption associated with uranium intoxication. Health Phys. 2007;92(4):345-348. [pmid: 17351498].
Puncher M, Bailey MR, Harrison JD. Uncertainty analysis of doses from inhalation of depleted uranium. Health Phys. 2008;95(3):300-309. [pmid: 18695411].
Purtymun WD, Peters RJ, Buhl TE, et al. Background concentrations of radionuclides in soils and river sediments in northern New Mexico, 1974–1986. Report: ISS LA-11134-MS. 1987. DE88001560.
Querol X, Alastuey A, Lopez-Soler A, et al. Trace element contents in atmospheric suspended particles: Inferences from instrumental neutron activation analysis. Fresenius J Anal Chem. 1997;357(7):934-940.
Racine R, Grandcolas L, Grison S, et al. Cholesterol 7α-hydroxylase (CYP7A1) activity is modified after chronic ingestion of depleted uranium in the rat. J Steroid Biochem Mol Biol. 2010;120(1):60-66. [pmid: 20362056].
Radenkovic MB, Cupac SA, Joksic JD, et al. Depleted uranium mobility and fractionation in contaminated soil (southern Serbia). Environ Sci Pollut Res Int. 2008;15(1):61-67. [pmid: 18306889].
Radford E, Renard K. Lung cancer in Swedish iron miners exposed to low doses of radon daughters. New Engl J Med. 1984;310:1485-1494. [pmid: 6325913].
Ramachandraiah C, Vijayakumari D, Lakshminarayana K. A sensitive spectrophotometric method for the determination of trace amounts of uranium(VI) using o-hydroxypropiophenone isonicotinoyl hydrazone. J Radioanal Nucl Chem Letters. 1993;175(3):185-190.
Raymond-Whish S, Mayer LP, O'Neal T, et al. Drinking water with uranium below the U.S. EPA water standard causes estrogen receptor-dependent responses in female mice. Environ Health Perspect. 2007;115(12):1711-1716. [pmid: 18087588].
Rayno DR. Estimated dose to man from uranium milling via the beef/milk food-chain pathway. Sci Total Environ. 1983;31:219-241. [pmid: 6362004].
Reyes M, Wilkinson GS, Tietjen G, et al. Brain tumors at a nuclear facility. J Occup Med. 1984;26:721-724. [pmid: 6491777].
Riley JE. Ultrahigh sensitivity uranium analyses using fission track counting: Further analyses of semiconductor packaging materials. J Radioanalytical Chem. 1982;72(1–2):89-99.
Roberts E. Voegtlin C, Hodge HC, editors. Uranyl nitrate. Pharmacology and toxicology of uranium compounds. New York. McGraw-Hill Book Company, Inc. 1949:561-585.
Rossol M. Ceramic glazes, frit metal enamels, and glass; personal communication and supporting materials. Arts, Crafts and Theater Safety. New York. 1997.
Roth P, Hollriegl V, Werner E, et al. Assessment of exposure to depleted uranium. Radiat Prot Dosimetry. 2003;105(1–4):157-161. [pmid: 14526948].
Rothermel JJ. Voegtlin C, Hodge HC, editors. Uranium tetrachloride. Pharmacology and toxicology of uranium compounds. New York. McGraw-Hill Book Company, Inc. 1949:588-602.
Rothstein A. Uranyl fluoride. Pharmacology and toxicology of uranium compounds. McGraw-Hill Book Company, Inc. 1949a:548-561.
Rothstein A. Voegtlin C, Hodge HC, editors. Uranium dioxide. Pharmacology and toxicology of uranium compounds. New York. McGraw-Hill Book Company, Inc. 1949b:614-621.
Rothstein A. Voegtlin C, Hodge HC, editors. Uranium trioxide. Pharmacology and toxicology of uranium compounds. New York. McGraw-Hill Book Company, Inc. 1949c:635-648.
*. Rothstein A. Voegtlin C, Hodge HC, editors. Sodium diuranate. Pharmacology and toxicology of uranium compounds. New York. McGraw-Hill Book Company, Inc. 1949:653-665.
Rouas C, Stefani J, Grison S, et al. Effect of nephrotoxic treatment with gentamicin on rats chronically exposed to uranium. Toxicology. 2011;279(1–3):27-35. [pmid: 20849911].
Russell JJ, Kathren RL. Uranium deposition and retention in a USTUR whole body case. Health Phys. 2004;86(3):273-284. [pmid: 14982228].
Russell J, Kathren R, Dietert S. A histological kidney study of uranium and non-uranium workers. Health phys. 1996;70(4):466-472. [pmid: 8617585].
Saccomanno G, Archer VE, Auerbach O, et al. Histologic types of lung cancer among uranium miners. Cancer. 1971;27:515-523. [pmid: 5549493].
Saccomanno G, Archer VE, Saunders RP, et al. Early indices of cancer risk among uranium miners with reference to modifying factors. Ann NY Acad Sciences. 1976;271:377-383.
Saccomanno G, Auerbach O, Kuschner M, et al. A comparison between the localization of lung tumors in uranium miners and in nonminers from 1947 to 1991. Cancer. 1996;77(7):1278-1283. [pmid: 8608503].
Saccomanno G, Huth GC, Auerbach O, et al. Relationship of radioactive radon daughters and cigarette smoking in the genesis of lung cancer in uranium miners. Cancer. 1988;62:1402-1408. [pmid: 3416280].
Saccomanno G, Thun MJ, Baker DB, et al. The contribution of uranium miners to lung cancer histogenesis renal toxicity in uranium mill workers. Cancer Res. 1982;82:43-52.
Saccomanno G, Yale C, Dixon W, et al. An epidemiological analysis of the relationship between exposure to radon progeny, smoking and bronchogenic carcinoma in the uranium-mining population of the Colorado Plateau (USA): 1960–1980. Health Phys. 1986;50:605-618. [pmid: 3700112].
Sahoo SK, Matsumoto M, Shiraishi K, et al. Dose effect for South Serbians due to 238U in natural drinking water. Radiat Prot Dosimetry. 2007;127(1–4):407-410. [pmid: 17567760].
Sairenji E, Moriwaki K, Shimizu M, et al. Estimation of radiation dose from porcelain teeth containing uranium compound. J Dent Res. 1980;59:1136-1140. [pmid: 6929807].
Samet JM, Kutvirt DM, Waxweiler RJ, et al. Uranium mining and lung cancer in Navaho men. N Eng J Med. 1984b;310:1481-1484.
Samet JM, Morgan MV, Key CR, et al. Studies of uranium miners in New Mexico. Ann Am Conf Gov Ind Hyg. 1986;15:351-355.
Samet JM, Pathak DR, Morgan MV, et al. Radon progeny exposure and lung cancer risk in New Mexico U miners: a case-control study. Health Phys. 1989;56(4):415-421. [pmid: 2538407].
Samet JM, Pathak DR, Morgan MV, et al. Lung cancer mortality and exposure to radon progeny in a cohort of New Mexico underground uranium miners. Health Phys. 1991;61(6):745-752. [pmid: 1659563].
Samet JM, Pathak DR, Morgan MV, et al. Silicosis and lung cancer risk in underground uranium miners. Health Phys. 1994;66(4):450-453. [pmid: 8138413].
Samet JM, Young RA, Morgan MV, et al. Prevalence survey of respiratory abnormalities in New Mexico uranium miners. Health Phys. 1984a;46(2):361-370. [pmid: 6693266].
Sánchez DJ, Belles M, Albina ML, et al. Exposure of pregnant rats to uranium and restraint stress: Effects on postnatal development and behavior of the offspring. Toxicology. 2006;228(2–3):323-332. [pmid: 17079065].
Sanders CL. Radiological health. Toxicological aspects of energy production. Columbus, OH. Battelle Press. 1986:253-284.
Sansone U, Stellato L, Jia G, et al. Levels of depleted uranium in Kosovo soils. Radiat Prot Dosimetry. 2001;97(4):317-320. [pmid: 11878410].
Scharer JM, Ibbotson B. Bacterial oxidation of inorganic compounds in mining waste. Conserv Recycling. 1982;5:47-53.
Schieferdecker H, Dilger H, Doerfel H, et al. Inhalation of uranium aerosols from uranium dioxide fuel element fabrication. Health Phys. 1985;48:29-48. [pmid: 3967974].
Schimmack W, Gerstmann U, Schultz W, et al. Long-term corrosion and leaching of depleted uranium (DU) in soil. Radiat Environ Biophys. 2007;46(3):221-227. [pmid: 17549506].
Schröder H, Heimers A, Frentzel-Beyme R, et al. Chromosome aberration analysis in peripheral lymphocytes of Gulf War and Balkans War veterans. Radiat Prot Dosimetry. 2003;103(3):211-219. [pmid: 12678382].
Scott LM, Bahler KW, De La Garza A, et al. Mortality experience of uranium and nonuranium workers. Health Phys. 1972;23:555-557. [pmid: 4634936].
Seldén AI, Lundholm C, Edlund B, et al. Nephrotoxicity of uranium in drinking water from private drilled wells. Environ Res. 2009;109(4):486-494. [pmid: 19278676].
Setchell BP, Waites GMH. Creep RO, Astwood EB, Geiger SR, editors. The blood-testis barrier. Handbook of physiology: Endocrinology V. Washington, DC. American Physiological Society. 1975:143-172.
Shaw TJ, Sholkovitz ER, Klinkhammer G. Redox dynamics in the Chesapeake Bay: The effect on sediment/water uranium exchange. Geochim Cosmochim Acta. 1994;58(14):2985-2995.
Sheppard MI, Thibault DH, Mitchell JH. Element leaching and capillary rise in sandy soil cores: Experimental results. J Environ Qual. 1987;16:273-284.
Sheppard MI, Vandergraaf TT, Thibault DH, et al. Technetium and uranium: Sorption by and plant uptake from peat and sand. Health Phys. 1983;44:635-644. [pmid: 6853186].
Shiraishi K, Igarashi Y, Takaku Y, et al. Daily intakes of 232Th and 238U in Japanese males. Health Phys. 1992;63(2):187-191. [pmid: 1399617].
Sikov MR, Mahlum DD. Cross-placental transfer of selected actinides in the rat. Health Phys. 1968;14(3):205-208. [pmid: 5637394].
Sikov MR, Rommereim DN. Evaluation of the embryotoxicity of uranium in rats. Teratology. 1986;33:41C.
Silva RJ, Benson LV, Apps JA. Studies of actinide sorption on selected geologic materials. ACS Symp Ser. 1979;100:215-240.
Simpson HJ, Trier RM, Toggweiler JR, et al. Radionuclides in Mono Lake, California, USA. Science. 1982;216:512-514. [pmid: 17735739].
Singh NP, Wrenn ME. Hemphill DD, editor. Uptake of uranium from drinking water. Trace substances in environmental health. Columbia, MO. University of Missouri. 1987:203-212.
Singh NP, Wrenn ME. Determinations of actinides in biological and environmental samples. Sci Total Environ. 1988;70:187-204. [pmid: 2834820].
*. Singh NP, Wrenn ME. Is the Beagle dog an appropriate experimental animal for extrapolating data to humans on organ distribution patterns of U, Th, and Pu?. Health Phys. 1989;57:91-96. [pmid: 2606709].
Singh NP, Zimmerman CJ, Lewis LL, et al. Quantitative determination of environmental levels of uranium, thorium and plutonium in bone by solvent extraction and alpha spectrometry. Nucl Instrum Methods Phys Res. 1984;223:558-562.
Singh NP, Bennett DB, Wrenn ME. Macro-distribution of naturally occurring d-emitting isotopes of U in the human skeleton. Health Phys. 1987b;52:769-773. [pmid: 3583741].
Singh NP, Burleigh DP, Ruth HM, et al. Daily U intake in Utah residents from food and drinking water. Health Phys. 1990;59(3):333-337. [pmid: 2394591].
Singh NP, Lewis LL, Wrenn ME. Uranium in human tissues of Colorado, Pennsylvania and Utah populations. Health Phys. 1986b;550:583.
Smith DD, Black SC. Actinide concentrations in tissues from cattle grazing near the Rocky Flats Plant. 1975. Report: ISS NERC-LV-539-36.
*. Sontag W. The early distribution of plutonium-239, americium-241 and uranium-233 in the soft tissues and skeleton of old rats. A comparative study. Hum Toxicol. 1983;2:91-100. [pmid: 6840797].
Sontag W. Multicompartment kinetic models for the metabolism of americium, plutonium and uranium in rats. Hum Toxicol. 1986;5:163-173. [pmid: 3710493].
Souidi M, Gueguen Y, Linard C, et al. In vivo effects of chronic contamination with depleted uranium on CYP3A and associated nuclear receptors PXR and CAR in the rat. Toxicology. 2005;214(1–2):113-122. [pmid: 16039771].
Spencer H, Osis D, Isabel M, et al. Measured intake and excretion patterns of naturally occurring ^234^U, ^238^U, and calcium in humans. Radiat Res. 1990;124:90-95. [pmid: 2236501].
Spiegl CJ. Pharmacology and toxicology of uranium compounds. New York, NY. McGraw- Hill Book Company, Inc. 1949:532-547.
Spoor NL, Hursh JB. Hodge HC, Stannard JN, Hursh JB, editors. Protection Criteria. I. The history of development of protection criteria for uranium in air. Handbook of experimental pharmacology. Uranium plutonium transplutonic elements. New York, NY. Springer-Verlag. 1973:241-270.
Sprague GF. Voegtlin C, Hodge HC, editors. Control studies. Pharmacology and toxicology of uranium compounds. New York, NY. McGraw-Hill Book Company, Inc. 1949:525-531.
Squibb KS, Leggett RW, McDiarmid MA. Prediction of renal concentrations of depleted uranium and radiation dose in Gulf War veterans with embedded shrapnel. Health Phys. 2005;89(3):267-273. [pmid: 16096502].
Squibb KS, McDiarmid MA. Depleted uranium exposure and health effects in Gulf War veterans. Philos Trans R Soc Lond B Biol Sci. 2006;361(1468):639-648. [pmid: 16687268].
Squibb KS, Gaitens JM, Engelhardt S, et al. Surveillance for long-term health effects associated with depleted uranium exposure and retained embedded fragments in US veterans. J Occup Environ Med. 2012;54:724-732. [pmid: 22544161].
*. Sram RJ, Binkova B, Dobias L, et al. Monitoring genotoxic exposure in uranium miners. Environ Health Perspect. 1993;99:303-305. [pmid: 8319649].
Stearns DM, Yazzie M, Bradley AS, et al. Uranyl acetate induces hprt mutations and uranium-DNA adducts in Chinese hamster ovary EM9 cells. Mutagenesis. 2005;20(6):417-423. [pmid: 16195314].
Stevens W, Bruenger FW, Atherton DR, et al. The distribution and retention of hexavalent uranium-233 in the Beagle. Radiat Res. 1980;83:109-126. [pmid: 6930687].
Stevenson KA, Hardy EP. Estimate of excess uranium in surface soil surrounding the feed materials production center using a requalified data base. Health Phys. 1993;65(3):283-287. [pmid: 8244697].
Stewart BD, McKlveen JW, Glinski RL. Determination of uranium and radium concentrations in the waters of the Grand Canyon by alpha spectrometry. J Radioanal Nucl Chem. 1988;123:121-132.
Stokinger HE, Baxter RC, Dygert HP, et al. Voegtlin C, Hodge HC, editors. Toxicity following inhalation for 1 and 2 years. Pharmacology and toxicology of uranium compounds. New York, NY. McGraw-Hill. 1953:1370-1776.
Storm HH, Jorgensen HO, Kejs AM, et al. Depleted uranium and cancer in Danish Balkan veterans deployed 1992–2001. Eur J Cancer. 2006;42(14):2355-2358. [pmid: 16857358].
*. Stradling GN, Stather JW, Gray SA, et al. The metabolism of ceramic and non-ceramic forms of uranium dioxide after deposition in the rat lung. Human Toxicol. 1988;7:133-139.
*. Stradling GN, Stather JW, Gray SA, et al. The metabolic behaviour of uranium octoxide bearing residues after their deposition in the rat lung: The implications for occupational exposure. Exp Pathol. 1989;37(1–4):76-82. [pmid: 2637175].
Stradling GN, Gray SA, Moody JC, et al. Efficacy of tiron for enhancing the excretion of uranium from the rat. Hum Exp Toxicol. 1991;10(3):195-198. [pmid: 1678949].
Stradling GN, Smith H, Cooper JR, et al. Factors affecting the abundance of uranium isotopes in body tissues and excreta following the deposition of enriched uranium dioxide in the lungs-The radiological implications. Health Phys. 1984;46:434-438. [pmid: 6693275].
Stradling GN, Stather JW, Gray SA, et al. Metabolism of uranium in the rat after inhalation of two industrial forms of ore concentrate: The implications for occupational exposure. Hum Toxicol. 1987;6:385-394. [pmid: 3679246].
Stuart WI, Adams RB, Smith HE. Solubility and hemolytic activity of uranium trioxide. Environ Res. 1979;18:385-396. [pmid: 41704].
Sullivan MF. Absorption of actinide elements from the gastrointestinal tract of rats, guinea pigs and dogs. Health Phys. 1980a;38:159-171. [pmid: 6246038].
Sullivan MF. Absorption of actinide elements from the gastrointestinal tract of neonatal animals. Health Phys. 1980b;38:173-185. [pmid: 6246039].
Sullivan MF, Gorham LS. Further studies on the absorption of actinide elements from the gastrointestinal tract of neonatal animals. Health Phys. 1982;43(4):509-519. [pmid: 6295981].
Sullivan MF, Ruemmler PS. Absorption of ^233^U, ^237^Np, ^238^Pu, ^241^Am and ^244^Cm from the gastrointestinal tracts of rats fed an iron-deficient diet. Health Phys. 1988;54:311-316. [pmid: 3346162].
Sullivan MF, Ruemmler PS, Ryan JL, et al. Influence of oxidizing or reducing agents on gastrointestinal absorption of uranium, plutonium, americium, curium, and promethium by rats. Health Phys. 1986;50:233-232. [pmid: 3949516].
Swanson SM. Levels of ^236^Ra, ^210^Pb and ^total^U in fish near a Saskatchewan uranium mine and mill. Health Phys. 1983;45(1):67-80. [pmid: 6688247].
Swanson SM. Food chain transfer of U-Series radionuclides in northern Saskatchewan aquatic system. Health Phys. 1985;49:747-770. [pmid: 4066338].
Szabo Z, Zapecza OS. Graves B, editor. Relation between natural radionuclide activities and chemical constituents in ground water in the Newark Basin New Jersey USA. Radon in ground water, radon, radium and other radioactivity in ground water: Hydrogeologic impact and application to indoor airborne contamination. Proc National Water Well Association conference. April 7–9, 1987. Somerset NJ. Chelsea, MI. Lewis Publishers, Inc. 1987:283-308.
Szrom F, Falo GA, Lodde GM, et al. Inhalation and ingestion intakes with associated dose estimates for level II and level III personnel using Capstone study data. Health Phys. 2009;96(3):363-379. [pmid: 19204492].
Tadmor J. Atmospheric release of volatilized species of radioelements from coal-fired plants. Health Phys. 1986;50:270-273. [pmid: 3949518].
Tannenbaum A, Silverstone H, Koziol J. Tannenbaum A, editor. Tracer studies of the distribution and excretion of uranium in mice, rats, and dogs. Toxicology of uranium compounds. New York, NY. McGraw-Hill. 1951:128-181.
Thiebault C, Carriere M, Milgram S, et al. Uranium induces apoptosis and is genotoxic to normal rat kidney (NRK-52E) proximal cells. Toxicol Sci. 2007;98(2):479-487. [pmid: 17522072].
Thind KS. A comparison of ICRP Publication 30 lung model-based predictions with measured bioassay data for airborne natural uranium dioxide exposure. Health Phys. 1987;53:59-66. [pmid: 3597099].
Thomas K, Colborn T. Colborn T, Clement C, editors. Organochlorine endocrine disruptors in human tissue. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ. Princeton Scientific Publishing. 1992:365-394.
Thomas P, Irvine J, Lyster J, et al. Radionuclides and trace metals in Canadian moose near uranium mines: comparison of radiation doses and food chain transfer with cattle and caribou. Health Phys. 2005;88(5):423-438. [pmid: 15824592].
Thun MJ, Baker DB, Steenland K, et al. Renal toxicity in uranium mill workers. Scand J Work Environ Health. 1985;11(2):83-90. [pmid: 3890163].
Ticknor KV. Uranium sorption on geological materials. Radiochimica Acta. 1994;64:229-236.
Tirmarche M, Raphalen A, Allin F, et al. Mortality of a cohort of French uranium miners exposed to relatively low radon concentrations. Br J Cancer. 1993;67(5):1090-1097. [pmid: 8494704].
Tirmarche M, Raphalen A, Chameaud J. Epidemiological study of French uranium miners. Cancer Detect Prev. 1992;16(3):169-172. [pmid: 1458506].
Tissandie E, Gueguen Y, Lobaccaro JM, et al. Effects of depleted uranium after short-term exposure on vitamin D metabolism in rat. Arch Toxicol. 2006;80(8):473-480. [pmid: 16502312].
Tissandie E, Gueguen Y, Lobaccaro JM, et al. In vivo effects of chronic contamination with depleted uranium on vitamin D_3_metabolism in rat. Biochim Biophys Acta. 2007;1770(2):266-272. [pmid: 17118558].
*. Tobias CA. Failla Memorial Lecture. The future of heavy-ion science in biology and medicine. Radiat Res. 1985;103(1):1-33. [pmid: 3906741].
Todorov TI, Xu H, Ejnik JW, et al. Depleted uranium analysis in blood by inductively coupled plasma mass spectrometry. J Anal Atom Spectrom. 2009;24:189-193.
Tomasek L, Rogel A, Tirmarche M, et al. Lung cancer in French and Czech uranium miners: Radon-associated risk at low exposure rates and modifying effects of time since exposure and age at exposure. Radiat Res. 2008;169(2):125-37. [pmid: 18220460].
Toohey RE. Excretion of depleted uranium by Gulf War veterans. Radiat Prot Dosimetry. 2003;105(1–4):171-174. [pmid: 14526951].
Toole J, McKay K, Baxter M. Determination of uranium in marine sediment pore waters by isotope dilution inductively coupled plasma mass spectrometry. Anal Chim Acta. 1991;245:83-88.
Tracy BL, Meyerhof DP. Uranium concentrations in air near a Canadian uranium refinery. Atmos Env. 1987;21:165-172.
*. Tracy BL, Quinn JM, Lahey J, et al. Absorption and retention of uranium from drinking water by rats and rabbits. Health Phys. 1992;62(1):65-73. [pmid: 1727413].
Twiss P, Watling RJ, Delev D. Determination of thorium and uranium in faecal material from occupationally-exposed workers using ICP-MS. Atom Spectrosc. 1994;15(1):36-39.
*. Ubios AM, Braun EM, Cabrini RL. Lethality due to uranium poisoning is prevented by ethane-1-hydroxy-1,1-biphosphonate (EHBP). Health Phys. 1994;66(5):540-544. [pmid: 8175360].
*. Ubios AM, Guglielmotti MB, Steimetz T, et al. Uranium inhibits bone formation in physiologic Alveolar bone modeling and remodeling. Environ Res. 1991;54:17-23. [pmid: 2004634].
UDOH. Cancer incidence study. A follow-up study of cancer incidence in Monticello City, Utah-1973–2004. Monticello City, San Juan County, Utah. Utah Department of Health. 2007. http://health.utah.gov/search/index.html?cx=015797132617248936942%3Afl9rxjqr2j4&cof=FORID%3A10&ie=UTF-8&q=Cancer+incidence+study.++A+follow-up+study+of+cancer+incidence+in+Monticello+City%2C+Utah-1973-2004.++Monticello+City%2C+San+Juan+County%2C+Utah. July 5, 2012.
UNSCEAR. United Nations Scientific Committee on the Effects of Atomic Radiation. Sources and effects of ionizing radiation. United Nations Document E.77.IX.1. New York, NY. 1977.
UNSCEAR. Ionizing radiation: Sources and biological effects. 1982 Report to the General Assembly, with annexes. United Nations Scientific Committee on the Effects of Atomic Radiation. 1982.
UNSCEAR. Genetic and somatic effects of ionizing radiation. New York, NY. United Nations Scientific Committee on the Effects of Atomic Radiation. 1986.
UNSCEAR. Sources, effects and risks of ionizing radiation. Report to the General Assembly, with annexes. New York, NY. United Nations Publications. United Nations Scientific Committee on the Effects of Atomic Radiation. 1988.
Uranium Institute. The nuclear fuel cycle. 1996. http://www.uilondon.org/nfc.htm. November 4, 1999.
USDOC. U.S. General imports and imports for consumption. Schedule A, commodity by country. Washington, DC. Bureau of Census, U.S. Department of Commerce. 1984:2-61-2-62.
USDOC. U.S. General imports and imports for consumption. Schedule A, commodity by country. Washington, DC. Bureau of Census, U.S. Department of Commerce. 1988:2-70-2-71. 2-149.
USDOC. National Trade Data Bank. U.S. Department of Commerce, Bureau of the Census. 1995.
USDOC. U.S. Merchandise import and export trade. Retrieved from National Trade Data Bank. United States Department of Commerce, Bureau of Census. 1997.
USDOC. National Trade Data Bank. U.S. Department of Commerce, Bureau of the Census. 1999.
USGS. History of the National Uranium Resource Evaluation Hydrogeochemical and Stream Sediment Reconnaissance Program. U.S. Geological Survey. 2006. http://pubs.usgs.gov/of/1997/ofr-97-0492/nurehist.htm. January 26, 2011.
USGS. Uranium in surface waters and sediments affected by historical mining in the Denver West 1:100,000 quadrangle, Colorado. Reston, VA. U.S. Geological Survey. 2008. Scientific Investigations Report 2007-5246. http://pubs.usgs.gov/sir/2007/5246/508ZielinskiSIR07_5246.pdf. January 26, 2011.
USGS. Groundwater restoration at uranium in-situ recovery mines, South Texas Coastal Plain. Reston, VA. U.S. Geological Survey. 2009. Open-File Report 2009-1143. http://pubs.usgs.gov/of/2009/1143/pdf/OF09-1143.pdf. January 26, 2011.
USGS. Volcanogenic uranium deposits: Geology, geochemical processes, and criteria for resource assessment. Reston, VA. U.S. Geological Survey. 2010a. Open-File Report 2010-1001 http://pubs.usgs.gov/of/2010/1001/pdf/OF10-1001.pdf. January 26, 2011.
USGS. Hydrological, geological, and biological site characterization of breccia pipe uranium deposits in Northern Arizona. Reston, VA. U.S. Geological Survey. 2010b. Scientific Investigations Report 2010–5025. http://pubs.usgs.gov/sir/2010/5025/pdf/sir2010-5025.pdf. January 26, 2011.
USGS. Geology, geochemistry, and geophysics of the Fry Canyon Uranium/Copper Project Site, Southeastern Utah—Indications of contaminant migration. Reston, VA. U.S. Geological Survey. 2010c. Scientific Investigations Report 2010-5075. http://pubs.usgs.gov/sir/2010/5075/pdf/SIR10-5075.pdf. January 26, 2011.
USNRC. Assessment of the public health impact from the accidental release of UP6 at the Sequoyah Fuels Corporation Facility at Gore, Oklahoma. Washington, DC. U.S. Nuclear Regulatory Commission. 1986. NUREG-1189-V1.
USNRC. Evaluation of health effects in Sequoyah Fuels Corporation workers from accidental exposure to uranium hexafluoride. Washington, DC. U.S. Nuclear Regulatory Commission. 1990. NUREG/CR-5566 PNL-7328.
USNRC. United States Nuclear Regulatory Commission. Standards for protection against radiation, general provisions, scope. Code of Federal Regulations. 10 CFR 20.1002. 1999.
USNRC. Radioactive waste: Production, storage, disposal. U.S. Nuclear Regulatory Commission. 2002. http://www.nrc.gov/reading-rm/doc-collections/nuregs/brochures/br0216/r2/br0216r2.pdf. January 26, 2011.
USNRC. Backgrounder. Uranium mill tailings. U.S. Nuclear Regulatory Commission. 2006. www.nrc.gov/reading-rm/doc-collections/fact-sheets/mill-tailings.pdf. April 28, 2011.
USNRC. Backgrounder. Radioactive waste. U.S. Nuclear Regulatory Commission. 2007. http://www.nrc.gov/reading-rm/doc-collections/fact-sheets/radwaste.pdf. January 26, 2011.
USNRC. Appendix B to part 20—Annual limits on intake (ALIs) and derived air concentrations (DACs) of radionuclides for occupational exposure; effluent concentrations; concentrations for release to sewerage. U.S. Nuclear Regulatory Commission. 2010a. Code of Federal Regulations 10 CFR 20, Appendix B http://edocket.access.gpo.gov/cfr_2010/janqtr/pdf/10cfr20AppB.pdf. January 27, 2011.
USNRC. Appendix G to part 20—Requirements for transfers of low-level radioactive waste intended for disposal at licensed land disposal facilities and manifests. U.S. Nuclear Regulatory Commission. 2010b. Code of Federal Regulations 10 CFR 20, Appendix G http://edocket.access.gpo.gov/cfr_2010/janqtr/pdf/10cfr20AppG.pdf. January 27, 2011.
USNRC. Definitions. U.S. Nuclear Regulatory Commission. 2010c. Code of Federal Regulations 10 CFR 20.1003 http://edocket.access.gpo.gov/cfr_2010/janqtr/pdf/10cfr20.1003.pdf. January 27, 2011.
USNRC. Dose equivalent to an embryo/fetus. U.S. Nuclear Regulatory Commission. 2010d. Code of Federal Regulations 10 CFR 20.1208 http://edocket.access.gpo.gov/cfr_2010/janqtr/pdf/10cfr20.1208.pdf. January 27, 2011.
USNRC. Dose limits for individual members of the public. U.S. Nuclear Regulatory Commission. 2010e. Code of Federal Regulations 10 CFR 20.1301 http://edocket.access.gpo.gov/cfr_2010/janqtr/pdf/10cfr20.1301.pdf. January 27, 2011.
USNRC. Occupational dose limits for minors. U.S. Nuclear Regulatory Commission. 2010f. Code of Federal Regulations 10 CFR 20.1207 http://edocket.access.gpo.gov/cfr_2010/janqtr/pdf/10cfr20.1207.pdf. January 27, 2011.
USNRC. Planned special exposures. U.S. Nuclear Regulatory Commission. 2010g. Code of Federal Regulations 10 CFR 20.1206 http://edocket.access.gpo.gov/cfr_2010/janqtr/pdf/10cfr20.1206.pdf. January 27, 2011.
USNRC. Subpart C—Occupational dose limits. U.S. Nuclear Regulatory Commission. 2010h. Code of Federal Regulations 10 CFR 20.1201, Subpart C http://edocket.access.gpo.gov/cfr_2010/janqtr/pdf/10cfr20.1201.pdf. January 27, 2011.
USNRC. Radiological criteria for license termination. U.S. Nuclear Regulatory Commission. 2010i. Code of Federal Regulations 10 CFR 20 Subpart E. http://www.gpo.gov/fdsys/pkg/CFR-2010-title10-vol1/pdf/CFR-2010-title10-vol1-part20-subpartE.pdf. February 2, 2011.
USNRC. Low-level waste disposal statistics. U.S. Nuclear Regulatory Commission. 2011. http://www.nrc.gov/waste/llw-disposal/licensing/statistics.html. April 28, 2011.
USNRC. Annual limits on intake (ALIs) and derived air concentrations (DACs) of radionuclides for occupational exposure; effluent concentrations; concentrations for release to sewerage. Nuclear Regulatory Commission. 2012a. Code of Federal Regulations 10 CFR 20, Appendix B http://www.gpo.gov/fdsys. June 15, 2012.
USNRC. Occupational dose limits. U.S. Nuclear Regulatory Commission. 2012b. Code of Federal Regulations 10 CFR 20, Subpart C http://www.gpo.gov/fdsys. June 15, 2012.
USTUR. USTUR database. U.S. Transuranium and Uranium Registry. 1999. http://www.tricity.wsu.edu/~ustur/database.html. February 16, 1999.
USTUR. United States transuranium and uranium registries radiochemical analysis procedures manual. Pullman, WA. Washington State University, Nuclear Radiation Center. 2011. Manual # 01.
Valdés M. Estimating the lung burden from exposure to aerosols of depleted uranium. Radiat Prot Dosimetry. 2009;134(1):23-29. [pmid: 19346527].
van den Berg CMG, Nimmo M. Direct determination of uranium in water by cathodic stripping voltammetry. Anal Chem. 1987;59:924-928.
Van Netten C, Morley DR. Uptake of uranium molybdenum copper and selenium by the radish from uranium rich soils. Arch Env Health. 1983;38:172-175. [pmid: 6870355].
Veselsky JC, Kwiecinska B, Wehrstein E, et al. Determination of uranium in minerals by laser fluorimetry. Analyst. 1988;113:451-455.
Veska E, Eaton RS. Abandoned Rayrock uranium mill tailings in the Northwest Territories: environmental conditions and radiological impact. Health Phys. 1991;60(3):399-409. [pmid: 1995512].
Vich Z, Kriklava J. Erythrocytes of uranium miners: The red blood picture. Br J Ind Med. 1970;27:83-85. [pmid: 5418924].
Vidic A, Ilić Z, Deljkič D, et al. Exposure of workers in Tusnica coal mine. Radiat Prot Dosimetry. 2011;144:672-674. [pmid: 20959336].
Vieira I, Sonnier M, Cresteil T. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem. 1996;238(2):476-483. [pmid: 8681961].
Waite DT, Joshi SR, Sommerstad H. The effect of uranium mine tailings on radionuclide concentrations in Langley Bay, Saskatchewan Canada. Arch Env Contam Tox. 1988;17:373-380.
Walinder G. Metabolism and sites of effects of uranium after incorporation along different routes in mice, rabbits and piglets. Radiat Prot Dosimetry. 1989;26(1/4):89-95.
Wang J, Wang J, Lu J, et al. Adsorptive stripping voltammetry of trace uranium critical comparison of various chelating agents. Anal Chim Acta. 1994;292:91-97.
Waxweiler RJ, Archer VE, Roscoe RJ. Mortality patterns among a retrospective cohort of uranium mill workers. Epidemiology applied to health physics. Proceedings of the sixteenth midyear topical meeting of the Health Physics society. January 9–13, 1983. Albuquerque, New Mexico. Albuquerque, NM. U.S. Department of Energy. Health Physics Society. 1983:428-435. DE83014383.
Waxweiler R, Roscoe R, Archer V, et al. Gomez M, editor. Mortality follow-up through 1977 of the white underground uranium miners cohort examined by the United States Public Health Service. International conference: Radiation hazards in mining. New York, NY. Society of Mining Engineers of American Institute of Mining, Metallurgical, and Petroleum Engineers, Inc. 1981a:823-830.
Waxweiler RJ, Roscoe RJ, Archer VE. Wiese WH, editor. Secondary sex ratio of first-born offspring of U.S. uranium miners. Birth effects in the Four Corners area. Transcript of Meeting Held February 27, 1981. Albuquerque, NM. University of New Mexico School of Medicine. 1981b:37-50.
Wedeen RP. Renal diseases of occupational origin. Occup Med. 1992;7(3):449-463. [pmid: 1496429].
Weigel F. Grayson M, editor. Uranium and uranium compounds. Kirk-Othmer encyclopedia of chemical technology. 3rd ed. New York, NY. John Wiley & Sons. 1983;Vol. 23:502-547.
Weissman SH, Carpenter RL, Newton GJ. Respirable aerosols from fluidized bed coal combustion: 3. Elemental composition of fly ash. Environ Sci Technol. 1983;17:65-71. [pmid: 22295955].
Welford GA, Baird R. Uranium levels in human diet and biological materials. Health Phys. 1967;13:1321-1324. [pmid: 6069847].
Welford GA, Morse RS, Alercio JS. Urinary uranium levels in non-exposed individuals. Am Ind Hyg Assoc J. 1960;21:68-70. [pmid: 13843837].
Wersin P, Hochella MF, Persson P, et al. Interaction between aqueous uranium (VI) and sulfide minerals: Spectroscopic evidence for sorption and reduction. Geochim Cosmochim Acta. 1994;58(13):2829-2843.
Wessman RA. Moore RH, editor. An overview of the radiochemical analysis of uranium. Biokinetics and analysis of uranium in man. Proceedings of a colloquium held at Richland, Washington. August 8–9, 1984. Washington, DC. United States Uranium Registry. U.S. Department of Energy. 1984:J-1-J-57. USUR-05 HEHF-47.
West CM, Scott LM. Uranium cases showing long chest burden retention an updating. Health Phys. 1969;17:781-791. [pmid: 5352748].
West CM, Scott LM, Schultz NB. 16 Years of uranium personnel monitoring experience--in retrospect. Health Phys. 1979;36:665-669. [pmid: 468537].
West JR, Smith HW, Chasis H. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr. 1948;32:10-18. [pmid: 18920567].
Whittemore AS, McMillan A. Lung cancer mortality among USA uranium miners: A reappraisal. J Natl Cancer Inst. 1983;71:489-499. [pmid: 6577225].
WHO. Uranium in drinking-water. Summary statement. Extract from Chapter 12 - Chemical fact sheets of WHO guidelines for drinking-water quality. 3rd edition. World Health Organization. 2003. 2004. WHO/SDE/WSH/03.04/118. http://www.who.int/water_sanitation_health/dwq/chemicals/uraniumsum.pdf. January 28, 2011.
WHO. Uranium in drinking-water. World Health Organization. 2004. WHO/SDE/WSH/03.04/118. http://www.who.int/water_sanitation_health/dwq/chemicals/uraniumsum.pdf. January 28, 2011.
WHO. Guidelines for drinking-water quality. 3rd ed. Geneva, Switzerland. World Health Organization. 2008. http://www.who.int/entity/water_sanitation_health/dwq/fulltext.pdf. April 25, 2012.
WHO. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland. World Health Organization. 2010. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
Widdowson EM, Dickerson JWT. Comar CL, Bronner F, editors. Chemical composition of the body. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York, NY. Academic Press. 1964:1-247.
Wiegand J, Yamamoto G, Gaston W. Graves B, editor. Elevated levels of radioactivity in water wells in Los Angeles and Orange counties, California. Radon, radium, and other radioactivity in ground water. Hydrogeologic impact and application to indoor airborne contamination. Proceedings of the NWWA Conference. April 7–9, 1987. Lewis Publishers. Association of Ground Water Scientists and Engineers. U.S. Environmental Protection Agency. 1987:71-82.
Wiese WH, Skipper BJ. Survey of reproductive outcomes in uranium and potash mine workers: Results of first analysis. Ann Am Conf Gov Ind Hyg. 1986;14:187-192.
*. Willis DL. Pharmacokinetics and chemical toxicity of uranium-238 in drinking water. Letter from David L. Willis to Lyman Condie. Submitted to the U.S. Environmental Protection Agency. 1985.
*. Wise SS, Thompson WD, Aboueissa AM, et al. Particulate depleted uranium is cytotoxic and clastogenic to human lung cells. Chem Res Toxicol. 2007;20(5):815-820. [pmid: 17432880].
WNA. Uranium, from mine to mill. WNA pocket guide. World Nuclear Association. 2010. http://www.world-nuclear.org/uploadedFiles/Pocket%20Guide%202009%20Uranium.pdf. March 23, 2011.
WNA. WNA Public Information Service - Full List of Pages. World Nuclear Association. 2011. http://www.world-nuclear.org/infomap.aspx. January 26, 2011.
Woodis TC, Trimm JR, Holmes JH, et al. Determination of uranium in phosphate rock and wet-process phosphoric acid by argon-plasma emission spectrometry. J Assoc Off Anal Chem. 1980;63:208-210.
Woodward A, Roder D, McMichael AJ, et al. Radon daughter exposures at the Radium Hill uranium mine and lung cancer rates among former workers, 1982–1987. Cancer Causes Control. 1991;2(4):213-220. [pmid: 1873450].
Wrenn ME, Bertelli L, Durbin PW, et al. A comprehensive metabolic model for uranium metabolism and dosimetry based on human and animal data. Radiat Prot Dosimetry. 1994;53(1–4):255-258.
Wrenn ME, Durbin PW, Howard B. Metabolism of ingested uranium and radium. Health Phys. 1985;48:601-633. [pmid: 3988524].
Wrenn ME, Durbin PW, Willis DL, et al. The potential toxicity of uranium in water. Am Water Works Assoc J. 1987;79:177-184.
Wrenn ME, Singh NP, Ruth H, et al. Gastrointestinal absorption of soluble uranium from drinking water by man. Radiat Prot Dosim. 1989;26:119-122.
Wrenn ME, Singh NP, Saccomanno G. Uranium and thorium isotopes and their state of equilibria in lungs from uranium miners. Health Phys. Suppl 1. 1983;44:385-389. [pmid: 6862915].
Xuan XZ, Lubin JH, Li JY, et al. A cohort study in southern China of tin miners exposed to radon and radon decay products. Health Phys. 1993;64(2):120-131. [pmid: 8449705].
Yamamoto T, Masuda K, Nukada K. Studies on environmental contamination by uranium. 6. Uranium in total diet and human urine from nonoccupationally exposed persons in Okayama Prefecture (1969–1971). J Radiation Res. 1971;13(1):5.
Yan M, Zhong G, Gao L, et al. The effects of depleted uranium on 1α-hydroxylase in kidney of rats. Hum Exp Toxicol. 2010. [epub ahead of print].
Yang IC, Edwards KW. Barney GS, Navratil JD, Schulz W, editors. Releases of radium and uranium into Ralston Creek and Reservoir Colorado, from uranium mining. ACS Symposium Series 246. Geochemical behavior of disposed radioactive waste. Washington, DC. American Chemical Society. 1984:271-286.
Yazzie M, Gamble SL, Civitello ER, et al. Uranyl acetate causes DNA single strand breaks in vitro in the presence of ascorbate (vitamin C). Chem Res Toxicol. 2003;16(4):524-530. [pmid: 12703969].
Yiin JH, Anderson JL, Daniels RD, et al. A nested case-control study of multiple myeloma risk and uranium exposure among workers at the Oak Ridge Gaseous Diffusion Plant. Radiat Res. 2009;171(6):637-645. [pmid: 19580470].
*. Yu RC, Sherwood RJ. The relationships between urinary elimination, airborne concentration, and radioactive hand contamination for workers exposed to uranium. AIHA. 1996;57(7):615-620.
*. Zalups RK. An evaluation of Tiron (sodium 4,5-dihydroxybenzene-1,3-disulfonate) as a rescue agent for the nephropathy induced by uranyl fluoride (UO_2_F_2_) in rats. Res Commun Chem Pathol Pharmacol. 1991;72(1):125-128. [pmid: 2052745].
Zhu G, Tan M, Li Y, et al. Accumulation and distribution of uranium in rats after implantation with depleted uranium fragments. J Radiat Res (Tokyo). 2009a;50(3):183-192. [pmid: 19531921].
Zhu G, Xiang X, Chen X, et al. Renal dysfunction induced by long-term exposure to depleted uranium in rats. Arch Toxicol. 2009b;83(1):37-46. [pmid: 18594794].
Ziegler EE, Edwards BB, Jensen RL, et al. Absorption and retention of lead by infants. Pediatr Res. 1978;12(1):29-34. [pmid: 643372].
Zielinski RA, McKown DM. Determination of uranium concentration in water by liquid anion-exchange-delayed-neutron analysis. J Radioanal Nucl Chem. 1984;84:207-212.