# GLOSSARY

Some terms in this glossary are generic and may not be used in this profile.

Absorbed Dose, Chemical: The amount of a substance that is either absorbed into the body or placed in contact with the skin. For oral or inhalation routes, this is normally the product of the intake quantity and the uptake fraction divided by the body weight and, if appropriate, the time, expressed as mg/kg for a single intake or mg/kg/day for multiple intakes. For dermal exposure, this is the amount of material applied to the skin, and is normally divided by the body mass and expressed as mg/kg.
Absorbed Dose, Radiation: The mean energy imparted to the irradiated medium, per unit mass, by ionizing radiation. Units: rad (rad), gray (Gy).
Absorbed Fraction: A term used in internal dosimetry. It is that fraction of the photon energy (emitted within a specified volume of material) which is absorbed by the volume. The absorbed fraction depends on the source distribution, the photon energy, and the size, shape and composition of the volume.
Absorption: The process by which a chemical penetrates the exchange boundaries of an organism after contact, or the process by which radiation imparts some or all of its energy to any material through which it passes.
Absorption Coefficient: Fractional absorption of the energy of an unscattered beam of x- or gamma-radiation per unit thickness (linear absorption coefficient), per unit mass (mass absorption coefficient), or per atom (atomic absorption coefficient) of absorber, due to transfer of energy to the absorber. The total absorption coefficient is the sum of individual energy absorption processes (see Compton Effect, Photoelectric Effect, and Pair Production).
Absorption Coefficient, Linear: A factor expressing the fraction of a beam of x- or gamma radiation absorbed in a unit thickness of material. In the expression I=I_o_e^−μx^, I_o_ is the initial intensity, I the intensity of the beam after passage through a thickness of the material x, and μ is the linear absorption coefficient.
Absorption Coefficient, Mass: The linear absorption coefficient per cm divided by the density of the absorber in grams per cubic centimeter. It is frequently expressed as μ/ρ, where μ is the linear absorption coefficient and ρ the absorber density.
Absorption Ratio, Differential: Ratio of concentration of a nuclide in a given organ or tissue to the concentration that would be obtained if the same administered quantity of this nuclide were uniformly distributed throughout the body.
Activation: The process of making a material radioactive by bombardment with neutrons or protons.
Activity: The number of radioactive nuclear transformations occurring in a material per unit time (see Curie, Becquerel). The term for activity per unit mass is specific activity.
Activity Median Aerodynamic Diameter (AMAD): The diameter of a unit-density sphere with the same terminal settling velocity in air as that of the aerosol particle whose activity is the median for the entire size distribution of the aerosol.
Acute Exposure, Chemical: Exposure to a chemical for a duration of 14 days or less, as specified in the Toxicological Profiles.
Acute Exposure, Radiation: The absorption of a relatively large amount of radiation (or intake of a radioactive material) over a short period of time.
Acute Radiation Syndrome: The symptoms which taken together characterize a person suffering from the effects of intense radiation. The effects occur within hours or days.
Ad libitum: Available in excess and freely accessible.
Adsorption Coefficient (K_oc_): The ratio of the amount of a chemical adsorbed per unit surface area or per unit weight of organic carbon of a specific particle size in the soil or sediment to the concentration of the chemical in solution at equilibrium.
Adsorption Ratio (K_d_): See Distribution Coefficient
Alpha Particle: A positively charged particle ejected spontaneously from the nuclei of some radioactive elements. It is identical to a helium nucleus, i.e., 2 neutrons and two protons, with a mass number of 4 and an electrostatic charge of +2.
Alpha Track: The track of ionized atoms (pattern of ionization) left in a medium by an alpha particle that has traveled through the medium.
Annihilation (Positron-Electron): An interaction between a positive and a negative electron in which they both disappear; their rest mass, being converted into electromagnetic radiation (called annihilation radiation) with two 0.51 MeV gamma photons emitted at an angle of 180° to each other.
Annual Limit on Intake (ALI): The derived limit for the amount of radioactive material taken into the body of an adult worker by inhalation or ingestion in a year. It is the smaller value of intake of a given radionuclide in a year by the reference man that would result in a committed effective dose equivalent of 5 rem or a committed dose equivalent of 50 rem to any organ or tissue.
Atom: The smallest particle of an element that cannot be divided or broken up by chemical means. It consists of a central core called the nucleus, which contains protons and neutrons and an outer shell of electrons.
Atomic Mass (u): The mass of a neutral atom of a nuclide, usually expressed in terms of "atomic mass units." The "atomic mass unit" is one-twelfth the mass of one neutral atom of carbon-12; equivalent to 1.6604×10^−24^ g.
Atomic Mass Number: See Mass Number.
Atomic Number: The number of protons in the nucleus of an atom. The "effective atomic number" is calculated from the composition and atomic numbers of a compound or mixture. An element of this atomic number would interact with photons in the same way as the compound or mixture. (Symbol: Z).
Atomic Weight: The weighted mean of the masses of the neutral isotopes of an element expressed in atomic mass units.
Attenuation: A process by which a beam from a source of radiation is reduced in intensity by absorption and scattering when passing through some material.
Attenuation Coefficient: The fractional reduction in the intensity of a beam of radiation as it passes through an absorbing medium. It may be expressed as reduction per unit distance, per unit mass thickness, or per atom, and is called the linear, mass, or atomic attenuation coefficient, respectively.
Auger Effect: The emission of an electron from the extranuclear portion of an excited atom when the atom undergoes a transition to a less excited state.
Background Radiation: The amount of radiation to which a member of the general population is exposed from natural sources, such as terrestrial radiation from naturally occurring radionuclides in the soil, cosmic radiation originating from outer space, and naturally occurring radionuclides deposited in the human body.
Becquerel (Bq): International System of Units unit of activity and equals that quantity of radioactive material in which one transformation (disintegration) occurs per second (see Units).
  - Terabecquerel (TBq)—One trillion becquerel.
  - Gigabecquerel (GBq)—One billion becquerel.
  - Megabecquerel (MBq)—One million becquerel.
  - Kilobecquerel (kBq)—One thousand becquerel.
  - Millibecquerel (mBq)—One-thousandth of a becquerel.
  - Microbecquerel (μBq)—One-millionth of a becquerel.
Benchmark Dose (BMD): Usually defined as the lower confidence limit on the dose that produces a specified magnitude of changes in a specified adverse response. For example, a BMD10 would be the dose at the 95% lower confidence limit on a 10% response, and the benchmark response (BMR) would be 10%. The BMD is determined by modeling the dose response curve in the region of the dose response relationship where biologically observable data are feasible.
Benchmark Dose Model: A statistical dose-response model applied to either experimental toxicological or epidemiological data to calculate a BMD.
Beta Particle: An electron that is emitted from the nucleus of an atom during one type of radioactive transformation. A beta particle has a mass and charge equal in magnitude to that of the electron. The charge may be either +1 or −1. Beta particles with +1 charges are called positrons (symbolized β^+^), and beta particles with −1 charges are called negatrons (symbolized β^−^).
Bioconcentration Factor (BCF): The quotient of the concentration of a chemical in aquatic organisms at a specific time or during a discrete time period of exposure divided by the concentration in the surrounding water at the same time or during the same period.
Biologic Effectiveness of Radiation: See Relative Biological Effectiveness.
Biological Half-time: The time required for a biological system, such as that of a human, to eliminate by natural process half of the amount of a substance (such as a chemical substance, either stable or radioactive) that has entered it.
Biomagnification: The progressive increase in the concentration of a bioaccumulated chemical in organisms as that chemical is passed from the bottom to the top of the food web.
Biomarkers: Broadly defined as indicators signaling events in biologic systems or samples. They have been classified as markers of exposure, markers of effect, and markers of susceptibility.
Body Burden, Chemical: The total amount of a chemical found in an animal or human body.
Body Burden, Radioactivity: The amount of radioactive material found in an animal or human body.
Bone Seeker: Any compound or ion which migrates in the body and preferentially deposits into bone.
Branching: The occurrence of two or more modes by which a radionuclide can undergo radioactive decay. For example, ^214^Bi can undergo alpha or beta minus decay, ^64^Cu can undergo beta minus, beta plus, or electron capture decay. An individual atom of a nuclide exhibiting branching disintegrates by one mode only. The fraction disintegrating by a particular mode is the "branching fraction" for that mode. The "branching ratio" is the ratio of two specified branching fractions (also called multiple disintegration).
Bremsstrahlung: X rays that are produced when a charged particle accelerates (speeds up, slows down, or changes direction) in the strong field of a nucleus.
Buildup Factor: The ratio of the radiation intensity, including both primary and scattered radiation, to the intensity of the primary (unscattered) radiation.
Cancer Effect Level (CEL): The lowest dose of chemical or radiation in a study, or group of studies, that produces significant increases in the incidence of cancer (or tumors) between the exposed population and its appropriate control.
Capture, Electron: A mode of radioactive decay involving the capture of an orbital electron by its nucleus. Capture from a particular electron shell, e.g., K or L shells, is designated as "K-electron capture" or "L-electron capture."
Capture, K-Electron: Electron capture from the K shell by the nucleus of the atom. Also loosely used to designate any orbital electron capture process.
Carcinogen: A chemical or radiation that is capable of inducing cancer.
Carcinoma: Malignant neoplasm composed of epithelial cells, regardless of their derivation.
Case-Control Study: A type of epidemiological study which examines the relationship between a particular outcome (disease or condition) and a variety of potential causative agents (such as toxic chemicals). In a case-controlled study, a group of people with a specified and well-defined outcome is identified and compared to a similar group of people without outcome.
Case Report: Describes a single individual with a particular disease or exposure. These may suggest some potential topics for scientific research but are not actual research studies.
Case Series: Describes the experience of a small number of individuals with the same disease or exposure. These may suggest potential topics for scientific research, but are not actual research studies.
Cataract: A clouding of the crystalline lens of the eye which obstructs the passage of light.
Ceiling Value: A concentration of a substance that should not be exceeded, even temporarily.
Charged Particle: A nuclear particle, atom, or molecule carrying a positive or negative charge.
Chronic Exposure: A long-term, continuous exposure to a chemical or radioactive material. For example, exposure to a chemical for 365 days or more, as specified in the Toxicological Profiles.
Cohort Study: A type of epidemiological study of a specific group or groups of people who have had a common insult (e.g., exposure to an agent suspected of causing disease or a common disease) and are followed forward from exposure to outcome. At least one exposed group is compared to one unexposed group.
Collective Dose: The sum of the individual doses received in a given period of time by a specified population from exposure to a specified source of radiation. Collective dose is expressed in units such as man-rem and person-sievert.
Compton Effect: An attenuation process observed for x- or gamma radiation in which an incident photon interacts with an orbital electron of an atom to produce a recoil electron and a scattered photon whose energy is less than the incident photon.
Containment: The confinement of a chemical or radioactive substance in such a way that it is prevented from being dispersed from its container or into the environment, or is released only at a specified rate.
Contamination: Deposition of a stable or radioactive substance in any place where it is not desired.
Cosmic Rays: High-energy particulate and electromagnetic radiations that originate outside the earth's atmosphere and interact with the atmosphere to produce a shower of secondary cosmic rays.
Count (Radiation Measurements): The external indication of a radiation-measuring device designed to enumerate ionizing events. It refers to a single detected event. The term “count rate” refers to the total number registered in a given period of time. The term is sometimes erroneously used to designate a disintegration, ionizing event, or voltage pulse.
Counter, Gas-flow Proportional (GPC): An instrument for detecting beta particle radiation. Beta particles are detected by ionization of the counter gas which results in an electrical impulse at an anode wire.
Counter, Geiger-Mueller (GM counter): Highly sensitive, gas-filled radiation-measuring device that detects (counts) individual photons or particulate radiation.
Counter, Scintillation: The combination of a crystal or phosphor, photomultiplier tube, and associated circuits for counting light emissions produced in the phosphors by ionizing radiation. Scintillation counters generally are more sensitive than GM counters for gamma radiation.
Counting, Cerenkov: Relatively energetic β-particles pass through a transparent medium of high refractive index and a highly-directional, bluish-white light ("Cerenkov" light) is emitted. This light is detected using liquid scintillation counting equipment.
Cross-sectional Study: A type of epidemiological study of a group or groups which examines the relationship between exposure and outcome to a chemical or to chemicals at one point in time.
Curie (Ci): A unit of radioactivity. One curie equals that quantity of radioactive material in which there are 3.7×10^10^ nuclear transformations per second. The activity of 1 gram of radium is approximately 1 Ci.
  - Attocurie (aCi)—One-thousandth of a femtocurie (3.7×10^−8^ disintegrations per second).
  - Femtocurie (fCi)—One-billionth of a microcurie (3.7×10^−5^ disintegrations per second).
  - Megacurie (MCi)—One million curies (3.7×10^16^ disintegrations per second).
  - Microcurie (μCi)—One-millionth of a curie (3.7×10^4^ disintegrations per second).
  - Millicurie (mCi)—One-thousandth of a curie (3.7×10^7^ disintegrations per second).
  - Nanocurie (nCi)—One-billionth of a curie (3.7×10^1^ disintegrations per second).
  - Picocurie (pCi)—One-millionth of a microcurie (3.7×10^−2^ disintegrations per second).
Data Needs: Substance-specific informational needs that if met would reduce the uncertainties of human health assessment.
Daughter Products: See Progeny and Decay Product
Decay Chain or Decay Series: A sequence of radioactive decays (transformations) beginning with one nucleus. The initial nucleus, the parent, decays into a daughter or progeny nucleus that differs from the first by whatever particles were emitted during the decay. If further decays take place, the subsequent nuclei are also usually called daughters or progeny. Sometimes, to distinguish the sequence, the daughter of the first daughter is called the granddaughter, etc.
Decay Constant (λ): The fraction of the number of atoms of a radioactive nuclide which decay in unit time (see Disintegration Constant).
Decay Product, Daughter Product, Progeny: A new nuclide formed as a result of radioactive decay. A nuclide resulting from the radioactive transformation of a radionuclide, formed either directly or as the result of successive transformations in a radioactive series. A decay product (daughter product or progeny) may be either radioactive or stable.
Decay, Radioactive: Transformation of the nucleus of an unstable nuclide by spontaneous emission of radiation, such as charged particles and/or photons (see Disintegration).
Delta Ray: An electron removed from an atom of a medium that is irradiated, or through which radiation passes, during the process of ionization (also called secondary electron). Delta rays cause a track of ionizations along their path.
Derived Air Concentration (DAC): The concentration of radioactive material in air that, if breathed by the reference man for a working year of 2000 hours under conditions of light work (at a rate of 1.2 liters of air per hour), would result in an intake of one ALI (see Annual Limit on Intake).
Deterministic Effect: A health effect, the severity of which varies with the dose and for which a threshold is believed to exist (also called a non-stochastic effect).
Developmental Toxicity: The occurrence of adverse effects on the developing organism that may result from exposure to a chemical or radiation prior to conception (either parent), during prenatal development, or postnatally to the time of sexual maturation. Adverse developmental effects may be detected at any point in the life span of the organism.
Disintegration Constant: Synonymous with decay constant. The fraction of the number of atoms of a radioactive material that decays per unit time (see Decay Constant.)
Disintegration, Nuclear: A spontaneous nuclear transformation (radioactivity) characterized by the emission of energy and mass from the nucleus. When large numbers of nuclei are involved, the process is characterized by a definite half-life (see Transformation, Nuclear).
Distribution Coefficient (Kd): Describes the distribution of a chemical between the solid and aqueous phase at thermodynamic equilibrium, is given as follows:
  K_d_ = ([ C ]_s_)/([ C ]_s_) , Units = ( L solution ) / ( kg solid ) ,
  where [C]_s_ is the concentration of the chemical associated with the solid phase in units of (mg)/(kg solid), and [C]_w_ is the concentration of the chemical in the aqueous phase in units of (mg)/(L solution). As the magnitude of K_d_ decreases, the potential mobility of the chemical to groundwater systems increases and vice versa.
Dose: A general term denoting the quantity of a substance, radiation, or energy absorbed. For special purposes it must be appropriately qualified. If unqualified, it refers to radiation absorbed dose.
  - Absorbed Dose—The energy imparted to matter by ionizing radiation per unit mass of irradiated material at the place of interest. The unit of absorbed dose is the rad. One rad equals 100 ergs per gram. In SI units, the absorbed dose is the gray which is 1 J/kg (see Rad).
  - Cumulative Dose (Radiation)—The total dose resulting from repeated or continuous exposures to radiation.
Dose Assessment: An estimate of the radiation dose to an individual or a population group usually by means of predictive modeling techniques, sometimes supplemented by the results of measurement.
Dose Equivalent (DE): A quantity used in radiation safety practice to account for the relative biological effectiveness of the several types of radiation. It expresses all radiations on a common scale for calculating the effective absorbed dose. The NRC defines it as the product of the absorbed dose, the quality factor, and all other modifying factors at the location of interest. ICRP has changed its definition to be the product of the absorbed dose and the radiation weighting factor. (The unit of dose equivalent is the rem. In SI units, the dose equivalent is the sievert, which equals 100 rem.)
Dose, Fractionation: A method of administering therapeutic radiation in which relatively small doses are given daily or at longer intervals.
Dose, Protraction: A method of administering therapeutic radiation by delivering it continuously over a relatively long period at a low Dose Rate.
Dose, Radiation: The amount of energy imparted to matter by ionizing radiation per unit mass of the matter, usually expressed as the unit rad, or in SI units, the gray. 100 rad=1 gray (Gy) (see Absorbed Dose).
  - Committed Dose Equivalent (H_T,50_)—The dose equivalent to organs or tissues of reference (T) that will be received from an intake of radioactive material by an individual during the 50 years following the intake.
  - Committed Effective Dose Equivalent (H_E,50_)—The sum of the products of the weighting factors applicable to each of the body organs or tissues that are irradiated and the committed dose equivalent to those organs or tissues.
  - Effective Dose—A dose value that attempts to normalize the detriment to the body (for cancer mortality and morbidity, hereditary effects, and years of life lost) from a non-uniform exposure to that of a uniform whole body exposure. Effective dose is calculated as the sum of products of the equivalent dose and the tissue weighting factor (w_T_) for each tissue exposed. (E = ΣD_T,R_ w_R_ w_T_).
  - Effective Dose Equivalent (H_E_)—This dose type is limited to internal exposures and is the sum of the products of the dose equivalent to the organ or tissue (H_T_) and the weighting factors (w_T_) applicable to each of the body organs or tissues that are irradiated. (H_E_ = Σw_T_ H_T_).
  - Equivalent Dose—A dose quantity that places the biological effect of all radiation types on a common scale for calculating tissue damage. Alpha particles, for example, are considered to cause 20 times more damage than gamma rays. Equivalent dose is calculated as the sum of products of the average absorbed dose (in gray) in an organ or tissue (DT,R) from each type of radiation and the radiation weighting factor (w_R_) for that radiation (ΣD_T,R_ w_R_).
  - External Dose—That portion of the dose equivalent received from radiation sources outside the body.
  - Internal Dose—That portion of the dose equivalent received from radioactive material taken into the body.
  - Limit—A permissible upper bound on the radiation dose.
  - Maximum Permissible Dose (MPD)—The greatest dose equivalent that a person or specified part thereof shall be allowed to receive in a given period of time.
  - Median Lethal Dose (MLD)Dose of radiation required to kill, within a specified period (usually 30 days), 50% of the individuals in a large group of animals or organisms. Also called the LD_50_, or LD_50/30_ if for 30 days.
  - Threshold Dose—The minimum absorbed dose that will produce a detectable degree of any given effect.
  - Tissue Dose—Absorbed dose received by tissue in the region of interest, expressed in rad (see Dose, Gray, and Rad).
Dose Rate: The amount of radiation dose delivered per unit time. Generically, the rate at which radiation dose is delivered to any material or tissue.
Dose-Response Relationship: The quantitative relationship between the amount of exposure to a toxicant and the incidence of the adverse effects.
Dosimetry: Quantification of radiation doses to cells, tissues, organs, individuals or populations resulting from radiation exposures.
Early Effects (of radiation exposure): Effects that appear within 60 days of an acute exposure.
Electron: A stable elementary particle having an electric charge equal to ±1.60210×10^−19^ C (Coulombs) and a rest mass equal to 9.1091×10^−31^ kg. A positron is a positively charged "electron" (see Positron).
Electron Volt: A unit of energy equivalent to the energy gained by an electron in passing through a potential difference of one volt. Larger multiple units of the Electron Volt are frequently used: keV for thousand or kilo Electron Volts; MeV for million or mega Electron Volts (eV). 1 eV=1.6×10^−12^ erg.
Embryotoxicity and Fetotoxicity: Any toxic effect on the conceptus as a result of prenatal exposure to a chemical; the distinguishing feature between the two terms is the stage of development during which the insult occurred. The terms, as used here, include malformations and variations, altered growth, and in utero death.
Energy: Capacity for doing work. Gravitationally, "potential energy" is the energy inherent in a mass because of its spatial relation to other masses. Chemically or radiologically, “potential energy” is the energy released when a chemical reaction or radiological transformation goes to completion. "Kinetic energy" is the energy possessed by a mass because of its motion (SI unit: joules):
  - Binding Energy (Electron)—The amount of energy that must be expended to remove an electron from an atom.
  - Binding Energy (Nuclear)—The energy represented by the difference in mass between the sum of the component parts and the actual mass of the nucleus. It represents the amount of energy that must be expended to break a nucleus into its component neutrons and protons.
  - Excitation Energy—The energy required to change a system from its ground state to an excited state. Each different excited state has a different excitation energy.
  - Ionizing Energy—The energy required to knock an electron out of an atom. The average energy lost by electrons or beta particles in producing an ion pair in air or in soft tissue is about 34 eV.
  - Radiant Energy—The energy of electromagnetic radiation, such as radio waves, visible light,×and gamma rays.
Enrichment, Isotopic: An isotopic separation process by which the relative abundances of the isotopes of a given element are altered, thus producing a form of the element that has been enriched in one or more isotopes and depleted in others. In uranium enrichment, the percentage of uranium-235 in natural uranium can be increased from 0.7% to >90% in a gaseous diffusion process based on the different thermal velocities of the constituents of natural uranium (^234^U, ^235^U, ^238^U) in the molecular form UF_6_.
EPA Health Advisory: An estimate of acceptable drinking water levels for a chemical substance based on health effects information. A health advisory is not a legally enforceable federal standard, but serves as technical guidance to assist federal, state, and local officials.
Epidemiology: Refers to the investigation of factors that determine the frequency and distribution of disease or other health-related conditions within a defined human population during a specified period.
Equilibrium, Radioactive: In a radioactive series, the state which prevails when the ratios between the activities of two or more successive members of the series remains constant.
  - Secular Equilibrium—If a parent element has a very much longer half-life than the daughters (so there is not appreciable change in its amount in the time interval required for later products to attain equilibrium) then, after equilibrium is reached, equal numbers of atoms of all members of the series disintegrate in unit time. This condition is never exactly attained, but is essentially established in such a case as ^226^Ra and its transformation series to stable ^206^Pb. The half-life of ^226^Ra is about 1,600 years; of ^222^Rn, approximately 3.82 days, and of each of the subsequent members, a few minutes. After about a month, essentially the equilibrium amount of radon is present; then (and for a long time) all members of the series disintegrate the same number of atoms per unit time. At this time, the activity of the daughter is equal to the activity of the parent.
  - Transient Equilibrium—If the half-life of the parent is short enough so the quantity present decreases appreciably during the period under consideration, but is still longer than that of successive members of the series, a stage of equilibrium will be reached after which all members of the series decrease in activity exponentially with the period of the parent. At this time, the ratio of the parent activity to the daughter activity is constant.
Equilibrium, Electron: The condition in a radiation field where the energy of the electrons entering a volume equals the energy of the electrons leaving that volume.
Excitation: The addition of energy to a system, thereby transferring it from its ground state to an excited state. Excitation of a nucleus, an atom, or a molecule can result from absorption of photons or from inelastic collisions with other particles. The excited state of an atom is an unstable or metastable state and will return to ground state by radiation of the excess energy.
Exposure (Chemical): Contact of an organism with a chemical or physical agent. Exposure is quantified as the amount of the agent available at the exchange boundaries of the organism (e.g., skin, lungs, gut) and available for absorption.
Exposure (Radiation): Subjection to ionizing radiation or to a radioactive material. For example, exposure in air is a measure of the ionization produced in air by×or gamma radiation; the sum of the electric charges on all ions of one sign produced in air when all electrons liberated by photons in a volume of air are completely stopped in air (dQ), divided by the mass of the air in the volume (dm). The unit of exposure in air is the roentgen, or coulomb per kilogram (SI units). One roentgen is equal to 2.58×10^−4^ coulomb per kilogram (C/kg).
Ex Vivo: Outside of the living body.
Fission, Nuclear: A nuclear transformation characterized by the splitting of a nucleus into at least two other nuclei with emission of several neutrons, accompanied by the release of a relatively large amount of energy.
Gamma Ray, Penetrating: Short wavelength electromagnetic radiation of nuclear origin.
Genotoxicity: Effects of chemical and physical agents on the hereditary material (DNA) and on the genetic processes of living cells.
Gray (Gy): SI unit of absorbed dose, 1 J/kg. One gray equals 100 rad (see Units).
Half-life, Effective: See Half-Time, Effective.
Half-life, Radioactive: Time required for a radioactive substance to lose 50% of its activity by decay. Each radio-nuclide has a unique physical half-life. Known also as physical half-time and symbolized as T_r_ or T_rad_.
Half-time, Biological: Time required for an organ, tissue, or the whole body to eliminate one-half of any absorbed substance by regular processes of elimination. This is the same for both stable and radioactive isotopes of a particular element, and is sometimes referred to as half-time, symbolized as t_biol_ or T_b_.
Half-time, Effective: Time required for a radioactive element in an organ, tissue, or the whole body to be diminished 50% as a result of the combined action of radioactive decay and biological elimination, symbolized as T_e_ or T_eff_.
  Effective half-time = (Biological half-time × Radioactive half-life)/(Biological half-time + Radioactive half-life)
Immediately Dangerous to Life or Health (IDLH): The maximum environmental concentration of a contaminant from which one could escape within 30 minutes without any escape-impairing symptoms or irreversible health effects.
Immunologic Toxicity: The occurrence of adverse effects on the immune system that may result from exposure to environmental agents such as chemicals.
Immunological Effects: Functional changes in the immune response.
Incidence: The ratio of individuals in a population who develop a specified condition to the total number of individuals in that population who could have developed that condition in a specified time period.
Intensity: Amount of energy per unit time passing through a unit area perpendicular to the line of propagation at the point in question.
Intermediate Exposure: Exposure to a chemical for a duration of 15—364 days, as specified in the Toxicological Profiles.
Internal Conversion: Process in which a gamma ray knocks an electron out of the same atom from which the gamma ray was emitted. The ratio of the number of internal conversion electrons to the number of gamma quanta emitted in the de-excitation of the nucleus is called the "conversion ratio."
In Vitro: Isolated from the living organism and artificially maintained, as in a test tube. Literally, “in glass.”
In Vivo: Occurring within the living organism. Literally, “in life.”
Ion: Atomic particle, atom or chemical radical bearing a net electrical charge, either negative or positive.
Ion Pair: Two particles of opposite charge, usually referring to the electron and positive atomic or molecular residue resulting after the interaction of ionizing radiation with the orbital electrons of atoms.
Ionization: The process by which a neutral atom or molecule acquires a positive or negative charge.
  - Primary Ionization—(1) In collision theory: the ionization produced by the primary particles as contrasted to the "total ionization" which includes the "secondary ionization" produced by delta rays. (2) In counter tubes: the total ionization produced by incident radiation without gas amplification.
  - Specific Ionization—Number of ion pairs per unit length of path of ionizing radiation in a medium; e.g., per centimeter of air or per micrometer of tissue.
  - Total Ionization—The total electric charge of one sign on the ions produced by radiation in the process of losing its kinetic energy. For a given gas, the total ionization is closely proportional to the initial ionization and is nearly independent of the nature of the ionizing radiation. It is frequently used as a measure of absorption of radiation energy.
Ionization Density: Number of ion pairs per unit volume.
Ionization Path (Track): The trail of ion pairs produced by an ionizing particle in its passage through matter.
Ionizing Radiation: Any radiation capable of knocking electrons out of atoms and producing ions. Examples: alpha, beta, gamma and×rays, and neutrons.
Isobars: Nuclides having the same mass number but different atomic numbers.
Isomers: Nuclides having the same number of neutrons and protons but capable of existing, for a measurable time, in different quantum states with different energies and radioactive properties. Commonly the isomer of higher energy decays to one with lower energy by the process of isomeric transition.
Isotopes: Nuclides having the same number of protons in their nuclei, and hence the same atomic number, but differing in the number of neutrons, and therefore in the mass number. Identical chemical properties exist in isotopes of a particular element. The term should not be used as a synonym for nuclide because isotopes refer specifically to different nuclei of the same element.
  - Stable Isotope—A nonradioactive isotope of an element.
Joule: The S.I. unit for work and energy. It is equal to the work done by raising a mass of one newton through a distance of one meter (J = Nm), which corresponds to about 0.7 ft-pound.
Kerma (k): A measure of the kinetic energy transferred from gamma rays or neutrons to a unit mass of absorbing medium in the initial collision between the radiation and the absorber atoms. The SI unit is J/kg. The special name of this unit is the rad (traditional system of units) or Gray (SI).
Labeled Compound: A compound containing one or more radioactive atoms intentionally added to its structure. By observations of radioactivity or isotopic composition, this compound or its fragments may be followed through physical, chemical, or biological processes.
Late Effects (of radiation exposure): Effects which appear 60 days or more following an acute exposure.
LD_50/30_: The dose of a chemical or radiation expected to cause 50% mortality in those exposed within 30 days. For radiation, this is about 350 rad (3.5 gray) received by humans over a short period of time.
Lethal Concentration_(Lo)_ (LC_Lo_): The lowest concentration of a chemical in air that has been reported to have caused death in humans or animals.
Lethal Concentration_(50)_ (LC_50_): A calculated concentration of a chemical in air to which exposure for a specific length of time is expected to cause death in 50% of a defined experimental animal population within a specified time, usually 30 days.
Lethal Dose_(Lo)_ (LD_Lo_): The lowest dose of a chemical introduced by a route other than inhalation that is expected to have caused death in humans or animals within a specified time, usually 30 days.
Lethal Dose_(50)_ (LD_50_): The dose of a chemical which has been calculated to cause death in 50% of a defined experimental animal population.
Lethal Time_(50)_ (LT_50_): A calculated period of time within which a specific concentration of a chemical is expected to cause death in 50% of a defined experimental animal population.
Linear Energy Transfer (LET): A measure of the energy that a charged particle transfers to a material per unit path length.
  - Average LET—The energy of a charged particle divided by the length of the path over which it deposits all its energy in a material. This is averaged over a number of particles.
  - High-LET—Energy transfer characteristic of heavy charged particles such as protons and alpha particles where the distance between ionizing events is small on the scale of a cellular nucleus.
  - Low-LET—Energy transfer characteristic of light charged particles such as electrons produced by×and gamma rays where the distance between ionizing events is large on the scale of a cellular nucleus.
Lowest-Observed-Adverse-Effect Level (LOAEL): The lowest dose of chemical in a study, or group of studies, that produces statistically or biologically significant increases in frequency or severity of adverse effects between the exposed population and its appropriate control.
Lung Clearance Class (fast, F; medium, M; slow, S): A classification scheme for inhaled material according to its rate of clearance from the pulmonary region of the lungs to the blood and the gastrointestinal tract.
Lymphoreticular Effects: Represent morphological effects involving lymphatic tissues such as the lymph nodes, spleen, and thymus.
Malformations: Permanent structural changes that may adversely affect survival, development, or function.
Mass Numbers (A): The number of nucleons (protons and neutrons) in the nucleus of an atom.
Minimal Risk Level: An estimate of daily human exposure to a substance that is likely to be without an appreciable risk of adverse noncancerous effects over a specified duration of exposure.
Modifying Factor (MF): A value (greater than zero) that is applied to the derivation of a Minimal Risk Level (MRL) to reflect additional concerns about the database that are not covered by the uncertainty factors. The default value for a MF is 1.
Morbidity: State of being diseased; morbidity rate is the incidence or prevalence of disease in a specific population.
Mortality: Death; mortality rate is a measure of the number of deaths in a population during a specified interval of time.
Mutagen: A substance that causes changes (mutations) in the genetic material in a cell. Mutations can lead to birth defects, miscarriages, or cancer.
Necropsy: The gross examination of the organs and tissues of a dead body to determine the cause of death or pathological conditions.
Neonates: Newborn infants.
Neurotoxicity: The occurrence of adverse effects on the nervous system following exposure to a substance.
Neutrino (ν): A neutral particle of infinitesimally small rest mass emitted during beta plus or beta minus decay. This particle accounts for conservation of energy in beta plus and beta minus decays. It plays no role in damage from radiation.
No-Observed-Adverse-Effect Level (NOAEL): The dose of a substance at which there were no statistically or biologically significant increases in frequency or severity of adverse effects seen between the exposed population and its appropriate control. Effects may be produced at this dose, but they are not considered to be adverse.
Nuclear Reactor: A power plant that heats the medium (typically water) by using the energy released from the nuclear fission of uranium or plutonium isotopes instead of burning coal, oil, or natural gas. All of these sources of energy simply heat water and use the steam which is produced to turn turbines that make electricity or propel a ship.
Nucleon: Common name for a constituent particle of the nucleus. Applied to a proton or neutron.
Nuclide: A species of atom characterized by the constitution of its nucleus. The nuclear constitution is specified by the number of protons (Z), number of neutrons (N), and energy content; or, alternatively, by the atomic number (Z), mass number A(N+Z), and atomic mass. To be regarded as a distinct nuclide, the atom must be capable of existing for a measurable time. Thus, nuclear isomers are separate nuclides, whereas promptly decaying excited nuclear states and unstable intermediates in nuclear reactions are not so considered.
Octanol-Water Partition Coefficient (K_ow_): The equilibrium ratio of the concentrations of a chemical in n-octanol and water, in dilute solution.
Odds Ratio (OR): A means of measuring the association between an exposure (such as toxic substances and a disease or condition) which represents the best estimate of relative risk (risk as a ratio of the incidence among subjects exposed to a particular risk factor divided by the incidence among subjects who were not exposed to the risk factor). An odds ratio of greater than 1 is considered to indicate greater risk of disease in the exposed group compared to the unexposed.
Organophosphate or Organophosphorus Compound: A phosphorus-containing organic compound and especially a pesticide that acts by inhibiting cholinesterase.
Pair Production: An absorption process for x- and gamma radiation in which the incident photon is absorbed in the vicinity of the nucleus of the absorbing atom, with subsequent production of an electron and positron pair (see annihilation). This reaction can only occur for incident photon energies exceeding 1.02 MeV.
Parent: Any radionuclide nuclide which, upon disintegration, yields a new nuclide (termed the progeny or daughter), either directly or as a later member of a radioactive series.
Permissible Exposure Limit (PEL): A maximum allowable atmospheric level of a substance in workplace air averaged over an 8-hour shift.
Pesticide: General classification of chemicals specifically developed and produced for use in the control of agricultural and public health pests.
Pharmacokinetic Model: A set of equations that can be used to describe the time course of a parent chemical or metabolite in an animal system. There are two types of pharmacokinetic models: data-based and physiologically-based. A data-based model divides the animal system into a series of compartments which, in general, do not represent real, identifiable anatomic regions of the body whereas the physiologically-based model compartments represent real anatomic regions of the body.
Pharmacokinetics: The dynamic behavior of a material in the body, used to predict the fate (disposition) of an exogenous substance in an organism. Utilizing computational techniques, it provides the means of studying the absorption, distribution, metabolism and excretion of chemicals by the body.
Physiologically Based Pharmacodynamic (PBPD) Model: A type of physiologically-based dose-response model which quantitatively describes the relationship between target tissue dose and toxic end points. These models advance the importance of physiologically based models in that they clearly describe the biological effect (response) produced by the system following exposure to an exogenous substance.
Physiologically Based Pharmacokinetic (PBPK) Model: A model comprising a series of compartments representing organs or tissue groups with realistic weights and blood flows. These models require a variety of physiological information: tissue volumes, blood flow rates to tissues, cardiac output, alveolar ventilation rates and, possibly membrane permeabilities. The models also utilize biochemical information such as air/blood partition coefficients, and metabolic parameters. PBPK models are also called biologically based tissue dosimetry models.
Photoelectric Effect: An attenuation process observed for×and gamma radiation in which an incident photon interacts with a tightly bound inner orbital electron of an atom delivering all of its energy to knock the electron out of the atom. The incident photon disappears in the process.
Photon: A quantum of electromagnetic energy (E) whose value is the product of its frequency (ν) in hertz and Planck's constant (h). The equation is: E = hν.
Population dose: See Collective dose.
Positron: A positively charged electron.
Potential, Ionization: The energy expressed as Electron Volts (eV) necessary to separate one electron from an atom, resulting in the formation of an ion pair.
Power, Stopping: A measure of the ability of a material to absorb energy from an ionizing particle passing through it; the greater the stopping power, the greater the energy absorbing ability (see Linear Energy Transfer).
Prevalence: The number of cases of a disease or condition in a population at one point in time.
Progeny: The decay product or daughter products resulting after a radioactive decay or a series of radioactive decays. The progeny can also be radioactive, and the chain continues until a stable nuclide is formed.
Prospective Study: A type of cohort study in which the pertinent observations are made on events occurring after the start of the study. A group is followed over time.
Proton: Elementary nuclear particle with a positive electric charge equal numerically to the charge of the electron and a rest mass of 1.007 mass units.
q_1_*: The upper-bound estimate of the low-dose slope of the dose-response curve as determined by the multistage procedure. The q_1_* can be used to calculate an estimate of carcinogenic potency, the incremental excess cancer risk per unit of exposure (usually μg/L for water, mg/kg/day for food, and μg/m^3^ for air).
Quality: A term describing the distribution of the energy deposited by a particle along its track; radiations that produce different densities of ionization per unit intensity are said to have different "qualities."
Quality Factor (Q): The linear-energy-transfer-dependent factor by which absorbed doses are multiplied to obtain (for radiation protection purposes) a quantity that expresses - on a common scale for all ionizing radiation - the approximate biological effectiveness of the absorbed dose.
  Type of radiation | Quality Factor
  X, gamma, or beta | 1
  Alpha particles | 20
  Neutrons of unknown energy | 10
  High energy protons | 10
Rad: The traditional unit of absorbed dose equal to 100 ergs per gram, or 0.01 joule per kilogram (0.01 Gy) in any medium (see Absorbed Dose).
Radiation: The emission and propagation of energy through space or through a material medium in the form of waves (e.g., the emission and propagation of electromagnetic waves, or of sound and elastic waves). The term radiation or radiant energy, when unqualified, usually refers to electromagnetic radiation. Such radiation commonly is classified according to frequency, as microwaves, infrared, visible (light), ultraviolet, and×and gamma rays (see Photon.) and, by extension, corpuscular emission, such as alpha and beta radiation, neutrons, or rays of mixed or unknown type, as cosmic radiation.
  - Radiation, Annihilation—Photons produced when an electron and a positron unite and cease to exist. The annihilation of a positron-electron pair results in the production of two photons, each of 0.51 MeV energy.
  - Radiation, Background—See Background Radiation.
  - Radiation, Characteristic (Discrete)—Radiation originating from an excited atom after removal of an electron from an atom. The wavelength of the emitted radiation is specific, depending only on the element and particular energy levels involved.
  - Radiation, External—Radiation from a source outside the body.
  - Radiation, Internal—Radiation from a source within the body (as a result of deposition of radionuclides in body tissues).
  - Radiation, Ionizing—Any electromagnetic or particulate radiation capable of producing ions, directly or indirectly, in its passage through matter (see Radiation).
  - Radiation, Monoenergetic—Radiation of a given type in which all particles or photons originate with and have the same energy.
  - Radiation, Scattered—Radiation which during its passage through a substance, has been deviated in direction. It may also have been modified by a decrease in energy.
  - Radiation, Secondary—A particle or ray that is produced when the primary radiation interacts with a material, and which has sufficient energy to produce its own ionization, such as bremsstrahlung or electrons knocked from atomic orbitals with enough energy to then produce ionization (see Delta Rays).
Radiation Weighting Factor (also called Quality Factor): In radiation protection, a factor (1 for x-rays, gamma rays, beta particles; 20 for alpha particles) weighting the absorbed dose of radiation of a specific type and energy for its effect on tissue.
Radioactive Material: Material containing radioactive atoms.
Radioactivity: Spontaneous nuclear transformations that result in the formation of new elements. These transformations are accomplished by emission of alpha or beta particles from the nucleus or by the capture of an orbital electron. Each of these reactions may or may not be accompanied by a gamma photon.
  - Radioactivity, Artificial—Man-made radioactivity produced by particle bombardment or nuclear fission, as opposed to naturally occurring radioactivity.
  - Radioactivity, Induced—Radioactivity produced in a substance after bombardment with neutrons or other particles. The resulting activity is "natural radioactivity" if formed by nuclear reactions occurring in nature and "artificial radioactivity" if the reactions are caused by man.
  - Radioactivity, Natural—The property of radioactivity exhibited by more than 50 naturally occurring radionuclides.
Radioisotope: An unstable or radioactive isotope of an element that decays or disintegrates spontaneously, emitting radiation.
Radionuclide: Any radioactive isotope of any element. Approximately 5,000 natural and artificial radioisotopes have been identified.
Radiosensitivity: Relative susceptibility of cells, tissues, organs, organisms, or any living substance to the injurious action of radiation. Radiosensitivity and its antonym, radioresistance, are used comparatively, rather than absolutely.
Recommended Exposure Limit (REL): A National Institute for Occupational Safety and Health (NIOSH) time-weighted average (TWA) concentration for up to a 10-hour workday during a 40-hour workweek.
Reference Concentration (RfC): An estimate (with uncertainty spanning perhaps an order of magnitude) of a continuous inhalation exposure to the human population (including sensitive subgroups) that is likely to be without an appreciable risk of deleterious noncancer health effects during a lifetime. It can be derived from a NOAEL, LOAEL, or benchmark concentration, with uncertainty factors generally applied to reflect limitations of the data used. The inhalation reference concentration is for continuous inhalation exposures and is appropriately expressed in units of mg/m^3^ or ppm.
Reference Dose (RfD): An estimate (with uncertainty spanning perhaps an order of magnitude) of a daily oral exposure to the human population (including sensitive subgroups) that is likely to be without an appreciable risk of deleterious effects during a lifetime. It can be derived from a NOAEL, LOAEL, or benchmark dose, with uncertainty factors generally applied to reflect limitations of the data used.
Relative Biological Effectiveness (RBE): The RBE is a factor used to compare the biological effectiveness of absorbed radiation doses (i.e., rad) due to different types of ionizing radiation. More specifically, it is the experimentally determined ratio of an absorbed dose of a radiation in question to the absorbed dose of a reference radiation (typically ^60^Co gamma rays or 200 kVp×rays) required to produce an identical biological effect in a particular experimental organism or tissue (see Quality Factor).
Rem: The traditional unit of dose equivalent that is used in the regulatory, administrative, and engineering design aspects of radiation safety practice. The dose equivalent in rem is numerically equal to the absorbed dose in rad multiplied by the quality factor (1 rem is equal to 0.01 sievert).
Reportable Quantity (RQ): The quantity of a hazardous substance that is considered reportable under CERCLA. Reportable quantities are (1) 1 pound or greater or (2) for selected substances, an amount established by regulation either under CERCLA or under Sect. 311 of the Clean Water Act. Quantities are measured over a 24-hour period.
Reproductive Toxicity: The occurrence of adverse effects on the reproductive system that may result from exposure to a chemical. The toxicity may be directed to the reproductive organs and/or the related endocrine system. The manifestation of such toxicity may be noted as alterations in sexual behavior, fertility, pregnancy outcomes, or modifications in other functions that are dependent on the integrity of this system.
Roentgen (R): A unit of exposure (in air) to ionizing radiation. It is the amount of×or gamma rays required to produce ions carrying 1 electrostatic unit of electrical charge in 1 cubic centimeter of dry air under standard conditions. Named after William Roentgen, a German scientist who discovered×rays in 1895.
Retrospective Study: A type of cohort study based on a group of persons known to have been exposed at some time in the past. Data are collected from routinely recorded events, up to the time the study is undertaken. Retrospective studies are limited to causal factors that can be ascertained from existing records and/or examining survivors of the cohort.
Risk: The possibility or chance that some adverse effect will result from a given exposure to a chemical.
Risk Factor: An aspect of personal behavior or lifestyle, an environmental exposure, or an inborn or inherited characteristic that is associated with an increased occurrence of disease or other health-related event or condition.
Risk Ratio: The ratio of the risk among persons with specific risk factors compared to the risk among persons without risk factors. A risk ratio greater than 1 indicates greater risk of disease in the exposed group compared to the unexposed group.
Self-Absorption: Absorption of radiation (emitted by radioactive atoms) by the material in which the atoms are located; in particular, the absorption of radiation within a sample being assayed.
Short-Term Exposure Limit (STEL): The maximum concentration to which workers can be exposed for up to 15 minutes continually. No more than four excursions are allowed per day, and there must be at least 60 minutes between exposure periods. The daily TLV-TWA may not be exceeded.
SI Units: The International System of Units as defined by the General Conference of Weights and Measures in 1960. These units are generally based on the meter/kilogram/second units, with special quantities for radiation including the becquerel, gray, and sievert.
Sickness, Acute Radiation (Syndrome): The complex symptoms and signs characterizing the condition resulting from excessive exposure of the whole body (or large part) to ionizing radiation. The earliest of these symptoms are nausea, fatigue, vomiting, and diarrhea, and may be followed by loss of hair (epilation), hemorrhage, inflammation of the mouth and throat, and general loss of energy. In severe cases, where the radiation dose is relatively high (over several hundred rad or several gray), death may occur within two to four weeks. Those who survive six weeks after exposure of a single high dose of radiation may generally be expected to recover.
Sievert (Sv): The SI unit of any of the quantities expressed as dose equivalent. The dose equivalent in sieverts is equal to the absorbed dose, in gray, multiplied by the quality factor (1 sievert equals 100 rem). The sievert is also the SI unit for effective dose equivalent, which is the sum of the products of the dose equivalent to each organ or tissue and its corresponding tissue weighting factor.
Specific-Activity: Radioactivity per unit mass of a radionuclide, expressed, for example, as Ci/gram or Bq/kilogram.
Specific Energy: The actual energy per unit mass deposited per unit volume in a small target, such as the cell or cell nucleus, as the result of one or more energy-depositing events. This is a stochastic quantity as opposed to the average value over a large number of instance (i.e., the absorbed dose).
Standardized Mortality Ratio (SMR): A ratio of the observed number of deaths and the expected number of deaths in a specific standard population.
Stochastic Effect: A health effect that occurs randomly and for which the probability of the effect occurring, rather than its severity, is assumed to be a linear function of dose without a threshold (also called a nondeterministic effect).
Stopping Power: The average rate of energy loss of a charged particle per unit thickness of a material or per unit mass of material traversed.
Surface-seeking Radionuclide: A bone-seeking internal emitter that deposits and remains on the bone surface for a long period of time, although it may eventually diffuse into the bone mineral. This contrasts with a volume seeker, which deposits more uniformly throughout the bone volume.
Target Organ Toxicity: This term covers a broad range of adverse effects on target organs or physiological systems (e.g., renal, cardiovascular) extending from those arising through a single limited exposure to those assumed over a lifetime of exposure to a chemical.
Target Theory (Hit Theory): A theory explaining some biological effects of radiation on the basis that ionization, occurring in a discrete volume (the target) within the cell, directly causes a lesion which subsequently results in a physiological response to the damage at that location. One, two, or more "hits" (ionizing events within the target) may be necessary to elicit the response.
Teratogen: A chemical that causes birth defects.
Threshold Limit Value (TLV): The maximum concentration of a substance to which most workers can be exposed without adverse effect. TLV is a term used exclusively by the ACGIH. Other terms used to express similar concepts are the MAC (Maximum Allowable Concentration) and PEL (Permissible Exposure Limits).
Time-Weighted Average (TWA): An allowable exposure concentration averaged over a normal 8-hour workday or 40-hour workweek.
Tissue Weighting Factor (Wt): Organ- or tissue-specific factor by which the equivalent dose is multiplied to give the portion of the effective dose for that organ or tissue. Recommended values of tissue weighting factors are:
  Tissue/Organ | Tissue Weighting Factor
  Gonads | 0.70
  Bone marrow (red) | 0.12
  Colon | 0.12
  Lung | 0.12
  Stomach | 0.12
  Bladder | 0.05
  Breast | 0.05
  Liver | 0.05
  Esophagus | 0.05
  Thyroid | 0.05
  Skin | 0.01
  Bone surface | 0.01
  Remainder (adrenals, brain, upper large intestine, small intestine, pancreas, spleen, thymus, and uterus) | 0.05
Toxic Dose (TD_50_): A calculated dose of a chemical, introduced by a route other than inhalation, which is expected to cause a specific toxic effect in 50% of a defined experimental animal population.
Toxicokinetic: The absorption, distribution and elimination of toxic compounds in the living organism.
Toxicosis: A diseased condition resulting from poisoning.
Transformation, Nuclear: The process of radioactive decay by which a nuclide is transformed into a different nuclide by absorbing or emitting particulate or electromagnetic radiation.
Transition, Isomeric: The process by which a nuclide decays to an isomeric nuclide (i.e., one of the same mass number and atomic number) of lower quantum energy. Isomeric transitions (often abbreviated I.T.) proceed by gamma ray and internal conversion electron emission.
Tritium: The hydrogen isotope with one proton and two neutrons in the nucleus (Symbol: ^3^H). It is radioactive and has a physical half-life of 12.3 years.
Unattached Fraction: That fraction of the radon daughters, usually ^218^Po and ^214^Po, which has not yet attached to a dust particle or to water vapor. As a free atom, it has a high probability of being exhaled and not retained within the lung. It is the attached fraction which is primarily retained.
Uncertainty Factor (UF): A factor used in operationally deriving the RfD from experimental data. UFs are intended to account for (1) the variation in sensitivity among the members of the human population, (2) the uncertainty in extrapolating animal data to the case of human, (3) the uncertainty in extrapolating from data obtained in a study that is of less than lifetime exposure, and (4) the uncertainty in using LOAEL data rather than NOAEL data. Usually each of these factors is set equal to 10.
Units, Prefixes: Many units of measure are expressed as submultiples or multiples of the primary unit (e.g., 10^−3^ curie is 1 mCi and 10^3^ becquerel is 1 kBq).
  Factor | Prefix | Symbol | Factor | Prefix | Symbol
  10^−18^ | atto | A | 10^3^ | kilo | k
  10^−15^ | femto | F | 10^6^ | mega | M
  10^−12^ | pico | p | 10^9^ | giga | G
  10^−9^ | nano | N | 10^12^ | tera | T
  10^−6^ | micro | Μ | 10^15^ | peta | P
  10^−3^ | milli | M | 10^18^ | exa | E
  10^−2^ | centi | C
Units, Radiological: Units | Equivalents
  Becquerel^*^ (Bq) | 1 disintegration per second = 2.7×10^−11^ Ci
  Curie (Ci) | 3.7×10^10^ disintegrations per second = 3.7×10^10^ Bq
  Gray * (Gy) | 1 J/kg = 100 rad
  Rad (rad) | 100 erg/g = 0.01 Gy
  Rem (rem) | 0.01 sievert
  Sievert^*^ (Sv) | 100 rem
  * International Units, designated (SI)
Working Level (WL): Any combination of short-lived radon daughters in 1 liter of air that will result in the ultimate emission of 1.3×10^5^ MeV of potential alpha energy.
Working Level Month (WLM): A unit of exposure to radon daughters corresponding to the product of the radon daughter concentration in Working Level (WL) and the exposure time in nominal months (1 nominal month = 170 hours). Inhalation of air with a concentration of 1 WL of radon daughters for 170 working hours results in an exposure of 1 WLM.
Xenobiotic: Any chemical that is foreign to the biological system.
X rays: Penetrating electromagnetic radiations whose wave lengths are very much shorter than those of visible light. They are usually produced by bombarding a metallic target with fast electrons in a high vacuum. X rays (called characteristic×rays) are also produced when an orbital electron falls from a high energy level to a low energy level.
Zero-Threshold Linear Hypothesis (or No-Threshold Linear Hypothesis): The assumption that a dose-response curve derived from data in the high dose and high dose-rate ranges may be extrapolated through the low dose and low dose range to zero, implying that, theoretically, any amount of radiation will cause some damage.