# REFERENCES

* Not cited in text

AARST. Protocols for radon measurements in homes (MAH Eptember 2005). American Association of Radon Scientists and Technologists, Inc. 2006.
Abdelkawi SA, Abo-Elmagd M, Soliman HA. Development of cataract and corneal opacity in mice due to radon exposure. Radiat Effects Defects Solids. 2008;163(7):661-671.
Abo-Elmagd M, Daif MM, Eissa HM. Cytogenetic effects of radon inhalation. Radiat Meas. 2008;43:1265-1269.
ACGIH. Ionizing radiation. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH. American Conference of Governmental Industrial Hygienists. 2007:172-173.
Adinolfi M. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol. 1985;27(4):532-537. [pmid: 4029526].
Adlercreutz H. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl. 1995;103(7):103-112.
AEC. The effect of inhaled radon on the survival, body weight and hemogram of the mouse following single exposures. >Rochester, NY. U. S. Atomic Energy Commission. University of Rochester. 1961:UR-593.
AEC. The effect of inhaled radon on the survival, body weight and hemogram of the mouse following multiple exposures. Rochester, NY. U. S. Atomic Energy Commission. University of Rochester. 1964:UR-624.
AEC. The effects on mice of continual exposure to radon and its decay products on dust. Rochester, NY. U. S. Atomic Energy Commission. University of Rochester. 1966:UR-669.
Agency for Toxic Substances and Disease Registry. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry, Division of Toxicology. Fed Regist. 1989;54(174):37618-37634.
Agency for Toxic Substances and Disease Registry. Toxicological profile for thorium. Agency for Toxic Substances and Disease Registry. 1990a. http://www.atsdr.cdc.gov/ToxProfiles/tp147.pdf. February 7, 2012.
Agency for Toxic Substances and Disease Registry. Toxicological profile for radium. Atlanta, GA. U. S. Department of Health and Human Services. Public Health Service. Agency for Toxic Substances and Disease Registry. 1990b.
Agency for Toxic Substances and Disease Registry. Toxicological profile for thallium. Agency for Toxic Substances and Disease Registry. 1992. http://www.atsdr.cdc.gov/ToxProfiles/tp54.pdf. February 7, 2012.
Agency for Toxic Substances and Disease Registry. Public health assessment. Monticello mill tailings (DOE) and Monticello radioactively contaminated properties. Agency for Toxic Substances and Disease Registry. 1997. http://www.atsdr.cdc.gov/HAC/pha/PHA.asp?docid=802&pg=0. February 7, 2012. (Retrieval in progress).
Agency for Toxic Substances and Disease Registry. Toxicological profile for uranium. Agency for Toxic Substances and Disease Registry. 1999a. http://www.atsdr.cdc.gov/toxprofiles/tp150.pdf. August 28, 2008.
Agency for Toxic Substances and Disease Registry. Toxicological profile for ionizing radiation. Agency for Toxic Substances and Disease Registry. 1999b. http://www.atsdr.cdc.gov/toxprofiles/tp149.pdf. May 15, 2008.
Agency for Toxic Substances and Disease Registry. Health consultation. An investigation of cancer incidence in Monticello, Utah. Atlanta, Georgia. U. S. Department of Health and Human Services, Agency for Toxic Substances and Disease Registry, Division of Health Assessment and Consultation. 2006. http://www.atsdr.cdc.gov/HAC/pha/CancerIncidenceInMonticelloUT/CancerIncidence-MonticelloHC051706.pdf. August 08, 2008.
Agency for Toxic Substances and Disease Registry. Toxicological profile for arsenic. Agency for Toxic Substances and Disease Registry. 2007a. http://www.atsdr.cdc.gov/toxprofiles/tp2.pdf. November 29, 2011.
Agency for Toxic Substances and Disease Registry. Toxicological profile for lead. Agency for Toxic Substances and Disease Registry. 2007b. http://www.atsdr.cdc.gov/toxprofiles/tp13.pdf. November 29, 2011.
Agency for Toxic Substances and Disease Registry. Toxicological profile for uranium. Agency for Toxic Substances and Disease Registry. (Retrieval in progress). 2011.
Al-Arifi MN, Alkartfy KM, Al-Suwayeh SA, et al. Levels of ^210^Po in blood, urine and hair of some Saudi smokers. J Radioanal Nucl Chem. 2006;269(1):115-118.
Alavanja MCR. Biologic damage resulting from exposure to tobacco smoke and from radon: Implication for preventive interactions. Oncogene. 2002;21:7365-7375. [pmid: 12379879].
Alavanja MC, Brownson RC, Lubin JH, et al. Residential radon exposure and lung cancer among nonsmoking women. (Comment in: J Natl Cancer Inst 86(24):1813-1814). J Natl Cancer Inst. 1994;86(24):1829-1837. [pmid: 7990157].
Alavanja MC, Lubin JH, Mahaffey JA, et al. Residential radon exposure and risk of lung cancer in Missouri. Am J Public Health. 1999;89(7):1042-1048. [pmid: 10394313].
Albering HJ, Hageman GJ, Kleinjans JC, et al. Indoor radon exposure and cytogenetic damage. Lancet. 1992;340(8821):739. [pmid: 1355847].
Alberts WM. Diagnosis and management of lung cancer executive summary. ACCP evidence-based clinical practice guidelines (2nd edition). Chest. 2007;132:1S-19S. http://chestjournal.chestpubs.org/content/132/3_suppl/1S.full.pdf+html. October 24, 2011. [pmid: 17873156].
Alter H, Oswald R. Nationwide distribution of indoor radon measurements: A preliminary database. J Air Pollut Control Assoc. 1987;37(3):227-231.
Altman PL, Dittmer DS. Biological handbooks: Biology data book. 2nd ed. Bethesda, MD. Federation of American Societies for Experimental Biology. 1974;Vol. III:1987-2008. 2041.
Amabile J-C, Leuraud K, Vacquier B, et al. Multifactorial study of the risk of lung cancer among French uranium miners: radon, smoking, and silicosis. Health Phys. 2009;97(6):613-621. [pmid: 19901596].
Andersen ME, Krishnan K. Salem H, editor. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. Animal test alternatives: Refinement, reduction, replacement. New York, NY. Marcel Dekker, Inc. 1994:9-25.
Andersen ME, Clewell HJ, Gargas ML, et al. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol. 1987;87(2):185-205. [pmid: 3824380].
Anttila A. Lead content of deciduous tooth enamel from a high-radon area. Acta Odontol Scand. 1987;45(4):283-288. [pmid: 3478933].
Archer VE. Rom W, Archer V, editors. Epidemiologic studies of lung disease among miners exposed to increased levels of radon daughters. Health implications of new energy technologies. Ann Arbor, MI. Ann Arbor Science. 1980:13-22.
Archer VE. Enhancement of lung cancer by cigarette smoking in uranium and other miners. Carcinogenesis. 1985;8:23-37.
Archer VE, Brinton HP, Wagoner JK. Pulmonary function of uranium miners. Health Phys. 1964;10:1183-1194. [pmid: 14244764].
Archer VE, Gillam JD, Wagoner JK. Respiratory disease mortality among uranium miners. Ann NY Acad Sci. 1976;271:280-293. [pmid: 1069515].
Archer VE, Radford EP, Axelson O. Radon daughter cancer in man: Factors in exposure-response relationships at low levels. Conference workshop on lung cancer epidemiology and industrial applications of sputum cytology. Golden, CO. Colorado School of Mines Press. 1979.
Archer VE, Saccomanno G, Jones JH. Frequency of different histologic types of bronchogenic carcinoma as related to radiation exposure. Cancer. 1974;34(6):2056-2060. [pmid: 4434335].
Archer VE, Wagoner JK, Lundin FE. Lung cancer among uranium miners in the United States. Health Phys. 1973;25(4):351-371. [pmid: 4361970].
ASTM. Method D 5072-98. Standard test method for radon in drinking water. 1999 Annual book of ASTM methods. Vol. 11.02 Water (III). West Conshohocken, PA. American Society for Testing and Materials. 1999:673-675.
Attfield MD, Schleiff PL, Lubin JH, et al. The diesel exhaust in miners study: A cohort mortality study with emphasis on lung cancer. J Natl Cancer Inst. 2012;104. [Epub ahead of print].
Auerbach O, Saccomanno G, Kuschner M, et al. Histologic findings in the tracheobronchial tree of uranium miners and non-miners with lung cancer. Cancer. 1978;42:483-489. [pmid: 679150].
Auvinen A, Makelainen I, Hakama M, et al. Indoor radon exposure and risk of lung cancer: A nested case-control study in Finland. (Erratum in: J Natl Cancer Inst 90(5):401-402). (Comment in: J Natl Cancer Inst 89(8):584-585). J Natl Cancer Inst. 1996;88(14):966-972. [pmid: 8667427].
Auvinen A, Salonen L, Pekkanen J, et al. Radon and other natural radionuclides in drinking water and risk of stomach cancer: A case-cohort study in Finland. Int J Cancer. 2005;114(1):109-113. [pmid: 15523702].
Axelson O, Sundell L. Mining, lung cancer and smoking. Scand J Work Environ Health. 1978;4(1):46-52. [pmid: 644266].
Bahtijari M, Stegnar P, Shemsidini Z, et al. Indoor air radon concentration in schools in Prizren, Kosovo. Radiat Prot Dosimetry. 2006;121(4):469-473. [pmid: 16766569].
Bair W. ICRP work in progress: Task group to review models of the respiratory tract. Radiol Prot Bull. 1985;63:5-6.
Band P, Feldstein M, Saccomanno G, et al. Potentiation of cigarette smoking and radiation: Evidence from a sputum cytology survey among uranium miners and controls. Cancer. 1980;45(6):1273-1277. [pmid: 7357519].
Barnes DG, Dourson M. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol. 1988;8(4):471-486. [pmid: 3222488].
Barros-Dios JM, Barreiro MA, Ruano-Ravina A, et al. Exposure to residential radon and lung cancer in Spain: A population-based case-control study. (Erratum in: Am J Epidemiol 157(9):859). Am J Epidemiol. 2002;156(6):548-555. [pmid: 12226002].
Bastide K, Guilly M-N, Bernaudin J-F, et al. Molecular analysis of the Ink4a/Rb1-Arf/Tp53 pathways in radon-induced rat lung tumors. Lung Cancer. 2009;63:348-353. [pmid: 18656278].
Bauchinger M, Schmid E, Braselmann H, et al. Chromosome aberrations in peripheral lymphocytes from occupants of houses with elevated indoor radon concentrations. Mutat Res. 1994;310(1):135-142. [pmid: 7523877].
Baysson H, Tirmarche M, Tymen G, et al. Indoor radon and lung cancer in France. (Comment in: Epidemiology 17(1):121, author reply 121-122). Epidemiology. 2004;15(6):709-716. [pmid: 15475720].
Becker K. Health effects of high radon environments in central Europe: Another test for the LNT hypothesis?. Dose Response Int J. 2003;1(1):3-35.
Bergdahl IA, Jonsson H, Eriksson K, et al. Lung cancer and exposure to quartz and diesel exhaust in Swedish iron ore miners with concurrent exposure to radon. Occup Environ Med. 2010;67:513-518. [pmid: 20519746].
Berger GS, editor. Epidemiology of endometriosis. Endometriosis: Advanced management and surgical techniques. New York, NY. Springer-Verlag. 1994:3-7.
Bhat R, Sridhar KR, Rajashekara KM, et al. ^210^Po bioaccumulation in coastal and sand dune wild legumes—Canavalia spp. of southwest coast of India. J Environ Monit. 2005;7:856-860. [pmid: 16121264].
Biberman R, Lusky A, Schlesinger T, et al. Increased risk for small cell lung cancer following residential exposure to low-dose radon: A pilot study. Arch Environ Health. 1993;48(4):209-212. [pmid: 8395166].
Bignon J, Monchaux G, Chameaud J, et al. Incidence of various types of thoracic malignancy induced in rats by intrapleural injection of 2 mg of various mineral dusts after inhalation of ^222^Ra. Carcinogenesis. 1983;4(5):621-628. [pmid: 6303618].
Bilban M, Jakopin CB. Incidence of cytogenetic damage in lead-zinc mine workers exposed to radon. Mutagenesis. 2005;20(3):187-191. [pmid: 15817573].
Birchall A, James AC. Uncertainty analysis of the effective dose per unit exposure from radon progeny and implications for ICRP risk-weighting factors. Radiat Prot Dosimetry. 1994;53(1):133-140.
Black SC, Archer VE, Dixon WC, et al. Correlation of radiation exposure and lead-210 in uranium miners. Health Phys. 1968;14(2):81-93. [pmid: 5639688].
Blanchard RL, Archer VE, Saccomanno G. Blood and skeletal levels of ^210^Pb–^210^Po as a measure of exposure to inhaled radon daughter products. Health Phys. 1969;16(5):585-596. [pmid: 5791185].
Blot WJ, Xu ZY, Boice JD, et al. Indoor radon and lung cancer in China. (Comment in: J Natl Cancer Inst 82(21):1722-1723). J Natl Cancer Inst. 1990;82(12):1025-1030. [pmid: 2348467].
Bochicchio F, Forastiere F, Farchi S, et al. Residential radon exposure, diet and lung cancer: A case-control study in a Mediterranean region. Int J Cancer. 2005;114(6):983-991. [pmid: 15645434].
Boice JD. Radon, your home or mine? (Comment on: Radiat Res 147(2)126-134). Radiat Res. 1997;147(2):135-137. [pmid: 9008204].
Boice JD, Cohen SS, Mumma MT, et al. A cohort study of uranium millers and miners of Grants, New Mexico, 1979–2005. J Radiol Prot. 2008;28:303-325. [pmid: 18714128].
Bonner MR, Bennett WP, Xiong W, et al. Radon, secondhand smoke, glutathione-S-transferase M1 and lung cancer among women. Int J Cancer. 2006;119(6):1462-1467. [pmid: 16642467].
Booker DV, Chamberlain AC, Newton D, et al. Uptake of radioactive lead following inhalation and injection. Br J Radiol. 1969;42:457-466. [pmid: 5810859].
Bowring CS. Short term radon measurements in buildings. J Radiol Prot. 1992;12(4):239-241.
Brandom WF, Saccomanno G, Archer VE, et al. Chromosome aberrations as a biological dose-response indicator of radiation exposure in uranium miners. Radiat Res. 1978;76(1):159-171. [pmid: 734043].
Brenner DJ, Ward JF. Constraints on energy deposition and target size of multiply damaged sites associated with DNA double-strand breaks. Int J Radiat Biol. 1992;61(6):737-748. [pmid: 1351522].
Breslin A. Techniques for measuring radon in buildings. Washington, DC. National Bureau of Standards Special Publication 581, In. Proceedings of a Roundtable Discussion of Radon in Buildings held at NSB. Gaithersburg, Maryland. 1980.
Bridges BA, Cole J, Arlett CF, et al. Possible association between mutant frequency in peripheral lymphocytes and domestic radon concentrations (Comment in: Lancet 337(8755):1476). Lancet. 1991;337(8751):1187-1189. [pmid: 1673739].
Brookins DG. Correlation of soil radon and uranium with indoor radon in the Albuquerque, New Mexico (USA). Environ Geol Water Sci. 1991;17(3):209-218.
Brooks AL, Khan MA, Duncan A, et al. Effectiveness of radon relative to acute ^60^Co γ-rays for induction of micronuclei in vitro and in vivo. Int J Radiat Biol. 1994;66(6):801-808. [pmid: 7814979].
Brooks AL, Rithidech K, Kitchin RM, et al. Evaluating chromosome damage to estimate dose to tracheal epithelial cells. Indoor radon and lung cancer: Reality or myth?. Twenty-ninth Hanford Symposium on health and the environment. October 15–19, 1990. Columbus, OH. Battelle Press. 1992:601-614.
Brown WL, Hess CT. Measurement of the biotransfer and time constant of radon from ingested water by human breath analysis. Health Phys. 1992;62(2):162-170. [pmid: 1730558].
Brüske-Hohlfeld I, Rosario AS, Wölke G, et al. Lung cancer risk among former uranium miners of the WISMUT Company in Germany. (Comment in: Health Phys 91(4):390-391, author reply 392). Health Phys. 2006;90(3):208-216. [pmid: 16505617].
Bunzl K, Ruckerbauer F, Winkler R. Temporal and small-scale spatial variability of ^222^Rn gas in a soil with a high gravel content. Sci Total Environ. 1998;220(2–3):157-166. [pmid: 9810724].
Butler C, Samet JM, Black WC, et al. Histopathologic findings of lung cancer in Navajo men: Relationship to U mining. Health Phys. 1986;51(3):365-368. [pmid: 3744838].
Buttafuoco G, Tallarico A, Falcone G. Mapping soil gas radon concentration: A comparative study of geostatistical methods. Environ Monit Assess. 2007;131(1–3):135-151. [pmid: 17242970].
Butterweck G, Schuler C, Vezzu G, et al. Experimental determination of the absorption rate of unattached radon progeny from respiratory tract to blood. Radiat Prot Dosimetry. 2002;102(4):343-348. [pmid: 12474944].
Carta P, Cocco P, Picchiri G. Lung cancer mortality and airways obstruction among metal miners exposed to silica and low levels of radon daughters. Am J Ind Med. 1994;25(4):489-506. [pmid: 8010293].
CDC. Radon testing in households with a residential smoker - United States, 1993–1994. Centers for Disease Control. MMWR Morb Mortal Wkly Rep. 1999;48(31):683-686. [pmid: 10484124].
Cember H. Introduction to health physics. 2nd ed. New York, NY. Pergamon Press. 1983:335-341.
Cember H, Johnson TE. Introduction to health physics. 4th ed. New York, NY. McGraw Hill. 2009:625.
Chamberlain AC, Dyson ED. The dose to the trachea and bronchi from the decay products of radon and thoron. Br J Radiol. 1956;29(342):317-325. [pmid: 13316020].
Chameaud J, Masse R, Lafuma J. Influence of radon daughter exposure at low doses on occurrence of lung cancer in rats. Radiation Protection Dosimetry. 1984;7:385-388.
Chameaud J, Perraud R, Chrétien J, et al. Sanders CL, Cross FT, Dagle GE, et al., editors. Combined effects of inhalation of radon daughter products and tobacco smoke. Pulmonary toxicology of respirable particles. Oak Ridge, TN. U. S. Department of Energy. 1980:551-557.
Chameaud J, Perraud R, Chrétien J, et al. Lung carcinogenesis during in vivo cigarette smoking and radon daughter exposure in rats. Recent Results Cancer Res. 1982b;82:11-20. [pmid: 7111833].
Chameaud J, Perraud R, LaFuma J, et al. Karbe E, Park J, editors. Lesions and lung cancers induced in rats by inhaled radon 222 at various equilibriums with radon daughters. Experimental lung cancer. Carcinogenesis and bioassays. New York, NY. Springer-Verlag. 1974:410-421.
Chameaud J, Perraud R, LaFuma J, et al. Clemente C, Nero A, Steinhausler F, et al., editors. Cancers induced by Rn-222 in the rat. Proceedings of the specialist meeting on the assessment of radon and daughter exposure and related biological effects. Salt Lake City, UT. RD Press. 1982a:198-209.
Chandrashekara MS, Sannappa J, Paramesh L. Studies on atmospheric electrical conductivity related to radon and its progeny concentrations in the lower atmosphere at Mysore. Atmos Environ. 2006;40(11):87-95.
Checkoway H, Matthre RM, Hickey JL, et al. Mortality among workers in the Florida phosphate industry. J Occup Med. 1985;27(12):885-892. [pmid: 4087054].
ChemIDplus. Radon and radon isotopes. ChemIDplus. Bethesda, MD. U. S. National Library of Medicine. 2012. http://sis.nlm.nih.gov/chemical.html. January 26, 2012.
Chernick CL, Claassen HH, Fields PR, et al. Fluorine compounds of xenon and radon. Science. 1962;138(3537):136-138. [pmid: 17818399].
Clemente GF, Renzetti A, Santori G, et al. Vohra K, Pillai K, Mishra U, et al., editors. Pb-210-Po-210 tooth content and radon daughter exposure. Proceedings of the second special symposium on natural radiation environment. New York, NY. John Wiley and Sons. 1982:269-274.
Clemente GF, Renzetti A, Santori G, et al. Relationship between the ^210^Pb content of teeth and exposure to Rn and Rn daughters. Health Phys. 1984;47(2):253-262. [pmid: 6090344].
Clewell HJ, Andersen ME. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health. 1985;1(4):111-131. [pmid: 3843496].
Cohen BL. Radon: Characteristics, natural occurrence, technological enhancement, and health effects. Prog Nucl Energy. 1979;4:1-24.
Cohen BL. A national survey of 222-Rn in U. S. homes and correlating factors. Health Phys. 1986;51:175-183. [pmid: 3733450].
Cohen BS. Particle deposition in human and canine tracheobronchial casts: A determinant of radon dose to the critical cells of the respiratory tract. Health Phys. 1996;70(5):695-705. [pmid: 8690581].
Cohen BL, Nason R. A diffusion barrier charcoal adsorption collector for measuring Rn concentrations in indoor air. Health Phys. 1986;50(4):457-463. [pmid: 3957669].
Cohen N, Jaakkola T, Wrenn ME. Lead-210 concentrations in the bone, blood and excreta of a former uranium miner. Health Phys. 1973;24(6):601-609. [pmid: 4784228].
Cole J, Green MH, Bridges BA, et al. Lack of evidence for an association between the frequency of mutants or translocations in circulating lymphocytes and exposure to radon gas in the home. Radiat Res. 1996;145(1):61-69. [pmid: 8532838].
Collé R, Kishore R. An update on the NIST radon-in-water standard generator: its performance efficacy and long-term stability. Nucl Instrum Methods Phys Res A. 1997;391(3):511-528.
Correia JA, Weise S, Callahan RJ, et al. Cumulative organ radioactivity concentrations of 222-radon and its progeny following ingestion. Journal of Nuclear Medicine. 1988;29(5):872-873.
Cothern CR. Cothern C, Smith J, editors. Properties. Environmental radon. New York, NY. Plenum Press. 1987a:1-29.
Cothern CR. Cothern C, Smith J, editors. History and uses. Environmental radon. New York, NY. Plenum Press. 1987b:31-58.
Cothern CR, Lappenbusch WL, Michel J. Drinking-water contribution to natural background radiation. Health Phys. 1986;50(1):33-47. [pmid: 3943972].
Crawford-Brown DJ. The biokinetics and dosimetry of radon-222 in the human body following ingestion of ground water. Environmental Geochemistry and Health. 1989;11:10-17.
Crawford-Brown DJ, Michel J. Cothern C, Smith J, editors. Measurement. Environmental radon. New York, NY. Plenum Press. 1987:59-80.
Cross FT. Radon inhalation studies in animals. Radiat Prot Dosim. 1988;24(1):463-466.
Cross FT. Invited commentary: Residential radon risks from the perspective of experimental animal studies. (Comment on: Am J Epidemiol 140(4):310-322). Am J Epidemiol. 1994;140(4):333-339. [pmid: 8059768].
Cross FT, Filipy RE, Loscutoff SM, et al. Histopathologic, morphometric and physiologic investigation of lungs of dogs exposed to uranium ore dust. International conference on radiation hazards in mining. 1981a:228-235.
Cross FT, Palmer RF, Busch RH, et al. Development of lesions in Syrian golden hamsters following exposure to radon daughters and uranium ore dust. Health Phys. 1981b;41(1):135-153. [pmid: 7275591].
Cross FT, Palmer RF, Busch RH, et al. Clement C, Nero A, Steinhausler F, et al., editors. Influence of radon daughter exposure rate and uranium ore dust concentration on occurrence of lung tumors. Proceedings of the specialist meeting on the assessment of radon and daughter exposure and related biological effects. Salt Lake City. RD Press. 1982a:189-197.
Cross FT, Palmer RF, Busch RH, et al. Thompson R, Mahaffey J, editors. An overview of PNL radon experiments with reference to epidemiological data. Life-span radiation effects studies in animals: What can they tell us?. Proceedings 22nd Hanford Life Sciences Symposium. Richland, WA. Springfield, VA. U. S. Department of Energy. 1986. DE87000490.
Cross FT, Palmer RF, Dagle G, et al. Influence of radon daughter exposure rate, unattachment fraction, and disequilibrium on occurrence of lung tumours. Radiation Protection Dosimetry. 1984;7:381-384.
Cross FT, Palmer RF, Filipy RE, et al. Carcinogenic effects of radon daughters, uranium ore dust and cigarette smoke in beagle dogs. Health Phys. 1982b;42(1):33-52. [pmid: 7056646].
Dagle GE, Cross FT, Gies RA. Morphology of respiratory tract lesions in rats exposed to radon progeny. Indoor radon and lung cancer: Reality or myth?. Twenty-ninth Hanford Symposium on health and the environment. October 15–19, 1990. Columbus, OH. Battelle Press. 1992:659-676.
Damber L, Larsson LG. Combined effects of mining and smoking in the causation of lung carcinoma. Acta Radiol Oncol. 1982;21(5):305-313. [pmid: 6297249].
Darby S, Hill D, Auvinen A, et al. Radon in homes and risk of lung cancer: Collaborative analysis of individual data from 13 European case-control studies. (Comment in: BMJ 330(7485):226-227; 330(7500):1151). BMJ. 2005;330(7485):223. [pmid: 15613366].
Darby S, Hill D, Deo H, et al. Residential radon and lung cancer--detailed results of a collaborative analysis of individual data on 7148 persons with lung cancer and 14,208 persons without lung cancer from 13 epidemiologic studies in Europe. (Erratum in: Scand J Work Environ Health. 33(1):80). Scand J Work Environ Health. Suppl 1. 2006;32:1-83. [pmid: 16538937].
Darby S, Whitley E, Silcocks P, et al. Risk of lung cancer associated with residential radon exposure in south-west England: A case-control study. (Comment in: Br J Cancer 79(9-10):1621-1623). Br J Cancer. 1998;78(3):394-408. [pmid: 9703290].
Davies B, Morris T. Physiological parameters in laboratory animals and humans. Pharmacology Research. 1993;10:1093-1095.
Dean R. Wiese W, editor. Semen analyses among uranium miners. Birth defects in the Four Corners area. Transcript of a meeting. Albuquerque, NM. University of New Mexico School of Medicine. 1981:51-54.
Dobbin M. Deep breath down under. US News World Rep. 1987;102:40.
DOE. Model for assessing radiation dose to epithelial cells of the human respiratory tract from radon progeny. Washington, DC. U. S. Department of Energy. 1990. DE91005614.
DOE. NuDat 2.4. National Nuclear Data CenterU.SDepartment of Energy. 2008. http://www.nndc.bnl.gov/nudat2/. June 23, 2008.
Eatough JP. Alpha-particle dosimetry for the basal layer of the skin and the radon progeny 218-Po and 214-Po. Phys Med Biol. 1997;42:1899-1911. [pmid: 9364586].
Eatough JP, Henshaw DL. Radon and thoron associated dose to the basal layer of the skin. Phys Med Biol. 1992;37(4):955-967. [pmid: 1317037].
Eatough JP, Worley A, Moss GR. Personal monitoring of ^218^Po and ^214^Po radionuclide deposition onto individuals under normal environmental exposure conditions. Phys Med Biol. 1999;44(9):2227-2239. [pmid: 10495117].
Edling C, Axelson O. Quantitative aspects of radon daughter exposure and lung cancer in underground miners. Br J Ind Med. 1983;40(2):182-187. [pmid: 6830715].
Eichholz G. Cothern C, Smith J, editors. Human exposure. Environmental radon. New York, NY. Plenum Press. 1987:131-172.
Eisenbud M, Laurer GR, Rosen JC, et al. In vivo measurement of lead-210 as an indicator of cumulative radon daughter exposure in uranium miners. Health Phys. 1969;16(5):637-646. [pmid: 5791190].
El-Hussein A, Ahmed AA, Mohammed A. Radiation dose to the human respiratory tract from inhalation of radon-222 and its progeny. Appl Radiat Isot. 1998;49(7):783-790. [pmid: 9570097].
Ellenhorn MJ, Schoenwald S, Ordog G, et al. Radiation poisoning. Ellenhorn’s medical toxicology: Diagnosis and treatment of human poisoning. Baltimore, MD. Williams & Wilkins. 1997:1682-1723.
*. EPA. A citizen’s guide to radon - what it is and what to do about it. Washington, DC. U. S. Environmental Protection Agency, Office of Air and Radiation. 1986a.
EPA. Interim radon and radon decay product measurement protocols. Washington, DC. U. S. Environmental Protection Agency, Office of Radiation Programs. 1986b. EPA52018604.
EPA. Interim protocols for screening and follow-up radon and radon decay product measurements. Washington, DC. U. S. Environmental Protection Agency. 1987a. EPA520860141. PB89224265.
EPA. Radiation protection guidance to federal agencies for occupational exposure; approval of U. S. Environmental Protection Agency recommendations U.S. Environmental Protection Agency. Fed Regist. 1987b;52:2823-2834.
EPA. Limiting values of radionuclide intake and air concentration and dose conversion factors for inhalation, submersion, and ingestion. Federal Guidance Report No. 11. Washington, DC. U. S. Environmental Protection Agency, Office of Radiation Programs. 1988. EPA520188020.
EPA. Risk assessment methodology. Environmental impact statement for NESHAPS radionuclides. Background information document. Washington, DC. U. S. Environmental Protection Agency, Office of Radiation Programs. 1989;Vol. 1. EPA520189005.
EPA. Indoor radon and radon decay product measurement device protocols. U.S. Environmental Protection Agency. 1992a. http://www.smallbiz-enviroweb.org/resources/sbopubs/jdocs/j08.pdf. November 29, 2011.
EPA. National residential radon survey: Summary report. Washington, DC. U. S. Environmental Protection Agency. 1992b. EPA402R92011.
*. EPA. External exposure to radionuclides in air, water, and soil. Washington, DC. U. S. Environmental Protection Agency. Office of Radiation and Indoor Air. 1993a. EPA402R93081 http://www.epa.gov/radiation/docs/federal/402-r-93-081.pdf. November 29, 2011.
EPA. Protocols for radon and radon decay product measurements in homes. U.S. Environmental Protection Agency. Office of Air and Radiation. 1993b. EPA 402R93003. http://www.epa.gov/radon/pdfs/homes_protocols.pdf. November 29, 2011.
EPA. Radon measurements in schools. Revised edition. U.S. Environmental Protection Agency. Office of Air and Radiation. 1993c. EPA402R92014. http://www.epa.gov/radon/pdfs/radon_measurement_in_schools.pdf. November 29, 2011.
EPA. Technical resource document. Extraction and beneficiation of ores and minerals. Vol. 5. Uranium. Washington, DC. U. S. Environmental Protection Agency. 1995.
EPA. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC. U. S. Environmental Protection Agency, Risk Assessment Forum. 1997. EPA630R96012.
EPA. Automated Form R for Windows: User’s guide (RY97). Washington, DC. U. S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. 1998.
EPA. Cancer risk coefficients for environmental exposure to radionuclides. Federal Guidance Report No. 13. Washington, DC. U. S. Environmental Protection Agency. 1999a. EPA402R99001.
EPA. National primary drinking water regulations; radon-222 U.S. Environmental Protection Agency. Federal Register. 1999b;64(211):59246-59377. http://www.gpo.gov/fdsys/pkg/FR-1999-11-02/pdf/99-27741.pdf. February 7, 2012.
EPA. National primary drinking water regulations; radionuclides; final rule U.S. Environmental Protection Agency. Federal Register. 2000;65(236):76708-76753. http://www.gpo.gov/fdsys/pkg/FR-2000-12-07/pdf/00-30421.pdf. February 7, 2012.
EPA. Radionuclide table: Radionuclide carcinogenicity – slope factors. Washington, DC. Office of Radiation and Indoor Air. U. S. Environmental Protection Agency. 2001. http://www.epa.gov/radiation/heast/docs/heast2_table_4-d2_0401.pdf. November 29, 2011.
EPA. EPA assessment of risks from radon in homes. U.S. Environmental Protection Agency. 2003. EPA402R03003. http://www.epa.gov/radiation/docs/assessment/402-r-03-003.pdf. November 29, 2011.
EPA. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. 2005. EPA260B05001.
EPA. Final report: Review of existing and proposed tailings impoundment technologies. U.S. Environmental Protection Agency. 2008a. http://www.epa.gov/radiation/docs/neshaps/subpart-w/tailings-impoundment-tech.pdf. Novevember 29, 2011.
EPA. Radon. U.S. Environmental Protection Agency. 2008b. http://www.epa.gov/radon/. May 13, 2008.
EPA. More action needed to protect public from indoor radon risks. Report No. 08-P-0174. Washington, DC. U. S. Environmental Protection Agency. 2008c.
EPA. A Citizen’s Guide to Radon. The guide to protecting yourself and your family from radon. U.S. Environmental Protection Agency. 2009a. EPA402K09001. http://www.epa.gov/radon/pdfs/citizensguide.pdf. December 6, 2011.
EPA. National recommended water quality criteria. Washington, DC. U. S. Environmental Protection Agency, Office of Water, Office of Science and Technology. 2009b. http://water.epa.gov/scitech/swguidance/standards/current/upload/nrwqc-2009.pdf. December 6, 2011.
EPA. Consumer's guide to radon reduction. How to fix your home. U.S. Environmental Protection Agency. 2010a. http://www.epa.gov/radon/pdfs/consguid.pdf. December 6, 2011.
EPA. The Clean Air Act amendments of 1990 list of hazardous air pollutants. Clean Air Act. U.S. Environmental Protection Agency. 2010b. United States Code. 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. December 6, 2011.
EPA. EPA map of radon zones. U.S. Environmental Protection Agency. 2011a. http://www.epa.gov/radon/zonemap.html. December 6, 2011.
EPA. EPA About the radiation and indoor environments national laboratory (RIENL). U.S. Environmental Protection Agency. 2011b. http://www.epa.gov/aboutepa/rienl.html. December 6, 2011.
EPA. National emission standards for hazardous air pollutants. Subpart T-National emission standards for radon emissions from the disposal of uranium mill tailings. U.S. Environmental Protection Agency. 2011c. 40 CFR 61 Subpart T. http://ecfr.gpoaccess.gov/cgi/t/text/textidx?c=ecfr&sid=415e04c6bdbe246fe055d37a57ed8701&rgn=div6&view=text&node=40:8.0.1.1.1.20&idno=40. December 7, 2011.
EPA. 2011 Edition of the drinking water standards and health advisories. Washington, DC. Office of Water. U. S. Environmental Protection Agency. 2011d. EPA820-R-11-002. http://water.epa.gov/action/advisories/drinking/upload/dwstandards2011.pdf. December 6, 2011.
EPA. Acute exposure guideline levels (AEGLs). Washington, DC. Office of Pollution Prevention and Toxics. U. S. Environmental Protection Agency. 2011e. http://www.epa.gov/oppt/aegl/pubs/compiled_aegls_nov072011.pdf. December 6,, 2011.
EPA. Designation of hazardous substances. U.S. Environmental Protection Agency. 2011f. Code of Federal Regulations. 40 CFR 302.4 http://www.gpo.gov/fdsys/pkg/CFR-2011-title40-vol28/pdf/CFR-2011-title40-vol28-sec302-4.pdf. December 6, 2011.
EPA. Listing of states and jurisdictions with RRNC codes. U.S. Environmental Protection Agency. 2011g. http://www.epa.gov/radon/rrnc/code_listing.html. February 7, 2012.
EPA. Provisions. Standands for management of thorium byproduct material pursuant to section 84 of the Atomic Energy Act of 1954, as amended. U.S. Environmental Protection Agency. 2011h. Code of Federal Regualations:40 CFR 192.141. http://www.gpo.gov/fdsys/pkg/CFR-2011-title40-vol25/pdf/CFR-2011-title40-vol25-sec192-41.pdf. February 8, 2012.
EPA. Standard. Subpart B-national emission standards for radon emissions from underground uranium mills. U.S. Environmental Protection Agency. 2011i. Code of Federal Regulations:40 CFR 61.22. http://www.gpo.gov/fdsys/pkg/CFR-2011-title40-vol8/pdf/CFR-2011-title40-vol8-sec61-22.pdf. February 8, 2012.
EPA. Standard. Subpart H-national emission standards for emissions of radionuclides other than radon from Department of Energy. U.S. Environmental Protection Agency. 2011j. Code of Federal Regulations:40 CFR 61.92. http://www.gpo.gov/fdsys/pkg/CFR-2011-title40-vol8/pdf/CFR-2011-title40-vol8-sec61-92.pdf. February 8, 2011.
EPA. Standard. Subpart Q-National emission standards for radon emissions from Department of Energy facilities. U.S. Environmental Protection Agency. 2011k. Code of Federal Regulations:40 CFR 61.192. http://www.gpo.gov/fdsys/pkg/CFR-2011-title40-vol8/pdf/CFR-2011-title40-vol8-sec61-192.pdf. February 8, 2012.
EPA. Standard. Subpart R-national emission standards for radon emissions from phosphogypsum stacks. U.S. Environmental Protection Agency. 2011l. Code of Federal Regulations:40 CFR 61.202. http://www.gpo.gov/fdsys/pkg/CFR-2011-title40-vol8/pdf/CFR-2011-title40-vol8-sec61-202.pdf. February 8, 2012.
EPA. Standard. Subpart T-National emission standards for radon emissions from the disposal of uranium mill tailings. U.S. Environmental Protection Agency. 2011m. Code of Federal Regulations:40 CFR 61.222. http://www.gpo.gov/fdsys/pkg/CFR-2011-title40-vol8/pdf/CFR-2011-title40-vol8-sec61-222.pdf. February 8, 2012.
EPA. Standard. Subpart W-National emission standards for radon emissions from operating mill tailings. 2011n. Code of Federal Regulations:40 CFR 61.252. http://www.gpo.gov/fdsys/pkg/CFR-2011-title40-vol8/pdf/CFR-2011-title40-vol8-sec61-252.pdf. February 8, 2012.
EPA. Emission standard. Subpart K-National emission standards for radionuclide emissions from elemental phosphorus plants. U.S. Environmental Protection Agency. 2011o. Code of Federal Regulations:40 CFR 61.122. http://www.gpo.gov/fdsys/pkg/CFR-2011-title40-vol8/pdf/CFR-2011-title40-vol8-sec61-122.pdf. November 29, 2011.
EPA. Aeration and air stripping. Drinking water treatability database. U.S. Environmental Protection Agency. 2012a. http://iaspub.epa.gov/tdb/pages/treatment/treatmentOverview.do?treatmentProcessId=346223903. May 16, 2012.
EPA. User's guide: Radionuclide carcinogenicity. Radiation protection. U.S. Environmental Protection Agency. 2012b. http://www.epa.gov/rpdweb00/heast/userguid.html. May 16, 2012.
Ericson JE, Pham PG. Radon levels in combustion stream of a natural gas incinerator power plant. Bull Environ Contam Toxicol. 2001;66(1):59-63. [pmid: 11080337].
European Commission. European collaborative action. Indoor air quality and its impact on man. Environment and quality of life. Report no. 15. Radon in indoor air. Luxenbourg. European Commission. 1995. http://www.inive.org/medias/ECA/ECA_Report15.pdf. November 29, 2011.
Evans HH. Obe G, editor. Cellular and molecular effects of radon and other alpha particle emitters. Advances in mutagenesis research. Berlin, Germany. Springer-Verlag. 1991;Vol. 3:28-52.
Evans HH. Relationship of the cellular and molecular effects of alpha-particle irradiation to radon-induced lung cancer. Indoor radon and lung cancer: Reality or myth?. Twenty-ninth Hanford Symposium on health and the environment. October 15–19, 1990. Columbus, OH. Battelle Press. 1992:537-552.
Evans HH, Mencl J, Bakale G, et al. Interlaboratory comparison of the effects of radon on L5178Y cells: Dose contribution of radon daughter association with cells. Radiat Res. 1993a;136(1):48-56. [pmid: 8210338].
Evans HH, Mencl J, Hui TE, et al. Cytotoxic and mutagenic effects of radon and radon daughters on murine L5178Y lines differing in DNA repair. Radiat Res. 1993b;136(1):57-64. [pmid: 8210339].
Field RW. Radon occurrence and health risk. Iowa City, IA. University of Iowa. 1999. http://www.cheec.uiowa.edu/misc/radon_occ.pdf. August 28, 2008.
Field RW. Three Mile Island epidemiologic radiation dose assessment revisited: 25 years after the accident. Radiat Prot Dosimetry. 2005;113(2):214-217. [pmid: 15657112].
Field RW, Kross BC. Iowa survey of waterborne ^222^Rn concentrations in private wells. Health Phys. 1998;74(2):249-252. [pmid: 9450594].
*. Field RW, Smith BJ, Lynch CF. Cohen’s paradox. (Comment on: Health Phys 76(4):439-440). Health Phys. 1999a;77(3):328-329. [pmid: 10456506].
Field RW, Smith BJ, Steck DJ, et al. Residential radon exposure and lung cancer: Variation in risk estimates using alternative exposure scenarios. J Expo Anal Environ Epidemiol. 2002;12(3):197-203. [pmid: 12032816].
Field RW, Steck DJ, Lynch CF, et al. Residential radon-222 exposure and lung cancer: Exposure assessment methodology. J Expo Anal Environ Epidemiol. 1996;6(2):181-195. [pmid: 8792296].
Field RW, Steck DJ, Parkhurst MA, et al. Intercomparison of retrospective radon detectors. Environ Health Perspect. 1999b;107(11):905-910. [pmid: 10545336].
Field RW, Steck DJ, Smith BJ, et al. Residential radon gas exposure and lung cancer: The Iowa Radon Lung Cancer Study. (Comment in: Am J Epidemiol 152(9):895-896). Am J Epidemiol. 2000;151(11):1091-1102. [pmid: 10873134].
Field RW, Steck DJ, Smith BJ, et al. The Iowa radon lung cancer study - phase I: Residential radon gas exposure and lung cancer. Sci Total Environ. 2001;272(1–3):67-72. [pmid: 11379939].
Filipy R, Stuart B, Palmer R, et al. Karbe E, Park J, editors. The effects of inhaled uranium mine air contaminants in beagle dogs. Experimental lung cancer. Carcinogenesis and bioassays. New York, NY. Springer-Verlag. 1974:403-410.
Fishbein L. Exposure from occupational versus other sources. Scand J Work Environ Health. 1992;18(1):5-16. [pmid: 1411379].
Fisher EL, Fuortes LJ, Field RW. Occupational exposure of water-plant operators to high concentrations of radon-222 gas. J Occup Environ Med. 1996;38(8):759-764. [pmid: 8863200].
Fitzgerald B, Hopke PK, Datye V, et al. Experimental assessment of the short- and long-term effects of ^222^Rn from domestic shower water on the dose burden incurred in normally occupied homes. Environ Sci Technol. 1997;31:1822-1829.
Fleischer R. A possible association between lung cancer and a geological outcrop. Health Phys. 1986;50:823-827. [pmid: 3011707].
Fomon SJ. Falkner F, editor. Body composition of the infant: Part I: The male reference infant. Human development. Philadelphia, PA. WB Saunders. 1966:239-246.
Fomon SJ, Haschke F, Ziegler EE, et al. Body composition of reference children from birth to age 10 years. Am J Clin Nutr. Suppl 5. 1982;35:1169-1175. [pmid: 7081099].
Fox A, Goldblatt P, Kinlen L. A study of the mortality of Cornish tin miners. Br J Ind Med. 1981;38:378-380. [pmid: 7317301].
Fronka A, Moucka L, Jerabek M. Detection properties of a measuring system for a continuous soil radon concentrations monitoring. Radiat Prot Dosimetry. 2008;130(1):56-59. [pmid: 18407971].
Fry F, Smith-Briggs J, O’Riordan M. Skeletal lead-210 as an index of exposure to radon decay products in mining. Br J Ind Med. 1983;40:58-60. [pmid: 6824600].
Fujiyoshi R, Morimoto H, Sawamura S. Investigation of the soil radon variation during the winter months in Sapporo, Japan. Chemosphere. 2002;47(4):369-373. [pmid: 11999612].
Furuno K. Applications of radioactive spring water and excretion of radon in the expired air. Okayama Daigaku Onsen Kenkyusho Hokoku. 1979;49:1-6. (Japanese).
Geiger EL. Radon film badge. Health Phys. 1967;13(4):407-411. [pmid: 6029686].
George AC. Makofske WJ, Edelstein MR, editors. Instruments and methods for measuring indoor radon and radon progeny concentrations. Radon and the environment. Park Ridge, NJ. Noyes Publications. 1988:118-136.
George A, Breslin A. Deposition of natural radon daughters in human subjects. Health Phys. 1967;13:375-378. [pmid: 5230380].
George A, Breslin A. Deposition of radon daughters in humans exposed to uranium mine atmospheres. Health Phys. 1969;17:115-124. [pmid: 5798567].
Gesell T. Background atmospheric 222-Rn concentrations outdoors and indoors: A review. Health Phys. 1983;45:289-302. [pmid: 6885430].
Gilbert ES, Cross FT, Dagle GE. Analysis of lung tumor risks in rats exposed to radon. Radiat Res. 1996;145(3):350-360. [pmid: 8927704].
Giwercman A, Carlsen E, Keiding N, et al. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl. 1993;101(2):65-71.
Gosink TA, Baskaran M, Holleman DF. Radon in the human body from drinking water. Health Phys. 1990;59(6):919-924. [pmid: 2228620].
Gotchy R, Schiager K. Bioassay methods for estimating current exposures to short-lived radon progeny. Health Phys. 1969;17:199-218. [pmid: 5802571].
Gottlieb L, Husen L. Lung cancer among Navajo uranium miners. Chest. 1982;81:449-452. [pmid: 6279361].
Gray A, Read S, McGale P, et al. Lung cancer deaths from indoor radon and the cost effectiveness and potential of policies to reduce them. BMJ. 2009;338:a3110. http://www.bmj.com/content/338/bmj.a3110.full. May 7, 2012. [pmid: 19129153].
Greenland S, Morgenstern H. Ecological bias, confounding, and effect modification. Int J Epidemiol. 1989;18(1):269-274. [pmid: 2656561].
Guyton A. Physiologic peculiarities of specific pulmonary abnormalities. Basic human physiology. Philadelphia, PA. W.B. Saunders Company. 1977:434-438.
Guzelian PS, Henry CJ, Olin SS, editors. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC. International Life Sciences Institute Press. 1992.
Hamza VZ, Mohankumar MN. Cytogenetic damage in human blood lymphocytes exposed in vitro to radon. Mutat Res. 2009;661:1-9. [pmid: 19022267].
Harley J. Stanley R, Moghissi A, editors. Environmental radon. Noble gases. Washington, DC. U. S. Energy Development and Research Agency, National Environmental Research Center. 1973:109-114. CONF-730915.
Harley N, Pasternack B. Environmental radon daughter alpha dose factors in a five-lobed human lung. Health Phys. 1982;42:789-799. [pmid: 6286535].
Harley NH, Robbins ES. A biokinetic model for ^222^Rn gas distribution and alpha dose in humans following ingestion. Environ Int. 1994;20(5):605-610.
Harley JH, Jetter ES, Nelson N. Elimination of Rn-222 from the body. Environ Int. 1994;20:573-584.
Hellman B, Friis L, Vaghef H, et al. Alkaline single cell gel electrophoresis and human biomonitoring for genotoxicity: A study on subjects with residential exposure to radon. Mutat Res. 1999;442(2):121-132. [pmid: 10393281].
Hess C, Michel J, Horton T, et al. The occurrence of radioactivity in public water supplies in the United States. Health Phys. 1985;48(5):553-586. [pmid: 3886603].
Hess C, Weiffenbach C, Norton S. Environmental radon and cancer correlations in Maine. Health Phys. 1983;45(2):339-348. [pmid: 6885433].
Hodgson JT, Jones RD. Mortality of a cohort of tin miners 1941–1986. (Erratum in: Br J Ind Med 47(12):846). Br J Ind Med. 1990b;47(10):665-676. [pmid: 2223659].
Hoel DG, Davis DL, Miller AB, et al. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst. 1992;84(5):313-320. [pmid: 1738181].
Hofmann W, Steinhausler F, Pohl E. Dose calculations for the respiratory tract from inhaled natural radioactive nuclides as a function of age. I. Health Phys. 1979;37:517-532. [pmid: 536214].
Hollcroft J, Lorenz E. Retention of radon by the mouseIExperimental determination of biodecay and energy absorbed. Nucleonics. 1949;9:63-71. [pmid: 18136977].
Hollcroft J, Lorenz E, Matthews M, et al. Long-term survival following X irradiation and the irradiation of the alpha particles from radon and its decay products. J Natl Cancer Inst. 1955;15:1059-1067. [pmid: 13233950].
Holleman D, Martz D, Schiager K. Total respiratory deposition of radon daughters from inhalation of uranium mine atmospheres. Health Phys. 1969;17:187-192. [pmid: 5802569].
Hopke P. Hopke P, editor. The indoor radon problem explained for the layman. Radon and its decay products. Washington, DC. American Chemical Society. 1987:572-586.
Hornung R, Meinhardt T. Quantitative risk assessment of lung cancer in U. S. uranium miners. Health Phys. 1987;52:417-430. [pmid: 3032855].
Hornung RW, Deddens J, Roscoe R. Modifiers of exposure-response estimates for lung cancer among miners exposed to radon progeny. Environ Health Perspect Suppl. 1995;103:49-53.
Hornung RW, Deddens JA, Roscoe RJ. Modifiers of lung cancer risk in uranium miners from the Colorado Plateau. Health Phys. 1998;74(1):12-21. [pmid: 9415577].
Howe GR, Stager RH. Risk of lung cancer mortality after exposure to radon decay products in the Beaverlodge cohort based on revised exposure estimates. Radiat Res. 1996;146(1):37-42. [pmid: 8677296].
Howe GR, Nair R, Newcombe H, et al. Lung cancer mortality (1950–80) in relation to radon daughter exposure in a cohort of workers at the Eldorado Beaverlodge uranium mine. J Natl Cancer Inst. 1986;77:357-362. [pmid: 3461198].
Howe GR, Nair R, Newcombe H, et al. Lung cancer mortality (1950–80) in relation to radon daughter exposure in a cohort of workers at the Eldorado Port Radium uranium mine: Possible modification of risk by exposure rate. J Natl Cancer Inst. 1987;79:1255-1260. [pmid: 3480377].
HPA. Radon and public health. Report of the independent advisory group on ionising radiation. Health Protection Agency. 2009. http://www.hpa.org.uk/webc/HPAwebFile/HPAweb_C/1243838496865. February 7, 2012.
HSDB. Radon, radioactive. Hazardous Substances Data Bank. National Library of Medicine. 2008. http://toxnet.nlm.nih.gov. June 25, 2008.
Hursh JB, Mercer TT. Measurement of ^212^Pb loss rate from human lungs. J Appl Physiol. 1970;28:268-274. [pmid: 5414756].
Hursh JB, Schraub A, Sattler EL, et al. Fate of 212Pb inhaled by human subjects. Health Phys. 1969a;16:257-267. [pmid: 5787740].
Hursh JB, Neuman WR, Toribara T, et al. Oral ingestion of uranium by man. Health Phys. 1969b;17:619-621. [pmid: 5344473].
Hursh J, Morken D, Davis T, et al. The fate of radon ingested by man. Health Phys. 1965;11:465-476. [pmid: 14325414].
Hutchinson JMR, Mullen PA, Collé R. Development of a regenerative radon-in-water radioactivity standard. Nucl Instrum Methods Phys Res. 1984;23(2–3):451-457. http://www.sciencedirect.com/science/article/pii/0167508784906914. (Retrieval in progress).
Hutchinson JMR, Mullen PA, Collé R. The NBS radon-water standard generator. Nucl Instrum Methods Phys Res A. 1986;247(2):385-389. http://www.sciencedirect.com/science/article/pii/0168900286913215. (Retrieval in progress).
Hwang S, Lein RD, Morgan DA. Noble gases. Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons. 2005. http://mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/gasehwan.a01/current/pdf. May 13, 2008.
IAEA. The long-term stabilisation of uranium mill tailings. Final report on the co-ordinated research project 2000–2004. Vienna, Austria. International Atomic Energy Agency. 2004. IAEA-TECDOC-1403. http://www-pub.iaea.org/MTCD/publications/PubDetails.asp?pubId=7054. August 26, 2008.
IARC. Agents reviewed by the IARC monographs: Vol. 1–99. Lyon, France. International Agency for Research on Cancer. 2008. http://monographs.iarc.fr/ENG/Classification/index.php. April 24, 2008.
ICRP. Report of the Task Group on Reference Man. ICRP Publication 23. New York, NY. International Commission on Radiological Protection. Pergamon Press. 1975.
ICRP. Recommendations of the International Commission on Radiological Protection. ICRP Publication No. 26. New York, NY. International Commission on Radiological Protection. Pergamon Press. 1977.
ICRP. Limits for inhaled radionuclides by workers. ICRP Publication 23. New York, NY. International Commission on Radiological Protection. Pergamon Press. 1978.
ICRP. Limits for intakes of radionuclides by workers. ICRP Publication 30 Part 1. New York, NY. International Commission on Radiological Protection. Pergamon Press. 1979.
ICRP. Limits for intakes of radionuclides by workers. ICRP Publication 30 Part 2. New York, NY. International Commission on Radiological Protection. Pergamon Press. 1980.
ICRP. Limits for inhalation of radon daughters by workers. ICRP Publication 32. New York, NY. International Commission on Radiological Protection. Pergamon Press. 1982.
ICRP. Age-dependent doses to members of the public from intake of radionuclides, Part 1. ICRP Publication 56. Elmsford, NY. International Commission on Radiological Protection. Pergamon Press. 1990:6-12.
ICRP. Age-dependent doses to members of the public from intake of radionuclides - Part 2 ingestion dose coefficients. ICRP Publication 67. Ann ICRP. 1992;22(3–4). (Retrieval in progress).
ICRP. Protection against radon-222 at home and at work. ICRP Publication 65. Tarrytown, NY. International Commission on Radiological Protection. Elsevier Science, Inc. 1994a;Vol. 23(No. 2).
ICRP. Human respiratory tract model for radiological protection. Oxford. International Commission on Radiological Protection. Pergamon Press. 1994b.
ICRP. Age-dependent doses to members of the public from intake of radionuclides. Part 2. Ingestion dose coefficients. ICRP Publication 67. Tarrytown, NY. International Commission on Radiological Protection. Elsevier Sciences, Inc. 1994c:75-84.
ICRP. Dose coefficients for intakes of radionuclides by workers. ICRP Publication 68. Tarrytown, NY. International Commission on Radiological Protection. Elsevier Science Inc. 1995c:1-13. 64. 65.
ICRP. Age-dependent doses to members of the public from intake of radionuclides - Part 3 ingestion dose coefficients. ICRP Publication 69. Ann ICRP. 1995a;25(1). (Retrieval in progress).
ICRP. Age-dependent doses to members of the public from intake of radionuclides - Part 4 inhalation dose coefficients. ICRP Publication 71. Ann ICRP. 1995b;25(3–4). (Retrieval in progress).
ICRP. Age-dependent doses to members of the public from intake of radionuclides: Part 4 Inhalation dose coefficients. Publication No. 71. Tarrytown, NY. Elsevier Science Inc. 1996a:9-23. 328. 345.
*. ICRP. Age-dependent doses to members of the public from intake of radionuclides: Part 5. Compilation of ingestion and inhalation dose coefficients. Publication No. 72. Tarrytown, NY. Elsevier Science Inc. 1996b:3-13. 38. 39. 75. 77.
ICRP. Bismuth, lead, polonium. The ICRP database of dose coefficients workers and members of the public. Version 2.01. International Commission on Radiological Protection. Elsevier Science Ltd. 2001.
ICRP. Lung cancer risk from radon and progeny and statement on radon. ICRP Publication 115. Ann ICRP. 2010;40(1):1-64.
IRIS. Radon-222. Integrated Risk Information System. Washington, DC. U. S. Environmental Protection Agency. 2012. http://www.epa.gov/iris/subst/index.html. February 7, 2012.
Ishikawa T, Narazaki Y, Yasuoka Y, et al. Bio-kinetics of radon ingested from drinking water. Radiat Prot Dosimetry. 2003b;105(1–4):65-70. [pmid: 14526929].
Ishikawa T, Yamada Y, Fukutsu K, et al. Deposition and clearance for radon progeny in the human respiratory tract. Radiat Prot Dosimetry. 2003a;105(1–4):143-148. [pmid: 14526945].
Ismail AH, Jaafar MS. Relationship between radon concentration, ventilation rate and male infertility: a case study in Iraqi Kurdistan. Int J Low Radiat. 2010;7(3):175-187.
Israeli M. Deposition rates on Rn progeny in houses. Health Phys. 1985;49:1069-1083. [pmid: 3000986].
Jacobi W. The dose to the human respiratory tract by inhalation of short-lived ^222^Rn- and ^220^Rn-decay products. Health Phys. 1964;10:1163-1175. [pmid: 14244762].
Jaki S, Hess V. Study of the distribution radon, thoron and their decay products above and below the ground. J Geophys Res. 1958;63:373-390.
James A. Hopke P, editor. A reconsideration of cells at risk and other key factors in radon daughter dosimetry. Radon and its decay products: Occurrence, properties and health effects. ACS Symposium Series 331. Washington, DC. American Chemical Society. 1987:400-418.
James AC, Birchall A, Akabani G. Comparative dosimetry of BEIR VI revisited. Radiat Prot Dosimetry. 2004;108(1):3-26. [pmid: 14974601].
James AC, Stahlhofen W, Rudolf G, et al. Deposition of inhaled particles. Ann ICRP. 1994;24:231-299.
Jin Y, Yie TA, Carothers AM. Non-random deletions at the dihydrofolate reductase locus of Chinese hamster ovary cells induced by alpha-particles simulating radon. Carcinogenesis. 1995;16(8):1981-1991. [pmid: 7634430].
Johanson CE. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res. 1980;190(1):3-16. [pmid: 6769537].
Johnston PN, Hult M, Gasparro J, et al. The distribution of ^210^Pb in human bone and its impact on methods for the retrospective estimation of ^222^Rn exposure from in vivo measurements. J Environ Radioact. 2005;80:245-257. [pmid: 15701386].
Jonassen N. On the effect of atmospheric pressure variations on the radon-222 concentration in unventilated rooms. Health Phys. 1975;29:216-220. [pmid: 1150459].
Jonsson H, Bergdahl IA, Åkerblom G, et al. Lung cancer risk and radon exposure in a cohort of iron ore miners in Malmberget, Sweden. Occup Environ Med. 2010;67:519-525. [pmid: 20647379].
Jorgensen H. Lung cancer among underground workers in the iron ore mine of Kiruna based on thirty years of observation. Ann Acad Med Singapore. 1984;13:371-377. [pmid: 6497340].
Jostes RF. Genetic, cytogenetic, and carcinogenic effects of radon: A review. Mutat Res. 1996;340(2–3):125-139. [pmid: 8692177].
Jostes RF, Fleck EW, Morgan TL, et al. Southern blot and polymerase chain reaction exon analyses of HPRT^−^ mutations induced by radon and radon progeny. Radiat Res. 1994;137(3):371-379. [pmid: 8146281].
Kaczynski DJ. Beryllium and beryllium alloys and composities. Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons, Inc. 2011. http://onlinelibrary.wiley.com/doi/10.1002/0471238961.0205182519201514.a01.pub3/abstract. December 5, 2011.
*. Kearney P, Mason G. Radon mitigation: Unusual results and techniques.Part II. Health Phys News. 2011;XXXIX(6):12.
Kendall GM, Smith TJ. Doses to organs and tissues from radon and its decay products. J Radiol Prot. 2002;22:389-406. [pmid: 12546226].
Kendall GM, Smith TJ. Doses from radon and its decay products to children. J Radiol Prot. 2005;25(3):241-256. [pmid: 16286688].
Khan AJ, Phillips C. Electrets for passive radon daughter dosimetry. Health Phys. 1984;46:141-149. [pmid: 6693234].
Khan MA, Cross FT, Buschbom RL, et al. Inhaled radon-induced genotoxicity in Wistar rat, Syrian hamster, and Chinese hamster deep-lung fibroblasts in vivo. Mutat Res. 1995;334(2):131-137. [pmid: 7885364].
Khan MA, Cross FT, Jostes R, et al. Micronuclei induced by radon and its progeny in deep-lung fibroblasts of rats in vivo and in vitro. Radiat Res. 1994;139(1):53-59. [pmid: 8016308].
Khan MF, Wesley SG. Bioaccumulation of ^210^Po and ^210^Pb in cephalopods collected from Kudankulam (southeastern coast of Gulf of Mannar, India) and assessment of dose in human beings. Radiat Prot Dosimetry. 2011;147(3):457-466. [pmid: 21149294].
Khursheed A. Doses to systemic tissues from radon gas. Radiat Prot Dosimetry. 2000;88(2):171-181.
Kinsara AA, Loyalka SK, Tompson RV, et al. Deposition patterns of molecular phase radon progeny (^218^Po) in lung bifurcations. Health Phys. 1995;68(3):371-382. [pmid: 7860308].
Kitto ME. Assessing radon concentrations in areas with few measurements. Environ Monit Assess. 2003;83(2):163-175. [pmid: 12691529].
Kitto ME, Kuhland MK, Dansereau RE. Direct comparison of three methods for the determination of radon in well water. Health Phys. 1996;70(3):358-362. [pmid: 8609027].
Klaassen C, Amdur M, Doull J. Casarett and Doull’s toxicology. 3rd edition. New York, NY. MacMillan Publishing Company. 1986:128.
Komori M, Nishio K, Kitada M, et al. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry. 1990;29(18):4430-4433. [pmid: 2350547].
Kotrappa P, Stieff LR, Volkovitsky P. Radon monitor calibration using NIST radon emanation standards: steady flow method. Radiation protection dosimetry. 2005;113(1):70-74. [pmid: 15561742].
Kozak JA, Reeves HW, Lewis BA. Modeling radium and radon transport through soil and vegetation. J Contam Hydrol. 2003;66(3–4):179-200. [pmid: 14568398].
Kreienbrock L, Kreuzer M, Gerken M, et al. Case-control study on lung cancer and residential radon in western Germany. Am J Epidemiol. 2001;153(1):42-52. [pmid: 11159146].
Kreuzer M, Gerken M, Kreienbrock L, et al. Lung cancer in lifetime nonsmoking men: Results of a case-control study in Germany. Br J Cancer. 2001;84(1):134-140. [pmid: 11139328].
Kreuzer M, Grosche B, Schnelzer M, et al. Radon and risk of death from cancer and cardiovascular diseases in the German uranium miners cohort study: follow-up 1946–2003. Radiat Environ Biophys. 2010;49(2):177-185. [pmid: 19855993].
Kreuzer M, Heinrich J, Kreienbrock L, et al. Risk factors for lung cancer among nonsmoking women. Int J Cancer. 2002;100(6):706-713. [pmid: 12209611].
Kreuzer M, Heinrich J, Wolke G, et al. Residential radon and risk of lung cancer in Eastern Germany. Epidemiology. 2003;14(5):559-568. [pmid: 14501271].
Kreuzer M, Müller KM, Brachner A, et al. Histopathologic findings of lung carcinoma in German uranium miners. Cancer. 2000;89(12):2613-2621. [pmid: 11135223].
Kreuzer M, Schneizer M, Tschense A, et al. Risk of lung cancer and other cancers in the German uranium miners cohort study. 2004. http://irpall.net/pdfs/lbl6.pdf. June 30, 2008.
Kreuzer M, Walsh L, Schnelzer M, et al. Radon and risk of extrapulmonary cancers: results of the German uranium miners’ cohort study, 1960–2003. Br J Cancer. 2008;99:1946-1953. [pmid: 19002172].
Krewski D, Lubin JH, Zielinski JM, et al. Residential radon and risk of lung cancer: A combined analysis of 7 North American case-control studies. Epidemiology. 2005;16(2):137-145. [pmid: 15703527].
Krewski D, Lubin JH, Zielinski JM, et al. A combined analysis of North American case-control studies of residential radon and lung cancer. J Toxicol Environ Health A. 2006;69(7):533-597. [pmid: 16608828].
Krishnan K, Andersen ME. Hayes AW, editor. Physiologically based pharmacokinetic modeling in toxicology. Principles and methods of toxicology. 3rd ed. New York, NY. Raven Press, Ltd. 1994:149-188.
Krishnan K, Andersen ME, Clewell HJ, et al. Yang RSH, editor. Physiologically based pharmacokinetic modeling of chemical mixtures. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA. Academic Press. 1994:399-437.
Kronenberg A. Radiation-induced geometric instability. Int J Radiat Biol. 1994;66:603-609. [pmid: 7983453].
Kulich M, Řeřicha V, Řeřicha R, et al. Incidence of non-solid cancers in Czech uranium miners: a case-cohort study. Environ Res. 2011;111:400-405. [pmid: 21256480].
Kurttio P, Salonen L, Ilus T, et al. Well water radioactivity and risk of cancers of the urinary organs. Environ Res. 2006;102(3):333-338. [pmid: 16448644].
Kusiak RA, Ritchie AC, Muller J, et al. Mortality from lung cancer in Ontario uranium miners. Br J Ind Med. 1993;50(10):920-928. [pmid: 8217852].
L’Abbé KA, Howe GR, Burch JD, et al. Radon exposure, cigarette smoking, and other mining experience in the Beaverlodge uranium miners cohort. Health Phys. 1991;60(4):489-495. [pmid: 2001944].
Lagarde F, Axelsson G, Damber L, et al. Residential radon and lung cancer among never-smokers in Sweden. Epidemiology. 2001;12(4):396-404. [pmid: 11416777].
Lagarde F, Falk R, Almrén K, et al. Glass-based radon-exposure assessment and lung cancer risk. J Expo Anal Environ Epidemiol. 2002;12(5):344-354. [pmid: 12198583].
Lagarde F, Pershagen G, Åkerblom G, et al. Residential radon and lung cancer in Sweden: Risk analysis accounting for random error in the exposure assessment. (Comment in: Health Phys 73(2):393; 73(2):394-395; 73(1):272-273). Health Phys. 1997;72(2):269-276. [pmid: 9003712].
Lam RHF, Brown JP, Fan AM. Wang RGM, editor. Chemicals in California drinking water: Source of contamination, risk assessment, and drinking water standards. Water contamination and health: Integration of exposure assessment, toxicology, and risk assessment. New York. Marcel Dekker, Inc.,. 1994:15-44.
Lane RSD, Frost SE, Howe GR, et al. Mortality (1950–1999) and cancer incidence (1969–1999) in the cohort of Eldorado uranium workers. Radiat Res. 2010;174:773-785. [pmid: 21128801].
Lange K, Evans R. Absorption of radon through the skin and its exhalation through the lungs. Radiology. 1947;48:514-516. [pmid: 20240128].
Laurier D, Tirmarche M, Mitton N, et al. An update of cancer mortality among the French cohort of uranium miners: Extended follow-up and new source of data for causes of death. Eur J Epidemiol. 2004;19(2):139-146. [pmid: 15074570].
Leeder JS, Kearns GL. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am. 1997;44(1):55-77. [pmid: 9057784].
Leggett RW. An age-specific kinetic model of lead metabolism in humans. Environ Health Perspect. 1993;101:598-616. [pmid: 8143593].
Leggett RW, Williams LR. Suggested reference values for regional blood volumes in humans. Health Phys. 1991;60(2):139-154. [pmid: 1989937].
Leggett RW, Williams LR. A proposed blood circulation model for Reference Man. Health Phys. 1995;69(2):187-201. [pmid: 7622365].
Leonard BE. High ^222^Rn levels, enhanced surface deposition, increased diffusion coefficient, humidity, and air change effects. Health Phys. 1996;70(3):372-387. [pmid: 8609030].
Leonard A, Delpoux M, Chameaud J, et al. Biological effects observed in mammals maintained in an area of very high natural radioactivity. Can J Genet Cytol. 1981;23:321-326. [pmid: 7296355].
Létourneau EG, Krewski D, Choi NW, et al. Case-control study of residential radon and lung cancer in Winnipeg, Manitoba, Canada. (Comment in: Am J Epidemiol 140(4):323-332; 140(4):333-339; 142(8):884-886; 142(10):1121-1122). Am J Epidemiol. 1994;140(4):310-322. [pmid: 8059766].
Leung HW. Ballentyne B, Marrs T, Turner P, editors. Physiologically-based pharmacokinetic modelling. General and applied toxicology. New York, NY. Stockton Press. 1993;Vol. 1:153-164.
Leuraud K, Billon S, Bergot D, et al. Lung cancer risk associated to exposure to radon and smoking in a case-control study of French uranium miners. Health Phys. 2007;92(4):371-378. [pmid: 17351502].
Leuraud K, Schnelzer M, Tomasek L, et al. Radon, smoking and lung cancer risk: Results of a joint analysis of three European case-control studies among uranium miners. Radiat Res. 2011;176:375-387. [pmid: 21714633].
Lewis RJ, editor. Hawley's condensed chemical dictionary. 14th ed. New York, NY. John Wiley & Sons, Inc. 2001:951.
Lewis RK. A Hot Spot Survey in the Reading Prong Area of Pennsylvania. Pennsylvania DEP, Bureau of Radiation Protection. 1996 International Radon Symposium IP-4.1. The American Association of Radon Scientists and Technologists, Proceedings. 1996. http://www.aarst.org/proceedings/1996/1996_11_A%20HotSpot_Survey_in_the_Reading_Prong_Area_of_Penns.pdf. August 28, 2008.
Lide DR, editor. CRC Handbook of chemistry and physics. New York, NY. CRC Press LLC. 2005:4-81.
Livingston AL. Forage plant estrogens. J Toxicol Environ Health. 1978;4(2–3):301-324. [pmid: 351201].
Longtin J. Cothern CR, Rebers PA, editors. Occurrence of radionuclides in drinking water, a national study. Radon, radium and uranium in drinking water. Chelsea, MI. Lewis Publishers. 1990:97-139.
Longtin JP. Occurrence of radon, radium, and uranium in groundwater. J Am Water Works Assoc. 1988;80(7):84-93.
Loucas BD, Geard CR. Initial damage in human interphase chromosomes from alpha particles with linear energy transfers relevant to radon exposure. Radiat Res. 1994;139(1):9-14. [pmid: 8016313].
Lubin JH, Boice JD. Lung cancer risk from residential radon: Meta-analysis of eight epidemiologic studies. (Comment in: J Natl Cancer Inst 89(1):4-6; 89(9):663-664, author reply 664-665). J Natl Cancer Inst. 1997;89(1):49-57. [pmid: 8978406].
Lubin JH, Boice JD, Edling C, et al. Lung cancer in radon-exposed miners and estimation of risk from indoor exposure. J Natl Cancer Inst. 1995a;87(11):817-827. [pmid: 7791231].
Lubin JH, Boice JD, Edling C, et al. Radon-exposed underground miners and inverse dose-rate (protraction enhancement) effects. Health Phys. 1995b;69(4):494-500. [pmid: 7558839].
Lubin JH, Liang Z, Hrubec Z, et al. Radon exposure in residences and lung cancer among women: Combined analysis of three studies. Cancer Causes Control. 1994;5(2):114-128. [pmid: 8167258].
Lubin JH, Qiao Y, Taylor PR, et al. Quantitative evaluation of the radon and lung cancer association in a case control study of Chinese tin miners. Cancer Res. 1990;50(1):174-180. [pmid: 2293552].
Lubin JH, Tomasek L, Edling C, et al. Estimating lung cancer mortality from residential radon using data for low exposures of miners. (Comment in: Radiat Res 147(2):135-137). Radiat Res. 1997;147:126-134. [pmid: 9008203].
Lubin JH, Wang ZY, Boice JD, et al. Risk of lung cancer and residential radon in China: Pooled results of two studies. Int J Cancer. 2004;109(1):132-137. [pmid: 14735479].
Lucas HF. Improved low-level alpha-scintillation counter for radon. Rev Sci Instrum. 1957;28:680-683.
Luebeck EG, Heidenreich WF, Hazelton WD, et al. Biologically based analysis of the data for the Colorado uranium miners cohort: Age, dose and dose-rate effects. Radiat Res. 1999;152(4):339-351. [pmid: 10477911].
Lundin F, Lloyd J, Smith E. Mortality of uranium miners in relation to radiation exposure, hard-rock mining and cigarette smoking--1950 through September 1967. Health Phys. 1969;16:571-578. [pmid: 5795875].
Lundin F, Wagoner J, Archer V. Radon daughter exposure and respiratory cancer quantitative and temporal aspects. Report from the epidemiological study of U. S. uranium miners. Washington, DC. National Institute of Occupational Safety and Health and National Institute for Environmental Health Sciences, Department of Health, Education, and Welfare. 1971. Joint Monograph No. 1.
Macdonald CR, Laverock MJ. Radiation exposure and dose to small mammals in radon-rich soils. Arch Environ Contam Toxicol. 1998;35(1):109-120. [pmid: 9601928].
Machta L, Lucas H. Radon in the upper atmosphere. Science. 1962;135:296-299. [pmid: 17834028].
Maciejewska A. Occupational exposure assessment for crystalline silica dust: Approach in Poland and worldwide. International Journal of Occupational Medicine and Environmental Health. 2008;21(1):1-23. http://versita.metapress.com/content/6238755v4r85k0g2/fulltext.pdf. February 7, 2012. [pmid: 18482900].
Maes A, Poffijn A, Verschaeve L. Case report: Karyotypic and chromosome aberration analysis of subjects exposed to indoor radon. Health Phys. 1996;71(5):641-643. [pmid: 8887508].
Mahaffey JA, Parkhurst MA, James AC, et al. Estimating past exposures to indoor radon from household glass. Health Physics. 1993;64(4):381-391. [pmid: 8449720].
Maiello M, Harley N. Egard: An environmental gamma-ray and ^222^Rn detector. Health Phys. 1987;53:301-305. [pmid: 3623919].
Marcinowski F, Lucas RM, Yeager WM. National and regional distributions of airborne radon concentrations in U. S. homes. Health Phys. 1994;66(6):699-706. [pmid: 8181942].
Markkanen M, Arvela H. Radon emanation from soils. Radiat Prot Dosimetry. 1992;45(1/4):269-272.
Marsh JW, Birchall A. Determination of lung-to-blood absorption rates for lead and bismuth which are appropriate for radon progeny. Radiat Prot Dosimetry. 1999;83(4):331-337.
Marsh JW, Birchall A. Sensitivity analysis of the weighted equivalent lung dose per unit exposure from radon progeny. Radiat Prot Dosimetry. 2000;87(3):167-178.
Martin D, Jacobi W. Diffusion deposition of small-sized particles in the bronchial tree. Health Phys. 1972;23:23-29. [pmid: 5077574].
Martin J, Mills W. Stanley R, Moghissi A, editors. Environmental radiation standards considerations for krypton-85 and radon. Noble gases. Washington, DC. U. S. Energy Development and Research Agency, National Environmental Research Center. 1973:647-653. CONF-730915.
Mayr U, Butsch A, Schneider S. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology. 1992;74(2–3):135-149. [pmid: 1387742].
Mays C, Lloyd R, Van Dilla M. Fractional radon retention in bone. Health Phys. 1975;29:761-765. [pmid: 1193888].
McPherson R. Environmental radon and radon daughter dosimetry in the respiratory tract. Health Phys. 1980;39:929-936. [pmid: 7204050].
Mendez D, Warner KE, Courant PN. Effects of radon mitigation vs smoking cessation in reducing radon-related risk of lung cancer. Am J Public Health. 1998;88:811-812. [pmid: 9585753].
Mendez D, Alshanqeety P, Warner K, et al. The impact of declining smoking on radon-related lung cancer in the United States. Am J Public Health. 2011;101:310-314. [pmid: 21228294].
Meyer S. Physikalische grundlagen von emanationskuren. Strahlentherapie. 1937;58:656-663.
Michel J. Cothern C, Smith J, editors. Sources. Environmental radon. New York, NY. Plenum Press. 1987:81-130.
Möhner M, Gellissen J, Marsh JM, et al. Occupational and diagnostic exposure to ionizing radiation and leukemia risk among German uranium miners. Health Phys. 2010;99(3):314-321. [pmid: 20699692].
Möhner M, Lindtner M, Otten H, et al. Leukemia and exposure to ionizing radiation among German uranium miners. Am J Ind Med. 2006;49(4):238-248. [pmid: 16550562].
Möhner M, Lindtner M, Otten H. Ionizing radiation and risk of laryngeal cancer among German uranium miners. Health Phys. 2008;95(6):725-733. [pmid: 19001899].
Momčilović B, Alkhatib HA, Duerre HA, et al. Environmental radon daughters reveal pathognomonic changes in the brain proteins and lipids in patients with Alzheimer’s disease and Parkinson’s disease, and cigarette smokers. Arh Hig Rada Toksikol. 1999;50:347-369. [pmid: 10851740].
Monchaux G. Risk of fatal versus incidental lung cancer in radon-exposed rats: A re-analysis of French data. Arch Oncol. 2004;12(1):7-12.
Monchaux G, Morlier JP. Influence of exposure rate on radon-induced lung cancer in rats. J Radiol Prot. 2002;22(3A):A81-A87. [pmid: 12400953].
Monchaux G, Morlier JP, Altmeyer S, et al. Influence of exposure rate on lung cancer induction in rats exposed to radon progeny. Radiat Res. Suppl 6. 1999;152:S137-S140. [pmid: 10564955].
Moolgavkar SH, Luebeck EG, Krewski D, et al. Radon, cigarette smoke, and lung cancer: A re-analysis of the Colorado Plateau uranium miners’ data. Epidemiology. 1993;4(3):204-217. [pmid: 8512985].
Morgenstern H. Ecologic studies in epidemiology: Concepts, principles, and methods. Annu Rev Public Health. 1995;16:61-81. [pmid: 7639884].
Morken D. Acute toxicity of radon. AMA Arch Ind Health. 1955;12:435-438. [pmid: 13257937].
Morken D. Stanley R, Moghissi A, editors. The biological effects of radon on the lung. Noble gases. Washington, DC. U. S. Energy Development and Research Agency, National Environmental Research Center. 1973:501-506. CONF-730915.
Morken D. The biological and health effects of radon: A review. National Bureau of Standards Special Publication 581, Proceedings of a roundtable discussion of radon in buildings held at NBS. Gaithersburg, MD. 1980:21-26.
Morlier JP, Morin M, Chameaud J, et al. Importance of exposure rate on tumour induction in rats after exposure. C R Acad Sci III. 1992;315:463-466. (French). [pmid: 1297522].
Morlier JP, Morin M, Monchaux G, et al. Lung cancer incidence after exposure of rats to low doses of radon: Influence of dose rate. Radiat Prot Dosimetry. 1994;56(1–4):93-97.
Morrison H, Semenciw R, Mao Y, et al. Stocker H, editor. Lung cancer mortality and radiation exposure among the Newfoundland fluorspar miners. Proceedings of the international conference. Toronto. Canadian Nuclear Association. 1985:354-364.
Morrison HI, Semenciw RM, Mao Y, et al. Cancer mortality among a group of fluorspar miners exposed to radon progeny. Am J Epidemiol. 1988;128(6):1266-1275. [pmid: 3195567].
Morrison HI, Villeneuve PJ, Lubin JH, et al. Radon-progeny exposure and lung cancer risk in a cohort of Newfoundland fluorspar miners. Radiat Res. 1998;150(1):58-65. [pmid: 9650603].
Morselli PL, Franco-Morselli R, Bossi L. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin. 1980;5(6):485-527.
MSHA. Annual exposure limits. Subpart D-Air quality, radiation, physical agents, and diesel particulate matter. U.S. Mine Safety and Health Administration. 2011a. Code of Federal Regulations: 30 CFR 57.5038. http://www.gpo.gov/fdsys/pkg/CFR-2011-title30-vol1/pdf/CFR-2011-title30-vol1-sec57-5038.pdf. February 8, 2012.
MSHA. Control of exposure to airborne contaminants. Subpart D-Air quality, radiation, physical agents, and diesel particulate matter. U.S. Mine Safety and Health Administration. 2011d. Code of Federal Regulations: 30 CFR 57.5005. http://www.gpo.gov/fdsys/pkg/CFR-2011-title30-vol1/pdf/CFR-2011-title30-vol1-sec57-5005.pdf. February 10, 2012.
MSHA. Mazimum permissible concentration. Subpart D-Air quality, radiation, physical agents, and diesel particulate matter. U.S. Mine Safety and Health Administration. 2011b. Code of Federal Regulations: 30 CFR 57.5039. http://www.gpo.gov/fdsys/pkg/CFR-2011-title30-vol1/pdf/CFR-2011-title30-vol1-sec57-5039.pdf. February 8, 2012.
MSHA. Radon daughter exposure monitoring. Subpart D-Air quality, radiation, physical agents, and diesel particulate matter. U.S. Mine Safety and Health Administration. 2011c. Code of Federal Regulations: 30 CFR 57.5037. http://www.gpo.gov/fdsys/pkg/CFR-2011-title30-vol1/pdf/CFR-2011-title30-vol1-sec57-5037.pdf. February 10, 2012.
Muikku M, Rahola T, Pusa S, et al. Estimation of human exposure to natural radionuclides using in vivo skull measurements. Radiat Prot Dosimetry. 2003;105(1–4):615-618. [pmid: 14527036].
Muller C, Ruzicka L, Bakstein J. The sex ratio in the offsprings of uranium miners. Acta Univ Carolinae [Med] (Praha). 1967;13:599-603.
Muller J, Wheeler W, Gentleman J, et al. Study of mortality of Ontario miners. Presented International Conference Occupational Radiation Safety in Mining. October 14–18, 1984. Toronto, Ontario. 1985.
Nagarkatti M, Nagarkatti PS, Brooks A. Effect of radon on the immune system: Alterations in the cellularity and functions of T cells in lymphoid organs of mouse. J Toxicol Environ Health. 1996;47(6):535-552. [pmid: 8614022].
NAS. Health risks of radon and other internally deposited alpha-emitters: BEIR IV. Committee on the Biological Effects of Ionizing Radiations, National Research Council. Washington, DC. National Academy of Sciences, National Academy Press. 1988:1-23. 367. 395. 430. 496.
NAS. Background information and scientific principles. Health effects of exposure to low levels of ionizing radiation: BEIR V. Committee on the Biological Effects of Ionizing Radiations, National Research Council. Washington, DC. National Academy of Sciences, National Academy Press. 1990:9-64.
NAS. Health effects of exposure to radon: Beir VI. Washington, DC. National Academy of Sciences. 1999a. http://books.nap.edu/catalog.php?record_id=5499. April 25, 2008.
NAS. Risk assessment of radon in drinking water. Washington, DC. National Academy of Sciences. 1999b. http://www.nap.edu/catalog.php?record_id=6287. April 25, 2008.
NAS/NRC. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC. National Academy of Sciences, National Research Council, National Academy Press. 1989:15-35.
Nazaroff W, Doyle S, Nero A, et al. Potable water as a source of airborne ^222^Rn in U. S. dwellings: A review and assessment. Health Phys. 1987;52:281-295. [pmid: 3818293].
NCRP. Natural background radiation in the United States. National Council on Radiation Protection and Measurements. 1975. NCRP Report No. 45.
NCRP. Management of persons accidentally contaminated with radionuclides. National Council on Radiation Protection and Measurements. 1980. Report No. 065. http://www.ncrppublications.org/Reports/065. February 8, 2012. (Retrieval in progress).
NCRP. Evaluation of occupational and environmental exposures to radon and radon daughters in the United States. National Council on Radiation Protection and Measurements. 1984a. NCRP Report No. 78.
NCRP. Exposures from the uranium series with emphasis on radon and its daughters. National Council on Radiation Protection and Measurements. 1984b. NCRP Report No. 77.
NCRP. Exposure of the population in the United States and Canada from natural background radiation. National Council on Radiation Protection and Measurements. NCRP Report No. 94. 1987.
NCRP. Measurement of radon and radon daughters in air. National Council on Radiation Protection and Measurements. 1988. NCRP Report No. 97.
NCRP. Deposition, retention and dosimetry of inhaled radioactive substances. Bathesda, MD. National Council on Radiation Protection and Measurements. 1997. NCRP Report No. 125.
NEA/OECD. Dosimetry aspects of exposure to radon and thoron daughter products. Paris. Nuclear Energy Agency/Organisation for Economic Co-operation and Development. 1983.
NEHA-NRPP. Certified performance test chambers. National Environmental Health Association-National Radon Proficiency Program. 2008. http://www.radongas.org/certified_performance_test_chamber.shtml. December 5, 2011.
Nero A. Gammage R, Kaye S, editors. Indoor concentrations of radon-222 and its daughters: Sources, range, and environmental influences. Indoor air and human health. Chelsea, MI. Lewis Publishers, Inc. 1987:43-67.
Nero A, Schwehr M, Nazaroff W, et al. Distribution of airborne radon-222 concentrations in U. S. homes. Science. 1986;234:992-997. [pmid: 3775373].
Nevissi A, Bodansky D. Bodansky D, Robkin M, Stadler D, editors. Radon sources and levels in the outside environment. Indoor radon and its hazards. Seattle, WA. University of Washington Press. 1987:42-50.
NIEHS. Study of the combined effects of smoking and inhalation of uranium ore dust, radon daughters and diesel oil exhaust fumes in hamsters and dogs. Research Triangle Park, NC. National Institute of Environmental Health Sciences. 1978. PNL-2744.
NIH. Radon and lung cancer risk: A joint analysis of 11 underground miners studies. Bethesda, MD. National Institutes of Health. 1994. NIH publication no. 94-3644.
NIOSH. A recommended standard for occupational exposure to radon progeny in underground mines. U.S. Department Health and Human Services, National Institute for Occupational Safety and Health. 1987:1-4. 16. 23. 32. 63. 65. 107. 126. 134. 137.
NIOSH. Characterization of occupational exposure to radium and radon progeny during recovery of uranium from phosphate materials. 2006. ORAUT-OTIB-0043. http://www.cdc.gov/NIOSH/ocas/pdfs/tibs/or-t43-r0.pdf. August 08, 2008.
NIOSH. Number of mining employees by detailed commodity and type of operation, 2005. National Institute for Occupational Safety and Health. 2008a. http://www.cdc.gov/niosh/mining/statistics/pdfs/emp.pdf. August 28, 2008.
NIOSH. Summary of mine-level characteristics by commodity, 2005. National Institute for Occupational Safety and Health. 2008b. http://www.cdc.gov/niosh/mining/statistics/tables/char.html. August 28, 2008.
NIST. Marie Curie and the NBS radium standards. National Institute of Standards of Technology. 2010. http://www.nist.gov/pml/general/curie/present.cfm. February 7, 2012.
NIST. Radiation physics. Secondary standards for Ra223. National Institute of Standards of Technology. 2011. http://www.nist.gov/pml/div682/grp04/ra223.cfm. February 7, 2012.
NJDEP. Summary of contractual, bidding, and funding arrangements. New Jersey Department of Environmental Protection. 2004. http://www.nj.gov/dep/rpp/radon/download/sr_scbfa.pdf. February 7, 2012.
NNDC. Ground and isomeric state information for 222Rn86. National Nuclear Data Center. U.S. Department of Energy. 2012b. http://www.nndc.bnl.gov/nudat2/reCenter.jsp?z=86&n=136.
NNDC. National Nuclear Data Center. U.S. Department of Energy. 2012a. http://www.nndc.bnl.gov/.
NRC. Indoor pollutants. Washington, DC. National Academy Press. 1981:63-69. 505. 509. 510. 514. 515.
NRC. Comparative dosimetry of radon in mines and homes. Washington, DC. National Research Council. National Academy Press. 1991.
NRC. Pesticides in the diets of infants and children. Washington, DC. National Research Council. National Academy Press. 1993.
NRPB. Industrial uranium compounds: Exposure limits, assessment of intake and toxicity after inhalation. Chilton. National Radiological Protection Board. 2002. NRPB-W22.
NTP. Ionizing radiation. Report on Carcinogens. Twelfth edition. National Toxicology Program. 2011. http://ntp.niehs.nih.gov/ntp/roc/twelfth/roc12.pdf. May 16, 2012.
Nusinovici S, Vacquier B, Leuraud K, et al. Mortality from circulatory system disease and low-level radon exposure in the French cohort study of uranium miners, 1946–1999. Scand J Work Environ Health. 2010;36(5):373-383. [pmid: 20101380].
Nussbaum E, Hursh JB. Radon solubility in rat tissues. Science. 1957;125:552-553. [pmid: 13409007].
Oberaigner W, Kreienbrock L, Schaffrath Rosario A, et al. Radon and lung cancer in the district of Imst, Austria. Landberg am Lech, Germany: Ecomed Verlagsgesellschaft, Fortschritte in der Umweltmedizin. 2002. (German).
Oberstedt S, Vanmarcke H. Volume traps-a new retrospective radon monitor. Health Phys. 1996;70(2):222-226. [pmid: 8567290].
O'Flaherty EJ. Physiologically based models for bone-seeking elements. IV. Kinetics of lead disposition in humans. Toxicol Appl Pharmacol. 1993;118(1):16-29. [pmid: 8430422].
O'Neil MJ, Heckelman PE, Koch CB, et al. The Merck index. 14th ed. Whitehouse Station, NJ. Merck & Co., Inc. 2006:1393-1394.
OSHA. Appendix B-Concentrations in air and water above natural background. Occupational Safety and Health Administration. 10 CFR 20. 1971. www.osha.gov/SLTC/pdf_files/10cfr20.pdf. February 9, 2012.
OSHA. Letter to Ms. DeWitte concerning occupational exposure to radon gas. Occupational Safety and Health Administration. 2002. http://www.gpo.gov/fdsys/pkg/CFR-2011-title29-vol6/pdf/CFR-2011-title29-vol6-sec1910-1096.pdf.
OSHA. Ionizing radiation. Toxic and hazardous substances. Occupational Safety and Health Administration. 2011. Code of Federal Regulations. 29 CFR 1910.1096. http://www.gpo.gov/fdsys/pkg/CFR-2011-title29-vol6/pdf/CFR-2011-title29-vol6-sec1910-1096.pdf. December 5, 2011.
Owen GM, Brozek J. Falkner F, editor. Influence of age, sex and nutrition on body composition during childhood and adolescence. Human development. Philadelphia, PA. WB Saunders. 1966:222-238.
Palmer R, Stuart B, Filipy R. Stanley R, Moghissi A, editors. Biological effects of daily inhalation of radon and its short-lived daughters in experimental animals. Noble gases. Washington, DC. U. S. Energy Development and Research Agency, National Environmental Research Center. 1973:507-519. CONF-730915.
Pearson J. Natural environmental radioactivity from radon222. Rockville, MD. U. S. Department of Health, Education, and Welfare, Public Health Service, Bureau of Disease Prevention and Environmental Control. 1967. Publication No. 999-RH-26.
Pelucchi C, Pira E, Piolatto G, et al. Occupational silica exposure and lung cancer risk: a review of epidemiological studies 1996–2005. Ann Oncol. 2006;17(7):1039-1050. [pmid: 16403810].
Pershagen G, Liang ZH, Hrubec Z, et al. Residential radon exposure and lung cancer in women. Health Phys. 1992;63:179-186. [pmid: 1399616].
Pershagen G, Akerblom G, Axelson O, et al. Residential radon exposure and lung cancer in Sweden. (Comment in: N Engl J Med 330(23)1684, author reply 1685). N Engl J Med. 1994;330(3):159-164. [pmid: 8264737].
Peterman BF, Perkins CJ. Dynamics of radioactive chemically inert gases in the human body. Radiat Prot Dosimetry. 1988;22(1):5-12.
Pillai PM, Paul AC, Bhat IS, et al. Deposition and clearance of ^212^Pb in humans. Health Phys. 1994;66(3):343-345. [pmid: 8106255].
Pisa FE, Barbone F, Betta A, et al. Residential radon and risk of lung cancer in an Italian alpine area. Arch Environ Health. 2001;56(3):208-215. [pmid: 11480496].
Planinić J, Šuveljak B, Faj Z. Radon distribution in dwellings. J Radiol Prot. 1994;14(3):235-239.
Pohl E. Biophysikalische untersuchungen uber die inkorporation der naturlich radioaktiven emanationen und deren zerfallsprodukte. New York, NY. Springer-Verlag. 1965:406-409.
Pohl-Rüling J, Fischer P. The dose-effect relationship of chromosome aberrations to alpha and gamma irradiation in a population subjected to an increased burden of natural radioactivity. Radiat Res. 1979;80:61-81. [pmid: 504574].
Pohl-Rüling J, Fischer P. Clemente C, Nero A, Steinhausler F, et al., editors. An epidemiological study of chromosome aberrations in a radon spa. Proceedings of the specialist meeting on the assessment of radon and daughter exposure and related biological effects. Salt Lake City. RD Press. 1982:210-219.
Pohl-Rüling J, Fischer P. Ishihara T, Sasaki M, editors. Chromosome aberrations in inhabitants of areas with elevated natural radioactivity. Radiation-induced chromosome damage in man. New York, NY. Alan R. Liss, Inc. 1983:527-560.
Pohl-Rüling J, Fischer P, Pohl E. Chromosome aberrations in peripheral blood lymphocytes dependent on various dose levels of natural radioactivity. Biological and environmental effects of low-level radiation. Vienna. International Atomic Energy Agency. 1976;Vol. II:317-324.
Pohl-Rüling J, Fischer P, Pohl E. Hopke P, editor. Effect on peripheral blood chromosomes. Radon and its decay products. Washington, DC. American Chemical Society. 1987:487-501.
Poncy JL, Walter C, Fritsch P, et al. Sanders C, Cross F, Dagle G, et al., editors. Delayed SCE frequency in rat bone-marrow cells after radon inhalation. Pulmonary toxicology of respirable particles. 19th Hanford Life Sciences Symposium. Oct 22–24, 1979. Richland, Washington. Oak Ridge, TN. US Department of Energy. 1980:479-485.
Porstendörfer J. Properties and behaviour of radon and thoron and their decay products in the air. J Aerosol Sci. 1994;25(2):219-263.
Porstendörfer J. Physical parameters and dose factors of the radon and thoron decay products. Radiat Prot Dosimetry. 2001;94(4):365-373. [pmid: 11499441].
Pressyanov D, Buysse J, Poffijn A, et al. The compact disk as radon detector - a laboratory study of the method. Health Phys. 2003;84(5):642-651. [pmid: 12747485].
Price JG, Rigby JG, Christensen L, et al. Radon in outdoor air in Nevada. Health Phys. 1994;66(4):433-438. [pmid: 8138410].
Prichard H, Marlen K. Desorption of radon from activated carbon into a liquid scintillator. Anal Chem. 1983;55:155-157.
Proescher F. The pathological anatomical changes in guinea pigs killed by exposure to high concentration of radium emanation. Radium. 1913;1:5-14.
Qiao YL, Taylor PR, Yao SX, et al. Relation of radon exposure and tobacco use to lung cancer among tin miners in Yunnan Province, China. Am J Ind Med. 1989;16(5):511-521. [pmid: 2589328].
Qiao YL, Taylor PR, Yao SX, et al. Risk factors and early detection of lung cancer in a cohort of Chinese tin miners. Ann Epidemiol. 1997;7(8):533-541. [pmid: 9408549].
Queval P, Beaumatin J, Morin M, et al. Inducibility of microsomal enzymes in normal and pre-cancerous lung tissue. Biomedicine. 1979;31:182-186. [pmid: 526540].
Radford E, Renard K. Lung cancer in Swedish iron miners exposed to low doses of radon daughters. New Engl J Med. 1984;310:1485-1494. [pmid: 6325913].
Rangarajan C, Eapen C. Optimizing the gross alpha counting method for determining Rn progeny levels in the atmosphere. Health Phys. 1987;52:469-471. [pmid: 3032856].
Rella J. Goldfrank LR, Flomenbaum NE, Lewis NA, et al., editors. Radiation. Goldfrank’s toxicologic emergencies. 7th ed. New York, NY. McGraw-Hill. 2002:1515-1526.
Renken KJ, Rosenberg T. Laboratory measurements of the transport of radon gas through concrete samples. Health Phys. 1995;68(6):800-808. [pmid: 7759258].
Řeřicha V, Kulich M, Řeřicha R, et al. Incidence of leukemia, lymphoma, and multiple myeloma in Czech uranium miners: A case-cohort study. (Comment in: Environ Health Perspect 115(4):A184, author reply A184-A185). Environ Health Perspect. 2006;114(6):818-822. [pmid: 16759978].
Richter ED, Neeman E, Fischer I, et al. Radon exposures in a Jerusalem public school. Environ Health Perspect. Suppl 6. 1997;105:1411-1416. [pmid: 9467053].
Rivera MP, Detterbeck F, Mehta AC. Diagnosis of lung cancer: The guidelines. Chest. 2003;123:129S-136S. http://chestjournal.chestpubs.org/content/123/1_suppl/129S.full.html. May 7, 2012.
Rogel A, Laurier D, Tirmarche M, et al. Lung cancer risk in the French cohort of uranium miners. J Radiol Prot. 2002;22(3A):A101-A106. [pmid: 12400956].
Ronca-Battista M, Magno P, Nyberg P. Standard measurement techniques and strategies for indoor ^222^Rn measurements. Health Phys. 1988;55:67-69. [pmid: 3292460].
Roscoe RJ. An update of mortality from all causes among white uranium miners from the Colorado Plateau study group. Am J Ind Med. 1997;31:211-222. [pmid: 9028438].
Roscoe RJ, Deddens JA, Salvan A, et al. Mortality among Navajo uranium miners. Am J Public Health. 1995;85(4):535-540. [pmid: 7702118].
Roscoe RJ, Steenland K, Halperin W, et al. Lung cancer mortality among nonsmoking uranium miners exposed to radon daughters. JAMA. 1989;262:629-633. [pmid: 2746814].
Ruosteenoja E, Mäkeläinen I, Rytömaa T, et al. Radon and lung cancer in Finland. Health Phys. 1996;71(2):185-189. [pmid: 8690601].
Saccomanno G, Archer V, Auerbach O, et al. Histologic types of lung cancer among uranium miners. Cancer. 1971;27:515-523. [pmid: 5549493].
Saccomanno G, Archer V, Auerbach O, et al. Development of carcinoma of the lung as reflected in exfoliated cells. Cancer. 1974;33:256-270. [pmid: 4810100].
Saccomanno G, Huth G, Auerbach O, et al. Relationship of radioactive radon daughters and cigarette smoking in the genesis of lung cancer in uranium miners. Cancer. 1988;62:1402-1408. [pmid: 3416280].
Samet JM. Radon and lung cancer. J Natl Cancer Inst. 1989;81:745-757. [pmid: 2654404].
Samet JM, Kutvirt D, Waxweiler R, et al. Uranium mining and lung cancer in Navajo men. New Engl J Med. 1984b;310:1481-1484. [pmid: 6717538].
Samet JM, Morgan MV, Key CR, et al. Studies of uranium miners in New Mexico. Ann Am Conf Gov Ind Hyg. 1986;14:351-355.
Samet JM, Pathak DR, Morgan MV, et al. Radon progeny exposure and lung cancer risk in New Mexico U miners: A case-control study. Health Phys. 1989;56:415-421. [pmid: 2538407].
Samet JM, Pathak DR, Morgan MV, et al. Lung cancer mortality and exposure to radon progeny in a cohort of New Mexico underground uranium miners. Health Phys. 1991;61(6):745-752. [pmid: 1659563].
Samet JM, Pathak DR, Morgan MV, et al. Silicosis and lung cancer risk in underground uranium miners. Health Phys. 1994;66(4):450-453. [pmid: 8138413].
Samet JM, Young R, Morgan M, et al. Prevalence survey of respiratory abnormalities in New Mexico uranium miners. Health Phys. 1984a;46:361-370. [pmid: 6693266].
Samuelsson C. Retrospective determination of radon in houses. Nature. 1988;334:338-340. [pmid: 3393224].
Sanders CL. Inhalation toxicology of 238PuO2 and 239PuO2 in Syrian golden hamsters. Radiat Res. 1977;70(2):334-344. [pmid: 860009].
Sandler DP, Weinberg CR, Archer VE, et al. Indoor radon and lung cancer risk: A case-control study in Connecticut and Utah. Radiat Res. 1999;151:103-104.
Sandler DP, Weinberg CR, Shore DL, et al. Indoor radon and lung cancer risk in Connecticut and Utah. J Toxicol Environ Health A. 2006;69(7):633-654. [pmid: 16608830].
Sasaki T, Gunji Y, Okuda T. Mathematical modeling of radon emanation. J Nucl Sci Technol. 2004;41(2):142-151.
Schnelzer M, Hammer GP, Kreuzer M, et al. Accounting for smoking in the radon-related lung cancer risk among German uranium miners: results of a nested case-control study. Health Phys. 2010;98(1):20-28. [pmid: 19959947].
Schery S, Gaeddert D, Wilkening M. Two-filter monitor for atmospheric ^222^Rn. Rev Sci Instrum. 1980;51:338-343. [pmid: 18647063].
Schoenberg JB, Klotz JB, Wilcox HB, et al. Case-control study of residential radon and lung cancer among New Jersey women. Cancer Res. 1990;50(20):6520-6524. [pmid: 2208111].
Schoenberg JB, Klotz JB, Wilcox HB, et al. Cross FT, editor. A case-control study of residential radon and lung cancer among New Jersey women. Twenty-ninth Hanford symposium on health and the environment. Indoor radon and lung cancer: Reality or myth?. Sponsored by the United States Department of Energy and Battelle, Pacific Northwest Laboratories; Richland, Washington, Columbus: Battelle Press. 1992:905-918.
Schubauer-Berigan MK, Daniels RD, Pinkerton LE. Radon exposure and mortality among white and American Indian uranium miners: An update of the Colorado Plateau cohort. Am J Epidemiol. 2009;169(6):718-730. [pmid: 19208723].
Schwartz JL, Shadley JD, Atcher RW, et al. Comparison of radon-daughter-induced effects in repair-proficient and repair-deficient CHO cell lines. Environ Mol Mutagen. 1990;16(3):178-184. [pmid: 2209573].
Semprini L, Hopkins OS, Tasker BR. Laboratory, field and modeling studies of radon-222 as a natural tracer for monitoring NAPL contamination. Transp Porous Media. 2000;38:223-240.
Setchell BP, Waites GMH. Creep RO, Astwood EB, Geiger SR, editors. The blood-testis barrier. Handbook of physiology: Endocrinology V. Washington, DC. American Physiological Society. 1975:143-172.
Ševc J, Kunz E, Plaček V, et al. Comments on lung cancer risk estimates. Health Phys. 1984;46:961-964. [pmid: 6706608].
Ševc J, Kunz E, Tomášek L, et al. Cancer in man after exposure to Rn daughters. Health Phys. 1988;54:27-46. [pmid: 2826364].
Ševc J, Tomášek L, Kunz E, et al. A survey of the Czechoslovak follow-up of lung cancer mortality in uranium miners. Health Phys. 1993;64(4):355-369. [pmid: 8449717].
Ševcová M, Ševc J, Thomas J. Alpha irradiation of the skin and the possibility of late effects. Health Phys. 1978;35:803-806. [pmid: 738885].
Shadley JD, Whitlock JL, Rotmensch J, et al. The effects of radon daughter α-particle irradiation in K1 and xrs-5 CHO cell lines. Mutat Res. 1991;248(1):73-83. [pmid: 2030713].
Shanahan EM, Peterson D, Roxby D, et al. Mutation rates at the glycophorin A and HPRT loci in uranium miners exposed to radon progeny. Occup Environ Med. 1996;53(7):439-444. [pmid: 8704866].
Sharma N, Hess CT, Thrall KD. A compartmental model of water radon contamination in the human body. Health Phys. 1997;72(2):261-268. [pmid: 9003711].
Sikov MR, Cross FT, Mast TJ, et al. Cross FT, editor. Developmental toxicology of radon exposures. Indoor radon and lung cancer: Reality or myth?. Columbus, OH. Battelle Press. 1992:677-691.
Skwarzec B, Jakusik A. ^210^Po bioaccumulation by mushrooms from Poland. J Environ Monit. 2003;5:791-794. [pmid: 14587851].
Skwarzec B, Fabisiak J. Bioaccumulation of polonium ^210^Po in marine birds. J Environ Radioact. 2007;93:119-126. [pmid: 17267081].
Smerhovsky Z, Landa K, Rössner P, et al. Risk of cancer in an occupationally exposed cohort with increased level of chromosomal aberrations. Environ Health Perspect. 2001;109(1):41-45. [pmid: 11171523].
Smerhovsky Z, Landa K, Rössner P, et al. Increased risk of cancer in radon-exposed miners with elevated frequency of chromosomal aberrations. Mutat Res. 2002;514(1–2):165-176. [pmid: 11815255].
Snihs J. Snyder W, editor. The approach to radon problems in non-uranium mines in Sweden. Proceedings of the third International Congress of the International Radiation Protection Association. U.S. Atomic Energy Commission. 1974:900-911. CONF-730907-P2.
Sobue T, Lee VS, Ye W, et al. Residential radon exposure and lung cancer risk in Misasa, Japan: A case-control study. J Radiat Res (Tokyo). 2000;41(2):81-92. [pmid: 11037576].
Solli H, Andersen A, Stranden E, et al. Cancer incidence among workers exposed to radon and thoron daughters in a niobium mine. Scand J Work Environ Health. 1985;11:7-13. [pmid: 2986282].
Somlai J, Gorjánácz Z, Várhegyi A, et al. Radon concentration in houses over a closed Hungarian uranium mine. Sci Total Environ. 2006;367(2–3):653-665. [pmid: 16725181].
Stayner L, Meinhardt T, Lemen R, et al. A retrospective cohort mortality study of a phosphate fertilizer production facility. Arch Environ Health. 1985;40:133-138. [pmid: 2992396].
Steck DJ, Field RW. The use of track registration detectors to reconstruct contemporary and historical airborne radon (222Rn) and radon progeny concentrations for a radon-lung cancer epidemiologic study. Radiat Meas. 1999;31:401-406.
Steck DJ, Alavanja MCR, Field RW, et al. ^210^Po implanted in glass surfaces by long term exposure to indoor radon. Health Phys. 2002;83(2):261-271. [pmid: 12132714].
Steck DJ, Field RW, Lynch CF. Exposure to atmospheric radon. Environ Health Perspect. 1999;107(2):123-127. [pmid: 9924007].
Stenstrand K, Annanmaki M, Rytomaa T. Cytogenetic investigation of people in Finland using household water with high natural radioactivity. Health Phys. 1979;36:441-444. [pmid: 489298].
Stidley CA, Samet JM. A review of ecologic studies of lung cancer and indoor radon. (Comment in: Health Phys 66(2):212). Health Phys. 1993;65(3):234-251. [pmid: 8244693].
Stram DO, Langholz B, Huberman M, et al. Correcting for exposure measurement error in a re-analysis of lung cancer mortality for the Colorado Plateau Uranium Miners cohort. Health Phys. 1999;77(3):265-275. [pmid: 10456497].
Stranden E, Kolstad AK, Lind B. Radon exhalation: Moisture and temperature dependence. Health Phys. 1984;47(3):480-484. [pmid: 6500953].
Sun K. Field calibration of the glass-based retrospective radon detectors for epidemiologic applications. Ph.D. dissertation. August. from the University of Iowa. 2008. 2008.
Suomela M, Kahlos H. Studies on the elimination rate and the radiation exposure following ingestion of ^222^Rn rich water. Health Phys. 1972;23:641-652. [pmid: 4653387].
Swift DL, Strong JC. Nasal deposition of ultrafine ^218^Po aerosols in human subjects. J Aerosol Sci. 1996;27(7):1125-1132.
Swistock BR, Sharpe WE, Robillard PD. A survey of lead nitrate and radon contamination of private individual water systems in Pennsylvania. J Environ Health. 1993;55(5):6-12.
Taeger D, Fritsch A, Wiethege T, et al. Role of exposure to radon and silicosis on the cell type of lung carcinoma in German uranium miners. Cancer. 2006;106(4):881-889. [pmid: 16411224].
Taeger D, Johnen G, Wiethege T, et al. Major histopathological patterns of lung cancer related to arsenic exposure in German uranium miners. Int Arch Occup Environ Health. 2009;82:867-875. [pmid: 19020892].
Taeger D, Krahn U, Wiethege T, et al. A study on lung cancer mortality related to radon, quartz, and arsenic exposures in German uranium miners. J Toxicol Environ Health. 2008;71:859-865.
Taheri M, Jafarizadeh M, Baradaran S, et al. Development of a high efficiency personal/environmental radon dosimeter using polycarbonate detectors. J Radiol Prot. 2006;26(4):389-395. [pmid: 17146123].
Taskayev A, Popova O, Alexakhin R, et al. Root absorption of ^222^Rn and its transfer into above+ground plant organs. Health Phys. 1986;50:589-594. [pmid: 3700110].
Taya A, Morgan A, Baker ST, et al. Changes in the rat lung after exposure to radon and its progeny: Effects on incorporation of bromodeoxyuridine in epithelial cells and on the incidence of nuclear aberrations in alveolar macrophages. Radiat Res. 1994;139(2):170-177. [pmid: 8052692].
Thomas K, Colborn T. Colborn T, Clement C, editors. Organochlorine endocrine disruptors in human tissue. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ. Princeton Scientific Publishing. 1992:365-394.
Thomas D, Pogoda J, Langholz B, et al. Temporal modifiers of the radon-smoking interaction. Health Phys. 1994;66(3):257-262. [pmid: 8106243].
Thompson RE, Nelson DF, Popkin JH, et al. Case-control study of lung cancer risk from residential radon exposure in Worcester county, Massachusetts. Health Phys. 2008;94(3):228-241. [pmid: 18301096].
Tirmarche M, Raphalen A, Allin F, et al. Mortality of a cohort of French uranium miners exposed to relatively low radon concentrations. Br J Cancer. 1993;67(5):1090-1097. [pmid: 8494704].
Tirmarche M, Raphalen A, Chameaud J. Epidemiological study of French uranium miners. Cancer Detect Prev. 1992;16(3):169-172. [pmid: 1458506].
Tomášek L. Czech miner studies of lung cancer risk from radon. J Radiol Prot. 2002;22(3A):A107-A112. [pmid: 12400957].
Tomášek L. Interaction of radon and smoking among Czech uranium miners. Radiat Prot Dosim. 2011;145(2–3):238-242.
Tomášek L, Darby SC. Recent results from the study of West Bohemian uranium miners exposed to radon and its progeny. Environ Health Perspect. Suppl 2. 1995;103:55-57. [pmid: 7614948].
Tomášek L, Plaček V. Radon exposure and lung cancer risk: Czech cohort study. Radiat Res. Suppl 6. 1999;152:S59-S63. [pmid: 10564939].
Tomášek L, Žárská H. Lung cancer risk among Czech tin and uranium miners--comparison of lifetime detriment. Neoplasma. 2004;51(4):255-260. [pmid: 15254655].
Tomášek L, Darby SC, Fearn T, et al. Patterns of lung cancer mortality among uranium miners in West Bohemia with varying rates of exposure to radon and its progeny. Radiat Res. 1994b;137(2):251-261. [pmid: 8134549].
Tomášek L, Darby SC, Swerdlow AJ, et al. Radon exposure and cancers other than lung cancer among uranium miners in West Bohemia. (Comment in: Lancet 342(8862):47). Lancet. 1993;341:919-923. [pmid: 8096265].
Tomášek L, Kunz E, Müller T, et al. Radon exposure and lung cancer risk - Czech cohort study on residential radon. Sci Total Environ. 2001;272(1–3):43-51. [pmid: 11379936].
Tomášek L, Plaček V, Müller T, et al. Czech studies of lung cancer risk from radon. Int J Low Radiat. 2003;1:50-62.
Tomášek L, Rogel A, Tirmarche M, et al. Lung cancer in French and Czech uranium miners: Radon-associated risk at low exposure rates and modifying effects of time since exposure and age at exposure. Radiat Res. 2008;169(2):125-137. [pmid: 18220460].
Tomášek L, Swerdlow AJ, Darby SC, et al. Mortality in uranium miners in west Bohemia: A long-term cohort study. Occup Environ Med. 1994a;51(5):308-315. [pmid: 8199680].
Trapp E, Renzetti A, Kobayashi T, et al. Cardiopulmonary function in uranium miners. Am Rev Respir Dis. 1970;101:27-43. [pmid: 4311987].
Turner MC, Krewski D, Chen Y, et al. Radon and lung cancer in the American Cancer Society cohort. Cancer Epidemiol Biomarkers Prev. 2011;20(3):438-448. [pmid: 21212062].
Turner MC, Krewski D, Chen Y, et al. Radon and COPD mortality in the American Cancer Society cohort. Eur Respir J. 2012;39(5):1113-1119. [pmid: 22005921].
Tuschl H, Altmann H, Kovac R, et al. Effects of low-dose radiation on repair processes in human lymphocytes. Radiat Res. 1980;81:1-9. [pmid: 7352192].
United Nations Scientific Committee on the Effects of Atomic Radiation. Ionizing radiation: Sources and biological effects. New York, NY. United Nations. 1982.
UNSCEAR. Annex B. Exposures from natural radiation sources. Sources and effects of ionizing radiation. United Nations Scientific Committee on the Effects of Atomic Radiation. 2000. http://www.unscear.org/docs/reports/annexb.pdf. August 28, 2008.
USGS. Trace elements and radon in groundwater across the United States, 1992–2003. U.S. Geological Survey. 2011. http://pubs.usgs.gov/sir/2011/5059/pdf/sir2011-5059_report-covers_508.pdf. December 5, 2011.
USNRC. Licensing requirements for land disposal of radioactive waste. U.S. Nuclear Regulatory Commission. 2008. Code of Federal Regulations 10 CFR 61. http://www.nrc.gov/reading-rm/doc-collections/cfr/part061/full-text.html. May 13, 2008.
USNRC. Annual limits on intakes (ALIs) and derived air concentrations (DACs) of radionuclides for occupational exposure; effluent concentrations; concentrations for release to sewerage. U.S. Nuclear Regulatory Commission. 2011. Code of Federal Regulations 10 CFR 20, Appendix B. http://www.gpo.gov/fdsys/pkg/CFR-2011-title10-vol1/pdf/CFR-2011-title10-vol1-part20-appB.pdf. December 5, 2011.
Uzunov I, Steinhausler F, Pohl E. Carcinogenic risk of exposure to radon daughters associated with radon spas. Health Phys. 1981;41:807-813. [pmid: 7333844].
Vacquier B, Caer S, Rogel A, et al. Mortality risk in the French cohort of uranium miners: extended follow-up 1946–1999. Occup Environ Med. 2007. [Epub ahead of print].
Vacquier B, Rogel A, Leuraud K, et al. Radon-associated lung cancer risk among French uranium miners: Modifying factors of the exposure-risk relationship. Radiat Environ Biophys. 2009;48:1-9. [pmid: 18949479].
Vaternahm T. Vergleichende untersuchungen uber den emanationsgehalt der ausatmungsluft nach trinken von emanationshaltigem wasser und Ol. Z phys diat Ther. 1922;26:361-364.
Veiga LH, Amaral EC, Colin D, et al. A retrospective mortality study of workers exposed to radon in a Brazilian underground coal mine. Radiat Environ Biophys. 2006;45(2):125-134. [pmid: 16715323].
Veiga LH, Koifman S, Melo VP, et al. Preliminary indoor radon risk assessment at the Pocos de Caldas Plateau, MG-Brazil. J Environ Radioact. 2003;70(3):161-176. [pmid: 12957547].
Vieira I, Sonnier M, Cresteil T. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem. 1996;238(2):476-483. [pmid: 8681961].
Vilenskiy V. Distribution of lead 210 and radium 226 in some soils. Geokhimiya. 1969;12:691-695.
Villeneuve PJ, Lane RS, Morrison HI. Coronary heart disease mortality and radon exposure in the Newfoundland fluorspar miners’ cohort, 1950–2001. Radiat Environ Biophys. 2007a;46(3):291-296. [pmid: 17453229].
Vuković B, Faj D, Radolić V, et al. Indoor radon and lung cancer: A case-control study. Isotopes Environ Health Stud. 2005;41(2):169-176. [pmid: 16191768].
Wadach J, Hess C. Radon-222 concentration measurements in soil using liquid scintillation and track etch. Health Phys. 1985;48:805-808. [pmid: 3997531].
Wagoner J, Archer V, Carroll B, et al. Cancer mortality patterns among. U. S. uranium miners and millers, 1950 through 1962. J Natl Cancer Inst. 1964;32:787-801.
Wagoner J, Miller R, Lundin F, et al. Unusual cancer mortality among a group of underground metal miners. New Engl J Med. 1963;269:284-289. [pmid: 13998279].
Walsh L, Tschense A, Schnelzer M, et al. The influence of radon exposures on lung cancer mortality in German uranium miners, 1946–2003. Radiat Res. 2010;173:79-90. [pmid: 20041762].
Wang RY, Chiang WK. Haddad LM, Shannon MW, Winchester JF, editors. Radiation poisoning. Clinical management of poisoning and drug overdose. 3rd ed. Philadelphia, PA. W.B Sanders Company. 1998:413-425.
Wang Z, Lubin JH, Wang L, et al. Residential radon and lung cancer risk in a high-exposure area of Gansu Province, China. Am J Epidemiol. 2002;155(6):554-564. [pmid: 11882529].
Ward JF. DNA damage produced by ionizing radiation in mammalian cells: Identities, mechanism of formation, and repairability. Prog Nucl Acid Res Mol Biol. 1988;35:95-125.
Ward JF. The yield of DNA double-strand breaks produced intracellularly by ionizing radiation: A review. Int J Radiat Biol. 1990;57:1141-1150. [pmid: 1971840].
Waselenko JK, MacVittle TJ, Blakely WF, et al. Medical management of the acute radiation syndrome: Recommendations of the strategic National Stockpile Radiation Working Group. Ann Intern Med. 2004;140(12):1037-1055. [pmid: 15197022].
Watson JE, Evans JP, Mabry AM. Analysis of ^222^Rn concentration in North Carolina household water supplies derived from private wells. Health Phys. 1993;65(2):156-160. [pmid: 8330961].
Waxweiler R, Roscoe R, Archer V, et al. Gomez M, editor. Mortality follow-up through 1977 of the white underground uranium miners cohort examined by the United States Public Health Service. International conference: Radiation hazards in mining. New York, NY. Society of Mining Engineers of American Institute of Mining, Metallurgical, and Petroleum Engineers, Inc. 1981:823-830.
Weast R. CRC handbook of chemistry and physics. Boca Raton, FL. CRC Press, Inc. 1980:B-19. B-119.
Weissbuch H, Gradinaru M, Mihail G. Correlation between concentrations of 210Pb in the biologic samples from miners and individual levels of exposure to short lived radon-222 daughter products. Radiation protection. New York, NY. Pergamon Press. 1980;Vol 2:1072-1074.
West JR, Smith HW, Chasis H. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr. 1948;32:10-18. [pmid: 18920567].
White SB, Bergsten JW, Alexander BV, et al. Indoor ^222^Rn concentrations in a probability sample of 43,000 houses across 30 states. Health Phys. 1992;62(1):41-50. [pmid: 1727411].
WHO. Selected radionuclides. Environmental Health Criteria. Geneva. World Health Organization. 1983;25.
WHO. Air quality guidelines. 2nd ed. Geneva, Switzerland. World Health Organization. 2000. http://www.euro.who.int/__data/assets/pdf_file/0005/74732/E71922.pdf. December 5, 2011.
WHO. Guidelines for drinking-water quality. Vol. 1. Recommendations. 3rd ed. Geneva, Switzerland. World Health Organization. 2004. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. March 08, 2006.
Wichmann HE, Rosario AS, Heid IM, et al. Increased lung cancer risk due to residential radon in a pooled and extended analysis of studies in Germany. Health Phys. 2005;88(1):71-79. [pmid: 15596992].
Widdowson EM, Dickerson JWT. Comar CL, Bronner F, editors. Chemical composition of the body. Mineral metabolism: An advanced treatise. Vol. II: The elements Part A. New York, NY. Academic Press. 1964:1-247.
Wiese W, Skipper B. Survey of reproductive outcomes in uranium and potash mine workers: Results of first analysis. Ann Am Conf Gov Ind Hyg. 1986;14:187-192.
Wilcox HB, Al-Zoughool M, Garner MJ, et al. Case-control study of radon and lung cancer in New Jersey. Radiat Prot Dosimetry. 2008;128(2):169-179. [pmid: 17611199].
Wolff S, Jostes R, Cross FT, et al. Adaptive response of human lymphocytes for the repair of radon-induced chromosomal damage. Mutat Res. 1991;250(1–2):299-306. [pmid: 1944344].
Woodward A, Roder D, McMichael AJ, et al. Radon daughter exposures at the Radium Hill uranium mine and lung cancer rates among former workers, 1952–87. Cancer Causes Control. 1991;2(4):213-220. [pmid: 1873450].
Xu ZY, Blot WJ, Xiao HP, et al. Smoking, air-pollution, and the high rates of lung cancer in Shenyang, China. J Natl Cancer Inst. 1989;81:1800-1806. [pmid: 2555531].
Xuan XZ, Lubin JH, Li JY, et al. A cohort study in southern China of tin miners exposed to radon and radon decay products. Health Phys. 1993;64(2):120-131. [pmid: 8449705].
Yang I. Graves B, editor. Sampling and analysis of dissolved radon-222 in surface and ground water. Radon, radium, and other radioactivity in ground water. Chelsea, MI. Lewis Publishers. 1987:193-203.
Yao SX, Lubin JH, Qiao YL, et al. Exposure to radon progeny, tobacco use and lung cancer in a case-control study in southern China. Radiat Res. 1994;138(3):326-336. [pmid: 8184006].
Yu KN, Lau BM, Nikezic D. Assessment of environmental radon hazard using human respiratory tract models. J Hazard Mater. 2006;132(1):98-110. [pmid: 16427190].
Ziegler EE, Edwards BB, Jensen RL, et al. Absorption and retention of lead by infants. Pediatr Res. 1978;12(1):29-34. [pmid: 643372].