# REGULATIONS, ADVISORIES, AND GUIDELINES

Recommendations for radiation protection for people in the general population as a result of exposure to radon in the environment are found in the International Commission on Radiological Protection (ICRP) Publication 65 (ICRP 1994a). National guidelines for occupational radiation protection are found in the “Federal Radiation Protection Guidance for Occupational Exposure” (EPA 1987b). The guidance presents general principles for the radiation protection of workers and specifies the numerical primary guides for limiting occupational exposure. These recommendations are consistent with the ICRP (ICRP 1994a).

The basic philosophy of radiation protection is the concept of ALARA (As Low As Reasonably Achievable). As a rule, all exposure should be kept as low as reasonably achievable and the regulations and guidelines are meant to give an upper limit to exposure. Based on the primary guides, guides for Annual Limits on Intake (ALIs) have been calculated (USNRC 2011). The ALI is defined as “that activity of a radionuclide which, if inhaled or ingested by Reference Man (ICRP 1975), will result in a dose equal to the most limiting primary guide for committed dose” (EPA 1988).

MRLs are substance specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

No inhalation or oral MRLs were derived for radon.

The international and national regulations, advisories, and guidelines regarding radon in air, water, and other media are summarized in Table 8-1.

The EPA IRIS database (IRIS 2012) has withdrawn its cancer classification for radionuclides, but the EPA Office of Air and Radiation believes that all radionuclides, including radon and its radioactive progeny, should be considered to be known carcinogens, and has assigned them to Group A (EPA 2012b). The EPA has not derived reference concentrations (RfCs) or reference doses (RfDs) for radon (IRIS 2012). EPA has not promulgated a maximum contaminant level (MCL) for radon in drinking water. In 1991, EPA proposed an MCL, but was directed in 1996 to withdraw it and did so in 1997. In 1999, EPA again proposed an MCL (EPA 1999b), but finalized the current radionuclides in drinking water rule in 2000 without a value for radon (EPA 2000) and this status has not changed. The EPA website contains a wealth of information, including a publication entitled A Citizen’s Guide to Radon (EPA 2009a). This guide includes information on the health risk from inhaling radon and its progeny, methods for radon testing in homes, methods and techniques for reducing the radon level, and a recommendation to use a certified radon mitigation specialist to ensure that appropriate methods are used to reduce radon levels. EPA recommends actions to take if the measured radon indoor level is ≥4 pCi/L and notes that radon levels <4 pCi/L still pose a health risk and can be reduced in many cases, and recommends not smoking as an additional way to reduce radon risk.

Table 8-1 Regulations, Advisories, and Guidelines Applicable to Radon

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | | IARC 2008
IARC | ^222^Rn and its decay products | Group 1^a^ | IARC 2008
ICRP | Summary of values recommended
ICRP | Nominal probability coefficient for radon- and radon-progeny-induced lung cancer | 5×10^−4^ per WLM (0.14 per J h m^−3^) | ICRP 2010
ICRP | Dose conversion convention, effective dose per unit of exposure | | ICRP 1994a
ICRP | At home | 1.1 mSv (mJ h m^−3^) | ICRP 1994a
ICRP | At work | 1.4 mSv (mJ h m^−3^) | ICRP 1994a
ICRP | Action level (dwellings) | | ICRP 1994a
ICRP | Radon concentration | 200–600 (Bq m^−3^)^b^ | ICRP 1994a
ICRP | Annual effective dose | 3–10 mSv | ICRP 1994a
ICRP | Action level (workplace) | | ICRP 1994a
ICRP | Radon concentration | 500–1,500 (Bq m^−3^)^b^ | ICRP 1994a
ICRP | Annual effective dose | 3–10 mSv | ICRP 1994a
ICRP | Occupational annual limit on exposure | | ICRP 1994a
ICRP | Per year, averaged over 5 years | 14 (mJ h m^−3^) | ICRP 1994a
ICRP | In a single year | 35 (mJ h m^−3^) | ICRP 1994a
WHO | Air quality guidelines | | WHO 2000
WHO | Risk estimates and recommended action level for radon progeny for exposure to 1 Bq/m^3^ | | WHO 2000
WHO | Lung cancer excess lifetime risk estimate | 3–6×10^−5^ | WHO 2000
WHO | Recommended level for remedial action in buildings | ≥100 Bq/m^3^ (2.7 pCi/L); annual average | WHO 2000
WHO | Drinking water quality guidelines | | WHO 2004
WHO | Radon | 100 Bq/L (2,700 pCi/L) | WHO 2004
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | Guidelines for exposure to ionizing radiation | | ACGIH 2007
ACGIH | Radon daughters | 4 WLM/year | ACGIH 2007
EPA | AEGL-1, -2, and -3 | No data | EPA 2011e
EPA | Hazardous air pollutant | | EPA 2010b
EPA | Radon | Yes | 42 USC 7412
EPA | Effective dose equivalent to public from ^222^Rn not to exceed 10 mrem/year | From operating uranium mine | EPA 2011i (40CFR61.22)
EPA | Effective dose equivalent to public from ^222^Rn not to exceed 10 mrem/year | From a DOE facility | EPA 2011j (40CFR61.92)
EPA | ^222^Rn emissions rate from soil not to exceed 20 pCi/m^2^-second average for entire source | From a DOE facility | EPA 2011k (40CFR61.192)
EPA | ^222^Rn emissions rate from soil not to exceed 20 pCi/m^2^-second average for entire source | From an inactive phosphogypsum stack | EPA 2011l (40CFR61.202)
EPA | ^222^Rn emissions rate from soil not to exceed 20 pCi/m^2^-second average for entire source | From a non-operational uranium mill tailings pile | EPA 2011m (40CFR61.222)
EPA | ^222^Rn emissions rate from soil not to exceed 20 pCi/m^2^-second average for entire source | From an existing uranium mill tailings pile | EPA 2011n (40CFR61.252)
EPA | Standards for uranium byproduct materials shall apply to thorium byproduct materials | Provisions from soil for ^222^Rn from uranium byproduct materials are applicable to ^220^Rn from thorium byproduct materials | EPA 2011h (40CFR192.41)
EPA | ^210^Po (^222^Rn progeny) | Emissions from elemental phosphorus plant <2 Ci/year, or 4.5 Ci/year with scrubbers | EPA 2011o (40CFR61.122)
EPA | Monitoring of radon in homes | | EPA 2009a
EPA | No action necessary | <4 pCi/L, 0.02 WL | EPA 2009a
EPA | Take necessary action to decrease indoor radon levels | ≥4 pCi/L | EPA 2009a
MSHA | Annual exposure limits | | MSHA 2011a 30 CFR 57.5038
MSHA | Radon daughters | 4 WLM in any calendar year underground | MSHA 2011a 30 CFR 57.5038
MSHA | Maximum permissible concentration | | MSHA 2011b 30CFR57.5039
MSHA | Radon daughters | 1 WL in active workings underground | MSHA 2011b 30CFR57.5039
NIOSH | REL (10-hour TWA) | No data
OSHA | OSHA adopted the 1971 version of USNRC regulatory limits in 10CFR20 Appendix B for exposure to radon in air. Applies to employers. OSHA states that following the current 10CFR20 App B is a de minimis violation. | Adult workers: 1×10^−7^ µCi/mL (100 pCi/L) averaged over 40-hour work week of 7 consecutive days | OSHA 2011 29 CFR 1910.1096; OSHA 1971; OSHA 2002
OSHA | | Workers under 18 years of age: 3×10^−9^ µCi/mL (3 pCi/L) averaged over 40-hour work week of 7 consecutive days | OSHA 2011 29CFR1910.1096 (c)(2); OSHA 1971, OSHA 2002
OSHA | | Surveys are required in order to comply | OSHA 2011, 29CFR1910.1096 (e)(4)ii
OSHA | | Post airborne radioactivity area signs when weekly average exceeds 25% of limit (i.e., 25 pCi/L adults, 0.75 pCi/L child workers) | OSHA 2011, 29CFR1910.1096 (e)(4)(i)(b)
USNRC | ALI for occupational exposure (values for oral ingestion) | | USNRC 2011 10 CFR 20, Appendix B
USNRC | ^220^Rn (with daughters removed) | Not listed | USNRC 2011 10 CFR 20, Appendix B
USNRC | ^220^Rn (with daughters present) | Not listed | USNRC 2011 10 CFR 20, Appendix B
USNRC | ^222^Rn (with daughters removed) | Not listed | USNRC 2011 10 CFR 20, Appendix B
USNRC | ^222^Rn (with daughters present) | Not listed | USNRC 2011 10 CFR 20, Appendix B
USNRC | ALI for occupational exposure (values for inhalation) | | USNRC 2011 10 CFR 20, Appendix B
USNRC | ^220^Rn (with daughters removed) | 20,000 µCi | USNRC 2011 10 CFR 20, Appendix B
USNRC | ^220^Rn (with daughters present) | 20 µCi (or 12 WLM) | USNRC 2011 10 CFR 20, Appendix B
USNRC | ^222^Rn (with daughters removed) | 10,000 µCi | USNRC 2011 10 CFR 20, Appendix B
USNRC | ^222^Rn (with daughters present) | 100 µCi (or 4 WLM) | USNRC 2011 10 CFR 20, Appendix B
USNRC | Derived air concentrations for occupational exposure (values for inhalation) | | USNRC 2011 10 CFR 20, Appendix B
USNRC | ^220^Rn (with daughters removed) | 7×10^−6^ µCi/mL | USNRC 2011 10 CFR 20, Appendix B
USNRC | ^220^Rn (with daughters present) | 9×10^−9^ µCi/mL (or 1.0 WL) | USNRC 2011 10 CFR 20, Appendix B
USNRC | ^222^Rn (with daughters removed) | 4×10^−6^ µCi/mL | USNRC 2011 10 CFR 20, Appendix B
USNRC | ^222^Rn (with daughters present) | 3×10^−8^ µCi/mL (or 0.33 WL) | USNRC 2011 10 CFR 20, Appendix B
USNRC | Annual average effluent air concentration (no values provided for effluent water) | | USNRC 2011 10 CFR 20, Appendix B
USNRC | ^220^Rn (with daughters removed) | 2×10^−8^ µCi/mL | USNRC 2011 10 CFR 20, Appendix B
USNRC | ^220^Rn (with daughters present) | 3×10^−11^ µCi/mL | USNRC 2011 10 CFR 20, Appendix B
USNRC | ^222^Rn (with daughters removed) | 1×10^−8^ µCi/mL | USNRC 2011 10 CFR 20, Appendix B
USNRC | ^222^Rn (with daughters present) | 1×10^−10^ µCi/mL | USNRC 2011 10 CFR 20, Appendix B
b. Water
EPA | Drinking water standards and health advisories for radon activity | None; EPA proposed an MCL for radon in 1991, withdrew it in 1997, and published the final rule in 2000 without a radon MCL | EPA 2011d, EPA 1997
EPA | National recommended water quality criteria | No data | EPA 2011d, EPA 1997
c. Food | | No data | EPA 2011d, EPA 1997
d. Other
ACGIH | Carcinogenicity classification | No data | ACGIH 2007
EPA | Carcinogenicity classification | | IRIS 2012
EPA | ^222^Rn | Withdrawn in 1993 | IRIS 2012
EPA | RfC | | IRIS 2012
EPA | ^222^Rn | Not established | IRIS 2012
EPA | RfD | | IRIS 2012
EPA | ^222^Rn | Not established | IRIS 2012
EPA | Superfund, emergency planning, and community right-to-know | | EPA 2011f 40 CFR 302.4 App B
EPA | Designated CERCLA hazardous substance | | EPA 2011f 40 CFR 302.4 App B
EPA | ^220^Rn^c^ | 0.1 Ci | EPA 2011f 40 CFR 302.4 App B
EPA | ^222^Rn^c^ | 0.1 Ci | EPA 2011f 40 CFR 302.4 App B
NTP | Carcinogenicity classification | | NTP 2011
NTP | Ionizing radiation (includes ^220^Rn and ^222^Rn) | Known to be a human carcinogen | NTP 2011

a Group 1: carcinogenic to humans.

b Assuming 7,000 hours/year indoors or 2,000 hours/year at work and an equilibrium factor of 0.4.

c Designated CERCLA hazardous substance pursuant to Section 112 of the Clean Air Act.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = Acute Exposure Guideline Levels; ALI = annual limit on intake; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; EPA = Environmental Protection Agency; IARC = International Agency for Research on Cancer; ICRP = International Commission on Radiological Protection; MCL = maximum contaminant level; MSHA = Mine Safety and Health Administration; NAS = National Academy of Sciences; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; USC = United States Code; USNRC = U.S. Nuclear Regulatory Commission; WHO = World Health Organization; WL = working level; WLM = working level months