# CHEMICAL, PHYSICAL, AND RADIOLOGICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Radon is a naturally occurring radionuclide. The largest source of radon in the environment is due to the ambient levels produced by the widespread distribution of uranium, thorium, and their decay products in the soil (Buttafuoco et al. 2007; Weast 1980). Radon is a decay product of radium and part of the uranium and thorium decay chains (see Figure 4-1) (Buttafuoco et al. 2007; O’Neil et al. 2006). The chemical identity of radon isotopes and identification numbers for several of the radon isotopes (^218^Rn, ^219^Rn, ^220^Rn, ^222^Rn, ^226^Rn, ^229^Rn, and ^230^Rn) are listed in Table 4-1.

## 4.2 PHYSICAL, CHEMICAL, AND RADIOLOGICAL PROPERTIES

Radon is the densest of all the gases. Important physical and chemical properties of radon are listed in Table 4-2. The radioactive properties of the important, short-lived daughters of ^222^Rn are listed in Table 4-3. Figure 4-1 depicts the ^238^U decay series containing ^222^Rn. Figure 4-2 depicts the ^232^Th decay series containing ^220^Rn (thoron). Figure 4-3 depicts the ^235^U decay series containing ^219^Rn (actinon).

Table 4-1 Chemical Identity of Radon

Characteristic | Radon | Reference
Isotope(s) | Recognized isotopes: | DOE 2008
Isotope(s) | ^195^Rn through ^228^Rn | DOE 2008
Isotope(s) | Naturally-occurring isotopes: | DOE 2008
Isotope(s) | ^222^Rn (radon) | DOE 2008
Isotope(s) | ^220^Rn (thoron) | DOE 2008
Isotope(s) | ^219^Rn (actinon) | DOE 2008
Registered trade name(s) | No data
Chemical formula | Rn
Chemical structure | Monatomic
Identification numbers:
CAS Registry | 10043-92-2 Radon | ChemIDPlus 2012
CAS Registry | 51712-92-6 (^230^Rn) | ChemIDPlus 2012
CAS Registry | 51712-91-5 (^229^Rn) | ChemIDPlus 2012
CAS Registry | 16369-95-2 (^226^Rn) | ChemIDPlus 2012
CAS Registry | 14859-67-7 (^222^Rn) | ChemIDPlus 2012
CAS Registry | 22481-48-7 (^220^Rn) | ChemIDPlus 2012
CAS Registry | 14835-02-0 (^219^Rn) | ChemIDPlus 2012
CAS Registry | 15411-71-9 (^218^Rn) | ChemIDPlus 2012
NIOSH RTECS | No data
EPA Hazardous Waste | No data
OHM/TADS | No data
DOT/UN/NA/IMDG | No data
HSDB | 6369 (radon radioactive) | HSDB 2008
NCI | No data

CAS = Chemical Abstracts Services; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; DOE = Department of Energy; Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical, Chemical, and Radiological Properties of Radon

Property | Radon | Reference
Molecular weight | 222 (radon), 220 (thoron), 219 (actinon) | Cothern 1987a
Color | Colorless | Lewis 2001
Physical state | Gas at 0 °C and 760 mm Hg | Lewis 2001
Melting point | −71 °C | Lide 2005
Boiling point | −61.8 °C | Lewis 2001
Density at −20 °C | 9.96×10^−3^ g/cm^3^ | Cothern 1987a
Odor^b^ | Odorless | O’Neil et al. 2006
Odor threshold:
Water | Odorless
Air | Odorless
Solubility:
Water at 20 °C | 230 cm^3^/L | O’Neil et al. 2006
Organic solvents | Organic liquid, slightly soluble in alcohol | Weast 1980
Vapor pressure at 25 °C^a^ | 395.2 mm Hg | Cothern 1987a
Henry’s Law constant | No data
Autoignition temperature | Noble gas; does not autoignite
Flash point | Noble gas; does not burn
Flammability limits | Noble gas; is not flammable
Half-life:
^222^Rn | 3.8235 days | DOE 2008
^220^Rn | 55.6 seconds | DOE 2008
^219^Rn | 3.96 seconds | DOE 2008
Decay energies (MeV), and intensities (%)
^222^Rn | Alpha particles: | DOE 2008
^222^Rn | 4.826 (0.0005%) | DOE 2008
^222^Rn | 4.986 (0.078%) | DOE 2008
^222^Rn | 5.48948 (99.920%) | DOE 2008
^222^Rn | Gamma rays: | DOE 2008
^222^Rn | 0.510 (0.076%) | DOE 2008
^220^Rn | Alpha particles: | DOE 2008
^220^Rn | 5.747 (0.114%) | DOE 2008
^220^Rn | 6.288 (99.886%) | DOE 2008
^220^Rn | Gamma rays: | DOE 2008
^220^Rn | 0.5497 (0.114%) | DOE 2008
^219^Rn | Alpha particles (15 reported): | U.S. DHEW 1970
^219^Rn | 6.425 (7.5%) | U.S. DHEW 1970
^219^Rn | 6.530 (0.12%) | U.S. DHEW 1970
^219^Rn | 6.553 (12.9%) | U.S. DHEW 1970
^219^Rn | 6.819 (79.4%) | U.S. DHEW 1970
^219^Rn | Gamma rays (dozens reported): | U.S. DHEW 1970
^219^Rn | 0.0111 (9.6% | U.S. DHEW 1970
^219^Rn | 0.0769 (5.0%) | U.S. DHEW 1970
^219^Rn | 0.0793 (8.4%) | U.S. DHEW 1970
^219^Rn | 0.2712 (10.8%) | U.S. DHEW 1970
Specific activity, nλ/mass (Ci/g):
^222^Rn | 1.538×10^5^ | Based on DOE 2008
^220^Rn | 9.135×10^8^ | Based on DOE 2008
^219^Rn | 1.301×10^10^ | Based on DOE 2008
Decay products: | Radon progeny (daughters)
^222^Rn (see Figure 4-1) | ^218^Po | DOE 2008
^222^Rn (see Figure 4-1) | ^214^Pb | DOE 2008
^222^Rn (see Figure 4-1) | ^214^Bi | DOE 2008
^222^Rn (see Figure 4-1) | ^214^Po | DOE 2008
^222^Rn (see Figure 4-1) | ^210^Tl | DOE 2008
^222^Rn (see Figure 4-1) | ^210^Pb | DOE 2008
^222^Rn (see Figure 4-1) | ^210^Bi | DOE 2008
^222^Rn (see Figure 4-1) | ^210^Po | DOE 2008
^222^Rn (see Figure 4-1) | ^206^Tl | DOE 2008
^222^Rn (see Figure 4-1) | ^206^Pb | DOE 2008
^220^Rn (see Figure 4-2) | ^216^Po | DOE 2008
^220^Rn (see Figure 4-2) | ^212^Pb | DOE 2008
^220^Rn (see Figure 4-2) | ^212^Bi | DOE 2008
^220^Rn (see Figure 4-2) | ^212^Po | DOE 2008
^220^Rn (see Figure 4-2) | ^208^Tl | DOE 2008
^220^Rn (see Figure 4-2) | ^208^Pb | DOE 2008
^219^Rn (see Figure 4-3) | ^215^Po | DOE 2008
^219^Rn (see Figure 4-3) | ^215^At | DOE 2008
^219^Rn (see Figure 4-3) | ^211^Pb | DOE 2008
^219^Rn (see Figure 4-3) | ^211^Bi | DOE 2008
^219^Rn (see Figure 4-3) | ^211^Po | DOE 2008
^219^Rn (see Figure 4-3) | ^207^Tl | DOE 2008
^219^Rn (see Figure 4-3) | ^207^Pb | DOE 2008

MeV = million electron volts

Table 4-3 Radioactive Properties of ^222^Rn and Its Short-lived Progeny

Isotope | Historical symbol | Principal radiation(s) | Q-Value of principal decay mode (MeV) | Half-life | Specific activity (Ci/g)
^222^Rn | Rn | α | 5.5903 | 3.8235 days | 1.54×10^5^
^218^Po^a^ | RaA | α | 6.1147 | 3.098 minutes | 2.78×10^8^
^218^At | At | α | 6.874 | 1.5 seconds | 3.45×10^10^
^214^Pb | RaB | β,γ | 1.023 | 26.8 minutes | 3.28×10^7^
^214^Bi | RaC | β,γ | 5.6168 | 19.9 minutes | 4.41×10^7^
^214^Poa | RaC’ | α | 7.8335 | 164.3 µseconds | 3.21×10^14^
^210^Tl | RaC” | β | 5.489 | 1.30 minutes | 6.89×10^8^

a Isotopes of primary radiological interest due to the potential for retention in the lung and subsequent alpha decay.

MeV = million electron volts

Source: DOE 2008

Figure 4-1 ^238^U Decay Series Showing Sources and Decay Products*

*All of the single transitions are 100%; other branching ratios are shown in the decay series. ↓ alpha (α) decay; ↗ beta (β^−^) decay or internal transition (IT)

Source: NNDC 2012b

Figure 4-2 ^232^Th Decay Series Showing Sources and Decay Products

*All of the single transitions are 100%; other branching ratios are shown in the decay series. ↓ alpha (α) decay; ↗ beta (β^−^) decay or internal transition (IT)

Source: NNDC 2012b

Figure 4-3 ^235^U Decay Series Showing Sources and Decay Products

*All of the single transitions are 100%; other branching ratios are shown in the decay series. ↓ alpha (α) decay; ↗ beta (β^−^) decay or internal transition (IT)

Source: NNDC 2012b