# OVERVIEW OF BASIC RADIATION PHYSICS, CHEMISTRY, AND BIOLOGY

Understanding the basic concepts in radiation physics, chemistry, and biology is important to the evaluation and interpretation of radiation-induced adverse health effects and to the derivation of radiation protection principles. This appendix presents a brief overview of the areas of radiation physics, chemistry, and biology and is based to a large extent on the reviews of Mettler and Moseley (1985), Hobbs and McClellan (1986), Eichholz (1982), Hendee (1973), Cember (1996, 2009), and Early et al. (1979).

## D.1 RADIONUCLIDES AND RADIOACTIVITY

The substances we call elements are composed of atoms. Atoms in turn are made up of neutrons, protons and electrons: neutrons and protons in the nucleus and electrons in a cloud of orbits around the nucleus. Nuclide is the general term referring to any nucleus along with its orbital electrons. The nuclide is characterized by the composition of its nucleus and hence by the number of protons and neutrons in the nucleus. All atoms of an element have the same number of protons (this is given by the atomic number) but may have different numbers of neutrons (this is reflected by the atomic mass numbers or atomic weight of the element). Atoms with different atomic mass but the same atomic numbers are referred to as isotopes of an element.

The numerical combination of protons and neutrons in most nuclides is such that the nucleus is quantum mechanically stable and the atom is said to be stable, i.e., not radioactive; however, if there are too few or too many neutrons, the nucleus is unstable and the atom is said to be radioactive. Unstable nuclides undergo radioactive transformation, a process in which a neutron or proton converts into the other and a beta particle is emitted, or else an alpha particle is emitted. Each type of decay is typically accompanied by the emission of gamma rays. These unstable atoms are called radionuclides; their emissions are called ionizing radiation; and the whole property is called radioactivity. Transformation or decay results in the formation of new nuclides some of which may themselves be radionuclides, while others are stable nuclides. This series of transformations is called the decay chain of the radionuclide. The first radionuclide in the chain is called the parent; the subsequent products of the transformation are called progeny, daughters, or decay products.

In general there are two classifications of radioactivity and radionuclides: natural and artificial (man-made). Naturally-occurring radioactive materials (NORM) exists in nature and no additional energy is necessary to place them in an unstable state. Natural radioactivity is the property of some naturally occurring, usually heavy elements, that are heavier than lead. Radionuclides, such as radium and uranium, primarily emit alpha particles. Some lighter elements such as carbon-14 and tritium (hydrogen-3) primarily emit beta particles as they transform to a more stable atom. Natural radioactive atoms heavier than lead cannot attain a stable nucleus heavier than lead. Everyone is exposed to background radiation from naturally-occurring radionuclides throughout life. This background radiation is the major source of radiation exposure to man and arises from several sources. The natural background exposures are frequently used as a standard of comparison for exposures to various artificial sources of ionizing radiation.

Artificial radioactive atoms are produced either as a by-product of fission of uranium or plutonium atoms in a nuclear reactor or by bombarding atoms with particles (such as neutrons, protons, or heavy nuclei) at high velocity via a particle accelerator. Goals of these efforts can include producing medical isotopes or new elements. These artificially produced radioactive elements usually decay by emission of particles, such as alpha particles, positive or negative beta particles, and one or more high energy photons (gamma rays). Unstable (radioactive) atoms of any element can be produced.

Both naturally occurring and artificial radioisotopes find application in medicine, industrial products, and consumer products. Some specific radioisotopes, called fall-out, are still found in the environment as a result of nuclear weapons use or testing, or nuclear power plant accidents (e.g., Three Mile Island Unit 2, Chernobyl, and Fukushima Dai-ichi).

## D.2 RADIOACTIVE DECAY

### D.2.1 Principles of Radioactive Decay

The stability of an atom is the result of the balance of the forces of the various components of the nucleus. An atom that is unstable (a radionuclide) will release energy (decay) in various ways and transform to stable atoms or to intermediate radioactive species called progeny or daughters, often with the release of ionizing radiation. If there are either too many or too few neutrons for a given number of protons, the resulting nucleus may undergo transformation. For some elements, a chain of progeny decay products may be produced until stable atoms are formed. Radionuclides can be characterized by the type and energy of the radiation emitted, the rate of decay, and the mode of decay. The mode of decay indicates how a parent compound undergoes transformation. Radiations considered here are primarily of nuclear origin, i.e., they arise from nuclear excitation, usually caused by the capture of charged or uncharged nucleons by a nucleus, or by the radioactive decay or transformation of an unstable nuclide. The type of radiation may be categorized as charged or uncharged particles, protons, and fission products) or electromagnetic radiation (gamma rays and×rays). Table D-1 summarizes the basic characteristics of the more common types of radiation encountered.

### D.2.2 Half-Life and Activity

For any given radionuclide, the rate of decay is a first-order process that is constant, regardless of the radioactive atoms present and is characteristic for each radionuclide. The process of decay is a series of random events; temperature, pressure, or chemical combinations do not affect the rate of decay. While it may not be possible to predict exactly which atom is going to undergo transformation at any given time, it is possible to predict, on average, the fraction of the radioactive atoms that will transform during any interval of time.

The activity is a measure of the quantity of radioactive materials. For these radioactive materials it is customary to describe the activity as the number of disintegrations (transformations) per unit time. The unit of activity is the curie (Ci), which was originally related to the activity of one gram of radium, but is now defined as the disintegration or transformation rate occurring in a quantity of radioactive materials. The definition is:

1 curie (Ci) = 3.7×10^10^ disintegrations (transformations)/second (dps) or = 2.22×10^12^ disintegrations (transformations)/minute (dpm).

The SI unit of activity is the becquerel (Bq); 1 Bq = that quantity of radioactive materials in which there is 1 transformation/second. Since activity is proportional to the number of atoms of the radioactive materials, the quantity of any radioactive materials is usually expressed in curies, regardless of its purity or concentration. The transformation of radioactive nuclei is a random process, and the number of transformations is directly proportional to the number of radioactive atoms present. For any pure radioactive substance, the rate of decay is usually described by its radiological half-life, t½, i.e., the time it takes for a specified source material to decay to half its initial activity. The specific activity is an indirect measure of the rate of decay, and is defined as the activity per unit mass or per unit volume. The higher the specific activity of a radioisotope, the faster it is decaying.

The activity of a radionuclide at time t may be calculated by:

A = A_o_e^−0.693t/t½^,

- where A = the activity in dps or curies or becquerels,
  A_o_ = the activity at time zero,
  t = the time at which measured, and
  t_½_ = the radiological half-life of the radionuclide (t½ and t must be in the same units of time).

The time when the activity of a sample of radioactivity becomes one-half its original value is the radioactive half-life and is expressed in any suitable unit of time.

Table D-1 Characteristics of Nuclear Radiations

Radiation | Rest mass^a^ | Charge | Typical energy range | Path length^b^ | | Comments
Radiation | Rest mass^a^ | Charge | Typical energy range | Air | Solid | Comments
Alpha (α) | 4.00 amu | +2 | 4–10 MeV | 5–10 cm | 25–80 µm | Identical to ionized He nucleus
Negatron (β^−^) | 5.48×10^−4^ amu; 0.51 MeV | −1 | 0–4 MeV | 0–10 m | 0–1 cm | Identical to electron
Positron (β^+^) | 5.48×10^−4^ amu; 0.51 MeV | +1 | 0–4 MeV | 0–10 m | 0–1 cm | Identical to electron except for sign of charge
Neutron | 1.00866 amu; 939.565 MeV | 0 | 0–15 MeV | b | b | Half life: 10.183 min
X ray_(e m. photon)_ | – | 0 | 5 keV–100 keV | b | b | Photon from transition of an electron between atomic orbits
Gamma (V̥)_(e.m. photon)_ | – | 0 | 10 keV–3 MeV | b | b | Photon from nuclear transformation

a The rest mass (in amu) has an energy equivalent in MeV that is obtained using the equation E=mc^2^, where 1 amu = 932 MeV.

b Path lengths are not applicable to x- and gamma rays since their intensities decrease exponentially; path lengths in solid tissue are variable, depending on particle energy, electron density of material, and other factors.

amu = atomic mass unit; e.m. = electromagnetic; MeV = MegaElectron Volts

The specific activity is a measure of activity, and is defined as the activity per unit mass or per unit volume. This activity is usually expressed in curies per gram and may be calculated by

curies/gram = 1.3×10^8^/(t_½_) (atomic weight) or [3.577×10^5^ × mass(g)] / [t_½_ × atomic weight]

where t_½_ = the radiological half-life in days.

In the case of radioactive materials contained in living organisms, an additional consideration is made for the reduction in observed activity due to regular processes of elimination of the respective chemical or biochemical substance from the organism. This introduces a rate constant called the biological half-life (tb) which is the time required for biological processes to eliminate one-half of the activity. This time is virtually the same for both stable and radioactive isotopes of any given element.

Under such conditions the time required for a radioactive element to be halved as a result of the combined action of radioactive decay and biological elimination is the effective clearance half-time:

t_eff_ = (t_b_ × t_½_) / (t_b_ + t_½_).

Table D-2 presents representative effective half-lives of particular interest.

Table D-2 Half-Lives of Some Radionuclides in Adult Body Organs

Radionuclide | Critical organ | Half-life^a^
Radionuclide | Critical organ | Physical | Biological | Effective
Uranium 238 | Kidney | 4,460,000,000 y | 4d | 4d
Hydrogen 3^b^ (Tritium) | Whole body | 12.3 y | 10 d | 10 d
Iodine 131 | Thyroid | 8d | 80 d | 7.3 d
Strontium 90 | Bone | 28 y | 50 y | 18y
Plutonium 239 | Bone surface | 24,400 y | 50 y | 50 y
Plutonium 239 | Lung | 24,400 y | 500 d | 500 d
Cobalt 60 | Whole body | 5.3 y | 99.5 d | 95 d
Iron 55 | Spleen | 2.7 y | 600 d | 388 d
Iron 59 | Spleen | 45.1 d | 600 d | 42 d
Manganese 54 | Liver | 303 d | 25 d | 23 d
Cesium 137 | Whole body | 30 y | 70 d | 70 d

a d = days, y = years

b Mixed in body water as tritiated water

### D.2.3 Interaction of Radiation with Matter

Both ionizing and nonionizing radiation will interact with materials; that is, radiation will lose kinetic energy to any solid, liquid or gas through which it passes by a variety of mechanisms. The transfer of energy to a medium by either electromagnetic or particulate radiation may be sufficient to cause formation of ions. This process is called ionization. Compared to other types of radiation that may be absorbed, such as radio waves or microwave radiation, ionizing radiation deposits a relatively large amount of energy into a small volume.

The method by which incident radiation interacts with the medium to cause ionization may be direct or indirect. Electromagnetic radiations (x rays and gamma photons) and neutral particles (neutrons) are indirectly ionizing; that is, they give up their energy in various interactions with cellular molecules, and the energy is then utilized to produce a fast-moving charged particle such as an electron. It is the electron that then may react with and transfer energy to a target molecule. This particle is called a “primary ionizing particle. Charged particles, in contrast, strike the tissue or medium and directly react with target molecules, such as oxygen or water. These particulate radiations are directly ionizing radiations. Examples of directly ionizing particles include alpha and beta particles. Indirectly ionizing radiations are always more penetrating than directly ionizing particulate radiations.

Mass, charge, and velocity of a particle, as well as the electron density of the material with which it interacts, all affect the rate at which ionization occurs. The higher the charge of the particle and the lower the velocity, the greater the propensity to cause ionization. Heavy, highly charged particles, such as alpha particles, lose energy rapidly with distance and, therefore, do not penetrate deeply. The result of these interaction processes is a gradual slowing down of any incident particle until it is brought to rest or "stopped" at the end of its range.

### D.2.4 Characteristics of Emitted Radiation

#### D.2.4.1 Alpha Emission

In alpha emission, an alpha particle consisting of two protons and two neutrons is emitted with a resulting decrease in the atomic mass number by four and reduction of the atomic number of two, thereby changing the parent to a different element. The alpha particle is identical to a helium nucleus consisting of two neutrons and two protons. It results from the radioactive decay of some heavy elements such as uranium, plutonium, radium, thorium, and radon. All alpha particles emitted by a given radioisotope have the same energy.

Most of the alpha particles that are likely to be found have energies in the range of about 4 to 8 MeV, depending on the isotope from which they came.

The alpha particle has an electrical charge of +2. Because of this double positive charge and their size, alpha particles have great ionizing power and, thus, lose their kinetic energy quickly. This results in very little penetrating power. In fact, an alpha particle cannot penetrate a sheet of paper. The range of an alpha particle (the distance the charged particle travels from the point of origin to its resting point) is about 4 cm in air, which decreases considerably to a few micrometers in tissue. These properties cause alpha emitters to be hazardous only if there is internal contamination (i.e., if the radionuclide is inside the body).

#### D.2.4.2 Beta Emission

A beta particle (β) is a high-velocity electron ejected from a disintegrating nucleus. The particle may be either a negatively charged electron, termed a negatron (β^Z^) or a positively charged electron, termed a positron (β^E^). Although the precise definition of "beta emission" refers to both β^Z^and β^E^, common usage of the term generally applies only to the negative particle, as distinguished from the positron emission, which refers to the β^E^particle.

##### D.2.4.2.1 Beta Negative Emission

Beta particle (β^Z^) emission is another process by which a radionuclide, with a neutron excess achieves stability. Beta particle emission decreases the number of neutrons by one and increases the number of protons by one, while the atomic mass number remains unchanged.^1^ This transformation results in the formation of a different element. The energy spectrum of beta particle emission ranges from a certain maximum down to zero with the mean energy of the spectrum being about one-third of the maximum. The range in tissue is much less. Beta negative emitting radionuclides can cause injury to the skin and superficial body tissues, but mostly present an internal contamination hazard.

1 Neutrinos accompany negative bet a particle emissions; anti-neutrinos accompany positron emissions

##### D.2.4.2.2 Positron Emission

In cases in which there are too many protons in the nucleus, positron emission may occur. In this case a proton may be thought of as being converted into a neutron, and a positron (β^E^) is emitted.^1^ This increases the number of neutrons by one, decreases the number of protons by one, and again leaves the atomic mass number unchanged. The gamma radiation resulting from the annihilation (see glossary) of the positron makes all positron emitting isotopes more of an external radiation hazard than pure β emitters of equal energy.

##### D.2.4.2.3 Gamma Emission

Radioactive decay by alpha, beta, or positron emission, or electron capture often leaves some of the energy resulting from these changes in the nucleus. As a result, the nucleus is raised to an excited level. None of these excited nuclei can remain in this high-energy state. Nuclei release this energy returning to ground state or to the lowest possible stable energy level. The energy released is in the form of gamma radiation (high energy photons) and has an energy equal to the change in the energy state of the nucleus. Gamma and×rays behave similarly but differ in their origin; gamma emissions originate in the nucleus while×rays originate in the orbital electron structure or from rapidly changing the velocity of an electron (e.g., as occurs when shielding high energy beta particles or stopping the electron beam in an×ray tube).

## D.3 ESTIMATION OF ENERGY DEPOSITION IN HUMAN TISSUES

Two forms of potential radiation exposures can result: internal and external. The term exposure denotes physical interaction of the radiation emitted from the radioactive materials with cells and tissues of the human body. An exposure can be "acute" or "chronic" depending on how long an individual or organ is exposed to the radiation. Internal exposures occur when radionuclides, which have entered the body (e.g., through the inhalation, ingestion, or dermal pathways), undergo radioactive decay resulting in the deposition of energy to internal organs. External exposures occur when radiation enters the body directly from sources located outside the body, such as radiation emitters from radionuclides on ground surfaces, dissolved in water, or dispersed in the air. In general, external exposures are from material emitting gamma radiation, which readily penetrate the skin and internal organs. Beta and alpha radiation from external sources are far less penetrating and deposit their energy primarily on the skin's outer layer. Consequently, their contribution to the absorbed dose of the total body dose, compared to that deposited by gamma rays, may be negligible.

Characterizing the radiation dose to persons as a result of exposure to radiation is a complex issue. It is difficult to: (1) measure internally the amount of energy actually transferred to an organic material and to correlate any observed effects with this energy deposition; and (2) account for and predict secondary processes, such as collision effects or biologically triggered effects, that are an indirect consequence of the primary interaction event. Radiation exposure (a measure of ionization density in air) is sometimes used as a surrogate for radiation dose in tissue from external radiation. Both exposure and dose are described below.

### D.3.1 Exposure (Roentgen)

The roentgen (R) is a unit of×or gamma-ray exposure and is a measured by the amount of ionization caused in air by gamma or×radiation. One roentgen produces 2.58×10^−4^ coulomb per kilogram of air. In the case of gamma radiation, over the commonly encountered range of photon energy, the energy deposition in tissue for an exposure of 1 R is about 0.0096 joules (J)/kg of tissue. Exposure is only defined for×and gamma radiation ionization in air, and is often incorrectly interchanged with the term dose.

### D.3.2 Absorbed Dose (Gy, rad) and Absorbed Dose Rate (Gy/hr, rad/hr)

The absorbed dose is defined as the energy absorbed from the incident radiation by a unit mass of the tissue or organ (dm). The differential equation for absorbed dose is:

D = de/dm

- where: D = absorbed dose
  e = mean energy deposited
  m = mass in which the energy was deposited.

The SI unit of absorbed dose in any medium is the J/kg with the special name of Gray (Gy), where 1 J/kg = 10,000 ergs/gram = 1 Gy. In the historical system, 0.01 J/kg = 100 ergs/g = 1 rad, so 1 Gy = 100 rad.. For neutrons, the absorbed dose may be estimated using the similar metric, kinetic energy released in matter (kerma). Kerma is the sum of initial kinetic energies of all charged ionizing particles liberated in a unit mass.

Absorbed dose is a measurable quantity, so there are primary national and international standards for its determination. In practice, absorbed dose is averaged over organ or tissue volumes. This allows the absorbed dose from both external and internal sources of radiation to be added. For low doses, the acceptance of the linear no threshold (LNT) theory allows the correlation of dose with degree of adverse deterministic health effects. Radiation that does not penetrate tissue well (low energy x-rays, beta particles, and alpha particles) can produce a nonuniform distribution of absorbed dose resulting in differential health effects across an organ or tissue. An example is using shielding in radiation therapy so that a kidney tumor receives a lethal dose while sparing as much health tissue as practical, thus maximizing the remaining kidney function.

Internal and external absorbed doses delivered by radiation sources are not usually instantaneous but are distributed over extended periods of time. The resulting rate of change of the absorbed dose to a small volume of mass is referred to as the absorbed dose rate, which has units of Gy/unit time or rad/unit time.

As a rough conversion, an exposure of 1 R in air results in an absorbed dose to soft tissue of approximately 0.01 J/kg.

See text below on other units of measure.

## D.4 UNITS IN RADIATION PROTECTION AND REGULATION

### D.4.1 Equivalent Dose (or Dose Equivalent)

Equivalent dose (international term) and dose equivalent (US term)are a radiation protection quantity used for setting limits that help ensure that deterministic effects (e.g. damage to a particular tissue) are kept within acceptable levels. The SI unit of equivalent dose is the J/kg, has the special name of Sievert (Sv) or rem, and is abbreviated HT. It is a special radiation protection quantity that is used, for administrative and radiation safety purposes only, to express the absorbed dose in a manner which considers the difference in biological effectiveness of various kinds of ionizing radiation. The equivalent dose concept is applicable only to doses that are not great enough to produce biomedical effects.

The equivalent dose in an organ or tissue (H_T_) is determined by multiplying the absorbed dose by a radiation weighting factor and any modifying factors at the location of interest. The absorbed dose in an organ or tissue from radiation of type R (D_T,R_) is a measurable or estimable quantity, while the radiation weighting factor (ωR) for each primary radiation type (ωR) has been studied and recommendations made for their values. The formula for calculating equivalent dose is:

H_T_ = ∑_R_ω_R_D_T,R_· or ∑_R_Q_R_D_T,R_.

- Where ω_R_ = radiation weighting factor,
  D_T,R_ = absorbed dose to tissue T from radiation type R, and
  Q_R_ = quality factor.

The radiation weighting factor (ω) or quality factor (Q) is a dimensionless quantity that depends in part on the stopping power for charged particles, and it accounts for the differences in biological effectiveness found among the types of radiation. Originally, relative biological effectiveness (RBE) was used rather than ω or Q to define the quantity, rem, which is of use in risk assessment. The NRC and DOE in the US, and the ICRU and ICRP in most of the remaining international community havepublished values for quality factors and radiation weighting factors provided in Tables D-3 and D-4.

The equivalent dose rate (or dose equivalent rate in the US) is the time rate of change of the equivalent dose (or dose equivalent) to organs and tissues and is expressed as Sv/unit time (or rem/unit time).

Table D-3 Recommended Values of Quality Factors and Radiation Weighting Factors

Type of Radiation | Quality Factor (NRC 2011) | Radiation Weighting Factor (w_R_) (ICRP 2007)
Photons (x and γ rays) | 1 | 1
Electrons | 1
Electrons and muons | | 1
High energy protons | 10
Protons and charged pions | | 2
Alpha particles, multiple-charged particles, fission fragments and heavy particles of unknown charge | 20
Alpha particles, fission fragments, heavy ions | | 20
Neutrons of unknown energy | 10
Neutrons of known energy | See Table D-4 | A continuous function of neutron energy (range 2.4–21; see equation)

Source:

USNRC. 2011. Standards for the protection against radiation, tables 1004(b).1 and 1004(b).2. 10 CFR 20.1004. U.S. Nuclear Regulatory Commission, Washington, D.C.

ICRP

Radiation weighting factors for neutrons are based on particle energy according to the following formulas (ICRP 2007):

ω_R_ = { 2.5 + 18.2 e^− (ln ( E_n_^2^ ))/(6)^ , E n < 1 M e V 5.0 + 17.0 e^− (ln ( 2 E_n_^2^ ))/(6)^ , 1 M e V ≤ E n ≤ 50 M e V 2.5 + 3.25 e^− (ln ( 0.04 E_n_^2^ ))/(6)^ , E n > 50 M e V

Table D-4 Mean Quality Factors, Q, and Fluence per Unit Dose Equivalent for Monoenergetic Neutrons

| Neutron energy (MeV) | Quality factor^a^ (Q) | Fluence per unit dose equivalent^b^ (neutrons cm ^−2^rem^−1^)
(thermal) | 2.5 x 10^−8^ | 2 | 980×10^6^
| 1×10^−7^ | 2 | 980×10^6^
| 1×10^−6^ | 2 | 810×10^6^
| 1×10^−5^ | 2 | 810×10^6^
| 1×10^−4^ | 2 | 840×10^6^
| 1×10^−3^ | 2 | 980×10^6^
| 1×10^−2^ | 2.5 | 1010×10^6^
| 1×10^−1^ | 7.5 | 170×10^6^
| 5×10^−1^ | 11 | 39×10^6^
| 1 | 11 | 27×10^6^
| 2.5 | 9 | 29×10^6^
| 5 | 8 | 23×10^6^
| 7 | 7 | 24×10^6^
| 10 | 6.5 | 24×10^6^
| 14 | 7.5 | 17×10^6^
| 20 | 8 | 16×10^6^
| 40 | 7 | 14×10^6^
| 60 | 5.5 | 16×10^6^
| 1×10^2^ | 4 | 20×10^6^
| 2×10^2^ | 3.5 | 19×10^6^
| 3×10^2^ | 3.5 | 16×10^6^
| 4×10^2^ | 3.5 | 14×10^6^

### D.4.2 Relative Biological Effectiveness

RBE is used to denote the experimentally determined ratio of the absorbed dose from one radiation type to the absorbed dose of a reference radiation required to produce an identical biological effect under the same conditions. Gamma rays from cobalt-60, cesium-137, and 200–250 keV x-rays have been used as reference standards. The term RBE has been widely used in experimental radiobiology, and the term radiation weighting factor used in calculations of dose equivalent for radiation safety purposes (ICRP 2007; NCRP 1971; UNSCEAR 1982). RBE applies only to a specific biological end point, in a specific exposure, under specific conditions to a specific species. There are no generally accepted values of RBE.

### D.4.3 Effective Dose or Effective Dose Equivalent

In an attempt to compare stochastic (e.g., cancer) detriment from absorbed dose of radiation in a limited portion of the body with the detriment from total body dose, the ICRP (1977) derived a concept of effective dose equivalent. ICRP changed this term to effective dose in 1990 (ICRP 1990) and reintroduced the term “effective dose equivalent” in 2007 (ICRP 2007). The term “effective dose equivalent” allows for the addition or direct comparison of cancer and genetic risk from various partial or whole body doses. In the U.S., the term “effective dose equivalent” is presently used by the NRC (NRC 2011) and DOE.

The effective dose (or effective dose equivalent) approach was developed to overcome limitations in using absorbed dose as a metric of the stochastic impact of ionizing radiation. The absorbed dose is usually defined as the mean absorbed dose within an organ or tissue. This represents a simplification of the actual problem. Normally when an individual ingests or inhales a radionuclide or is exposed to external radiation that enters the body (gamma), the dose is not uniform throughout the whole body.

The simplifying assumption is that the detriment will be the same whether the body is uniformly or non-uniformly irradiated. This required the development of a tissue weighting factor, which represents the estimated proportion of the stochastic risk resulting from tissue, T, to the stochastic risk when the whole body is uniformly irradiated for occupational exposures under certain conditions (ICRP 1977).

The effective dose (or effective dose equivalent) (HE) is weighted for both the type of radiation (R) and the type of tissue (T), and has the formula:

H_E_ = ∑_T_ω_T_H_T_ = ∑_T_ω_T_∑_R_ω_R_D_T,R_,

- where H_E_ = the effective dose (or effective dose equivalent) in tissue T,
  ω_T_ = the tissue weighting factor in tissue T,
  H_T_ = the equivalent dose (or dose equivalent dose),
  ω_R_ = the radiation weighting factor, and
  D_T,R_ = the absorbed dose from radiation R to tissue T.

Tissue weighting factors for selected tissues are listed in Table D-5.

Table D-5 Tissue Weighting Factors for Calculating Effective Dose (or Effective Dose Equivalent) for Selected Tissues

Tissue | Tissue Weighting factor
Tissue | NRC (2011) /ICRP26 | NCRP115 and ICRP60 | ICRP103
Bladder | | 0.05 | 0.04
Bone marrow (red) | 0.12 | 0.12 | 0.12
Bone surface | 0.03 | 0.01 | 0.01
Brain | | | 0.01
Breast | 0.15 | 0.05 | 0.12
Colon | — | 0.12 | 0.12
Esophagus | – | 0.05 | 0.04
Gonads | 0.25 | 0.20 | 0.08
Liver | — | 0.05 | 0.04
Lung | 0.12 | 0.12 | 0.12
Salivary glands | | | 0.01
Skin | – | 0.01 | 0.01
Stomach | — | 0.12 | 0.12
Thyroid | 0.03 | 0.05 | 0.04
Subtotal | 0.70 | 0.95 | 0.88
Remainder | 0.30 | 0.05 | 0.12^a^
Total | 1.00 | 1.00 | 1.00

ICRP60 = International Commission on Radiological Protection, 1990 Recommendations of the ICRP

NCRP115 = National Council on Radiation Protection and Measurements. 1993. Risk Estimates for Radiation Protection, Report 115. Bethesda, Maryland

NRC = Nuclear Regulatory Commission, Title 10, Code of Federal Regulations, Part 20

a ICRP Publication 103 remainder tissues include adrenals, extrathoracic (ET) region, gall bladder, heart, kidneys, lymphatic nodes, muscle, oral mucosa, pancreas, prostate, small intestine, spleen, thymus, uterus/cervix

The ICRU (1980), ICRP (1984), and NCRP (1985) recommended that the terms rad, roentgen, curie, and rem be replaced by the SI units: gray (Gy), Coulomb per kilogram (C/kg), Becquerel (Bq), and sievert (Sv), respectively. The relationship between the historical units and the international system of units (SI) for radiological quantities is shown in Table D-6.

Table D-6 Comparison of Common and SI Units for Radiation Quantities

Quantity (Abbreviation) | Historical Unit | Historical Definition | SI unit | SI Definition
Activity (A) | curie (Ci) | 3.7×10^10^ transformations s^−1^ | becquerel (Bq) | s^−1^
Absorbed dose (D) | rad (rad) | 10^−2^ Jkg^−1^ | gray (Gy) | Jkg^−1^
Absorbed dose rate(Ď) | rad per second (rad s^−1^) | 10^−2^ Jkg^−1^ s^−1^ | gray per second (Gy s^−1^) | Jkg^−1^ s^−1^
Equivalent Dose (or Dose equivalent) (H_T_) | rem | 10^−2^Jkg^−1^ | siever (Sv) | Jkg^−1^
Equivalent Dose Rate (or Dose equivalent rate) Effective dose (or Effective Dose Equivalent) (H_E_) Linear energy transfer (LET) | rem per second (rem s^−1^) | 10^−2^Jkg^−1^s^−1^ | sievert per second (Sv s^−1^) | Jkg^−1^s^−1^
Equivalent Dose Rate (or Dose equivalent rate) Effective dose (or Effective Dose Equivalent) (H_E_) Linear energy transfer (LET) | rem | 10^−2^Jkg^−1^ | siever (Sv) | Jkg^−1^
Equivalent Dose Rate (or Dose equivalent rate) Effective dose (or Effective Dose Equivalent) (H_E_) Linear energy transfer (LET) | kiloelectron volts per mirometer (keV µm^−1^) | 1.602×10^−10^ Jm^−1^ | kiloelectron volts per micrometer (keV µm^−1^) | 1.60210^−10^ Jm^−1^

Jkg^−1^ = Joules per kilogram; Jkg^−1^s^−1^ = Joules per kilogram per second; ^−1^ = Joules per meter; s^−1^ = per second

### D.4.4 Working Levels and Working Level Months (for Radon Dosimetry)

Working level (WL) is a measure of the atmospheric concentration of radon and its short-lived progeny. One WL is defined as any combination of short-lived radon progeny (through polonium-214 [^214^Po]), per liter of air, that will result in the emission of 1.3×10^5^ MeV of alpha energy. An activity concentration of 100 pCi ^222^Rn/L of air, in equilibrium with its progeny, corresponds approximately to a potential alpha-energy concentration of 1 WL. The WL unit can also be used for thoron or ^220^Rn. In this case, 1.3×10^5^ MeV of alpha energy (1 WL) is released by 7.5 pCi ^220^Rn/L in equilibrium with its progeny. The potential alpha energy exposure of miners is commonly expressed in the unit Working Level Month (WLM). One WLM corresponds to inhalinga concentration of 1 WL for the reference period of 170 hours, or more generally

WLM = concentration (WL) × exposure time (months) / (one “month” = 170 working hours).

## D.5 Dosimetry Models

Dosimetry models are used to estimate the dose from internally deposited radioactive substances. The models for internal dosimetry consider the amount of radionuclides entering the body, the factors affecting their movement or transport through the body, distribution and retention of radionuclides in the body, and the energy deposited in organs and tissues from the radiation that is emitted during spontaneous decay processes. The dose pattern for radioactive materials in the body may be strongly influenced by the route of entry of the material. For industrial workers, inhalation of radioactive particles with pulmonary deposition and puncture wounds with subcutaneous deposition have been the most frequent. The general population has been exposed via ingestion, inhalation, and external exposure to low levels of naturally occurring radionuclides as well as artificial radionuclides used in nuclear medicine procedures and released from isotope generation facilities, nuclear weapons testing, and nuclear reactor operations and accidents.

The models for external dosimetry consider only the photon doses (and neutron doses, where applicable) to organs of individuals who are immersed in air or are exposed to a contaminated object.

### D.5.1 Ingestion

Ingestion of radioactive materials is most likely to occur from eating food or drinking water containing naturally occurring radioactive materials and possibly also contaminated with artificial radionuclides. Also, a portion of inhaled radionuclides initially deposited in the lung will relocate to the throat and be swallowed. Ingestion of a sufficient amount of radioactive materials may result in toxic effects as a result of either absorption of the radionuclide or irradiation of the gastrointestinal tract during passage through the tract, or a combination of both. The fraction of a radioactive materials absorbed from the gastrointestinal tract is variable, depending on the specific element, the physical and chemical form of the material ingested, and the diet, as well as some other metabolic and physiological factors. The absorption of some elements is influenced by age, usually with higher absorption in the very young.

### D.5.2 Inhalation

The nose and mouth have long been recognized as being a major portal of entry for both nonradioactive and radioactive materials. The deposition of particles within the lung is largely dependent upon the size and shape of the particles being inhaled (sometimes termed the atmospheric mean aerodynamic diameter or AMAD). After a particle is deposited, its retention will depend upon the physical and chemical properties of the dust and the physiological status of the lung. The retention of the particle in the lung depends on the location of deposition, in addition to the physical and chemical properties of the particles. The converse of pulmonary retention is pulmonary clearance. There are three distinct mechanisms of clearance which operate simultaneously. Ciliary clearance acts only in the upper respiratory tract. The second and third mechanisms act mainly in the deep respiratory tract. These are phagocytosis and absorption. Phagocytosis is the engulfing of foreign bodies by alveolar macrophages and their subsequent removal either up the ciliary "escalator" or by entrance into the lymphatic system. Some inhaled soluble particles are absorbed into the blood and translocated to other organs and tissues.

### D.5.3 Internal Emitters

An internal emitter is a radionuclide that is inside the body. The absorbed dose from internally deposited radioisotopes depends on the energy absorbed per unit tissue by the irradiated tissue. For a radioisotope distributed uniformly throughout an infinitely large medium, the concentration of absorbed energy must be equal to the concentration of energy emitted by the isotope. An infinitely large medium may be approximated by a tissue mass whose dimensions exceed the range of the particle. All alpha and most beta radiation will be absorbed in the organ (or tissue) of reference. Gamma-emitting isotope emissions are penetrating radiation, and a substantial fraction of gamma energy may not be absorbed in tissue. The dose to an organ or tissue is a function of the effective retention half-time, the energy released in the tissue, the amount of radioactivity initially introduced, and the mass of the organ or tissue.

## D.6 BIOLOGICAL EFFECTS OF RADIATION

When biological material is exposed to ionizing radiation, a chain of cellular events occurs as the ionizing particle passes through the biological material. A number of theories have been proposed to describe the interaction of radiation with biologically important molecules in cells and to explain the resulting damage to biological systems from those interactions. Many factors may modify the response of a living organism to a given dose of radiation. Factors related to the exposure include the dose rate, the energy of the radiation, and the temporal pattern of the exposure (e.g., protracted or fractionated exposures). Biological considerations include factors such as species, age, sex, and the portion of the body exposed. Several excellent reviews of the biological effects of radiation have been published, and the reader is referred to these for a more in-depth discussion (Brodsky 1996; Klaassen 2001; Hobbs and McClellan 1986; ICRP 1984; Mettler and Moseley 1985; Rubin and Casarett 1968).

### D.6.1 Radiation Effects at the Cellular Level

breaks in DNA may be produced. These single strand breaks may be repaired rapidly. With doses in the range of 0.5–5 Gy (50–500 rad), irreparable double-stranded DNA breaks are likely, resulting in cellular reproductive death after one or more divisions of the irradiated parent cell. At large doses of radiation, usually greater than 5 Gy (500 rad), direct cell death before division (interphase death) may occur from the direct interaction of free-radicals with essentially cellular macromolecules. Morphological changes at the cellular level, the severity of which are dose-dependent, may also be observed.

The sensitivity of various cell types varies. According to the Bergonie-Tribondeau law, the sensitivity of cell lines is directly proportional to their mitotic rate and inversely proportional to the degree of differentiation (Mettler and Moseley 1985). Rubin and Casarett (1968) devised a classification system that categorized cells according to type, function, and mitotic activity. The categories range from the most sensitive type, "vegetative intermitotic cells, " found in the stem cells of the bone marrow and the gastrointestinal tract, to the least sensitive cell type, "fixed postmitotic cells, " found in striated muscles or long-lived neural tissues.

Cellular changes may result in cell death, which if extensive, may produce irreversible damage to an organ or tissue or may result in the death of the individual. If the cell recovers, altered metabolism and function may still occur, which may be repaired or may result in the manifestation of clinical symptoms. These changes may also be expressed at a later time as tumors, cellular mutations, or transformed tissue (scar tissue) which may result in abnormal tissue or compromised function.

### D.6.2 Radiation Effects at the Organ Level

In most organs and tissues the injury and the underlying mechanism for that injury are complex and may involve a combination of events. The extent and severity of this tissue injury are dependent upon the radiosensitivity of the various cell types in that organ system. Rubin and Casarett (1968) describe and schematically display the events following radiation in several organ system types. These include: a rapid renewal system, such as the gastrointestinal mucosa; a slow renewal system, such as the pulmonary epithelium; and a nonrenewal system, such as neural or muscle tissue. In the rapid renewal system, organ injury results from the direct destruction of highly radiosensitive cells, such as the stem cells in the bone marrow. Injury may also result from constriction of the microcirculation and from edema and inflammation of the basement membrane, designated as the histohematic barrier (HHB), which may progress to fibrosis. In slow renewal and nonrenewal systems, the radiation may have little effect on the parenchymal cells, but ultimate parenchymal atrophy and death over several months result from HHB fibrosis and occlusion of the microcirculation.

### D.6.3 Low Level Radiation Effects

Cancer is the major latent harmful effect produced by ionizing radiation and the one that most people exposed to radiation are concerned about. The ability of alpha, beta, and gamma radiation to produce cancer in virtually every tissue and organ in laboratory animals has been well-demonstrated, while radiogenic cancer has not been observed in some human tissues and organs. The development of cancer is not an immediate effect. In humans, radiation-induced leukemia has the shortest latent period at 2 years, thyroid cancer after Chernobyl showed up in children about four years after the accident, while other radiation induced cancers have latent periods >20 years. For the non-radiogenic cancers, it has been hypothesized either that repair mechanisms effectively protect the individual or that the latency period exceeds the current human life span (Raabe 2010). The mechanism by which cancer is induced in living cells is complex and is a topic of intense study. Exposure to ionizing radiation can produce cancer; however, some sites appear to be more common than others, such as the breast, lung, stomach, and thyroid.

DNA is a major target molecule during exposure to ionizing radiation. Other macromolecules, such as lipids and proteins, are also at risk of damage when exposed to ionizing radiation. The genotoxicity of ionizing radiation is an area of intense study, as damage to the DNA is ultimately responsible for many of the adverse toxicological effects ascribed to ionizing radiation, including cancer. Damage to genetic material is basic to developmental or teratogenic effects, as well.

There is limited evidence of non-cancer human effects at low radiation doses. Non-cancer effects that have been reported are associated with the Japanese atomic bomb survivor population and include neurological and cardiovascular effects. Neurological effects were observed in fetuses exposed to prompt radiation during the detonations while they were in gestation weeks 8–15, less so for weeks 16–25, and were not observed for other developmental time frames. Cardiovascular effects have been reported for atomic bomb survivors following 60 years of follow-up. These include a statistically significant increase in heart disease (% elevated relative risk per Gy with 95% confidence interval = 14 [6–23] %/Gy, p<0.001) and a non-statistically significant increase in stroke (9 [1–17]%/Gy, p=0.02) above a dose of 0.5 Gy. These radiation-induced circulatory effects may be increased by other factors such as smoking, microvascular damage in the kidney and associated hypertension, high serum cholerterol, diabetes, and infection.

## REFERENCES FOR APPENDIX D

ATSDR. Toxicological profile for thorium. Atlanta, GA. U.S. Department of Health and Human Services. Public Health Service. Agency for Toxic Substances and Disease Registry. 1990a.
ATSDR. Toxicological profile for radium. Atlanta, GA. U.S. Department of Health and Human Services. Public Health Service. Agency for Toxic Substances and Disease Registry. 1990b.
ATSDR. Toxicological profile for radon. Atlanta, GA. U.S. Department of Health and Human Services. Public Health Service. Agency for Toxic Substances and Disease Registry. 1990c.
ATSDR. Toxicological profile for uranium. Atlanta, GA. U.S. Department of Health and Human Services. Public Health Service. Agency for Toxic Substances and Disease Registry. 1999.
BEIR III. The effects on populations of exposure to low levels of ionizing radiation. Committee on the Biological Effects of Ionizing Radiations, National Research Council. Washington, DC. National Academy Press. 1980.
BEIR IV. Health risks of radon and other internally deposited alpha emitters. Committee on the Biological Effects of Ionizing Radiations, National Research Council. Washington, DC. National Academy Press. 1988.
BEIR V. Health effects of exposure to low levels of ionizing radiation. Committee on the Biological Effects of Ionizing Radiations, National Research Council. Washington, DC. National Academy Press. 1988.
Brodsky A. Review of radiation risks and uranium toxicity with application to decisions associated with decommissioning clean-up criteria. Hebron, Connecticut. RSA Publications. 1996.
Cember H. Introduction to health physics. New York, NY. McGraw Hill. 1996.
Cember H, Johnson T. 2007.
Early P, Razzak M, Sodee D. Nuclear medicine technology. 2nd ed. St. Louis. C. V. Mosby Company. 1979.
Eichholz G. Environmental aspects of nuclear power. Ann Arbor, MI. Ann Arbor Science. 1982.
Hendee W. Radioactive isotopes in biological research. New York, NY. John Wiley and Sons. 1973.
Hobbs C, McClellan R. Doull J, et al., editors. Radiation and radioactive materials. Casarett and Doull's Toxicology. 3rd ed. New York, NY. Macmillan Publishing. Co. Inc. 1986:497-530.
ICRP. International Commission on Radiological Protection. Recommendations of the International Commission on Radiological Protection. ICRP Publication 26. Oxford. Pergamon Press. 1977;Vol 1(No. 3).
ICRP. International Commission on Radiological Protection. Limits for intakes of radionuclides by workers. ICRP Publication 20. Oxford. Pergamon Press. 1979;Vol. 3(No. 1–4).
ICRP. Limits for Intakes of Radionuclides by Workers. Publication 30. International Commission on Radiological Protection. Pergamon Press. 1979.
ICRP. International Commission on Radiological Protection. A compilation of the major concepts and quantities in use by ICRP. ICRP Publication 42. Oxford. Pergamon Press. 1984.
ICRP. International Commission on Radiological Protection 1990 Recommendations of the ICRP. 1990.
ICRP. Publication No.103, The 2007 Recommendations of the International Commission on Radiological Protection. ICRP. 2007;37(2–4):1-332.
ICRU. International Commission on Radiation Units and Measurements. ICRU Report No. 33. Washington, DC. 1980.
James A. Hopke P, editor. A reconsideration of cells at risk and other key factors in radon daughter dosimetry. Radon and its decay products: Occurrence, properties and health effects. ACS Symposium Series 331. Washington, DC. American Chemical Society. 1987:400-418.
James A, Roy M. Gerber G, et al., editors. Dosimetric lung models. Age-related factors in radionuclide metabolism and dosimetry. Boston. Martinus Nijhoff Publishers. 1987:95-108.
Kondo S. Health effects of low-level radiation. Osaka, Japan. Kinki University Press. 1993. (available from Medical Physics Publishing, Madison, Wisconsin).
Kato H, Schull W. Studies of the mortality of A-bomb survivors. Report 7 Part 8, Cancer mortality among atomic bomb survivors, 1950–78. Radiat Res. 1982;90:395-432. [pmid: 7079470].
Klaassen. Casarett and Doull’s toxicology: The basic science of poisons. McGraw-Hill. 2001.
LBL. Atomic and nuclear properties of materials: Neutron (n). Lawrence Berkeley Laboratory. 2011. http://pdg.lbl.gov/2011/AtomicNuclearProperties/neutron.html. (December 7, 2011).
Mettler F, Moseley R. Medical effects of ionizing radiation. New York. Grune and Stratton. 1985.
Nakamura. Particle data group. The review of particle physics and 2011 partial update. J Phys G. 2012;37. 075021. http://pdg.lbl.gov/. (December 7, 2011).
NCRP. Basic radiation protection criteria. National Council on Radiation Protection and Measurements. Report No. 39. Washington, DC. 1971.
NCRP. A handbook of radioactivity measurements procedures. National Council on Radiation Protection and Measurements. Report No. 58. 2nd ed. Bethesda, MD. 1985.
NCRP. Risk estimates for radiation protection. National Council on Radiation Protection and Measurements. Report 115. Bethesda, Maryland. 1993.
NCRP. Electronic Code of Federal Regulations. Title 10: Energy. Part 20-Standards for protection against radon. Subpart A-General provisions. § 20.1003 Definitions. 2012a. http://ecfr.gpoaccess.gov/cgi/t/text/text-idx?c=ecfr&sid=48e22c6aa171831075552dcbea1a5939&rgn=div8&view=text&node=10:1.0.1.1.16.1.76.3&idno=10. (January 27, 2012).
NCRP. Electronic Code of Federal Regulations. Title 10: Energy. Part 20-Standards for protection against radon. Subpart A-General provisions. § 20.1004 Units of radiation dose. 2012b. http://ecfr.gpoaccess.gov/cgi/t/text/text-idx?c=ecfr;sid=1f508d141b96be7c2a197d0724844aa5;rgn=div5;view=text;node=10%3A1.0.1.1.16;idno=10;cc=ecfr#10:1.0.1.1.16.1.76.4. (January 27, 2012).
Oganessian YT, Abdullin FS, Bailey PD, et al. Synthesis of a new element with atomic number Z = 117. Phys Rev Lett. 2010;104(14):142502-1-142402-4. [pmid: 20481935].
Otake M, Schull W. Mental retardation in children exposed in utero to the atomic bombs: A reassessment. Technical Report RERF TR 1–83, Radiation Effects Research Foundation, Japan. 1984.
Raabe OG. Concerning the health effects of internally deposited radionuclides. Health Phys. 2010;98(3):515-536. [pmid: 20147792].
Rubin P, Casarett G. Clinical radiation pathology. Philadelphia. W. B. Sanders Company. 1968:33.
Schull WJ. Effect on intelligence test score of prenatal exposure to ionizing radiation in Hiroshima and Nagasaki: A comparison of the T65DR and DS86 dosimetry systems. Radiation Effects Research Foundation. Japan. 1988.
Shimizu Y, Kodama K, Nishi N, et al. Radiation exposure and circulatory disease risk: Hiroshima and Nagasaik atomic bomb survivor data, 1950–2003. Brit Med J. 2010;340:b5349. [pmid: 20075151].
Thisgaard H, Jensen M, Elema DR. Medium to large scale radioisotope production for targeted radiotherapy using a small PET cyclotron. Appl Radiat Isot. 2001;69(1):1-7. [pmid: 20724171].
UNSCEAR. United Nations Scientific Committee on the Effects of Atomic Radiation. Sources and effects of ionizing radiation. New York. United Nations. 1977.
UNSCEAR. United Nations Scientific Committee on the Effects of Atomic Radiation. Ionizing radiation: Sources and biological effects. New York. United Nations. 1982.
UNSCEAR. United Nations Scientific Committee on the Effects of Atomic Radiation. Genetic and somatic effects of ionizing radiation. New York. United Nations. 1986.
UNSCEAR. United Nations Scientific Committee on the Effects of Atomic Radiation. Sources, effects and risks of ionization radiation. New York. United Nations. 1988.
UNSCEAR. United Nations Scientific Committee on the Effects of Atomic Radiation. Sources and effects of ionizing radiation. New York. United Nations. 1993.
USNRC. Title 10, Code of Federal Regulations Part 20.1003. Washington, DC. U. S. Nuclear Regulatory Commission. 2011a. http://ecfr.gpoaccess.gov/cgi/t/text/textidx?c=ecfr&sid=a0927f5dead51eb92d3892fad0f1ac42&rgn=div8&view=text&node=10:1.0.1.1.16.1.76.3&idno=10. (December 9, 2011).
USNRC. Title 10 Code of Federal Regulations Part 20, Table 1004(b).1. Washington, D.C. U.S. Nuclear Regulatory Commission. 2011. http://ecfr.gpoaccess.gov/cgi/t/text/text-idx?c=ecfr&sid=a0927f5dead51eb92d3892fad0f1ac42&rgn=div8&view=text&node=10:1.0.1.1.16.1.76.4&idno=10. (December 9, 2011).