# ACRONYMS, ABBREVIATIONS, AND SYMBOLS

AARST: American Association of Radon Scientists and Technologists
ACGIH: American Conference of Governmental Industrial Hygienists
ACOEM: American College of Occupational and Environmental Medicine
ADI: acceptable daily intake
ADME: absorption, distribution, metabolism, and excretion
AED: atomic emission detection
AFID: alkali flame ionization detector
AFOSH: Air Force Office of Safety and Health
ALT: alanine aminotransferase
AML: acute myeloid leukemia
AOAC: Association of Official Analytical Chemists
AOEC: Association of Occupational and Environmental Clinics
AP: alkaline phosphatase
APHA: American Public Health Association
ASD: active soil depressurization
AST: aspartate aminotransferase
atm: atmosphere
ATSDR: Agency for Toxic Substances and Disease Registry
AWQC: Ambient Water Quality Criteria
BAT: best available technology
BCF: bioconcentration factor
BEI: Biological Exposure Index
BMD: benchmark dose
BMD/C: benchmark dose or benchmark concentration
BMD_X_: dose that produces a X% change in response rate of an adverse effect
BMDL_X_: 95% lower confidence limit on the BMD_X_
BMDS: Benchmark Dose Software
BSC: Board of Scientific Counselors
C: centigrade
CAA: Clean Air Act
CAG: Cancer Assessment Group of the U.S. Environmental Protection Agency
CAS: Chemical Abstract Services
CDC: Centers for Disease Control and Prevention
CEL: cancer effect level
CELDS: Computer-Environmental Legislative Data System
CERCLA: Comprehensive Environmental Response, Compensation, and Liability Act
CFR: Code of Federal Regulations
Ci: curie
CI: confidence interval
CL: ceiling limit value
CLP: Contract Laboratory Program
cm: centimeter
CML: chronic myeloid leukemia
CPSC: Consumer Products Safety Commission
CRM: continuous radon monitor
CWA: Clean Water Act
CWM: continuous working level monitor
DHEW: Department of Health, Education, and Welfare
DHHS: Department of Health and Human Services
DNA: deoxyribonucleic acid
DOD: Department of Defense
DOE: Department of Energy
DOL: Department of Labor
DOT: Department of Transportation
DOT/UN/NA/IMDG: Department of Transportation/United Nations/North America/Intergovernmental Maritime Dangerous Goods Code
DWEL: drinking water exposure level
ECD: electron capture detection
ECG/EKG: electrocardiogram
EEG: electroencephalogram
EEGL: Emergency Exposure Guidance Level
EPA: Environmental Protection Agency
ERR: excess relative risk
F: Fahrenheit
F_1_: first-filial generation
FAO: Food and Agricultural Organization of the United Nations
FDA: Food and Drug Administration
FEMA: Federal Emergency Management Agency
FIFRA: Federal Insecticide, Fungicide, and Rodenticide Act
FPD: flame photometric detection
fpm: feet per minute
FR: Federal Register
FSH: follicle stimulating hormone
g: gram
GC: gas chromatography
gd: gestational day
GLC: gas liquid chromatography
GPC: gel permeation chromatography
HPLC: high-performance liquid chromatography
HRGC: high resolution gas chromatography
HSDB: Hazardous Substance Data Bank
IARC: International Agency for Research on Cancer
IDLH: immediately dangerous to life and health
ILO: International Labor Organization
IRIS: Integrated Risk Information System
Kd: adsorption ratio
kg: kilogram
kkg: metric ton
K_oc_: organic carbon partition coefficient
K_ow_: octanol-water partition coefficient
L: liter
LC: liquid chromatography
LC_50_: lethal concentration, 50% kill
LC_Lo_: lethal concentration, low
LD_50_: lethal dose, 50% kill
LD_Lo_: lethal dose, low
LDH: lactic dehydrogenase
LH: luteinizing hormone
LOAEL: lowest-observed-adverse-effect level
LSE: Levels of Significant Exposure
LT_50_: lethal time, 50% kill
m: meter
MA: trans,trans-muconic acid
MAL: maximum allowable level
mCi: millicurie
MCL: maximum contaminant level
MCLG: maximum contaminant level goal
MF: modifying factor
MFO: mixed function oxidase
mg: milligram
mL: milliliter
mm: millimeter
mmHg: millimeters of mercury
mmol: millimole
mppcf: millions of particles per cubic foot
MRL: Minimal Risk Level
MS: mass spectrometry
NAAQS: National Ambient Air Quality Standard
NAS: National Academy of Science
NATICH: National Air Toxics Information Clearinghouse
NATO: North Atlantic Treaty Organization
NCE: normochromatic erythrocytes
NCEH: National Center for Environmental Health
NCI: National Cancer Institute
ND: not detected
NFPA: National Fire Protection Association
ng: nanogram
NHANES: National Health and Nutrition Examination Survey
NIEHS: National Institute of Environmental Health Sciences
NIOSH: National Institute for Occupational Safety and Health
NIOSHTIC: NIOSH's Computerized Information Retrieval System
NLM: National Library of Medicine
nm: nanometer
nmol: nanomole
NOAEL: no-observed-adverse-effect level
NOES: National Occupational Exposure Survey
NOHS: National Occupational Hazard Survey
NPD: nitrogen phosphorus detection
NPDES: National Pollutant Discharge Elimination System
NPL: National Priorities List
NR: not reported
NRC: National Research Council
NRPP: National Radon Proficiency Program
NRSB: National Radon Safety Board
NS: not specified
NSPS: New Source Performance Standards
NTIS: National Technical Information Service
NTP: National Toxicology Program
ODW: Office of Drinking Water, EPA
OERR: Office of Emergency and Remedial Response, EPA
OHM/TADS: Oil and Hazardous Materials/Technical Assistance Data System
OPP: Office of Pesticide Programs, EPA
OPPT: Office of Pollution Prevention and Toxics, EPA
OPPTS: Office of Prevention, Pesticides and Toxic Substances, EPA
OR: odds ratio
OSHA: Occupational Safety and Health Administration
OSW: Office of Solid Waste, EPA
OTS: Office of Toxic Substances
OW: Office of Water
OWRS: Office of Water Regulations and Standards, EPA
PAH: polycyclic aromatic hydrocarbon
PBPD: physiologically based pharmacodynamic
PBPK: physiologically based pharmacokinetic
PCE: polychromatic erythrocytes
PEL: permissible exposure limit
pg: picogram
PHS: Public Health Service
PID: photo ionization detector
pmol: picomole
PMR: proportionate mortality ratio
ppb: parts per billion
ppm: parts per million
ppt: parts per trillion
PSNS: pretreatment standards for new sources
RADEP: RAdon Dose Evaluation Program
RBC: red blood cell
REL: recommended exposure level/limit
RfC: reference concentration
RfD: reference dose
RNA: ribonucleic acid
RQ: reportable quantity
RR: relative risk
RTECS: Registry of Toxic Effects of Chemical Substances
SARA: Superfund Amendments and Reauthorization Act
SCE: sister chromatid exchange
SGOT: serum glutamic oxaloacetic transaminase
SGPT: serum glutamic pyruvic transaminase
SIC: standard industrial classification
SIM: selected ion monitoring
SMCL: secondary maximum contaminant level
SMR: standardized mortality ratio
SNARL: suggested no adverse response level
SPEGL: Short-Term Public Emergency Guidance Level
STEL: short term exposure limit
STORET: Storage and Retrieval
TD_50_: toxic dose, 50% specific toxic effect
TLV: threshold limit value
TOC: total organic carbon
TPQ: threshold planning quantity
TRI: Toxics Release Inventory
TSCA: Toxic Substances Control Act
TWA: time-weighted average
UF: uncertainty factor
U.S.: United States
USDA: United States Department of Agriculture
USGS: United States Geological Survey
VOC: volatile organic compound
WBC: white blood cell
WHO: World Health Organization
>: greater than
≥: greater than or equal to
=: equal to
<: less than
≤: less than or equal to
%: percent
α: alpha
β: beta
γ: gamma
δ: delta
μm: micrometer
μg: microgram
q_1_^*^: cancer slope factor
−: negative
+: positive
(+): weakly positive result
(−): weakly negative result