# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Henry Abadin, M.S.P.H. (Lead)
  Jessilynn Taylor, M.S., CDR USPHS
  Melanie Buser, M.P.H.
  Franco Scinicariello, M.D., M.P.H.
  Jennifer Przybyla, Ph.D.
- ATSDR, Division of Toxicology and Human Health Sciences, Atlanta, GA
- Julie M. Klotzbach, Ph.D.
  Gary L. Diamond, Ph.D.
  Mario Citra, Ph.D.
  Lara L. Chappell, Ph.D.
  Laura A. McIlroy, B.A.
- SRC, Inc., North Syracuse, NY

## REVIEWERS

Interagency Minimal Risk Level Workgroup:

Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).

Additional reviews for science and/or policy:

ATSDR, Division of Community Health Investigations; ATSDR, Office of Science; NCEH, Division of Laboratory Science; NCEH, Division of Environmental Health Science and Practice; Occupational Safety and Health Administration (OSHA); Department of Defense (DoD); EPA; NIOSH.

## PEER REVIEWERS

1. Howard Hu, M.D., M.P.H., Sc.D., Department of Environmental Health Sciences, University of Michigan School of Public Health, Ann Arbor, Michigan
2. Anthony Knafla, M.Sc., DABT, P. Biol., Founder/Senior Scientist & Manager, Equilibrium Environmental Inc., Calgary, Canada
3. Nelly Mañay, Ph.D., Professor, Department of Toxicology and Environmental Hygiene, Faculty of Chemistry, University of the Republic of Uruguay, Montevideo, Uruguay

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.