# CHAPTER 8 REFERENCES

AAP. 1998. Screening for elevated blood lead levels. American Academy of Pediatrics. Pediatrics 101(6):1072–1078.
AAP. 2005. Lead exposure in children: Prevention, detection, and management. American Academy of Pediatrics. Pediatrics 116(4):1036–1046.16199720
AAP. 2016. Prevention of childhood lead toxicity. Council on Environmental Health. (Erratum in: Pediatrics 140(2):e20171490). American Academy of Pediatrics. Pediatrics 138(1):e20161493. 10.1542/peds.2016-1493.27325637
Abadin HG, Wheeler JS, Jones DE, . 1997. A framework to guide public health assessment decisions at lead sites. J Clean Technol Environ Toxicol Occup Med 6(3):225–237.
Abam E, Okediran BS, Odukoya OO, . 2008. Reversal of ionoregulatory disruptions in occupational lead exposure by vitamin C. Environ Toxicol Pharmacol 26(3):297–304. 10.1016/j.etap.2008.05.008.21791378
Abdelouahab N, Mergler D, Takser L, . 2008. Gender differences in the effects of organochlorines, mercury, and lead on thyroid hormone levels in lakeside communities of Quebec (Canada). Environ Res 107(3):380–392. 10.1016/j.envres.2008.01.006.18313043
ACGIH. 2018. TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
ACMT. 2010. American College of Medical Toxicology position statement on post-chelator challenge urinary metal testing. American College of Medical Toxicology. J Med Toxicol 6:74–75.20354920
Adebonojo FO. 1974. Hematologic status of urban black children in Philadelphia. Clin Pediatr (Phila) 13(10):874–888.4413649
Ademuyiwa O, Ugbaja RN, Idumebor F, . 2005. Plasma lipid profiles and risk of cardiovascular disease in occupational lead exposure in Abeokuta, Nigeria. Lipids Health Dis 4:19. 10.1186/1476-511X-4-19.16191200
Afeiche M, Peterson KE, Sánchez BN, . 2011. Prenatal lead exposure and weight of 0- to 5 year-old children in Mexico City. Environ Health Perspect 119(10):1436–1441. 10.1289/ehp.1003184.21715242
Ahamed M, Siddiqui MK. 2007. Low level lead exposure and oxidative stress: Current opinions. Clin Chim Acta 383(1–2):57–64. 10.1016/j.cca.2007.04.024.17573057
Ahamed M, Verma S, Kumar A, . 2005. Environmental exposure to lead and its correlation with biochemical indices in children. Sci Total Environ 346(1–3):48–55. 10.1016/j.scitotenv.2004.12.019.15993681
Ahamed M, Verma S, Kumar A, . 2006. Delta-aminolevulinic acid dehydratase inhibition and oxidative stress in relation to blood lead among urban adolescents. Hum Exp Toxicol 25(9):547–553. 10.1191/0960327106het657oa.17017008
Ahamed M, Singh S, Behari JR, . 2007. Interaction of lead with some essential trace metals in the blood of anemic children from Lucknow, India. Clin Chim Acta 377(1–2):92–97. 10.1016/j.cca.2006.08.032.17027950
Ahn J, Kim NS, Lee BK, . 2018. Association of blood pressure with blood lead and cadmium levels in Korean adolescents: Analysis of data from the 2010-2016 Korean National Health and Nutrition Examination Survey. J Korean Med Sci 33(44):e278. 10.3346/jkms.2018.33.e278.30369859
Aiba Y, Ohshiba S, Horiguchi S, . 1999. Peripheral hemodynamics evaluated by acceleration plethysmography in workers exposed to lead. Ind Health 37:3–8.10052293
Åkesson A, Stal P, Vahter M. 2000. Phlebotomy increases cadmium uptake in hemochromatosis. Environ Health Perspect 108:289–291.10753085
Åkesson A, Lundh T, Vahter M, . 2005. Tubular and glomerular kidney effects in Swedish women with low environmental cadmium exposure. Environ Health Perspect 113(11):1627–1631. 10.1289/ehp.8033.16263522
Akhavan J. 2004. Explosives and propellants. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 10. New York: John Wiley & Sons, 719–744. http://onlinelibrary.wiley.com/doi/10.1002/0471238961.0524161212091404.a01.pub2/pdf. March 30, 2017.
Akram Z, Riaz S, Kayani MA, . 2019. Lead induces DNA damage and alteration of ALAD and antioxidant genes mRNA expression in construction site workers. Arch Environ Occup Health 74(4):171–178. 10.1080/19338244.2018.1428523.29336731
Al Bakheet SA, Attafi IM, Maayah ZH, . 2013. Effect of long-term human exposure to environmental heavy metals on the expression of detoxification and DNA repair genes. Environ Pollut 181:226–232.23872045
Alessio L. 1988. Relationship between “chelatable lead” and the indicators of exposure and effect in current and past occupational life. Sci Total Environ 71:293–299.3136543
Alessio L, Bertazzi PA, Monelli O, . 1976. Free erythrocyte protoporphyrin as an indicator of the biological effect of lead in adult males. Int Arch Occup Environ Health 37:89–105.1279013
Alexander FW, Clayton BE, Delves HT. 1974. Mineral and trace-metal balances in children receiving normal and synthetic diets. Q J Med 169:89–111.
Alexander BH, Checkoway H, Faustman EM, . 1998a. Contrasting associations of blood and semen lead concentrations with semen quality among lead smelter workers. Am J Ind Med 34:464–469.9787850
Alexander BH, Checkoway H, Costa-Mallen P, . 1998b. Interaction of blood lead and delta-aminolevulinic acid dehydratase genotype on markers of heme synthesis and sperm production in lead smelter workers. Environ Health Perspect 106:213–216.9495797
Al-Hakkak ZS, Hamamy HA, Murad AM, . 1986. Chromosome aberrations in workers at a storage battery plant in Iraq. Mutat Res Genet Toxicol 171(1):53–60.
Ali Z, Ulrik CS. 2013. Obesity and asthma: A coincidence or a causal relationship? A systematic review. Respir Med 107:1287–1300.23642708
Aligne CA, Auinger P, Byrd RS, . 2000. Risk factors for pediatric asthma: Contributions of poverty, race, and urban residence. Am J Respir Crit Care Med 162(3 Pt. 1):873–877.10988098
Almeida Lopes ACB, Silbergeld EK, Navas-Acien A, . 2017. Association between blood lead and blood pressure: A population-based study in Brazilian adults. Environ Health 16(1):27. 10.1186/s12940-017-0233-5.28292314
Al-Modhefer AJ, Bradbury MWB, Simons TJB. 1991. Observations on the chemical nature of lead in human blood serum. Clin Sci 81:823–829.
Al-Neamy FR, Almehdi AM, Alwash R, . 2001. Occupational lead exposure and amino acid profiles and liver function tests in industrial workers. Int J Environ Health Res 11(2):181–188.11382350
Alomran AH, Shleamoon MN. 1988. The influence of chronic lead exposure on lymphocyte proliferative response and immunoglobulin levels in storage battery workers. J Biol Sci 19(3):575–585.
Al-Saleh I, Shinwari N, Mashhour A, . 2005. Is lead considered as a risk factor for high blood pressure during menopause period among Saudi women? Int J Hyg Environ Health 208(5):341–356.16217919
Al-Saleh I, Shinwari N, Mashhour A, . 2014. Birth outcome measures and maternal exposure to heavy metals (lead, cadmium and mercury) in Saudi Arabian population. Int J Hyg Environ Health 217(2–3):205–218. 10.1016/j.ijheh.2013.04.009.23735463
Alvarez-Ortega N, Caballero-Gallardo K, Olivero-Verbel J. 2019. Toxicological effects in children exposed to lead: A cross-sectional study at the Colombian Caribbean coast. Environ Int 130:104809. 10.1016/j.envint.2019.05.003.31302530
Amaral JH, Rezende VB, Quintana SM, . 2010. The relationship between blood and serum lead levels in peripartum women and their respective umbilical cords. Basic Clin Pharmacol Toxicol 107(6):971–975. 10.1111/j.1742-7843.2010.00616.x.20629654
Amato MS, Magzamen S, Imm P, . 2013. Early lead exposure (<3 years old) prospectively predicts fourth grade school suspension in Milwaukee, Wisconsin (USA). Environ Res 126:60–65. 10.1016/j.envres.2013.07.008.23948117
Ames SK, Ellis KJ, Gunn SK, . 1999. Vitamin D receptor gene Fok1 polymorphism predicts calcium absorption and bone mineral density in children. J Bone Miner Res 14(5):740–746.10320522
Amitai Y, Graef JW, Brown MJ, . 1987. Hazards of ‘deleading’ homes of children with lead poisoning. Am J Dis Child 141:758–760.2438931
An HC, Sung JH, Lee J, . 2017. The association between cadmium and lead exposure and blood pressure among workers of a smelting industry: A cross-sectional study. Ann Occup Environ Med 29:47. 10.1186/s40557-017-0202-z.29034097
Anetor J, Adeniyi F. 1997. Decreased immune status in Nigerian workers occupationally exposed to lead. Afr J Med Sci 27(3–4):169–172.
Angel BM, Apte SC, Batley GE, . 2016. Lead solubility in seawater: An experimental study. Huanjing Huaxue 13(3):489. 10.1071/en15150.
Angelova VR, Ivanova RV, Todorov JM, . 2010. Lead, cadmium, zinc, and copper bioavailability in the soil-plant-animal system in a polluted area. ScientificWorldJournal 10:273–285. 10.1100/tsw.2010.33.20191239
Angle CR, Manton WI, Stanek KL. 1995. Stable isotope identification of lead sources in preschool children - The Omaha Study. Clin Toxicol 33(6):657–662.
Angle CR, McIntire MS, Swanson MS, . 1982. Erythrocyte nucleotides in children - Increased blood lead and cytidine triphosphate. Pediatr Res 16:331–334.7079004
Anttila A, Heikkila P, Pukkala E, . 1995. Excess lung cancer among workers exposed to lead. Scand J Work Environ Health 21:460–469.8824752
Anttila A, Heikkila P, Nykyri E, . 1996. Risk of nervous system cancer among workers exposed to lead. J Occup Environ Med 38(2):131–136.8673517
Anwar WA, Kamal AA. 1988. Cytogenetic effects in a group of traffic policemen in Cairo. Mutat Res 208(3–4):225–231.2456461
Aoki Y, Brody DJ, Flegal KM, . 2016. Blood lead and other metal biomarkers as risk factors for cardiovascular disease mortality. Medicine 95(1):e2223. 10.1097/md.0000000000002223.26735529
Apostoli P, Maranelli G, Cas LD, . 1990. Blood lead and blood pressure: A cross sectional study in a general population group. Cardiologia 35(7):597–603.2088605
Apostolou A, Garcia-Esquinas E, Fadrowski JJ, . 2012. Secondhand tobacco smoke: A source of lead exposure in US children and adolescents. Am J Public Health 102(20):12. 10.2105/AJPH.2011.300161.
Araki S, Murata K, Aono H. 1987. Central and peripheral nervous system dysfunction in workers exposed to lead, zinc and copper. Int Arch Occup Environ Health 59:177–187.3557626
Araki S, Sata F, Murata K. 1990. Adjustment for urinary flow rate: An improved approach to biological monitoring. Int Arch Occup Environ Health 62(6):471–477.2246067
Araki S, Honma T, Yanagihara S, . 1980. Recovery of slowed nerve conduction velocity in lead-exposed workers. Int Arch Occup Environ Health 46:151–157.7399723
Araki S, Aono H, Yokoyama K, . 1986. Filterable plasma concentration, glomerular filtration, tubular balance, and renal clearance of heavy metals and organic substances in metal workers. Arch Environ Health 41(4; 4):216–221.3767431
Araki S, Sato H, Yokoyama K, . 2000. Subclinical neurophysiological effects of lead: A review on peripheral, central, and autonomic nervous system effects in lead workers. Am J Ind Med 37:193–204.10615100
Arbuckle TE, Davis K, Boylan K, . 2016. Processed data for CHMS 2007-2009: Bisphenol A, phthalates and lead and learning and behavioral problems in Canadian children 6-19 years of age. Data Brief 8:784–802. 10.1016/j.dib.2016.06.017.27500191
Ari E, Kaya Y, Demir H, . 2011. The correlation of serum trace elements and heavy metals with carotid artery atherosclerosis in maintenance hemodialysis patients. Biol Trace Elem Res 144(1–3):351–359. 10.1007/s12011-011-9103-0.21647752
Armstrong R, Chettle DR, Scott MC, . 1992. Repeated measurements of tibia lead concentrations by in vivo x-ray fluorescence in occupational exposure. Br J Ind Med 49(1):14–16.1733451
Arnvig E, Grandjean P, Beckmann J. 1980. Neurotoxic effects of heavy lead exposure determined with psychological tests. Toxicol Lett 5:399–404.7394836
Aro A, Amarasiriwardena C, Lee ML, . 2000. Validation of K x-ray fluorescence bone lead measurements by inductively coupled plasma mass spectrometry in cadaver legs. Med Phys 27(1):119–123 10659745
Arora M, Ettinger AS, Peterson KE, . 2008. Maternal dietary intake of polyunsaturated fatty acids modifies the relationship between lead levels in bone and breast milk. J Nutr 138:73–79.18156407
Arora M, Weuve J, Weisskopf MG, . 2009. Cumulative lead exposure and tooth loss in men: The normative aging study. Environ Health Perspect 117(10):1531–1534.20019902
Arora M, Austin C, Sarrafpour B, . 2014. Determining prenatal, early childhood and cumulative long-term lead exposure using micro-spatial deciduous dentine levels. PLoS ONE 9(5):e97805. 10.1371/journal.pone.0097805.24841926
Aschengrau A, Beiser A, Bellinger D, . 1994. The impact of soil lead abatement on urban children’s blood lead levels: Phase II results from Boston Lead-in-Soil Demonstration project. Environ Res 67:125–148.7982389
Assennato G, Paci C, Baser ME, . 1987. Sperm count suppression without endocrine dysfunction in lead-exposed men. Arch Environ Health 42:124–127.3579367
Astrin KH, Bishop DF, Wetmur JG, . 1987. delta-Aminolevulinic acid dehydratase isozymes and lead toxicity. Ann N Y Acad Sci 514:23–39.3442386
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 1995. Multisite lead and cadmium exposure study with biological markers incorporated. Atlanta, GA: Agency for Toxic Substances and Disease Registry, U.S. Department of Health and Human Services.
ATSDR. 2004a. Interaction profile for arsenic, cadmium, chromium, and lead. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/interactionprofiles/ip04.html. July 3, 2017.
ATSDR. 2004b. Interaction profile for lead, manganese, zinc, and copper. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/interactionprofiles/ip06.html. July 3, 2017.
ATSDR. 2006. Interaction profile for chlorpyrifos, lead, mercury, and methylmercury. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/interactionprofiles/IP-11/ip11.pdf. July 3, 2017.
ATSDR. 2007. Toxicological profile for lead. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/toxprofiles/tp13.pdf. June 20, 2017.
ATSDR. 2017. Case studies in environmental medicine (CSEM). Lead toxicity. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/csem/lead/docs/csem-lead_toxicity_508.pdf. August 30, 2018.
ATSDR. 2019. Lead. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry.
Aucott M, Caldarelli A. 2012. Quantity of lead released to the environment in New Jersey in the form of motor vehicle wheel weights. Water Air Soil Pollut 223(4):1743–1752. 10.1007/s11270-011-0979-2.
Aufderheide AC, Wittmers LE. 1992. Selected aspects of the spatial distribution of lead in bone. Neurotoxicology 13:809–820.1302307
Aungst BJ, Fung HL. 1981. Kinetic characterization of in vitro lead transport across the rat small intestine. Toxicol Appl Pharmacol 61:39–47.7292501
Aungst BJ, Dolce JA, Fung HL. 1981. The effect of dose on the disposition of lead in rats after intravenous and oral administration. Toxicol Appl Pharmacol 61:48–57.7292502
Avula B, Wang YH, Smillie TJ, . 2010. Quantitative determination of multiple elements in botanicals and dietary supplements using ICP-MS. J Agric Food Chem 58:8887–8894.20681579
Awad el Karim MA, Hamed AS, Elhaimi YA, . 1986. Effects of exposure to lead among lead-acid battery factory workers in Sudan. Arch Environ Health 41(4):261–265. 10.1080/00039896.1986.9938342.3767435
Azar A, Trochimowicz HJ, Maxfield ME. 1973. Review of lead studies in animals carried out at Haskell Laboratory: Two year feeding study and response to hemorrhage study In: Barth D, Berlin A, Engel R, ., eds. Environmental health aspects of lead: Proceedings of an international symposium. Vol. 5004. Luxembourg: Commission of the European Communities, 199–210.
Baertlein L, Yendell S. 2017. Selection bias in estimates of elevated blood lead levels in children. J Pediatr 181:330. 10.1016/j.jpeds.2016.09.044.
Baeyens W, Vrjens J, Gao Y, . 2014. Trace metals in blood and urine of newborn/mother pairs, adolescents and adults of the Flemish population (2007-2011). Int J Hyg Environ Health 217(8):878–890.25041848
Bagci C, Bozkurt A, Cakmak E, . 2004. Blood lead levels of the battery and exhaust workers and their pulmonary function tests. Int J Clin Pract 58(6):568–572.15311556
Baghurst PA, Robertson EF, McMichael AJ, . 1987. The Port Pirie cohort study: Lead effects on pregnancy outcome and early childhood development. Neurotoxicology 8(3):395–402.2443882
Baghurst PA, McMichael AJ, Wigg NR, . 1992. Environmental exposure to lead and children’s intelligence at the age of seven years. N Engl J Med 327(18):1279–1284.1383818
Baghurst PA, McMichael AJ, Tong S, . 1995. Exposure to environmental lead and visual-motor integration at age 7 years: The Port Pirie cohort study. Epidemiology 6(2):104–109.7742393
Bailey MR, Roy M. 1994. Clearance of particles from the respiratory tract. In: Human respiratory tract model for radiological protection: A report of a task group of the International Commission on Radiological Protection. Oxford, UK: Pergamon Press, 301–413.
Baker EL, Landrigan PJ, Barbour AG, . 1979. Occupational lead poisoning in the United States: Clinical and biochemical findings related to blood lead levels. Br J Ind Med 36:314–322.508643
Baker EL, Feldman RG, White RF, . 1983. The role of occupational lead exposure in the genesis of psychiatric and behavioral disturbances. Acta Psychiatr Scand Suppl 303:38–48.6613618
Bakulski KM, Rozek LS, Dolinoy DC, . 2012. Alzheimer’s disease and environmental exposure to lead: The epidemiologic evidence and potential role of epigenetics. Curr Alzheimer Res 9(5):563–573.22272628
Balo J, Attila B, Bela S. 1965. [Experimental adenomas of the kidney produced by chronic administration of lead phosphate]. Magy Onkol 9:141–151. (Hungarian)
Bandeen-Roche K, Glass TA, Bolla KI, . 2009. Cumulative lead dose and cognitive function in older adults. Epidemiology 20(6):831–839. 10.1097/EDE.0b013e3181b5f100.19752734
Bannon DI, Williams MA. 2017. Matching target dose to target organ. F1000 Research 5:2785. https://f1000research.com/articles/5-2785/v2. February 18, 2020.
Bannon DI, Olivi L, Bressler J. 2000. The role of anion exchange in the uptake of Pb by human erythrocytes and Madin-Darby canine kidney cells. Toxicology 147:101–107.10874157
Bannon DI, Portnoy ME, Olivi L, . 2002. Uptake of lead and iron by divalent metal transporter 1 in yeast and mammalian cells. Biochem Biophys Res Commun 295(4):978–984.12127992
Bannon DI, Abounader R, Lees PS, . 2003. Effect of DMT1 knockdown on iron, cadmium, and lead uptake in Caco-2 cells. Am J Physiol Cell Physiol 284(1):C44–50. 10.1152/ajpcell.00184.2002.12388109
Bannon DI, Drexler JW, Fent GM, . 2009. Evaluation of small arms range soils for metal contamination and lead bioavailability. Environ Sci Technol 43(24):9071–9076. 10.1021/es901834h.20000496
Bao QS, Lu CY, Song H, . 2009. Behavioural development of school-aged children who live around a multi-metal sulphide mine in Guangdong province, China: A cross-sectional study. BMC Public Health 9(1):217. 10.1186/1471-2458-9-217.19573251
Baranowska-Bosiacka I, Kosinska I, Jamiol D, . 2016. Environmental lead (Pb) exposure versus fatty acid content in blood and milk of the mother and in the blood of newborn children. Biol Trace Elem Res 170:279–287. 10.1007/s12011-015-0482-5.26315304
Barbosa F, Tanus-Santos JE, Gerlach RQ, . 2005. A critical review of biomarkers used for monitoring human exposure to lead: Advantages, limitations, and future needs. Environ Health Perspect 113(12):1669–1674.16330345
Barbosa F, Ramires I, Rodrigues MHC, . 2006a. Contrasting effects of age on the plasma/whole blood lead ratio in men and women with a history of lead exposure. Environ Res 102(1):90–95. 10.1016/j.envres.2006.03.007.16678152
Barbosa F, Sandrim VC, Uzuelli JA, . 2006b. eNOS genotype-dependent correlation between whole blood lead and plasma nitric oxide products concentrations. Nitric Oxide 14(1):58–64. 10.1016/j.niox.2005.09.007.16271308
Barbosa F, Correa Rodrigues MH, Buzalaf MR, . 2006c. Evaluation of the use of salivary lead levels as a surrogate of blood lead or plasma lead levels in lead exposed subjects. Arch Toxicol 80(10):633–637. 10.1007/s00204-006-0096-y.16614825
Barltrop D, Meek F. 1979. Effect of particle size on lead absorption from the gut. Arch Environ Health 34(4):280–285. 10.1080/00039896.1979.10667414.475473
Barman T, Kalahasthi R, Rajmohan HR. 2014. Effects of lead exposure on the status of platelet indices in workers involved in a lead-acid battery manufacturing plant. J Expo Sci Environ Epidemiol 24(6):629–633. 10.1038/jes.2014.4.24849799
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barregård L, Svalander C, Schütz A, . 1999. Cadmium, mercury, and lead in kidney cortex of the general Swedish population: A study of biopsies from living kidney donors. Environ Health Perspect 107(11):867–871.10544153
Barry PSI. 1975. A comparison of concentrations of lead in human tissues. Br J Ind Med 32:119–139.1131339
Barry PSI. 1981. Concentrations of lead in the tissues of children. Br J Ind Med 38:61–71.7193476
Barry V, Steenland K. 2019. Lead exposure and mortality among U.S. workers in a surveillance program: Results from 10 additional years of follow-up. Environ Res 177:108625. 10.1016/j.envres.2019.108625.31401374
Barry V, Todd AC, Steenland K. 2019. Bone lead associations with blood lead, kidney function and blood pressure among US, lead-exposed workers in a surveillance programme. Occup Environ Med 76(5):349–354. 10.1136/oemed-2018-105505.30661026
Barth A, Schaffer AW, Osterode W, . 2002. Reduced cognitive abilities in lead-exposed men. Int Arch Occup Environ Health 75:394–398.12070635
Barton JC. 1984. Active transport of lead-210 by everted segments of rat duodenum. Am J Physiol 247:G193–G198.6465315
Barton JC, Conrad ME, Harrison L, . 1978a. Effects of calcium on the absorption and retention of lead. J Lab Clin Med 91(3):366–376.24077
Barton JC, Conrad ME, Nuby S, . 1978b. Effects of iron on the absorption and retention of lead. J Lab Clin Med 92(4):536–547.712193
Barton JC, Patton MA, Edwards CQ, . 1994. Blood lead concentrations in hereditary hemochromatosis. J Lab Clin Med 124(2):193–198.8051482
Basaran N, Undeger U. 2000. Effects of lead on immune parameters in occupationally exposed workers. Am J Ind Med 38:349–354.10940975
Battistuzzi G, Petrucci R, Silvagni L, . 1981. δ-Aminolevulinate dehydrase: A new genetic polymorphism in man. Ann Hum Genet 45(3):223–229.7305279
Bauchinger M, Dresp J, Schmid E, . 1977. Chromosome analyses of children after ecological lead exposure. Mutat Res 56:75–80.593297
BCI. 2019. National recycling rate study. Battery Council International.
Beck BD, Mattuck RL, Bowers TS, . 2001. The development of a stochastic physiologically-based pharmacokinetic model for lead. Sci Total Environ 274:15–19.11453291
Beckley AL, Caspi A, Broadbent J, . 2018. Association of childhood blood lead levels with criminal offending. JAMA Pediatrics 172(2):166–173. 10.1001/jamapediatrics.2017.4005.29279896
Beers MH, Berkow R, eds. 1999. Injuries, poisoning, and cardiopulmonary resuscitation. In: The Merck manual of diagnosis and therapy Whitehouse Station, NJ: Merck Research Laboratories, 2254–2300.
Behinaein S, Chettle DR, Atanackovic J, . 2011. In vivo measurement of lead in the bones of smelter workers using the four-element ‘clover-leaf’ geometry detector system. Phys Med Biol 56(3):653–665. 10.1088/0031-9155/56/3/008.21220841
Behinaein S, Chettle DR, Egden LM, . 2012. Nonlinearity in the relationship between bone lead concentrations and CBLI for lead smelter employees. J Environ Monit 14(12):3267–3275. 10.1039/c2em30652b.23152131
Behinaein S, Chettle DR, Egden LM, . 2014. The estimation of the rates of lead exchange between body compartments of smelter employees. Environ Sci Process Impacts 16(7):1705–1715. 10.1039/c4em00032c.24810478
Bellinger DC. 2004. Assessing environmental neurotoxicant exposures and child neurobehavior: Confounded by confounding? Epidemiology 15(4):383–384.15232396
Bellinger DC. 2011. The protean toxicities of lead: New chapters in a familiar story. Int J Environ Res Public Health 8(7):2593–2628. 10.3390/ijerph8072593.21845148
Bellinger D, Needleman HL. 2003. Intellectual impairment and blood lead levels. N Engl J Med 349(5):500. 10.1056/NEJM200307313490515.
Bellinger D, Leviton A, Sloman J. 1990. Antecedents and correlates of improved cognitive performance of children exposed in utero to low levels of lead. Environ Health Perspect 89:5–11.2088755
Bellinger DC, Stiles KM, Needleman HL. 1992. Low-level lead exposure, intelligence and academic achievement: A long-term follow-up study. Pediatrics 90(6):855–861.1437425
Bellinger DC, Leviton A, Waternaux C, . 1987. Longitudinal analyses of prenatal and postnatal lead exposure and early cognitive development. N Engl J Med 316:1037–1043.3561456
Bellinger D, Sloman J, Leviton A, . 1991. Low-level lead exposure and children’s cognitive function in the preschool years. Pediatrics 87(2):219–227.1987535
Bellinger D, Hu H, Titlebaum L, . 1994. Attentional correlates of dentin and bone lead levels in adolescents. Arch Environ Health 49(2):98–105. 10.1080/00039896.1994.9937461.8161248
Bener A, Almehdi AM, Alwash R, . 2001. A pilot survey of blood lead levels in various types of workers in the United Arab Emirates. Environ Int 27(4):311–314. 10.1016/S0160-4120(01)00061-7.11686641
Bergdahl IA, Skerfving S. 1997. Partition of circulating lead between plasma and red cells does not seem to be different for internal and external sources of lead. Letter to the editor. Am J Ind Med 32:317–318.9219665
Bergdahl IA, Schutz A, Grubb A. 1996. Application of liquid chromatography-inductively coupled plasma mass spectrometry to the study of protein-bond lead in human erythrocytes. J Anal Atom Spectrom 11:735–738.
Bergdahl IA, Grubb A, Schütz A, . 1997a. Lead binding to δ-aminolevulinic acid dehydratase (ALAD) in human erythrocytes. Basic Clin Pharmacol Toxicol 81(4):153–158.
Bergdahl IA, Gerhardsson L, Schütz A, . 1997b. delta-Aminolevulinic acid dehydratase polymorphism: Influence on lead levels and kidney function in humans. Arch Environ Health 52(2):91–96.9124881
Bergdahl IA, Schutz A, Gerhardsson L, . 1997c. Lead concentrations in human plasma, urine and whole blood. Scand J Work Environ Health 23(5):359–363.9403466
Bergdahl IA, Sheveleva M, Schutz A, . 1998. Plasma and blood lead in humans: Capacity-limited binding to delta-aminolevulinic acid dehydratase and other lead-binding components. Toxicol Sci 46:247–253.10048127
Bergdahl IA, Vahter M, Counter SA, . 1999. Lead in plasma and whole blood from lead-exposed children. Environ Res 80:25–33. 10.1006/enrs.1998.3880.9931224
Bergdahl IA, Gerhardsson L, Liljelind IE, . 2006. Plasma-lead concentration: Investigations into its usefulness for biological monitoring of occupational lead exposure. Am J Ind Med 49(2):93–101.16419091
Bergeret A, Pouget E, Tedone R, . 1990. Neutrophil functions in lead-exposed workers. Hum Exp Toxicol 9(4):231–233. 10.1177/096032719000900405.2390320
Berkowitz GS, Wolff MS, Lapinski RH, . 2004. Prospective study of blood and tibia lead in women undergoing surgical menopause. Environ Health Perspect 112(17):1673–1678.15579412
Bernard BP, Becker CE. 1988. Environmental lead exposure and the kidney. Clin Toxicol 26(1&2):1–34.
Bernard AM, Vyskocil A, Roels H, . 1995. Renal effects in children living in the vicinity of a lead smelter. Environ Res 68:91–95.7601077
Bert JL, Van DLJ, Grace JR. 1989. A generalized model for the prediction of lead body burdens. Environ Res 48:117–127.2914562
Bertazzi PA, Zocchetti C. 1980. A mortality study of newspaper printing workers. Am J Ind Med 1:85–97.7342757
Berthelot Y, Valton E, Auroy A, . 2008. Integration of toxicological and chemical tools to assess the bioavailability of metals and energetic compounds in contaminated soils. Chemosphere 74:166–177.18829064
Bhattacharya A, Shukla R, Dietrich KN, . 2006. Effect of early lead exposure on the maturation of children’s postural balance: A longitudinal study. Neurotoxicol Teratol 28(3):376–385. 10.1016/j.ntt.2006.02.003.16624520
Bhatti P, Stewart PA, Hutchinson A, . 2009. Lead exposure, polymorphisms in genes related to oxidative stress, and risk of adult brain tumors. Cancer Epidemiol Biomarkers Prev 18(6):1841–1848. 10.1158/1055-9965.EPI-09-0197.19505917
Biagini G, Caudarella R, Vangelista A. 1977. Renal morphological and functional modification in chronic lead poisoning. In: Brown SS, ed. Clinical chemistry and chemical toxicology of metals. Elsevier/North-Holland Biomedical Press, 123–126.
Biggins PDE, Harrison RM. 1979. Atmospheric chemistry of automotive lead. Environ Sci Technol 13:558–565.
Billick IH, Gray VE. 1978. Executive summary. In: Lead based paint poisoning research: Review and evaluation, 1971-1977. U.S. Deptartment of Housing and Urban Development, vi–vii.
Bindler R, Renberg I, Klaminder J. 2008. Bridging the gap between ancient metal pollution and contemporary biogeochemistry. J Paleolimnol 40(3):755–770.
Blackowicz MJ, Hryhorczuk DO, Rankin KM, . 2016. The impact of low-level lead toxicity on school performance among Hispanic subgroups in the Chicago public schools. Int J Environ Res Public Health 13(8):774. 10.3390/ijerph13080774.27490560
Blake K, Mann M. 1983. Effect of calcium and phosphorus on the gastrointestinal absorption of 203Pb in man. Environ Res 30(1):188–194.6687570
Blake KC, Barbezat H, Mann M. 1983. Effect of dietary constituents on the gastrointestinal absorption of 203Pb in man. Environ Res 30:182–187.
Bloom MS, Parsons PJ, Steuerwald AJ, . 2010. Toxic trace metals and human oocytes during in vitro fertilization (IVF). Reprod Toxicol 29(3):298–305. 10.1016/j.reprotox.2010.01.003.20096775
Bloom MS, Louis GMB, Sundaram R, . 2011. Associations between blood metals and fecundity among women residing in New York State. Reprod Toxicol 31(2):158–163. 10.1016/j.reprotox.2010.09.013.20933593
Bloom MS, Buck Louis GM, Sundaram R, . 2015. Birth outcomes and background exposures to select elements, the Longitudinal Investigation of Fertility and the Environment (LIFE). Environ Res 138:118–129. 10.1016/j.envres.2015.01.008.25707016
Bockelmann I, Pfister EA, McGauran N, . 2002. Assessing the suitability of cross-sectional and longitudinal cardiac rhythm tests with regard to identifying effects of occupational chronic lead exposure. J Occup Environ Med 44:59–65.11802467
Boileau J, Fauquignon C, Napoly C. 1987. Explosives. In: Ullmann’s encyclopedia of industrial chemistry. Vol. A10. Weinheim, Germany: VCH Verlag GmbH & Co., 143–172.
Boileau J, Fauguigson C, Hlueber B, . 2012. Explosives. In: Ullmann’s encyclopedia of industrial chemistry. Weinheim, Germany: Wiley-VCH Verlag GmbH & Co., 621–654. http://onlinelibrary.wiley.com/doi/10.1002/14356007.a10_143.pub2/pdf. March 30, 2017.
Bolanowska W, Piotrowski J, Garczynski H. 1967. Triethyl lead in the biological material in cases of acute tetraethyl lead poisoning. Arch Toxikol 22:278–282.4967511
Bonanno LJ, Freeman NCG, Greenburg M, . 2001. Multivariate analysis on levels of selected metals, particulate matter, VOC, and household characteristics and activities from the midwestern states NHEXAS. Appl Occup Environ Hyg 16(9):859–874.
Bonde JP, Joffe M, Apostoli P, . 2002. Sperm count and chromatin structure in men exposed to inorganic lead: Lowest adverse effect levels. Occup Environ Med 59(4):234–242.11934950
Bonithon-Kopp C, Huel G, Grasmick C, . 1986. Effects of pregnancy on the inter-individual variations in blood levels of lead, cadmium and mercury. Biol Res Pregnancy Perinatol 7(1):37–42.3955127
Borja-Aburto VH, Hertz-Picciotto I, Lopez MR, . 1999. Blood lead levels measured prospectively and risk of spontaneous abortion. Am J Epidemiol 150:590–597.10489998
Borjesson J, Gerhardsson L, Schutz A, . 1997. In vivo measurements of lead in fingerbone in active and retired lead smelters. Int Arch Occup Environ Health 69:97–105.9001915
Bornschein RL, Succop PA, Krafft KM, . 1986. Exterior surface dust lead, interior house dust lead and childhood lead exposure in an urban environment. Trace Subst Environ Health 20:322–332.
Bornschein RL, Grote J, Mitchell T, . 1989. Effects of prenatal lead exposure on infant size at birth. In: Smith MA, Grant LD, Sors AI, eds. Lead exposure and child development. Dordrecht: Springer, 307–319. 10.1007/978-94-009-0847-5_18.
Bos AJJ, van der Stap CCAH, Valkovic V, . 1985. Incorporation routes of elements into human hair: Implications for hair analysis used for monitoring. Sci Total Environ 42:157–169.4012277
Boscolo P, Di Gioacchino M, Sabbioni E, . 1999. Expression of lymphocyte subpopulations, cytokine serum levels, and blood and urinary trace elements in asymptomatic atopic men exposed to an urban environment. Int Arch Occup Environ Health 72(1):26–32. 10.1007/s004200050330.10029227
Boscolo P, Di Gioacchino M, Sabbioni E, . 2000. Lymphocyte subpopulations, cytokines and trace elements in asymptomatic atopic women exposed to an urban environment. Life Sci 67(10):1119–1126. 10.1016/S0024-3205(00)00712-8.10954046
Bost L, Primatesta P, Dong W, . 1999. Blood lead and blood pressure: Evidence from the health survey for England 1995. J Hum Hypertens 13(2; 2):123–128.10100061
Bouchard MF, Bellinger DC, Weuve J, . 2009. Blood lead levels and major depressive disorder, panic disorder, and generalized anxiety disorder in US young adults. Arch Gen Psychiatry 66(12):1313–1319. 10.1001/archgenpsychiatry.2009.164.19996036
Boucher O, Jacobson SW, Plusquellec P, . 2012. Prenatal methylmercury, postnatal lead exposure, and evidence of attention deficit/hyperactivity disorder among Inuit children in Arctic Quebec. Environ Health Perspect 120(10):1456–1461. 10.1289/ehp.1204976.23008274
Boucher O, Muckle G, Jacobson JL, . 2014. Domain-specific effects of prenatal exposure to PCBs, mercury, and lead on infant cognition: Results from the Environmental Contaminants and Child Development Study in Nunavik. Environ Health Perspect 122(3):310–316. 10.1289/ehp.1206323.24441767
Boudene C, Malet D, Masse R. 1977. Fate of Pb inhaled by rats. Toxicol Appl Pharmacol 41:271–276.898197
Boudene C, Despaux-Pages N, Comoy E, . 1984. Immunological and enzymatic studies of erythrocytic δ-aminolevulinate dehydratase. Int Arch Occup Environ Health 55(1):87–96.6526504
Bound JP, Harvey PW, Francis BJ, . 1997. Involvement of deprivation and environmental lead in neural tube defects: A matched case-control study. Arch Dis Child 76(2):107–112.9068297
Bouton C, Pevsner J. 2000. Effects of lead on gene expression. Neurotoxicology 21(6):1045–1056.11233751
Bowen HJM. 1966. Trace elements in biochemistry. New York, NY: Academic Press. 31–32.
Bowers TS, Mattuck RL. 2001. Further comparisons of empirical and epidemiological data with predictions of the Integrated Exposure Uptake Biokinetic Model for lead in children. Hum Ecol Risk Assess 7:1699–1713.
Bowers TS, Beck BD. 2006. What is the meaning of non-linear dose-response relationships between blood lead concentrations and IQ? Neurotoxicology 27(4):520–524. 10.1016/j.neuro.2006.02.001. http://www.ncbi.nlm.nih.gov/pubmed/16551479.16551479
Bowers TS, Beck BD, Karam HS. 1994. Assessing the relationship between environmental lead concentrations and adult blood lead levels. Risk Anal 14(2):183–189.8008927
Bradham KD, Green W, Hayes H, . 2016. Estimating relative bioavailability of soil lead in the mouse. J Toxicol Environ Health A 79(24):1179–1182. 10.1080/15287394.2016.1221789.27767405
Bradham KD, Nelson CM, Diamond GL, . 2019. Dietary lead and phosphate interactions affect oral bioavailability of soil lead in the mouse. Environ Sci Technol 53(21):12556–12564. 10.1021/acs.est.9b02803.31557437
Bradley SB, Cox JJ. 1988. The potential availability of cadmium, copper, iron, lead, manganese, nickel and zinc in standard river sediment (NBS 1645). Environ Technol Lett 9:733–739.
Braun JM, Kahn RS, Froehlich T, . 2006. Exposures to environmental toxicants and attention deficit hyperactivity disorder in U.S. children. Environ Health Perspect 114(12):1904–1909. 10.1289/ehp.9478.17185283
Braun JM, Froehlich TE, Daniels JL, . 2008. Association of environmental toxicants and conduct disorder in U.S. children: NHANES 2001-2004. Environ Health Perspect 116(7):956–962. 10.1289/ehp.11177.18629321
Braun JM, Hoffman E, Schwartz J, . 2012. Assessing windows of susceptibility to lead-induced cognitive deficits in Mexican children. Neurotoxicology 33(5):1040–1047. 10.1016/j.neuro.2012.04.022.22579785
Braun JM, Wright RJ, Just AC, . 2014. Relationships between lead biomarkers and diurnal salivary cortisol indices in pregnant women from Mexico City: A cross-sectional study. Environ Health 13(1):50. 10.1186/1476-069x-13-50.24916609
Braunstein GD, Dahlgren J, Loriaux DL. 1978. Hypogonadism in chronically lead-poisoned men. Infertility 1(1):33–51.12265605
Brender JD, Suarez L, Felkner M, . 2006. Maternal exposure to arsenic, cadmium, lead, and mercury and neural tube defects in offspring. Environ Res 101(1):132–139. 10.1016/j.envres.2005.08.003.16171797
Bres EF, Voegel JC, Barry JC, . 1986. Feasibility study for the detection of lead substitution sites in the hydroxyapatite crystal structure using high resolution electron microscopy (HREM) at optimum focus. J Appl Cryst 19:168–173.
Bress WC, Bidanset JH. 1991. Percutaneous in vivo and in vitro absorption of lead. Vet Hum Toxicol 33(3):212–214.1858297
Bressler J, Kim K, Chakraborti T, . 1999. Molecular mechanisms of lead neurotoxicity. Neurochem Res 24(4):595–600.10227691
Bressler JP, Olivi L, Kim Y, . 2005. Plasma membrane transporters for lead and cadmium. J Appl Pharmacol 13(1):1–6.
Brito JAA, McNeill FE, Webber CE, . 2005. Grid search: An innovative method for the estimation of the rates of lead exchange between body compartments. J Environ Monit 7(3):241–247.15735782
Broberg K, Engstrom K, Ameer S. 2015. Gene-environment interactions for metals. In: Nordberg GF, Fowler BA, Nordberg M, eds. Handbook on the toxicology of metals. 4th ed. Elsevier, 239–264. 10.1016/B978-0-444-59453-2.00012-3.
Brodeur J, Lacasse Y, Talbot D. 1983. Influence of removal from occupational lead exposure on blood and saliva lead concentrations. Toxicol Lett 19(1–2):195–199.6658825
Brody DJ, Pirkle JL, Kramer RA, . 1994. Blood lead levels in the US population: Phase I of the third National Health and Nutrition Examination Survey (NHANES III, 1968-1991). J Am Med Assoc 272(4):277–283.
Bronner F, Pansu D, Stein WD. 1986. An analysis of intestinal calcium transport across the rat intestine. Am J Physiol 250(13):G561–G569.2939728
Brown S, Chaney RL, Hallfrisch J, . 2004. In situ soil treatments to reduce the phyto- and bioavailability of lead, zinc and cadmium. J Environ Qual 33:522–531.15074803
Brown RW, Gonzales C, Hooper MJ, . 2008. Soil lead (Pb) in residential transects through Lubbock, Texas: A preliminary assessment. Environ Geochem Health 30(6):541–547. 10.1007/s10653-008-9180-y.18546057
Brubaker CJ, Dietrich KN, Lanphear BP, . 2010. The influence of age of lead exposure on adult gray matter volume. Neurotoxicology 31(3):259–266. 10.1016/j.neuro.2010.03.004.20226811
Brunekreef B. 1984. The relationship between air lead and blood lead in children: A critical review. Sci Total Environ 38:79–123.6395339
Buc H, Kaplan J. 1978. Red-cell pyrimidine 5′-nucleotidase and lead poisoning. Clin Chim Acta 87(1):49–55.668145
Buchet JP, Roels H, Bernard A, . 1980. Assessment of renal function of workers exposed to inorganic lead, cadmium or mercury vapor. J Occup Environ Med 22(11):741–750.
Budtz-Jorgensen E, Bellinger D, Lanphear B, . 2013. An international pooled analysis for obtaining a benchmark dose for environmental lead exposure in children. Risk Anal 33(3):450–461. 10.1111/j.1539-6924.2012.01882.x.22924487
Bulsma JB, de France HF. 1976. Cytogenetic investigations in volunteers ingesting inorganic lead. Int Arch Occup Environ Health 38:145–148.1002307
Burns JS, Williams PL, Lee ML, . 2017. Peripubertal blood lead levels and growth among Russian boys. Environ Int 106:53–59. 10.1016/j.envint.2017.05.023.28599171
Buser MC, Scinicariello F. 2017. Cadmium, lead, and depressive symptoms: Analysis of National Health and Nutrition Examination Survey 2011-2012. J Clin Psychiatry 78(5):e515–e521. 10.4088/JCP.15m10383.27929609
Bushnik T, Levallois P, D’Amour M, . 2014. Association between blood lead and blood pressure: Results from the Canadian Health Measures Survey (2007 to 2011). Health Rep 25(7):12–22.
Businelli D, Onofri A, Massaccesi L. 2011. Factors involved in uptake of lead by some edible crops grown in agricultural soils of Central Italy. Soil Sci 176(9):472–478.
Butterweck G, Schuler C, Vezzù G, . 2002. Experimental determination of the absorption rate of unattached radon progeny from respiratory tract to blood. Radiat Prot Dosimetry 102(4):343–348.12474944
Cabral M, Dieme D, Verdin A, . 2012. Low-level environmental exposure to lead and renal adverse effects: A cross-sectional study in the population of children bordering the Mbeubeuss landfill near Dakar, Senegal. Hum Exp Toxicol 31(12):1280–1291. 10.1177/0960327112446815.22837546
Cake K, Bowins R, Vaillancourt C, . 1996. Partition of circulating lead between serum and red cells is different for internal and external sources of lead. Am J Ind Med 29(5):440–445.8732917
Cal EPA. 2013. Estimating workplace air and worker blood lead concentration using an updated physiologically-based pharmacokinetic (PBPB) model. California Environmental Protection Agency. https://oehha.ca.gov/media/downloads/air/document/pbpk2013.pdf. April 03, 2014.
Cal EPA. 2017. User’s guide to LeadSpread 8 and recommendations for evaluation of lead exposures in adults. California Environmental Protection Agency. http://www.dtsc.ca.gov/AssessingRisk/upload/LeadSpread8_UserGuide.pdf. September 1, 2017.
Calabrese EJ, Stanek EJ, Gilbert CE, . 1990. Preliminary adult soil ingestion estimates: Results of a pilot study. Regul Toxicol Pharmacol 12(1):88–95.2217921
Calderon-Salinas JV, Quintanar-Escorcia MA, Gonzalez-Martinez MT, . 1999. Lead and calcium transport in human erythrocyte. Hum Exp Toxicol 18:327–332.10372755
Calello DP, Henretig FM. 2014. Lead. In: Goldfrank’s toxicologic emergencies. Tenth ed. New York, NY: McGraw-Hill, 1219–1234.
Campara P, D’Andrea F, Micciolo R, . 1984. Psychological performance of workers with blood-lead concentration below the current threshold limit value. Int Arch Occup Environ Health 53:233–246.6706419
Campbell JR, Toribara TY. 2001. Hair-root lead to screen for lead toxicity. J Trace Elem Exp Med 14:69–72.
Campbell JR, Auinger P. 2007. The association between blood lead levels and osteoporosis among adults - Results from the third National Health and Nutrition Examination Survey (NHANES III). Environ Health Perspect 115(7):1018–1022. 10.1289/ehp.9716.17637916
Campbell JR, Moss ME, Raubertas RF. 2000a. The association between caries and childhood lead exposure. Environ Health Perspect 108(11):1099–1102.11102303
Campbell TF, Needleman HL, Riess JA, . 2000b. Bone lead levels and language processing performance. Dev Neuropsychol 18(2):171–186.11280963
Campbell JR, Rosier RN, Novotny L, . 2004. The association between environmental lead exposure and bone density in children. Environ Health Perspect 112:1200–1203.15289167
Can S, Bagci C, Ozaslan M, . 2008. Occupational lead exposure effect on liver functions and biochemical parameters. Acta Physiol Hung 95(4):395–403. 10.1556/APhysiol.95.2008.4.6.19009914
Canfield RL, Henderson CR, Cory-Slechta DA, . 2003. Intellectual impairment in children with blood lead concentrations below 10 micrograms per deciliter. N Engl J Med 348(16):1517–1526. 10.1056/NEJMoa022848.12700371
Canonne-Hergaux F, Gruenheid S, Ponka P, . 1999. Cellular and subcellular localization of the nramp2 iron transporter in the intestinal brush border and regulation by dietary iron. Blood 93(12):4406–4417.10361139
Cantonwine D, Hu H, Tellez-Rojo MM, . 2010. HFE gene variants modify the association between maternal lead burden and infant birthweight: A prospective birth cohort study in Mexico City, Mexico. Environmental Health: A Global Access Science Source 9:43. 10.1186/1476-069X-9-43.20659343
Cao X, Ma LQ, Chen M, . 2003a. Lead transformation and distribution in the soils of shooting ranges in Florida, USA. Sci Total Environ 307:179–189.12711433
Cao X, Ma LQ, Chen M, . 2003b. Weathering of lead bullets and their environmental effects at outdoor shooting ranges. J Environ Qual 32:526–534.12708676
Carbone R, Laforgia N, Crollo E, . 1998. Maternal and neonatal lead exposure in southern Italy. Biol Neonate 73:362–366.9618053
Cardenas A, Roels H, Bernard A, . 1993. Markers of early renal changes induced by industrial pollutants. II. Application to workers exposed to lead. Br J Ind Med 50(1):28–36.8431388
Cardozo dos Santos A, Colacciopo S, Dal Bó CM, . 1994. Occupational exposure to lead, kidney function tests, and blood pressure. Am J Ind Med 26(5):635–643.7832211
Carlisle JC, Wade MJ. 1992. Predicting blood lead concentrations from environmental concentrations. Regul Toxicol Pharmacol 16(3):280–289.1293645
Carr DS. 1995. Lead compounds: Lead salts. In: Kirk-Othmer encyclopedia of chemical technology. 4th edition ed. New York: John Wiley & Sons, 132–152.
Carr DS, Spangenberg WC, Chronley K, . 2004. Lead compounds. In: Kirk-Othmer encyclopedia of chemical technology. New York: John Wiley & Sons, 1–26.
Casjens S, Pesch B, van Thriel C, . 2018. Associations between blood lead, olfaction and fine-motor skills in elderly men: Results from the Heinz Nixdorf Recall Study. Neurotoxicology 68:66–72. 10.1016/j.neuro.2018.06.013.30009858
Cassidy-Bushrow AE, Havstad S, Basu N, . 2016. Detectable blood lead level and body size in early childhood. Biol Trace Elem Res 171(1):41–47. 10.1007/s12011-015-0500-7.26358768
Casteel SW, Cowart RP, Weis CP, . 1997. Bioavailability of lead to juvenile swine dosed with soil from the Smuggler Mountain NPL site of Aspen, Colorado. Toxicol Sci 36(2):177–187.
Casteel SW, Weis CP, Henningsen GM, . 2006. Estimation of relative bioavailability of lead in soil and soil-like materials using young swine. Environ Health Perspect 114(8):1162–1171.16882520
Cavalleri A, Minoia C, Pozzoli L, . 1978. Determination of plasma lead levels in normal subjects and lead-exposed workers. Br J Ind Med 35:21–26.629885
CDC. 1985. Preventing lead poisoning in young children. Atlanta, GA: Centers for Disease Control and Prevention. Publication No. 99-2230.
CDC. 1991. Preventing lead poisoning in young children. Atlanta, GA: Centers for Disease Control and Prevention.
CDC. 1997a. Children with elevated blood lead levels attributed to home renovation and remodeling activities – New York, 1993-1994. Centers for Disease Control and Prevention. MMWR Morb Mortal Wkly Rep 45:1120–1123. https://www.cdc.gov/mmwr/preview/mmwrhtml/00045033.htm. February 18, 2020.9005310
CDC. 1997b. Update: Blood lead levels – United States, 1991-1994. Centers for Disease Control and Prevention. MMWR Morb Mortal Wkly Rep 46(7):141–146. http://www.cdc.gov/epo/mmwr/preview/mmwrhtml/00048339.htm. February 18, 2020.9072671
CDC. 1998. Lead poisoning associated with imported candy and powdered food coloring – California and Michigan. Centers for Disease Control and Prevention. MMWR Morb Mortal Wkly Rep 47(48):1041–1043. http://www.cdc.gov/mmwr/preview/mmwrhtml/00055939.htm. February 18, 2020.9869075
CDC. 2002a. Managing elevated blood levels among young children. Recommendations from the Advisory Committee on Childhood Lead Poisoning. Centers for Disease Control and Prevention. http://www.cdc.gov/nceh/lead/casemanagement/managingEBLLs.pdf. July 18, 2018.
CDC. 2002b. Childhood lead poisoning associated with tamarind candy and fold remedies ---California, 1999-2000. Centers for Disease Control and Prevention. MMWR Morb Mortal Wkly Rep 51(31):684–686. https://www.cdc.gov/mmwr/preview/mmwrhtml/mm5131a3.htm. June 28, 2017.12233910
CDC. 2004b. Lead poisoning associated with ayurvedic medications - five states, 2000-2003. MMWR Morb Mortal Wkly Rep 53(26):582–584. https://www.cdc.gov/mmwr/preview/mmwrhtml/mm5326a3.htm.15241300
CDC. 2005. Lead poisoning associated with use of litargirio-Rhode Island, 2003. Centers for Disease Control and Prevention. MMWR Morb Mortal Wkly Rep 54(09):227–229. https://www.cdc.gov/mmwr/preview/mmwrhtml/mm5409a5.htm. June 28, 2017.15758896
CDC. 2009. Fourth national report on human exposure to environmental chemicals. Atlanta, GA: Centers for Disease Control and Prevention. http://www.cdc.gov/exposurereport. April 20, 2014.
CDC. 2011. State-based prevalence data of ADHD diagnosis. Atlanta, GA: Centers for Disease Control and Prevention. http://www.cdc.gov/ncbddd/adhd/prevalence.html. February 18, 2020.
CDC. 2012a. Infant lead poisoning associated with use of tiro, an eye cosmetic from Nigeria — Boston, Massachusetts, 2011. Centers for Disease Control and Prevention. MMWR Morb Mortal Wkly Rep 61(30):574–576. https://www.cdc.gov/mmwr/preview/mmwrhtml/mm6130a3.htm?s_cid=mm6130a3_w. June 29, 2017.22854626
CDC. 2012b. Lead in drinking water and human blood lead levels in the United States. Centers for Disease Control and Prevention. MMWR Morb Mortal Wkly Rep 61(Supplement: August 10, 2012):1–9. https://www.cdc.gov/mmwr/pdf/other/su6104.pdf. June 29, 2017.
CDC. 2012c. Lead poisoning in pregnant women who used Ayurvedic medications from India-New York City, 2011-2012. Centers for Disease Control and Prevention. MMWR Morb Mortal Wkly Rep 61(33):641–646. https://www.cdc.gov/mmwr/preview/mmwrhtml/mm6133a1.htm?s_cid=mm6133a1_w. June 28, 2017.22914225
CDC. 2012d. CDC response to Advisory Committee on Childhood Lead Poisoning Prevention. Recommendations in “Low level lead exposure harms children: A renewed call for primary prevention.”. Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/nceh/lead/acclpp/cdc_response_lead_exposure_recs.pdf. December 8, 2017.
CDC. 2012e. Low level lead exposure harms children: A renewed call for primary prevention. Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/nceh/lead/acclpp/final_document_030712.pdf. August 25, 2017.
CDC. 2012f. Recommended actions based on blood lead level. Centers for Disease Control and Prevention. https://www.cdc.gov/nceh/lead/advisory/acclpp/actions-blls.htm. June 16, 2020.
CDC. 2013. Childhood lead exposure associated with the use of kajal, an eye cosmetic from Afghanistan — Albuquerque, New Mexico, 2013. Centers for Disease Control and Prevention. MMWR Morb Mortal Wkly Rep 62(46):917–919. https://www.cdc.gov/mmwr/pdf/wk/mm6246.pdf. June 29, 2017.24257200
CDC. 2016. Standard surveillance definitions and classifications. Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/nceh/lead/data/case-definitions-classifications.htm. February 18, 2020.
CDC. 2018a. Fourth national report on human exposure to environmental chemicals. Updated tables, March 2018, Volumes 1 & 2. Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/. May 01, 2018.
CDC. 2018b. Lead. Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/nceh/lead/default.htm. February 5, 2019.
CDC. 2018c. Lead hazards in some holiday toys and toy jewelry. Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/features/leadintoys/index.html. March 08, 2018.
CDC. 2019. Fourth report on human exposure to environmental chemicals, updated tables (January 2019). Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/. January 23, 2020.
Cecil KM, Brubaker CJ, Adler CM, . 2008. Decreased brain volume in adults with childhood lead exposure. PLoS Med 5(5):e112. 10.1371/journal.pmed.0050112.18507499
Cecil KM, Dietrich KN, Altaye M, . 2011. Proton magnetic resonance spectroscopy in adults with childhood lead exposure. Environ Health Perspect 119(3):403–408. 10.1289/ehp.1002176.20947467
Chamberlain AC. 1983. Effect of airborne lead on blood lead. Atmos Environ 17:677–692.
Chamberlain AC, Heard MJ, Little P, . 1978. Investigations into lead from motor vehicles. Harwell: Atomic Energy Research Establishment. United Kingdom Atomic Energy Authority. International Lead Zinc Research Organization. AERE-R9198.
Chamberlain AC, Heard MJ, Little P, . 1979. The dispersion of lead from motor exhausts. Phil Trans R Soc London A 290:577–589.
Chandramouli K, Steer CD, Ellis M, . 2009. Effects of early childhood lead exposure on academic performance and behaviour of school age children. Arch Dis Child 94(11):844–848. 10.1136/adc.2008.149955.19770197
Chaney RL, Mielke HW, Sterrett SB. 1988. Speciation, mobility and bioavailability of soil lead. In: Davies BE, Wixson BG, eds. Lead in soil: Issues and guidelines. Northwood: Science Reviews Ltd., 105–130.
Chang SH, Cheng BH, Lee SL, . 2006. Low blood lead concentration in association with infertility in women. Environ Res 101(3):380–386. 10.1016/j.envres.2005.10.004.16360143
Chao K, Hutton H, Levin A. 2015. Laboratory assessment of kidney disease. Glomerular filtration rate, urinalysis and proteinuria. In: Shorecki K, Chertow GM, Mardsen PA, ., eds. Brenner and Rector’s the kidney. Elsevier, 780–803.
Charney E, Sayre J, Coulter M. 1980. Increased lead absorption in inner city children: Where does the lead come from? Pediatrics 65(2):226–231.7354967
Chen PC, Pan IJ, Wang JD. 2006. Parental exposure to lead and small for gestational age births. Am J Ind Med 49(6):417–422. 10.1002/ajim.20313.16586408
Chen A, Dietrich KN, Ware JH, . 2005. IQ and blood lead from 2 to 7 years of age: Are the effects in older children the residual of high blood lead concentrations in 2-year-olds? Environ Health Perspect 113(5):597–601. 10.1289/ehp.7625.15866769
Chen A, Cai B, Dietrich KN, . 2007. Lead exposure, IQ, and behavior in urban 5- to 7-year-olds: Does lead affect behavior only by lowering IQ? Pediatrics 119(3):e650–e658. 10.1542/peds.2006-1973.17332184
Chen HI, Chiu YW, Hsu YK, . 2010. The association of metallothionein-4 gene polymorphism and renal function in long-term lead-exposed workers. Biol Trace Elem Res 137:55–62.19921116
Chen CC, Yen HW, Lo YH, . 2013. The association of prolonged QT interval on electrocardiography and chronic lead exposure. J Occup Environ Med 55(6):614–619. 10.1097/JOM.0b013e318291787a.23722940
Chen Z, Myers R, Wei T, . 2014. Placental transfer and concentrations of cadmium, mercury, lead, and selenium in mothers, newborns, and young children. J Expo Sci Environ Epidemiol 24(5):537–544. 10.1038/jes.2014.26.24756102
Chen C, Wang N, Zhai H, . 2016. Associations of blood lead levels with reproductive hormone levels in men and postmenopausal women: Results from the SPECT-China Study. Sci Rep 6:37809. 10.1038/srep37809.27898110
Chen C, Li Q, Nie X, . 2017. Association of lead exposure with cardiovascular risk factors and diseases in Chinese adults. Environ Sci Pollut Res Int 24(28):22275–22283. 10.1007/s11356-017-9884-6.28799038
Chen Y, Xu X, Zeng Z, . 2019. Blood lead and cadmium levels associated with hematological and hepatic functions in patients from an e-waste-polluted area. Chemosphere 220:531–538. 10.1016/j.chemosphere.2018.12.129.30594806
Cheng Y, Schwartz J, Vokonas PS, . 1998. Electrocardiographic conduction disturbances in association with low-level lead exposure (the Normative Aging Study). Am J Cardiol 82:594–599.9732886
Cheng Y, Schwartz J, Sparrow D, . 2001. Bone lead and blood lead levels in relation to baseline blood pressure and the prospective development of hypertension: The Normative Aging Study. Am J Epidemiol 153(2):164–171. 10.1093/aje/153.2.164.11159162
Chettle DR, Scott MC, Somervaille LJ. 1991. Lead in bone: Sampling and quantitation using K X-rays excited by 109Cd. Environ Health Perspect 91:49–55.2040251
Chettle DR, Arnold ML, Aro ACA, . 2003. An agreed statement on calculating lead concentration and uncertainty in XRF in vivo bone lead analysis. Appl Radiat Isot 58:603–605.12735978
Cheung MR. 2013. Blood lead concentration correlates with all cause, all cancer and lung cancer mortality in adults: A population based study. Asian Pac J Cancer Prev 14(5):3105–3108. 10.7314/apjcp.2013.14.5.3105.23803087
Chia KS, Mutti A, Tan C, . 1994. Urinary N-acetyl-beta-D-glucosaminidase activity in workers exposed to inorganic lead. Occup Environ Med 51:125–129.8111460
Chia KS, Jeyaratnam J, Tan C, . 1995a. Glomerular function of lead-exposed workers. Toxicol Lett 77(1–3):319–328.7542405
Chia KS, Jeyaratnam J, Lee J, . 1995b. Lead-induced nephropathy: Relationship between various biological exposure indices and early markers of nephrotoxicity. Am J Ind Med 27(6):883–895.7544066
Chia SE, Chia HP, Ong CN, . 1996. Cumulative concentrations of blood lead and postural stability. Occup Environ Med 53:264–268.8664965
Chia SE, Zhou H, Tham MT, . 2005. Possible influence of “delta”-aminolevulinic acid dehydratase polymorphism and susceptibility to renal toxicity of lead: A study of a Vietnamese population. Environ Health Perspect 113(10):1313–1317. 10.1289/ehp.7904.16203232
Chiang WF, Yang HJ, Lung SC, . 2008. A comparison of elementary schoolchildren’s exposure to arsenic and lead. J Environ Sci Health C Environ Carcinog Ecotoxicol Rev 26(3):237–255. 10.1080/10590500802343958.18781537
Chien LC, Tsou MC, Hsi HC, . 2017. Soil ingestion rates for children under 3 years old in Taiwan. J Expo Sci Environ Epidemiol 27(1):33–40. 10.1038/jes.2015.61.26443469
Chinde S, Kumari M, Devi KR, . 2014. Assessment of genotoxic effects of lead in occupationally exposed workers. Environ Sci Pollut Res Int 21(19):11469–11480. 10.1007/s11356-014-3128-9.24906834
Chiodo LM, Jacobson SW, Jacobson JL. 2004. Neurodevelopmental effects of postnatal lead exposure at very low levels. Neurotoxicol Teratol 26(3):359–371. 10.1016/j.ntt.2004.01.010.15113598
Chisolm JJ. 1977. Lead poisoning. In: Rudolph AM, ed. Pediatrics. New York, NY: Prentice-Hall, Inc., 797–806.
Chisolm JJ. 1986. Editorial. Removal of lead paint from old housing: The need for a new approach. Am J Public Health 76(3):236–237.3946708
Chisolm JJ, Mellits ED, Barrett MB. 1976. Interrelationships among blood lead concentration, quantitative daily ALA-U and urinary lead output following calcium EDTA. In: Nordberg GF, ed. Effects and dose relationships of toxic metals. Amsterdam, The Netherlands: Elsevier Scientific Publishing Company, 416–433.
Chiu Y, Liu T, Chuang H. 2013. The effects of lead exposure on the activities of δ-aminolevulinic acid dehydratase with the modification of the relative genotypes. E3S Web Conf 1:26005. 10.1051/e3sconf/20130126005.
Cho SH, Richmond-Bryant J, Thornburg J, . 2011. A literature review of concentrations and size distributions of ambient airborne Pb-containing particulate matter. Atmos Environ 45(28):5005–5015. 10.1016/j.atmosenv.2011.05.009.
Choate LM, Ranville JF, Bunge AL, . 2006a. Dermally adhered soil: 1. Amount and particle-size distribution. Integr Environ Assess Manag 2(4):375–384.17069179
Choate LM, Ranville JF, Bunge AL, . 2006b. Dermally adhered soil: 2. Reconstruction of dry-sieve particle-size distributions from wet-sieve data. Integr Environ Assess Manag 2(4):385–390.17069180
Choi YH, Hu H, Mukherjee B, . 2012. Environmental cadmium and lead exposures and hearing loss in U.S. adults: The National Health and Nutrition Examination Survey, 1999 to 2004. Environ Health Perspect 120(11):1544–1550. 10.1289/ehp.1104863.22851306
Choi WJ, Kwon HJ, Lim MH, . 2016. Blood lead, parental marital status and the risk of attention-deficit/hyperactivity disorder in elementary school children: A longitudinal study. Psychiatry Res 236:42–46. 10.1016/j.psychres.2016.01.002.26774190
Choie DD, Richter GW. 1972. Lead poisoning: Rapid formation of intranuclear inclusions. Science 177:1194–1195.4341569
Chowdhury R, Sarnat SE, Darrow L, . 2014. Mortality among participants in a lead surveillance program. Environ Res 132:100–104. 10.1016/j.envres.2014.03.008.24769120
Chrastny V, Komarek M, Hajek T. 2010. Lead contamination of an agricultural soil in the vicinity of a shooting range. Environ Monit Assess 162:37–46. 10.1007/s10661-009-0774-3.19229644
Chu NF, Liou SH, Wu TN, . 1999. Reappraisal of the relation between blood lead concentration and blood pressure among the general population in Taiwan. Occup Environ Med 56:30–33.10341743
Chuan MC, Shu GY, Liu JC. 1996. Solubility of heavy metals in a contaminated soil: Effects of redox potential and pH. Water Air Soil Pollut 90:543–556.
Chuang HY, Schwartz J, Tsai SY, . 2000. Vibration perception thresholds in workers with long term exposure to lead. Occup Environ Med 57(9):588–594.10935939
Chuang HY, Kuo CH, Chiu YW, . 2007. A case-control study on the relationship of hearing function and blood concentrations of lead, manganese, arsenic, and selenium. Sci Total Environ 387(1–3):79–85. 10.1016/j.scitotenv.2007.07.032.17764724
Chung HK, Chang YS, Ahn CW. 2015. Effects of blood lead levels on airflow limitations in Korean adults: Findings from the 5th KNHNES 2011. Environ Res 136:274–279. 10.1016/j.envres.2014.10.027.25460646
Chwalba A, Maksym B, Dobrakowski M, . 2018. The effect of occupational chronic lead exposure on the complete blood count and the levels of selected hematopoietic cytokines. Toxicol Appl Pharmacol 355:174–179. 10.1016/j.taap.2018.05.034.29857081
Clark C, Bornschein R, Succop P, . 1985. Condition and type of housing as an indicator of potential environmental lead exposure and pediatric blood lead levels. Environ Res 38(1):46–53.4076111
Clark S, Menrath W, Chen M, . 2004. The influence of exterior dust and soil lead on interior dust lead levels in housing that had undergone lead-based paint hazard control. J Occup Environ Hyg 1(5):273–282. 10.1080/15459620490439036.15238335
Clausing P, Brunekreef B, van Wijnen JH. 1987. A method for estimating soil ingestion by children. Int Arch Occup Environ Health 59(1):73–82.3793247
Clayton CA, Pellizzari ED, Quackenboss JJ. 2002. National Human Exposure Assessment Survey: Analysis of exposure pathways and routes for arsenic and lead in EPA Region 5. J Expo Anal Environ Epidemiol 12:29–43.11859431
Clayton CA, Pellizzari ED, Whitmore RW, . 1999. National Human Exposure Assessment Survey (NHEXAS): Distributions and associations of lead, arsenic and volatile organic compounds in EPA region 5. J Expo Anal Environ Epidemiol 9(5):381–392.10554141
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Coate D, Fowles R. 1989. Is there statistical evidence for a blood lead-blood pressure relationship? J Health Econ 8:173–184.10294438
Cocco P, Dosemeci M, Heineman EF. 1998a. Brain cancer and occupational exposure to lead. J Occup Environ Med 40(11):937–942.9830598
Cocco P, Ward MH, Dosemeci M. 1998b. Occupational risk factors for cancer of the gastric cardia. J Occup Environ Med 40(10):855–861.9800169
Cocco P, Heineman EF, Dosemeci M. 1999a. Occupational risk factors for cancer of the central nervous system (CNS) among US women. Am J Ind Med 36:70–74.10361589
Cocco P, Ward MH, Dosemeci M. 1999b. Risk of stomach cancer associated with 12 workplace hazards: Analysis of death certificates from 24 states of the United States with the aid of job exposure matrices. Occup Environ Med 56:781–787.10658565
Cocco PL, Carta P, Belli S, . 1994. Mortality of Sardinian lead and zinc miners: 1960-1968. Occup Environ Med 51:674–682.8000492
Cocco P, Hua F, Boffetta P, . 1997. Mortality of Italian lead smelter workers. Scand J Work Environ Health 23:15–23.9098907
Cockcroft DW, Gault MH. 1976. Prediction of creatinine clearance from serum creatinine. Nephron 16:31–41.1244564
Cohen AJ, Roe FJC. 1991. Review of lead toxicology relevant to the safety assessment of lead acetate as a hair colouring. Food Chem Toxicol 29(7):485–507.1894216
Cohen N, Modai D, Golik A, . 1989. Increased concanavalin A-induced suppressor cell activity in humans with occupational lead exposure. Environ Res 48(1):1–6. 10.1016/S0013-9351(89)80079-9.2521599
Comino E, Menegatti S, Fiorucci A, . 2011. Accumulation and translocation capacity of As, Co, Cr and Pb by forage plants. Agrochimica 55(EPFL-ARTICLE-171227):105–115.
Conterato GM, Bulcao RP, Sobieski R, . 2013. Blood thioredoxin reductase activity, oxidative stress and hematological parameters in painters and battery workers: Relationship with lead and cadmium levels in blood. J Appl Toxicol 33(2):142–150. 10.1002/jat.1731.21910133
Cools A, Salle HJA, Verberk MM, . 1976. Short communications. Biochemical response of male volunteers ingesting inorganic lead for 49 days. Int Arch Occup Environ Health 38:129–139.1002305
Coon S, Stark A, Peterson E, . 2006. Whole-body lifetime occupational lead exposure and risk of Parkinson’s disease. Environ Health Perspect 114(12):1872–1876. 10.1289/ehp.9102.17185278
Cooper WC. 1988. Deaths from chronic renal disease in US battery and lead production workers. Environ Health Perspect 78:61–63.3203648
Cooper GS, Umbach DM. 1996. Are vitamin D receptor polymorphisms associated with bone mineral density? A meta-analysis. J Bone Miner Res 11(12):1841–1849.8970884
Cooper WC, Wong O, Kheifets L. 1985. Mortality among employees of lead battery plants and lead-producing plants, 1947-1980. Scand J Work Environ Health 11:331–345.4070998
Corrin ML, Natusch DF. 1977. Physical and chemical characteristics of environmental lead. In: Lead in the environment. Washington, DC: National Science Foundation, 7–31.
Cory-Slechta DA. 1995. Relationships between lead-induced learning impairments and changes in dopaminergic, cholinergic, and glutamatergic neurotransmitter system functions. Annu Rev Pharmacol Toxicol 35:391–415.7598500
Cory-Slechta DA. 2003. Lead-induced impairments in complex cognitive function: Offerings from experimental studies. Child Neuropsychol 9(1):54–75.12815522
Cory-Slechta DA, Weiss B, Cox C. 1987. Mobilization and redistribution of lead over the course of calcium disodium ethylenediamine tetraacetate chelation therapy. J Pharmacol Exp Ther 243(3):804–813.3121845
Costa de Almeida GR, Pereira Saraiva Mda C, Barbosa F, . 2007. Lead contents in the surface enamel of deciduous teeth sampled in vivo from children in uncontaminated and in lead-contaminated areas. Environ Res 104(3):337–345. 10.1016/j.envres.2007.03.007.17512519
Costa de Almeida GR, Umbelino de Freitas C, Barbosa F, . 2009. Lead in saliva from lead-exposed and unexposed children. Sci Total Environ 407(5):1547–1550. 10.1016/j.scitotenv.2008.10.058.19046759
Costa de Almeida GR, de Freitas Tavares CF, de Souza AM, . 2010. Whole blood, serum, and saliva lead concentrations in 6- to 8-year-old children. Sci Total Environ 408(7):1551–1556. 10.1016/j.scitotenv.2009.12.034.20060572
Costa de Almeida GR, de Sousa Guerra C, de Angelo Souza Leite G, . 2011. Lead contents in the surface enamel of primary and permanent teeth, whole blood, serum, and saliva of 6- to 8-year-old children. Sci Total Environ 409(10):1799–1805. 10.1016/j.scitotenv.2011.01.004.21353293
Coste J, Mandereau L, Pessione F, . 1991. Lead-exposed workmen and fertility: A cohort study on 354 subjects. Eur J Epidemiol 7(2):154–158.2044712
Counter SA, Buchanan LH, Ortega F, . 2014. Lead levels in the breast milk of nursing Andean mothers living in a lead-contaminated environment. J Toxicol Environ Health A 77(17):993–1003. 10.1080/15287394.2014.897281.25072821
Cox WM, Pesola GR. 2005. Buckshot ingestion. N Engl J Med 353(26):e23.16382055
CPSC. 1996. CPSC finds lead poisoning hazard for young children in imported vinyl miniblinds. U.S. Consumer Product Safety Commission. https://groups.google.com/forum/#!topic/misc.kids/Actbkpo1E_Q. July 12, 2017.
Craig JR, Rimstidt JD, Bonnaffon CA, . 1999. Surface water transport of lead at shooting range. Bull Environ Contam Toxicol 63:312–319.10475908
Cramer K, Goyer RA, Jagenburg R, . 1974. Renal ultrastructure, renal function, and parameters of lead toxicity in workers with different periods of lead exposure. Br J Ind Med 31:113–127.4830763
Crump KS, Van Landingham C, Bowers TS, . 2013. A statistical reevaluation of the data used in the Lanphear et al. (2005) pooled-analysis that related low levels of blood lead to intellectual deficits in children. Crit Rev Toxicol 43(9):785–799. 10.3109/10408444.2013.832726.24040996
Cui S, Zhou Q, Chao L. 2007. Potential hyperaccumulation of Pb, Zn, Cu and Cd in endurant plants distributed in an old smeltery, northeast China. Environ Geol 51(6):1043–1048.
Cullen MR, Kayne RD, Robins JM. 1984. Endocrine and reproductive dysfunction in men associated with occupational inorganic lead intoxication. Arch Environ Health 39(6):431–440.6441528
Dallaire R, Dewailly E, Ayotte P, . 2014. Growth in Inuit children exposed to polychlorinated biphenyls and lead during fetal development and childhood. Environ Res 134:17–23. 10.1016/j.envres.2014.06.023.25042032
Dalpra L, Tibiletti MG, Nocera G, . 1983. SCE analysis in children exposed to lead emission from a smelting plant. Mutat Res 120:249–256.6855793
Danadevi K, Rozati R, Banu BS, . 2003. DNA damage in workers exposed to lead using comet assay. Toxicology 187(2):183–193.12699907
Davidson A, Ryman J, Sutherland CA, . 2014. Lead. In: Ullmann’s encyclopedia of industrial chemistry. Weinheim, Germany: Wiley-VCH Verlag GmbH & Co. 10.1002/14356007.a15_193.pub3.
Davies JM. 1984a. Lung cancer mortality among workers making lead chromate and zinc chromate pigments at three English factories. Br J Ind Med 41:158–169.6722042
Davies JM. 1984b. Long term mortality study of chromate pigment workers who suffered lead poisoning. Br J Ind Med 41:170–178.6722043
Davis JM, Svendsgaard DJ. 1990. Nerve conduction velocity and lead: A critical review and meta-analysis. In: Advances in neurobehavioral toxicology: Applications in environmental and occupational health. Chelsea, MI: Lewis Publishers, 353–376.
Davis S, Mirick DK. 2006. Soil ingestion in children and adults in the same family. J Expo Sci Environ Epidemiol 16(1):63–75. 10.1038/sj.jea.7500438.16047041
Davis A, Ruby MV, Bergstrom PD. 1994. Factors controlling lead bioavailability in the Butte mining district, Montana, USA. Environ Geochem Health 16(3/4; 3/4):147–157.24197209
Davis AP, Shokouhian M, Ni S. 2001. Loading estimates of lead, copper, cadmium, and zinc in urban runoff from specific sources. Chemosphere 44:997–1009.11513434
Davis MA, Gilbert-Diamond D, Karagas MR, . 2014. A dietary-wide association study (DWAS) of environmental metal exposure in US children and adults. PLoS ONE 9(9):e104768. 10.1371/journal.pone.0104768.25198543
de Burbure C, Buchet JP, Leroyer A, . 2006. Renal and neurologic effects of cadmium, lead, mercury, and arsenic in children: Evidence of early effects and multiple interactions at environmental exposure levels. Environ Health Perspect 114(4):584–590. 10.1289/ehp.8202.16581550
De Kort WL, Zwennis WC. 1988. Blood lead and blood pressure: Some implications for the situation in The Netherlands. Environ Health Perspect 78:67–70.3203650
De Kort WLAM, Verschoor MA, Wibowo AAE, . 1987. Occupational exposure to lead and blood pressure: A study in 105 workers. Am J Ind Med 11:145–156.3826077
de Restrepo HG, Sicard D, Torres MM. 2000. DNA damage and repair in cells of lead exposed people. Am J Ind Med 38(3):330–334.10940972
Deierlein AL, Teitelbaum SL, Windham GC, . 2019. Lead exposure during childhood and subsequent anthropometry through adolescence in girls. Environ Int 122:310–315. 10.1016/j.envint.2018.11.031.30503317
DeJonghe W, Adams F. 1986. Biogeochemical cycling of organic lead compounds. Adv Environ Sci Technol 17:561–594.
Den Hond E, Nawrot T, Staessen JA. 2001. Relationship between blood pressure and blood lead in NHANES III. J Hypertens 19(2):S57.
Den Hond E, Nawrot T, Staessen JA. 2002. The relationship between blood pressure and blood lead in NHANES III. J Hum Hypertens 16:563–568.12149662
Den Hond E, Dhooge W, Bruckers L, . 2011. Internal exposure to pollutants and sexual maturation in Flemish adolescents. J Expo Sci Environ Epidemiol 21(3):224–233. 10.1038/jes.2010.2.20197795
Denaix L, Semlali RM, Douay F. 2001. Dissolved and colloidal transport of Cd, Pb, and Zn in a silt loam soil affected by atmospheric industrial deposition. Environ Pollut 113:29–38.
Deng H, Ye Z, Wong M. 2004. Accumulation of lead, zinc, copper and cadmium by 12 wetland plant species thriving in metal-contaminated sites in China. Environ Pollut 132(1):29–40.15276271
Denham M, Schell LM, Deane G, . 2005. Relationship of lead, mercury, mirex, dichlorodiphenyldichloroethylene, hexachlorobenzene, and polychlorinated biphenyls to timing of menarche among Akwesasne Mohawk girls. Pediatrics 115(2):e127–e134. 10.1542/peds.2004-1161.15653789
Desilva PE. 1981. Determination of lead in plasma and studies on its relationship to lead in erythrocytes. Br J Ind Med 38:209–217.6791682
Desrochers-Couture M, Oulhote Y, Arbuckle TE, . 2018. Prenatal, concurrent, and sex-specific associations between blood lead concentrations and IQ in preschool Canadian children. Environ Int 121(Pt 2):1235–1242. 10.1016/j.envint.2018.10.043.30392942
Desrochers-Couture M, Courtemanche Y, Forget-Dubois N, . 2019. Association between early lead exposure and externalizing behaviors in adolescence: A developmental cascade. Environ Res 178:108679. 10.1016/j.envres.2019.108679.31454729
Devoz PP, Gomes WR, De Araujo ML, . 2017. Lead (Pb) exposure induces disturbances in epigenetic status in workers exposed to this metal. J Toxicol Environ Health A 80(19–21):1098–1105. 10.1080/15287394.2017.1357364.28862539
Dewailly E, Ayotte P, Bruneau S, . 2001. Exposure of the Inuit population of Nunavik (Arctic Quebec) to lead and mercury. Arch Environ Health 56(4):350–357.11572279
Di Lorenzo L, Silvestroni A, Martino MG, . 2006. Evaluation of peripheral blood neutrophil leucocytes in lead-exposed workers. Int Arch Occup Environ Health 79(6):491–498. 10.1007/s00420-005-0073-4.16416288
Diamond GL. 1988. Biological monitoring of urine for exposure to toxic metals. In: Clarkson TW, Friberg L, Nordberg GF, ., eds. Biological monitoring of toxic metals. New York, NY: Plenum Publishing Corporation, 515–529.
Diamond GL. 2005. Risk assessment of nephrotoxic metals. In: Tarloff J, Lash L, eds. The toxicology of the kidney. London, England: CRC Press, 1099–1132.
Diamond GL, Thayer WC, Brown JS, . 2019. Estimates of urinary blood lead clearance and its relationship to glomerular filtration rate based on a large population survey. J Toxicol Environ Health A 82(5):379–382. 10.1080/15287394.2019.1603280.30983525
Dietrich KN, Berger OG, Succop PA. 1993b. Lead exposure and the motor developmental status of urban six-year-old children in the Cincinnati prospective study. Pediatrics 91(2):301–307.7678702
Dietrich KN, Krafft KM, Bier M, . 1986. Early effects of fetal lead exposure: Neurobehavioral findings at 6 months. Int J Biosoc Res 8(2):151–168.
Dietrich KN, Krafft KM, Shukla R, . 1987. The neurobehavioral effects of early lead exposure. In: Schroeder SR, ed. Toxic substances and mental retardation: Neurobehavioral toxicology and teratology. Washington, DC: American Association on Mental Deficiency, 71–95.
Dietrich KN, Krafft KM, Bier M, . 1989. Neurobehavioral effects of foetal lead exposure: The first year of life. In: Lead exposure and child development. Dordrecht: Springer, 320–331. 10.1007/978-94-009-0847-5_19.
Dietrich KN, Succop PA, Berger OG, . 1991. Lead exposure and the cognitive development of urban preschool children: The Cincinnati Lead Study cohort at age 4 years. Neurotoxicol Teratol 13(2):203–211.1710765
Dietrich KN, Succop PA, Berger OG, . 1992. Lead exposure and the central auditory processing abilities and cognitive development of urban children: The Cincinnati Lead Study cohort at age 5 years. Neurotoxicol Teratol 14(1):51–56.1593979
Dietrich KN, Berger OG, Succop PA, . 1993a. The developmental consequences of low to moderate prenatal and postnatal lead exposure: Intellectual attainment in the Cincinnati Lead Study Cohort following school entry. Neurotoxicol Teratol 15(1):37–44.8459787
Dietrich KN, Douglas RM, Succop PA, . 2001. Early exposure to lead and juvenile delinquency. Neurotoxicol Teratol 23(6):511–518.11792521
Ding N, Wang X, Weisskopf MG, . 2016. Lead-related genetic loci, cumulative lead exposure and incident coronary heart disease: The normative aging study. PLoS ONE 11(9):e0161472. 10.1371/journal.pone.0161472.27584680
Ding N, Wang X, Tucker KL, . 2019. Dietary patterns, bone lead and incident coronary heart disease among middle-aged to elderly men. Environ Res 168:222–229. 10.1016/j.envres.2018.09.035.30317107
Dingwall-Fordyce I, Lane RE. 1963. A follow-up study of lead workers. Br J Ind Med 20:313–315.14072623
Disha, Sharma S, Goyal M, . 2019. Association of raised blood lead levels in pregnant women with preeclampsia: A study at tertiary centre. Taiwan J Obstet Gynecol 58(1):60–63. 10.1016/j.tjog.2018.11.011.30638482
Dixon SL, Gaitens JM, Jacobs DE, . 2009. Exposure of U.S. children to residential dust lead, 1999-2004: II. The contribution of lead-contaminated dust to children’s blood lead levels. Environ Health Perspect 117(3):468–474. 10.1289/ehp.11918.19337524
do Nascimento SN, Charao MF, Moro AM, . 2014. Evaluation of toxic metals and essential elements in children with learning disabilities from a rural area of southern Brazil. Int J Environ Res Public Health 11(10):10806–10823. 10.3390/ijerph111010806.25329533
Dobrakowski M, Boron M, Czuba ZP, . 2016. Blood morphology and the levels of selected cytokines related to hematopoiesis in occupational short-term exposure to lead. Toxicol Appl Pharmacol 305:111–117. 10.1016/j.taap.2016.06.015.27298078
Dobrakowski M, Pawlas N, Kasperczyk A, . 2017. Oxidative DNA damage and oxidative stress in lead-exposed workers. Hum Exp Toxicol 36(7):744–754. 10.1177/0960327116665674.27596070
DOE. 2018a. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 26, 2018.
DOE. 2018b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/. July 26, 2018.
Dong Z, Yan K, Liu Y, . 2016. A meta-analysis to correlate lead bioavailability and bioaccessibility and predict lead bioavailability. Environ Int 92–93:139–145. 10.1016/j.envint.2016.04.009.
Dongre NN, Suryakar AN, Patil AJ, . 2013. Biochemical effects of lead exposure on battery manufacture workers with reference to blood pressure, calcium metabolism and bone mineral density. Indian J Clin Biochem 28(1):65–70. 10.1007/s12291-012-0241-8.24381424
Dorsey CD, Lee B, Bolla KI, . 2006. Comparison of patella lead with blood lead and tibia lead and their associations with neurobehavioral test scores. J Occup Environ Med 48(5):489–496.16688005
Doyle JR, Blais JM, Holmes RD, . 2012. A soil ingestion pilot study of a population following a traditional lifestyle typical of rural or wilderness areas. Sci Total Environ 424:110–120. 10.1016/j.scitotenv.2012.02.043.22459882
Drasch GA, Bohm J, Baur C. 1987. Lead in human bones. Investigations on an occupationally non-exposed population in southern Bavaria (F.R.G.). I. Adults. Sci Total Environ 64:303–315.3602995
Drasch G, Wanghofer E, Roider G. 1997. Are blood, urine, hair, and muscle valid biomonitors for the internal burden of men with the heavy metals mercury, lead and cadmium: An investigation on 150 deceased. Trace Elem Electrolytes 14(3):116–123.
Drexler JW, Brattin WJ. 2007. An in vitro procedure for estimation of lead relative bioavailability: With validation. Hum Ecol Risk Assess 13(2):383–401. 10.1080/10807030701226350.
Dundar B, Öktem F, Arslan MK, . 2006. The effect of long-term low-dose lead exposure on thyroid function in adolescents. Environ Res 101(1):140–145. 10.1016/j.envres.2005.10.002.16360141
DuVal GE, Fowler BA. 1989. Preliminary purification and characterization studies of a low molecular weight, high affinity cytosolic lead-binding protein in rat brain. Biochem Biophys Res Commun 159:177–184.2564273
Duydu Y, Dur A, Süzen HS. 2005. Evaluation of increased proportion of cells with unusually high sister chromatid exchange counts as a cytogenetic biomarker for lead exposure. Biol Trace Elem Res 104(2):121–129. 10.1385/BTER:104:2:121.15894812
Duydu Y, Süzen H, Aydin A, . 2001. Correlation between lead exposure indicators and sister chromatid exchange (SCE) frequencies in lymphocytes from inorganic lead exposed workers. Arch Environ Contam Toxicol 41(2):241–246.11462150
Dye BA, Hirsch R, Brody DJ. 2002. The relationship between blood lead levels and periodontal bone loss in the United States, 1988-1994. Environ Health Perspect 110(10):997–1002.12361924
Eaton DL, Stacey NH, Wong KL, . 1980. Dose response effects of various metal ions on rat liver metallothionein, glutathione, heme oxygenase, and cytochrome P-450. Toxicol Appl Pharmacol 55:393–402.6893504
Eckel WP, Jacob TA. 1988. Ambient levels of 24 dissolved metals in U.S. surface and ground waters. Prepr Pap Natl Meet Am Chem Soc Div Environ Chem 28:371–372.
Egeghy PP, Quackenboss JJ, Catlin S, . 2005. Determinants of temporal variability in NHEXAS-Maryland environmental concentrations, exposures, and biomarkers. J Expo Anal Environ Epidemiol 15(5):388–397. 10.1038/sj.jea.7500415.15602583
Ehrlich R, Robins T, Jordaan E, . 1998. Lead absorption and renal dysfunction in a South African battery factory. Occup Environ Med 55:453–460.9816378
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15(1):30–38.
Eisler R. 1988. Lead hazards to fish, wildlife, and invertebrates: A synoptic review. Fish and Wildlife Service. U.S. Department of the Interior. Biological Report 85(1.14).
Elbaz-Poulichet F, Holliger P, Huang WW, . 1984. Lead cycling in estuaries, illustrated by the Gironde estuary, France. Nature 308:409–414.
Elias SM, Hashim Z, Marjan ZM, . 2007. Relationship between blood lead concentration and nutritional status among Malay primary school children in Kuala Lumpur, Malaysia. Asia Pac J Public Health 19(3):29–37. 10.1177/101053950701900306.
Elmarsafawy SF, Jain NB, Schwartz J, . 2006. Dietary calcium as a potential modifier of the relationship of lead burden to blood pressure. Epidemiology 17(5):531–537.16878040
Elwood PC, Davey-Smith G, Oldham PD, . 1988a. Two Welsh surveys of blood lead and blood pressure. Environ Health Perspect 78:119–121.3203630
Elwood PC, Yarnell JWG, Oldham PD, . 1988b. Blood pressure and blood lead in surveys in Wales. Am J Epidemiol 127(5):942–945.3358414
Emory E, Ansari Z, Pattillo R, . 2003. Maternal blood lead effects on infant intelligence at age 7 months. Am J Obstet Gynecol 188(4):S26–S32.12712133
Englyst V, Lundstrom NG, Gerhardsson L, . 2001. Lung cancer risks among lead smelter workers also exposed to arsenic. Sci Total Environ 273:77–82.11419604
Environment and Climate Change Canada. 2016. Canadian environmental sustainability indicators: Releases of harmful substances to the environment. Minister of Environment and Climate Change. http://www.ec.gc.ca/indicateurs-indicators/3C4C1124-63E6-40BB-941A-EB87E1A23387/Releases%20of%20Harmful%20Substances_EN.pdf. June 26, 2017.
EPA. 1977. Standards of performance for secondary lead smelters. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60; Subpart L.
EPA. 1979. Lead. Water-related environmental fate of 129 priority pollutants. U.S. Environmental Protection Agency. 13-11 - 13-19. EPA440479029a.
EPA. 1982a. Standards of performance for lead-acid battery manufacturing plants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60; Subpart KK.
EPA. 1982b. Test methods. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 80.3.
EPA. 1982c. An exposure and risk assessment for lead. Washington, DC: U.S. Environmental Protection Agency. EPA440485010. PB85220606.
EPA. 1985a. Controls applicable to gasoline refiners and importers. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 80.20.
EPA. 1985b. Determination of reportable quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3.
EPA. 1985c. Lead exposures in the human environment. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600D86185. PB86241007.
EPA. 1985d. Regulation of fuels and fuel additives; gasoline lead content. Fed Regist 50(45):9386–9399.
EPA. 1986a. Air quality criteria for lead. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600883028F.
EPA. 1986b. Superfund record of decision (EPA Region 5): Forest Waste Disposal Site, Genesee County, Michigan, June 1986. Washington, DC: U.S. Environmental Protection Agency. EPARODR0586034. PB87189890.
EPA. 1988. Specific toxic chemical listings. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65.
EPA. 1989a. Exposure factors handbook. Washington, DC: U.S. Environmental Protection Agency. EPA600889043.
EPA. 1989b. National primary drinking water regulations. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141,142.
EPA. 1991. Reference air concentrations. Health based limits for exclusion of waste-derived residues. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266, Appendices IV and VII.
EPA. 1994a. Guidance manual for the integrated exposure uptake biokinetic model for lead in children. U.S. Environmental Protection Agency. EPA540R93081. PB93963510.
EPA. 1994b. Technical support document: Parameters and equations used in integrated exposure uptake biokinetic model for lead in children (v0.99d). Washington, DC: U.S. Environmental Protection Agency. EPA540R94040. PB94963505.
EPA. 1994c. Validation strategy for the integrated exposure uptake biokinetic model for lead in children. Washington, DC: U.S. Environmental Protection Agency. EPA540R94039. PB94963504.
EPA. 1994d. Methods for the determination of metals in environmental samples. Supplement 1. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600R94111. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=300036HL.txt. March 30, 2017.
EPA. 1994e. Revised interim soil lead guidance for CERCLA sites and RCRA corrective action facilities. Washington, DC: U.S. Environmental Protection Agency. OSWER Directive #9355.4-12.
EPA. 1994f. Method 200.8, revision 5.4: Determination of trace elements in waters and wastes by inductively coupled plasma-mass spectrometry. Cincinnati, OH: U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2015-08/documents/method_200-8_rev_5-4_1994.pdf. December 8, 2017.
EPA. 1995a. Guidance for assessing chemical contaminant data for use in fish advisories. Volume 1: Fish sampling and analysis. U.S. Environmental Protection Agency. EPA823R95007.
EPA. 1995b. Report on the national survey of lead based paint in housing - base report. U.S. Environmental Protection Agency.
EPA. 1996a. Prohibition on gasoline containing lead or lead additives for highway use. U.S. Environmental Protection Agency. Fed Regist 61(23):3832.
EPA. 1996b. National air quality and emissions trends report 1995. U.S. Environmental Protection Agency. EPA454R96005.
EPA. 1996c. Urban soil lead abatement demonstration project. Volume I: EPA integrated report. U.S. Environmental Protection Agency. EPA600P93001aF.
EPA. 1997a. Implementation of the mercury-containing and rechargeable battery management act. U.S. Environmental Protection Agency. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=10000MXZ.txt. February 18, 2020.
EPA. 1997b. Methods for the determination of chemical substances in marine and estuarine environmental matrices- 2nd edition. Washington, DC: U.S. Environmental Protection Agency. EPA600R97072. https://cfpub.epa.gov/si/si_public_record_report.cfm?dirEntryId=309412. March 30, 2017.
EPA. 1998. Clarification to the 1994 revised interim soil lead guidance for CERCLA sites and RCRA corrective action facilities. U.S. Environmental Protection Agency. EPA540F98030. https://www.epa.gov/superfund/lead-superfund-sites-guidance. August 25, 2017.
EPA. 1999. Determination of metals in ambient particulate matter using X-ray fluorescence (XRF) spectroscopy. Compendium Method 10-3.3. Cincinnati, OH: U.S. Environmental Protection Agency. EPA625R96010a. https://www3.epa.gov/ttnamti1/files/ambient/inorganic/mthd-3-3.pdf. March 30, 2017.
EPA. 2001. Guidance for reporting releases and other waste management quantities of toxic chemicals: Lead and lead compounds. Washington, DC: U.S. Environmental Protection Agency. https://ofmpub.epa.gov/apex/guideme_ext/guideme_ext/guideme/file/lead%20and%20lead%20compounds.pdf. February 25, 2020.
EPA. 2002a. Reference manual for the Integrated Exposure Uptake Biokinetic Model for lead in children (IEUBK) Windows 32 bit version. U.S. Environmental Protection Agency. EPA9285.7-44 https://www.epa.gov/superfund/lead-superfund-sites-software-and-users-manuals#technical. February 18, 2020.
EPA. 2002b. The “battery act”. Enforcement alert. U.S. Environmental Protection Agency. EPA300N02002.
EPA. 2002c. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F02013. http://www.epa.gov/safewater/mcl.html. February 18, 2020.
EPA. 2003. Method 200.5: Determination of trace elements in drinking water by axially viewed inductively coupled plasma- atomic emission spectrometry. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600R06115. https://www.epa.gov/sites/production/files/2015-08/documents/method_200-5_rev_4-2_2003.pdf. March 30, 2017.
EPA. 2004. Lead and copper rule: A quick reference guide. U.S. Environmental Protection Agency. EPA816F04009. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30006646.txt. February 5, 2019.
EPA. 2005a. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2005b. STORET database access. U.S. Environmental Protection Agency. http://www.epa.gov/storet/dbtop.html. May 20, 2005.
EPA. 2006. Air quality criteria for lead. Volume 1 of II. U.S. Environmental Protection Agency. EPA600R5144aF. http://ofmpub.epa.gov/eims/eimscomm.getfile?p_download_id=459555. June 27, 2017.
EPA. 2007a. National primary drinking water regulations for lead and copper: Short-term regulatory revisions and clarifications. U.S. Environmental Protection Agency. Fed Regist 72(195):57782–57820. https://www.gpo.gov/fdsys/pkg/FR-2007-10-10/pdf/E7-19432.pdf. June 28, 2017.
EPA. 2007b. The national listing of fish advisories. Advisory report output. U.S. Environmental Protection Agency.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. February 28, 2017.
EPA. 2010. Lead and copper rule monitoring and reporting guidance for public water systems. U.S. Environmental Protection Agency. EPA816R10004. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100DP2P.txt. February 5, 2019.
EPA. 2013. Providing safe drinking water in America: 2013 National Public Water Systems Compliance Report. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2015-06/documents/sdwacom2013.pdf. February 18, 2020.
EPA. 2014a. Development and evaluation of the all ages lead model (AALM). U.S. Environmental Protection Agency.
EPA. 2014b. Approach for estimating exposures and incremental health effects from lead due to renovation, repair, and painting activities in public and commercial buildings. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2014-08/documents/approachdocument_0.pdf. April 03, 2017.
EPA. 2014c. Integrated science assessment for lead. Contains errata sheet created 5/12/2014. U.S. Environmental Protection Agency. EPA600R10075F. https://cfpub.epa.gov/ncea/isa/recordisplay.cfm?deid=255721. October 21, 2016.
EPA. 2014d. Lead and lead compounds. Chemical data access tool (CDAT). [2012 Chemical Data Reporting (CDR)]. U.S. Environmental Protection Agency. https://java.epa.gov/oppt_chemical_search/. June 26, 2017.
EPA. 2014e. Identification and consideration of errors in Lanphear et al. (2005), “Low-level environmental lead exposure and children’s intellectual function: An international pooled analysis”. Memorandum to Integrated Science Assessment for lead docket (EPA-HQ-ORD-2011-0051). Research Triangle Park, NC: U.S. Environmental Protection Agency. https://ofmpub.epa.gov/eims/eimscomm.getfile?p_download_id=518543. February 5, 2019.
EPA. 2015. Report on the environment. Lead emissions. U.S. Environmental Protection Agency. https://cfpub.epa.gov/roe/. June 27, 2017.
EPA. 2016a. Optimal corrosion control treatment evaluation technical recommendations for primacy agencies and public water systems. U.S. Environmental Protection Agency. EPA816B16003. https://www.epa.gov/dwreginfo/optimal-corrosion-control-treatment-evaluation-technical-recommendations. February 18, 2020.
EPA. 2016b. Memorandum. Updated scientific considerations for lead in soil cleanups. U.S. Environmental Protection Agency. https://assets.documentcloud.org/documents/3525442/EPA-Memo-Updated-Scientific-Considerations-for.pdf. June 28, 2017.
EPA. 2016c. 2014 National emissions inventory, version 1. Technical support document. Research Triangle Park, NC: U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2016-12/documents/nei2014v1_tsd.pdf. February 18, 2020.
EPA. 2016d. Updated scientific considerations for lead in soil cleanups. U.S. Environmental Protection Agency, Office of Land and Emergency Management. https://quicksilver.epa.gov/work/08/1884174.pdf. August 25, 2017.
EPA. 2017a. Lead air releases trend in the 2015 TRI national analysis. U.S. Environmental Protection Agency.
EPA. 2017b. Supporting data files for the 2015 TRI national analysis: 2015 Toxics Release Inventory national analysis: Releases of chemicals: Lead air releases trend. U.S. Environmental Protection Agency. https://www.epa.gov/trinationalanalysis/supporting-data-files-2015-tri-national-analysis.
EPA. 2017c. TRI basic data files: Calendar years 1987 - 2015 [US data from 2015]. U.S. Environmental Protection Agency.
EPA. 2017d. Transmittal of update to the adult lead methodology’s default baseline blood lead concentration and geometric standard deviation parameters. OLEM Directive 9285-56. Washington, DC: U.S. Environmental Protection Agency. https://semspub.epa.gov/work/HQ/196766.pdf. August 25, 2017.
EPA. 2017e. Review of Michigan’s lead and copper rule. Review of the Michigan Department of Environmental Quality Drinking Water Program 2016. U.S. Environmental Protection Agency. 16–29.
EPA. 2018a. Lead trends: National trends in lead levels. U.S. Environmental Protection Agency. https://www.epa.gov/air-trends/lead-trends. February 18, 2020.
EPA. 2018b. Air quality system: Lead. U.S. Environmental Protection Agency. https://www.epa.gov/aqs. February 18, 2020.
EPA. 2018c. 2018 Edition of the drinking water standards and health advisories tables. Washington, DC: U.S. Environmental Protection Agency. EPA822F18001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. May 4, 2017.
EPA. 2018d. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. June 5, 2019.
EPA. 2019a. National primary drinking water regulations: Proposed lead and copper rule revisions. U.S. Environmental Protection Agency. Fed Regist 84(219):61684–61774. https://www.regulations.gov/contentStreamer?documentId=EPA-HQ-OW-2017-0300-0001&contentType=pdf. January 14, 2020.
EPA. 2019b. National primary and secondary ambient air quality standards for lead. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 50.16. https://www.govinfo.gov/content/pkg/CFR-2019-title40-vol2/pdf/CFR-2019-title40-vol2-sec50-16.pdf. February 18, 2020.
EPA. 2019c. Review of the dust-lead hazard standards and the definition of lead based paints. U. S. Environmental Protection Agency. Fed Regist 84(131):32632–32648. https://www.regulations.gov/document?D=EPA-HQ-OPPT-2018-0166-0360. October 25, 2019.
EPA. 2020a. Regulation of fuels and fuel additives. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 80.
EPA. 2020b. Standards for the management of specific hazardous wastes and specific types of hazardous waste management facilities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266.
Erenberg G, Rinsler SS, Fish BG. 1974. Lead neuropathy and sickle cell disease. Pediatrics 54:438–441.4370143
Erfurth EM, Gerhardsson L, Nilsson A, . 2001. Effects of lead on the endocrine system in lead smelter workers. Arch Environ Health 56(5):449–455.11777027
Ergurhan-Ilhan I, Cadir B, Koyuncu-Arslan M, . 2008. Level of oxidative stress and damage in erythrocytes in apprentices indirectly exposed to lead. Pediatr Int 50(1):45–50. 10.1111/j.1442-200X.2007.02442.x.18279204
Ericson JE. 2001. Enamel lead biomarker for prenatal exposure assessment. Environ Res 87(3):136–140. 10.1006/enrs.2001.4283.11771927
Erie JC, Good JA, Butz JA. 2009. Excess lead in the neural retina in age-related macular degeneration. Am J Ophthalmol 148(6):890–894. 10.1016/j.ajo.2009.07.001.19733830
Erkkila J, Armstrong R, Riihimaki V, . 1992. In vivo measurements of lead in bone at four anatomical sites: Long term occupational and consequent endogenous exposure. Br J Ind Med 49:631–644.1390269
Ernhart CB, Morrow-Tlucak M, Wolf AW, . 1989. Low level lead exposure in the prenatal and early preschool periods: Intelligence prior to school entry. Neurotoxicol Teratol 11(2):161–170.2733654
Esteban M, Castano A. 2009. Non-invasive matrices in human biomonitoring: A review. Environ Int 35:438–449.18951632
Esteban E, Rubin CH, Jones RL, . 1999. Hair and blood as substrates for screening children for lead poisoning. Arch Environ Health 54(6):436–440.10634234
Esteban-Vasallo MD, Aragones N, Pollan M, . 2012. Mercury, cadmium, and lead levels in human placenta: A systematic review. Environ Health Perspect 120(10):1369–1377. 10.1289/ehp.1204952.22591711
Ethier AA, Muckle G, Bastien C, . 2012. Effects of environmental contaminant exposure on visual brain development: A prospective electrophysiological study in school-aged children. Neurotoxicology 33(5):1075–1085. 10.1016/j.neuro.2012.05.010.22683800
Ettinger AS, Tellez-Rojo MM, Amarasiriwardena C, . 2004. Levels of lead in breast milk and their relation to maternal blood and bone lead levels at one month postpartum. Environ Health Perspect 112:926–931 15175184
Ettinger AS, Tellez-Rojo MM, Amarasiriwardena C, . 2006. Influence of maternal bone lead burden and calcium intake on levels of lead in breast milk over the course of lactation. Am J Epidemiol 163(1):48–56.16282237
Ettinger AS, Lamadrid-Figueroa H, Tellez-Rojo MM, . 2009. Effect of calcium supplementation on blood lead levels in pregnancy: A randomized placebo-controlled trial. Environ Health Perspect 117(1):26–31.19165383
Ettinger AS, Roy A, Amarasiriwardena CJ, . 2014. Maternal blood, plasma, and breast milk lead: Lactational transfer and contribution to infant exposure. Environ Health Perspect 122(1):87–92. 10.1289/ehp.1307187.24184948
Eum KD, Nie LH, Schwartz J, . 2011. Prospective cohort study of lead exposure and electrocardiographic conduction disturbances in the Department of Veterans Affairs Normative Aging Study. Environ Health Perspect 119(7):490–494. 10.1289/ehp.1003279.
Eum KD, Wang FT, Schwartz J, . 2013. Modifying roles of glutathione S-transferase polymorphisms on the association between cumulative lead exposure and cognitive function. Neurotoxicology 39:65–71. 10.1016/j.neuro.2013.08.002.23958642
Eum KD, Weisskopf MG, Nie LH, . 2014. Cumulative lead exposure and age at menopause in the Nurses’ Health Study cohort. Environ Health Perspect 122(3):229–234. 10.1289/ehp.1206399.24398113
Eum KD, Seals RM, Taylor KM, . 2015. Modification of the association between lead exposure and amyotrophic lateral sclerosis by iron and oxidative stress related gene polymorphisms. Amyotroph Lateral Scler Frontotemporal Degener 16(1–2):72–79. 10.3109/21678421.2014.964259.25293352
Evans RD, Rigler FH. 1985. Long distance transport of anthropogenic lead as measured by lake sediments. Water Air Soil Pollut 24:141–151.
Evans M, Elinder CG. 2011. Chronic renal failure from lead: Myth or evidence-based fact? Kidney Int 79(3):272–279. 10.1038/ki.2010.394.20944550
Evens A, Hryhorczuk D, Lanphear BP, . 2015. The impact of low-level lead toxicity on school performance among children in the Chicago public schools: A population-based retrospective cohort study. Environ Health 14:21. 10.1186/s12940-015-0008-9.25889033
Ewers U, Stiller-Winkler R, Idel H. 1982. Serum immunoglobulin, complement C3, and salivary IgA levels in lead workers. Environ Res 29(2):351–357. 10.1016/0013-9351(82)90036-6.7160352
Factor-Litvak P, Graziano JH, Kline JK, . 1991. A prospective study of birthweight and length of gestation in a population surrounding a lead smelter in Kosovo, Yugoslavia. Int J Epidemiol 20:722–728.1955258
Factor-Litvak P, Kline JK, Popovac D, . 1996. Blood lead and blood pressure in young children. Epidemiology 7(6):633–637. 10.1097/00001648-199611000-00012.8899391
Factor-Litvak P, Slavkovich V, Liu X, . 1998. Hyperproduction of erythropoietin in nonanemic lead-exposed children. Environ Health Perspect 106(6):361–364.9618353
Factor-Litvak P, Wasserman G, Kline JK, . 1999. The Yugoslavia prospective study of environmental lead exposure. Environ Health Perspect 107(1):9–15.9872712
Fadrowski JJ, Navas-Acien A, Tellez-Plaza M, . 2010. Blood lead level and kidney function in US adolescents: The Third National Health and Nutrition Examination Survey. Arch Intern Med 170(1):75–82. 10.1001/archinternmed.2009.417.20065202
Famurewa AC, Ugwuja EI. 2017. Association of blood and seminal plasma cadmium and lead levels with semen quality in non-occupationally exposed infertile men in Abakaliki, South East Nigeria. J Family Reprod Health 11(2):97–103.29282417
Fan G, Du G, Li H, . 2014. The effect of the hemochromatosis (HFE) genotype on lead load and iron metabolism among lead smelter workers. PLoS ONE 9(7):e101537. 10.1371/journal.pone.0101537.24988074
Fan Y, Sheng J, Liang C, . 2020. Association of blood lead levels with the risk of depressive symptoms in the elderly Chinese population: Baseline data of a cohort study. Biol Trace Elem Res 194(1):76–83. 10.1007/s12011-019-01755-x.31147977
Fang F, Kwee LC, Allen KD, . 2010. Association between blood lead and the risk of amyotrophic lateral sclerosis. Am J Epidemiol 171(10):1126–1133. 10.1093/aje/kwq063.20406759
Fanning D. 1988. A mortality study of lead workers, 1926-1985. Arch Environ Health 43(3):247–251.3382250
Faramawi MF, Delongchamp R, Lin YS, . 2015. Environmental lead exposure is associated with visit-to-visit systolic blood pressure variability in the US adults. Int Arch Occup Environ Health 88(3):381–388. 10.1007/s00420-014-0970-5.25086568
Farhat A, Mohammadzadeh A, Balali-Mood M, . 2013. Correlation of blood lead level in mothers and exclusively breastfed infants: A study on infants aged less than six months. Asia Pac J Med Toxicol 2:150–152.
Farias P, Echavarria M, Hernandez-Avila M, . 2005. Bone, blood and semen lead in men with environmental and moderate occupational exposure. Int J Environ Health Res 15(1):21–31.16028333
Farooqui Z, Bakulski KM, Power MC, . 2017. Associations of cumulative Pb exposure and longitudinal changes in Mini-Mental Status Exam scores, global cognition and domains of cognition: The VA Normative Aging Study. Environ Res 152:102–108. 10.1016/j.envres.2016.10.007.27770710
Fayerweather WE, Karns ME, Nuwayhid IA, . 1997. Case-control study of cancer risk in tetraethyl lead manufacturing. Am J Ind Med 31:28–35.8986251
Fazli D, Malekirad AA, Mirzaee M, . 2014. Study on the link between lead exposure and hematological, psychological, and memorial parameters in automobile repair workers. Sci Res 6:712–719.
FDA. 1995. Substances prohibited from use in human food. Substances prohibited from indirect addition to human food through food-contact surfaces. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 189.240.
FDA. 2006. Supporting document for recommended maximum level for lead in candy likely to be consumed frequently by small children. U.S. Food and Drug Administration. https://www.fda.gov/food/foodborneillnesscontaminants/metals/ucm172050.htm. June 28, 2017.
FDA. 2016a. Lead and cadmium in foods. Combination metals testing. U.S. Food and Drug Administration. https://www.fda.gov/Food/FoodborneIllnessContaminants/Metals/ucm521427.htm. March 23, 2017.
FDA. 2016b. Total diet study elements results summary statistics. Market baskets 2006 through 2011. U.S. Food and Drug Administration. March 23, 2017.
FDA. 2019a. Substances added to food. Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/?set=FoodSubstances. September 2, 2019.
FDA. 2019b. Subpart B - Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. https://www.govinfo.gov/content/pkg/CFR-2019-title21-vol2/pdf/CFR-2019-title21-vol2-part165.pdf. December 5, 2019.
Fears TR, Elashoff RM, Schneiderman MA. 1989. The statistical analysis of a carcinogen mixture experiment. III. Carcinogens with different target systems, aflatoxin B1, n-butyl-N(4-hydroxybutyl)nitrosamine, lead acetate, and thiouracil. Toxicol Ind Health 5(1):1–23.
Feldhake CJ, Stevens CD. 1963. The solubility of tetraethyllead in water. J Chem Eng Data 8(2):196–197. 10.1021/je60017a016.
Fels LM, Bundschuh I, Gwinner W, . 1994. Early urinary markers of target nephron segments as studied in cadmium toxicity. Kidney Int Suppl 47:S81–88.
Fels LM, Wunsch M, Baranowski J, . 1998. Adverse effects of chronic low level lead exposure on kidney function - A risk group study in children. Nephrol Dial Transplant 13:2248–2256.9761504
Fenga C, Gangemi S, Alibrandi A, . 2016. Relationship between lead exposure and mild cognitive impairment. J Prev Med Hyg 57(4):E205–E210.28167858
Fergusson DM, Horwood LJ, Lynskey MT. 1993. Early dentine lead levels and subsequent cognitive and behavioural development. J Child Psychol Psychiatry 34(2):215–227. 10.1111/j.1469-7610.1993.tb00980.x.8444993
Fernandes KC, Martins AC, Oliveira AA, . 2016. Polymorphism of metallothionein 2A modifies lead body burden in workers chronically exposed to the metal. Public health genomics 19(1):47–52. 10.1159/000441713.26594907
Finster ME, Gray KA, Binns HJ. 2004. Lead levels of edibles grown in contaminated residential soils: A field survey. Sci Total Environ 320(2):245–257.15016510
Fischbein A, Anderson KE, Sassa S, . 1981. Lead poisoning from “Do-It-Yourself” heat guns for removing lead-based paint: Report of two cases. Environ Res 24:425–431.
Fischbein A, Tsang P, Luo JCJ, . 1993. Phenotypic aberrations of CD3+ and CD4+ cells and functional impairments of lymphocytes at low-level occupational exposure to lead. Clin Immunol Immunopathol 66(2):163–168.8095868
Flanagan PR, Hamilton DL, Haist J, . 1979. Interrelationships between iron and lead absorption in iron-deficient mice. Gastroenterology 77:1074–1081.488634
Flegal AR, Smith DR. 1995. Measurements of environmental lead contamination and human exposure. Rev Environ Contam Toxicol 143:1–45.7501865
Fleisch AF, Burns JS, Williams PL, . 2013. Blood lead levels and serum insulin-like growth factor 1 concentrations in peripubertal boys. Environ Health Perspect 121(7):854–858. 10.1289/ehp.1206105.23632160
Fleming D, Boulay D, Richard NS, . 1997. Accumulated body burden and endogenous release of lead in employees of a lead smelter. Environ Health Perspect 105(2):224–233.9105798
Fleming MD, Romano MA, Su MA, . 1998a. Nramp2 is mutated in the anemic Belgrade (b) rat: Evidence of a role for Nramp2 in endosomal iron transport. Proc Natl Acad Sci 95(3):1148–1153.9448300
Fleming DEB, Chettle DR, Wetmur JG, . 1998b. Effect of the delta-aminolevulinate dehydratase polymorphism on the accumulation of lead in bone and blood in lead smelter workers. Environ Res 77:49–61.9593628
Flora G, Gupta D, Tiwari A. 2012. Toxicity of lead: A review with recent updates. Interdiscip Toxicol 5(2):47–58. 10.2478/v10102-012-0009-2.23118587
Forbes GB, Reina JC. 1972. Effect of age on gastrointestinal absorption (Fe, Sr, Pb) in the rat. J Nutr 102:647–652.5022199
Forni A, Cambiaghi G, Secchi GC. 1976. Initial occupational exposure to lead. Chromosome and biochemical findings. Arch Environ Health 31:73–78.1259473
Fosse G, Wesenberg GR, Tvinnereim HM, . 1995. Lead in deciduous teeth from larger cities of some countries. Int J Environ Stud 47:203–210.
Foster P, Gray LE. 2008. Toxic responses of the reproductive system. In: Klaassen CD, ed. Casarett and Doull’s toxicology. The basic science of poisons. New York, NY: The McGraw-Hill Companies, Inc, 761–806.
Fowler BA, DuVal G. 1991. Effects of lead on the kidney: Roles of high-affinity lead-binding proteins. Environ Health Perspect 91:77–80.1710180
Fracasso ME, Perbellini L, Soldà S, . 2002. Lead induced DNA strand breaks in lymphocytes of exposed workers: Role of reactive oxygen species and protein kinase C. Mutat Res Genet Toxicol Environ Mutagen 515(1):159–169.
Franklin CA, Inskip MJ, Baccanale CL, . 1997. Use of sequentially administered stable lead isotopes to investigate changes in blood lead during pregnancy in a nonhuman primate (Macaca fascicularis). Fundam Appl Toxicol 39:109–119.9344623
Fraser S, Muckle G, Despres C. 2006. The relationship between lead exposure, motor function and behaviour in Inuit preschool children. Neurotoxicol Teratol 28(1):18–27. 10.1016/j.ntt.2005.10.008.16337107
Freeman GB, Johnson JD, Killinger JM, . 1992. Relative bioavailability of lead from mining waste soil in rats. Fundam Appl Toxicol 19(3):388–398.1459371
Freeman GB, Johnson JD, Liao SC, . 1994. Absolute bioavailability of lead acetate and mining waste lead in rats. Toxicology 91:151–163.8059439
Freeman GB, Dill JA, Johnson JD, . 1996. Comparative absorption of lead from contaminated soil and lead salts by weanling Fischer 344 rats. Fundam Appl Toxicol 33:109–119.8812247
Frisancho AR, Ryan AS. 1991. Decreased stature associated with moderate blood lead concentrations in Mexican-American children. Am J Clin Nutr 54:516–519.1877508
Froehlich TE, Lanphear BP, Dietrich KN, . 2007. Interactive effects of a DRD4 polymorphism, lead and sex on executive functions in children. Biol Psychiatry 62(3):243–249. 10.1016/j.biopsych.2006.09.039.17239353
Froehlich TE, Lanphear BP, Auinger P, . 2009. Association of tobacco and lead exposures with attention-deficit/hyperactivity disorder. Pediatrics 124(6):E1054–E1063. 10.1542/peds.2009-0738.19933729
Froom P, Kristal-Boneh E, Benbassat J, . 1998. Predictive value of determinations of zinc protoporphyrin for increased blood lead concentrations. Clin Chem 44(6):1283–1288.9625054
Fruh V, Rifas-Shiman SL, Amarasiriwardena C, . 2019. Prenatal lead exposure and childhood executive function and behavioral difficulties in project viva. Neurotoxicology 75:105–115. 10.1016/j.neuro.2019.09.006.31513824
Fujita H, Sato K, Sano S. 1982. Increase in the amount of erythrocyte delta-aminolevulinic acid dehydratase in workers with moderate lead exposure. Int Arch Occup Environ Health 50:287–297.7129653
Fukui Y, Miki M, Ukai H, . 1999. Urinary lead as a possible surrogate of blood lead among workers occupationally exposed to lead. Int Arch Occup Environ Health 72(8):516–520.10592003
Fukumoto K, Karai I, Horiguchi S. 1983. Effect of lead on erythrocyte membranes. Br J Ind Med 40:220–223.6830722
Fullmer CS, Rosen JF. 1990. Effect of dietary calcium and lead status on intestinal calcium absorption. Environ Res 51:91–99.2153538
Gambelunghe A, Sallsten G, Borne Y, . 2016. Low-level exposure to lead, blood pressure, and hypertension in a population-based cohort. Environ Res 149:157–163. 10.1016/j.envres.2016.05.015.27208466
Gao K, Pearce J, Jones J, . 1999. Interaction between peat, humic acid and aqueous metal ions. Environ Geochem Health 21(1):13–26.
Gao A, Lu XT, Li QY, . 2010. Effect of the delta-aminolevulinic acid dehydratase gene polymorphism on renal and neurobehavioral function in workers exposed to lead in China. Sci Total Environ 408(19):4052–4055. 10.1016/j.scitotenv.2010.04.024.20510440
Garavan C, Breen J, Moles R, . 2008. A case study of the health impacts in an abandoned lead mining area, using children’s blood lead levels. Int J Min Reclam Environ 22(4):265–284.
Garcia-Esquinas E, Aragones N, Fernandez MA, . 2014. Newborns and low to moderate prenatal environmental lead exposure: Might fathers be the key? Environ Sci Pollut Res Int 21(13):7886–7898. 10.1007/s11356-014-2738-6.24647583
Garcia-Leston J, Mendez J, Pasaro E, . 2010. Genotoxic effects of lead: An updated review. Environ Int 36(6):623–636. 10.1016/j.envint.2010.04.011.20466424
Garcia-Leston J, Roma-Torres J, Mayan O, . 2012. Assessment of immunotoxicity parameters in individuals occupationally exposed to lead. J Toxicol Environ Health A 75(13–15):807–818. 10.1080/15287394.2012.690327.22788368
García-Lestón J, Roma-Torres J, Vilares M, . 2011. Biomonitoring of a population of Portuguese workers exposed to lead. Mutat Res 721(1):81–88. 10.1016/j.mrgentox.2011.01.001.21241821
Garcon G, Leleu B, Marez T, . 2007. Biomonitoring of the adverse effects induced by the chronic exposure to lead and cadmium on kidney function: Usefulness of alpha-glutathione S-transferase. Sci Total Environ 377(2–3):165–172. 10.1016/j.scitotenv.2007.02.002.17379277
Garrido Latorre F, Hernandez-Avila M, Orozco JT, . 2003. Relationship of blood and bone lead to menopause and bone mineral density among middle-age women in Mexico City. Environ Health Perspect 111(4):631–636.12676627
Gartside PS. 1988. The relationship of blood lead levels and blood pressure in NHANES II: Additional calculations. Environ Health Perspect 78:31–34.3203642
Garvey GJ, Hahn G, Lee RV, . 2001. Heavy metal hazards of Asian traditional remedies. Int J Environ Health Res 11(1):63–71.11260788
Ge Y, Murray P, Hendershot W. 2000. Trace metal speciation and bioavailability in urban soils. Environ Pollut 107(1):137–144.15093017
Geier DA, Kern JK, Geier MR. 2017. Blood lead levels and learning disabilities: A cross-sectional study of the 2003-2004 National Health and Nutrition Examination Survey (NHANES). Int J Environ Res Public Health 14(10):1202. 10.3390/ijerph14101202.28994742
Geier DA, Kern JK, Geier MR. 2018. A cross-sectional study of the relationship between blood lead levels and reported attention deficit disorder: An assessment of the economic impact on the United States. Metab Brain Dis 33(1):201–208. 10.1007/s11011-017-0146-6.29134344
Gemmel A, Tavares M, Alperin S, . 2002. Blood lead level and dental caries in school-age children. Environ Health Perspect 110(10):A625–A630.12361944
Gennart JP, Bernard A, Lauwerys R. 1992. Assessment of thyroid, testes, kidney and autonomic nervous system function in lead-exposed workers. Int Arch Occup Environ Health 64:49–57.1399015
Genuis SJ, Birkholz D, Rodushkin I, . 2011. Blood, urine, and sweat (BUS) study: Monitoring and elimination of bioaccumulated toxic elements. Arch Environ Contam Toxicol 61(2):344–357. 10.1007/s00244-010-9611-5.21057782
Gercken B, Barnes RM. 1991. Determination of lead and other trace element species in blood by size exclusion chromatography and inductively coupled plasma/mass spectrometry. Anal Chem 63:283–287.1824013
Gerhardsson L, Brune D, Nordberg GF, . 1986. Distribution of cadmium, lead and zinc in lung, liver and kidney in long-term exposed smelter workers. Sci Total Environ 50:65–85.3704626
Gerhardsson L, Chettle D, Englyst V, . 1992. Kidney effects in long term exposed lead smelter workers. Br J Ind Med 49(3):186–192.1554615
Gerhardsson L, Attewell R, Chettle DR, . 1993. In vivo measurements of lead in bone in long-term exposed lead smelter workers. Arch Environ Health 48(3):147–156. 10.1080/00039896.1993.9940813.8333784
Gerhardsson L, Hagmar L, Rylander L, . 1995a. Mortality and cancer incidence among secondary lead smelter workers. Occup Environ Med 52:667–672.7489057
Gerhardsson L, Englyst V, Lundstrom NG, . 1995b. Lead in tissues of deceased lead smelter worker. J Trace Elem Med Biol 9:136–143.8605601
Gerhardt RE, Crecelius EA, Hudson JB. 1980. Trace element content of moonshine. Arch Environ Health 35:332–334.7458415
Gerr F, Letz R, Stokes L, . 2002. Association between bone lead concentration and blood pressure among young adults. Am J Ind Med 42:98–106.12125085
Gersberg RM, Gaynor K, Tenczar D, . 1997. Quantitative modeling of lead exposure from glazed ceramic pottery in childhood lead poisoning cases. Int J Environ Health Res 7:193–202.
Getz LL, Rolfe GL, Haney AW, . 1977. Transport and distribution in a watershed ecosystem. In: Boggess WR, ed. Lead in the environment. Washington, DC: National Science Foundation, 105–134.
Ghiasvand M, Aghakhani K, Salimi A, . 2013. Ischemic heart disease risk factors in lead exposed workers: Research study. J Occup Med Toxicol 8:11. 10.1186/1745-6673-8-11.23607481
Ghiasvand M, Mohammadi S, Roth B, . 2016. The relationship between occupational exposure to lead and hearing loss in a cross-sectional survey of Iranian workers. Front Public Health 4:19. 10.3389/fpubh.2016.00019.26909343
Gibbs PNB, Gore MG, Jordan PM. 1985. Investigation of the effect of metal ions on the reactivity of thiol groups in human 5-aminolaevulinate dehydratase. Biochem J 225:573–580.3977848
Giddings JC. 1973. Lead in gasoline. In: Chemistry, man, and environmental change. An integrated approach. New York, NY: Canfield Press, 351–353.
Gilbert M, Lasley SM. 2002. Long-term consequences of developmental exposure to lead or polychlorinated biphenyls: Synaptic transmission and plasticity in the rodent CNS. Environ Toxicol Pharmacol 12(2):105–117.21782630
Glass TA, Bandeen-Roche K, McAtee M, . 2009. Neighborhood psychosocial hazards and the association of cumulative lead dose with cognitive function in older adults. Am J Epidemiol 169(6):683–692. 10.1093/aje/kwn390.19155330
Glenn BS, Stewart WF, Links JM, . 2003. The longitudinal association of lead with blood pressure. Epidemiology 14(1):30–36.12500043
Glenn BS, Bandeen-Roche K, Lee BK, . 2006. Changes in systolic blood pressure associated with lead in blood and bone. Epidemiology 17(5):538–544. 10.1097/01.ede.0000231284.19078.4b.16906055
Goering PL, Fowler BA. 1987. Metal constitution of metallothionein influences inhibition of δ-aminolaevulinic acid dehydratase (porphobilinogen synthase) by lead. Biochem J 245(2):339–345.3663161
Goldberg RL, Hicks AM, O’Leary LM, . 1991. Lead exposure at uncovered outdoor firing ranges. J Occup Med 33(6):718–719.1865252
Gollenberg AL, Hediger ML, Lee PA, . 2010. Association between lead and cadmium and reproductive hormones in peripubertal U.S. girls. Environ Health Perspect 118(12):1782–1787. 10.1289/ehp.1001943.20675266
Golub NI, Winters PC, van Wijngaarden E. 2010. A population-based study of blood lead levels in relation to depression in the United States. Int Arch Occup Environ Health 83(7):771–777.19967393
Gomaa A, Howard H, Bellinger D, . 2002. Maternal bone lead as an independent risk factor for fetal neurotoxicity: A prospective study. Pediatrics 110(1):110–118.12093955
Gomes VE, Rosario de Sousa ML, Barbosa F, . 2004. In vivo studies on lead content of deciduous teeth superficial enamel of preschool children. Sci Total Environ 320(1):25–35. 10.1016/j.scitotenv.2003.08.013.14987924
Gomez HF, Borgialli DA, Sharman M, . 2018. Blood lead levels of children in Flint, Michigan: 2006-2016. J Pediatr 197:158–164. 10.1016/j.jpeds.2017.12.063.29599069
Gomez HF, Borgialli DA, Sharman M, . 2019. Blood lead levels in females of childbearing age in Flint, Michigan, and the water crisis. Obstet Gynecol 134(3):628–635. 10.1097/aog.0000000000003416.31403597
Gonick HC. 2011. Lead-binding proteins: A review. Journal of toxicology 2011:686050. 10.1155/2011/686050.21941540
González-Cossío T, Peterson KE, Sanin L, . 1997. Decrease in birth weight in relation to maternal bone-lead burden. Pediatrics 100(5):856–862.9346987
Goodman M, LaVerda N, Clarke C, . 2002. Neurobehavioural testing in workers occupationally exposed to lead: Systematic review and meta-analysis of publications. Occup Environ Med 59(4):217–223.11934948
Goodrum PE, Diamond GL, Hassett JM, . 1996. Monte Carlo modeling of childhood lead exposure: Development of a probabilistic methodology for use with the USEPA IEUBK model for lead in children. Hum Ecol Risk Assess 2(4):681–708.
Goyer RA. 1989. Mechanisms of lead and cadmium nephrotoxicity. Toxicol Lett 46:153–162.2650022
Goyer RA. 1990. Transplacental transport of lead. Environ Health Perspect 89:101–105.2088735
Goyer RA. 2001. Lead. In: Bingham E, Cohrssen B, Powell CH, eds. Patty’s toxicology. Vol. 2. 5th ed. New York, NY: John Wiley & Sons, Inc., 611–675.
Goyer RA, Leonard DL, Moore JF, . 1970a. Lead dosage and the role of the intranuclear inclusion body: An experimental study. Arch Environ Health 20:705–711.5443344
Goyer RA, May P, Cates MM, . 1970b. Lead and protein content of isolated intranuclear inclusion bodies from kidneys of lead-poisoned rats. Lab Invest 22(3):245–251.5436518
Grabo TN. 1997. Unknown toxic exposures: Arts and crafts materials. AAOHN J 45(3):124–130.9146113
Grandjean P. 1979. Occupational lead exposure in Denmark: Screening with the haematofluorometer. Br J Ind Med 36:52–58.444441
Grandjean P, Lintrup J. 1978. Erythrocyte-Zn-protoporphyrin as an indicator of lead exposure. Scand J Clin Lab Invest 38:669–675.715369
Grandjean P, Bach E. 1986. Indirect exposures: The significance of bystanders at work and at home. Am Ind Hyg Assoc J 47(12):819–824.3799485
Grandjean P, Wulf HC, Niebuhr E. 1983. Sister chromatid exchange in response to variations in occupational lead exposure. Environ Res 32(1):199–204.6617612
Grandjean P, Jorgensen PJ, Viskum S. 1991. Temporal and interindividual variation in erythrocyte zinc-protoporphyrin in lead exposed workers. Br J Ind Med 48:254–257.2025591
Grandjean P, Hollnagel H, Hedegaard L, . 1989. Blood lead-blood pressure relations: Alcohol intake and hemoglobin as confounders. Am J Epidemiol 129(4):732–739.2923121
Grashow R, Miller MW, McKinney A, . 2013a. Lead exposure and fear-potentiated startle in the VA Normative Aging Study: A pilot study of a novel physiological approach to investigating neurotoxicant effects. Neurotoxicol Teratol 38:21–28. 10.1016/j.ntt.2013.04.003.23603705
Grashow R, Spiro A, Taylor KM, . 2013b. Cumulative lead exposure in community-dwelling adults and fine motor function: Comparing standard and novel tasks in the VA normative aging study. Neurotoxicology 35:154–161. 10.1016/j.neuro.2013.01.005.23370289
Grashow R, Sparrow D, Hu H, . 2015. Cumulative lead exposure is associated with reduced olfactory recognition performance in elderly men: The Normative Aging Study. Neurotoxicology 49:158–164. 10.1016/j.neuro.2015.06.006.26121922
Graziano JH. 1994. Validity of lead exposure markers in diagnosis and surveillance. Clin Chem 40(7):1387–1390.8013124
Graziano JH, Blum C. 1991. Lead exposure from lead crystal. Lancet 337:141–142.1670790
Graziano JH, Popovac D, Factor-Litvak P, . 1990. Determinants of elevated blood lead during pregnancy in a population surrounding a lead smelter in Kosovo, Yugoslavia. Environ Health Perspect 89:95–100.2088762
Graziano JH, Blum CB, Lolacono NJ, . 1996. A human in vivo model for the determination of lead bioavailability using stable isotope dilution. Environ Health Perspect 104(2):176–179. 10.1289/ehp.96104176.8820585
Graziano J, Slavkovich V, Liu X, . 2004. A prospective study of prenatal and childhood lead exposure and erythropoietin production. J Occup Environ Med 46(9):924–929.15354056
Greenberg M, Hamilton R. 1999. Lack of blood lead elevations in police officers following small arms qualification on an indoor range. J Toxicol Clin Toxicol 37(5):627.
Griffin TB, Coulston F, Wills H. 1975. Biological and clinical effects of continuous exposure to airborne particulate lead. Arh Hig Rada Toksikol 26:191–208.
Griffin S, Goodrum PE, Diamond GL, . 1999. Application of a probabilistic risk assessment methodology to a lead smelter site. Hum Ecol Risk Assess 5(4):845–868.
Gross M, Kumar R. 1990. Physiology and biochemistry of vitamin D-dependent calcium binding proteins. Am J Physiol 259:F195–F209.2201202
Gross SB, Pfitzer EA, Yeager DW, . 1975. Lead in human tissues. Toxicol Appl Pharmacol 32:638–651.1154419
Grover P, Rekhadevi PV, Danadevi K, . 2010. Genotoxicity evaluation in workers occupationally exposed to lead. Int J Hyg Environ Health 213(2):99–106. 10.1016/j.ijheh.2010.01.005.20153251
Guibaud G, Tixier N, Bouju A, . 2003. Relation between extracellular polymers’ composition and its ability to complex Cd, Cu and Pb. Chemosphere 52(10):1701–1710.12871737
Gulson BL. 1996. Tooth analyses of sources and intensity of lead exposure in children. Environ Health Perspect 104(3):306–312. 10.1289/ehp.96104306.8919769
Gulson BL. 2000. Revision of estimates of skeletal contribution to blood during pregnancy and postpartum period. J Lab Clin Med 136(3):250–251. 10.1067/mlc.2000.108752.10985504
Gulson B, Wilson D. 1994. History of lead exposure in children revealed from isotopic analyses of teeth. Arch Environ Health 49(4):279–283. 10.1080/00039896.1994.9937480.8031185
Gulson BL, Palmer JM, Bryce A. 2002. Changes in blood lead of a recreational shooter. Sci Total Environ 293(1):143–150.12109468
Gulson BL, Mizon KJ, Korsch MJ, . 1996. Impact on blood lead in children and adults following relocation from their source of exposure and contribution of skeletal tissue to blood lead. Bull Environ Contam Toxicol 56(4):543–550. 10.1007/s001289900078.8645908
Gulson BL, James M, Giblin AM, . 1997a. Maintenance of elevated lead levels in drinking water from occasional use and potential impact on blood leads in children. Sci Total Environ 205:271–275.9372633
Gulson BL, Jameson CW, Mahaffey KR, . 1997b. Pregnancy increases mobilization of lead from maternal skeleton. J Lab Clin Med 130:51–62.9242366
Gulson BL, Jameson CW, Mahaffey KR, . 1998a. Relationships of lead in breast milk to lead in blood, urine, and diet of the infant and mother. Environ Health Perspect 106(10):667–674.9755144
Gulson BL, Mahaffey KR, Jameson CW, . 1998b. Mobilization of lead from the skeleton during the postnatal period is larger than during pregnancy. J Lab Clin Med 131:324–329.9579385
Gulson BL, Gray B, Mahaffey KR, . 1999a. Comparison of the rates of exchange of lead in the blood of newly born infants and their mothers with lead from their current environment. J Lab Clin Med 133(2):171–178.9989769
Gulson BL, Pounds JG, Mushak P, . 1999b. Estimation of cumulative lead releases (lead flux) from the maternal skeleton during pregnancy and lactation. J Lab Clin Med 134(6):631–640.10595792
Gulson BL, Mahaffey KR, Jameson CW, . 1999c. Impact of diet on lead in blood and urine in female adults and relevance to mobilization of lead from bone stores. Environ Health Perspect 107(4):257–263.10090703
Gulson BL, Mizon KJ, Korsch MJ, . 2003. Mobilization of lead from human bone tissue during pregnancy and lactation - A summary of long-term research. Sci Total Environ 303:79–104.12568766
Gulson BL, Mizon KJ, Palmer JM, . 2004. Blood lead changes during pregnancy and postpartum with calcium supplementation. Environ Health Perspect 12(15):1499–1507.
Gulson B, Mizon K, Taylor A, . 2008. Longitudinal monitoring of selected elements in blood of healthy young children. J Trace Elem Med Biol 22(3):206–214. 10.1016/j.jtemb.2008.04.001.18755396
Gulson B, Korsch M, Matisons M, . 2009. Windblown lead carbonate as the main source of lead in blood of children from a seaside community: An example of local birds as “canaries in the mine”. Environ Health Perspect 117(1):148–154. 10.1289/ehp.11577.19165402
Gulson B, Mizon K, Korsch M, . 2016. Revisiting mobilisation of skeletal lead during pregnancy based on monthly sampling and cord/maternal blood lead relationships confirm placental transfer of lead. Arch Toxicol 90(4):805–816. 10.1007/s00204-015-1515-8.25877328
Gump BB, Stewart P, Reihman J, . 2005. Prenatal and early childhood blood lead levels and cardiovascular functioning in 9 1/2 year old children. Neurotoxicol Teratol 27(4):655–665. 10.1016/j.ntt.2005.04.002.15919179
Gump BB, Stewart P, Reihman J, . 2008. Low-level prenatal and postnatal blood lead exposure and adrenocortical responses to acute stress in children. Environ Health Perspect 116(2):249–255. 10.1289/ehp.10391.18288326
Gump BB, Mackenzie JA, Bendinskas K, . 2011. Low-level Pb and cardiovascular responses to acute stress in children: The role of cardiac autonomic regulation. Neurotoxicol Teratol 33(2):212–219. 10.1016/j.ntt.2010.10.001.20934510
Gundacker C, Wittmann KJ, Kukuckova M, . 2009. Genetic background of lead and mercury metabolism in a group of medical students in Austria. Environ Res 109:786–796.19515364
Gundacker C, Fröhlich S, Graf-Rohrmeister K, . 2010. Perinatal lead and mercury exposure in Austria. Sci Total Environ 408(23):5744–5749. 10.1016/j.scitotenv.2010.07.079.20825977
Guo M, He L, Strong PJ, . 2014. Binding between lead ions and the high-abundance serum proteins. Chemosphere 112:472–480. 10.1016/j.chemosphere.2014.05.018.25048942
Gurer-Orhan H, Sabır HU, Özgüneş H. 2004. Correlation between clinical indicators of lead poisoning and oxidative stress parameters in controls and lead-exposed workers. Toxicology 195(2):147–154.14751670
Gustafson A, Hedner P, Schutz A, . 1989. Occupational lead exposure and pituitary function. Int Arch Occup Environ Health 61:277–281.2498211
Guyette RP, Cutter BE, Henderson GS. 1991. Long-term correlations between mining activity and levels of lead and cadmium in tree-rings of eastern red-cedar. J Environ Qual 20(1):146–150
Haenninen H, Hernberg S, Mantere P, . 1978. Psychological performance of subjects with low exposure to lead. J Occup Med 20(10):683–689.722355
Haley VB, Talbot TO. 2004. Seasonality and trend in blood lead levels of New York State children. BMC Pediatr 4(1):8. 10.1186/1471-2431-4-8.15180903
Hamurcu Z, Donmez H, Saraymen R, . 2001. Micronucleus frequency in human lymphocyte exposed to occupational lead, zinc, and cadmium. Biol Trace Elem Res 83(2):97–102.11762535
Han L, Wang X, Han R, . 2018. Association between blood lead level and blood pressure: An occupational population-based study in Jiangsu province, China. PLoS ONE 13(7):e0200289. 10.1371/journal.pone.0200289.29979755
Hanna CW, Bloom MS, Robinson WP, . 2012. DNA methylation changes in whole blood is associated with exposure to the environmental contaminants, mercury, lead, cadmium and bisphenol A, in women undergoing ovarian stimulation for IVF. Hum Reprod 27(5):1401–1410. 10.1093/humrep/des038.22381621
Hanna-Attisha M, LaChance J, Sadler RC, . 2016. Elevated blood lead levels in children associated with the Flint drinking water crisis: A spatial analysis of risk and public health response. Am J Public Health 106(2):283–290. 10.2105/ajph.2015.303003.26691115
Hanninen H, Aitio A, Kovala T, . 1998. Occupational exposure to lead and neuropsychological dysfunction. Occup Environ Med 55:202–209.9624272
Hansen S, Nieboer E, Sandanger TM, . 2011. Changes in maternal blood concentrations of selected essential and toxic elements during and after pregnancy. J Environ Monit 13(8):2143–2152. 10.1039/c1em10051c.21738945
Harari F, Sallsten G, Christensson A, . 2018. Blood lead levels and decreased kidney function in a population-based cohort. Am J Kidney Dis 72(3):381–389. 10.1053/j.ajkd.2018.02.358.29699886
Hardison DW, Ma LQ, Luongo T, . 2004. Lead contamination in shooting range soils from abrasion of lead bullets and subsequent weathering. Sci Total Environ 328:175–183. 10.1016/j.scitotenv.2003.12.013.15207582
Harlan WR. 1988. The relationship of blood lead levels to blood pressure in the U.S. population. Environ Health Perspect 78:9–13.3203651
Harlan WR, Landis JR, Schmouder RL, . 1985. Blood lead and blood pressure. Relationship in the adolescent and adult US population. J Am Med Assoc 253:530–534.
Harville EW, Hertz-Picciotto I, Schramm M, . 2005. Factors influencing the difference between maternal and cord blood lead. Occup Environ Med 62(4):263–269.15778260
Hauser R, Sergeyev O, Korrick S, . 2008. Association of blood lead levels with onset of puberty in Russian boys. Environ Health Perspect 116(7):976–980. 10.1289/ehp.10516.18629324
Havlena J, Kanarek MS, Coons M. 2009. Factors associated with the seasonality of blood lead levels among preschool Wisconsin children. WMJ 108(3):151–155.19552353
Hayes EB, McElvaine MD, Orbach HG, . 1994. Long-term trends in blood lead levels among children in Chicago: Relationship to air lead levels. Pediatrics 93(2):195–200.8121731
Haynes WM. 2014. Lead. In: CRC handbook of chemistry and physics. 95th ed. Boca Raton, FL: CRC Press, 4–20.
Haynes EN, Kalkwarf HJ, Hornung R, . 2003. Vitamin D receptor Fok1 polymorphism and blood lead concentration in children. Environ Health Perspect 111:1665–1669.14527848
He J, Ning H, Huang R. 2019. Low blood lead levels and attention-deficit hyperactivity disorder in children: A systematic review and meta-analysis. Environ Sci Pollut Res Int 26(18):17875–17884. 10.1007/s11356-017-9799-2.28780688
Healey N, Chettle DR, McNeill FE, . 2008. Uncertainties in the relationship between tibia lead and cumulative blood lead index. Environ Health Perspect 116(3):A109–110. 10.1289/ehp.10778.18335076
Healy MA, Harrison PG, Aslam M, . 1982. Lead sulphide and traditional preparations: Routes for ingestion, and solubility and reactions in gastric fluid. J Clin Hosp Pharm 7:169–173.7174831
Heard MJ, Chamberlain AC. 1982. Effect of minerals and food on uptake of lead from the gastrointestinal tract in humans. Hum Toxicol 1:411–415.7173926
Heard MJ, Chamberlain AC, Sherlock JC. 1983. Uptake of lead by humans and effect of minerals and food. Sci Total Environ 30:245–253. 10.1016/0048-9697(83)90016-5.6648511
Heard MJ, Wells AC, Newton D, . 1979. Human uptake and metabolism of tetra ethyl and tetra methyl lead vapour labelled with 203Pb. In: International conference on management and control of heavy metals in the environment. Edinburgh, United Kingdom CEP Consultants, Ltd., 103–108.
Hengstler JG, Bolm-Audorff U, Faldum A, . 2003. Occupational exposure to heavy metals: DNA damage induction and DNA repair inhibition prove co-exposures to cadmium, cobalt and lead as more dangerous than hitherto expected. Carcinogenesis 24(1):63–73.12538350
Hense HW, Filipiak B, Keil U. 1993. The association of blood lead and blood pressure in population surveys. Epidemiology 4:173–179.8452907
Heo Y, Lee BK, Ahn KD, . 2004. Serum IgE elevation correlates with blood lead levels in battery manufacturing workers. Hum Exp Toxicol 23(5):209–213. 10.1191/0960327104ht442oa.15222397
Hernandez-Avila M, Gonzalez-Cossio T, Palazuelos E, . 1996. Dietary and environmental determinants of blood and bone lead levels in lactating postpartum women living in Mexico City. Environ Health Perspect 104(10):1076–1082.8930549
Hernandez-Avila M, Smith D, Meneses F, . 1998. The influence of bone and blood lead on plasma lead levels in environmentally exposed adults. Environ Health Perspect 106(8):473–477.
Hernandez-Avila M, Villalpano CG, Palazuelos E, . 2000. Determinants of blood lead levels across the menopausal transition. Arch Environ Health 53:355–360.
Hernandez-Avila M, Peterson KE, Gonzalez-Cossio T, . 2002. Effect of maternal bone lead on length and head circumference of newborns and 1-month-old infants. Arch Environ Health 57(5):482–488.12641193
Hernández-Ochoa I, García-Vargas G, López-Carrillo L, . 2005. Low lead environmental exposure alters semen quality and sperm chromatin condensation in northern Mexico. Reprod Toxicol 20(2):221–228. 10.1016/j.reprotox.2005.01.007.15907657
Hernberg S, Nikkanen J, Mellin G, . 1970. δ-Aminolevulinic acid dehydrase as a measure of lead exposure. Arch Environ Health 21:140–145.5429999
Hertz-Picciotto I, Croft J. 1993. Review of the relation between blood lead and blood pressure. Epidemiol Rev 15(2):352–373.8174662
Hertz-Picciotto I, Schramm M, Watt-Morse M, . 2000. Patterns and determinants of blood lead during pregnancy. Am J Epidemiol 152:829–837.11085394
Hettiarachchi GM, Pierzynski GM, Oehme FW, . 2003. Treatment of contaminated soil with phosphorus and manganese oxide reduces lead absorption by Sprague-Dawley rats. J Environ Qual 32:1335–1345.12931889
Higgs FJ, Mielke HW, Brisco M. 1999. Soil lead at elementary public schools: Comparison between school properties and residential neighbourhoods of New Orleans. Environ Geochem Health 21(1):27–36.
Hill CP. 2011. Overview of internal corrosion impacts in drinking water distribution systems. In: Internal corrosion control in water distribution systems. American Water Works Association, 1–11.
Hilts SR. 2003. Effect of smelter emission reductions on children’s blood lead levels. Sci Total Environ 303(1–2):51–58.12568764
Hirata M, Kosaka H. 1993. Effects of lead exposure on neurophysiological parameters. Environ Res 63:60–69.8404776
Hogan K, Marcus A, Smith R, . 1998. Integrated exposure uptake biokinetic model for lead in children: Empirical comparisons with epidemiologic data. Environ Health Perspect 106(Suppl 6):1557–1567.9860915
Hogstedt C, Hane M, Agrell A, . 1983. Neuropsychological test results and symptoms among workers with well-defined long-term exposure to lead. Br J Ind Med 40:99–105.6824607
Holland MG, Cawthon D. 2016. ACOEM position statement. Workplace lead exposure. J Occup Environ Med 58(12):e371–e374.27930493
Holmgren GGS, Meyer MW, Chaney RL, . 1993. Cadmium, lead, zinc, copper, and nickel in agricultural soils of the United States of America. J Environ Qual 22:335–348.
Hon KL, Ching GK, Hung EC, . 2009. Serum lead levels in childhood eczema. Clin Exp Dermatol 34(7):e508–e509. 10.1111/j.1365-2230.2009.03596.x.19747335
Hon KLE, Wang SS, Hung ECW, . 2010. Serum levels of heavy metals in childhood eczema and skin diseases: Friends or foes. Pediatric Allergy and Immunology 21(5):831–836. 10.1111/j.1399-3038.2010.01022.x.20337961
Hong CD, Hanenson IB, Lerner S, . 1980. Occupational exposure to lead: Effects on renal function. Kidney Int 18:489–494.7230612
Hong YC, Kulkarni SS, Lim YH, . 2014. Postnatal growth following prenatal lead exposure and calcium intake. Pediatrics 134(6):1151–1159. 10.1542/peds.2014-1658.25422017
Hong SB, Im MH, Kim JW, . 2015. Environmental lead exposure and attention deficit/hyperactivity disorder symptom domains in a community sample of South Korean school-age children. Environ Health Perspect 123(3):271–276. 10.1289/ehp.1307420.25280233
Hopkins MR, Ettinger AS, Hernández-Avila M, . 2008. Variants in iron metabolism genes predict higher blood lead levels in young children. Environ Health Perspect 116(9):1261–1266. 10.1289/ehp.11233.18795173
Hoppin JA, Aro A, Hu H, . 1997. In vivo bone lead measurement in suburban teenagers. Pediatrics 100(3):365–370. 10.1542/peds.100.3.365.9282707
Hornung RW, Lanphear BP. 2014. The supralinear dose-response for environmental toxicants: A statistical artifact? Clin Toxicol (Phila) 52(2):88–90. 10.3109/15563650.2013.878946.24443997
Hornung RW, Lanphear BP, Dietrich KN. 2009. Age of greatest susceptibility to childhood lead exposure: A new statistical approach. Environ Health Perspect 117(8):1309–1312. 10.1289/ehp.0800426.19672413
Hryhorczuk DO, Rabinowitz MB, Hessl SM, . 1985. Elimination kinetics of blood lead in workers with chronic lead intoxication. Am J Ind Med 8(1):33–42. 10.1002/ajim.4700080105.3927718
Hsiao CL, Wu KH, Wan KS. 2011. Effects of environmental lead exposure on T-helper cell-specific cytokines in children. J Immunotoxicol 8(4):284–287. 10.3109/1547691X.2011.592162.21726182
Hsiao CY, Wu HI, Lai JS, . 2001. A longitudinal study of the effects of long-term exposure to lead among lead battery factory workers in Taiwan (1989–1999). Sci Total Environ 279(1):151–158.11712592
Hsieh LL, Liou SH, Chen YH, . 2000. Association between aminolevulinate dehydrogenase genotype and blood lead levels in Taiwan. J Occup Environ Med 42(2):151–155.10693075
Hsieh TJ, Chen YC, Li CW, . 2009. A proton magnetic resonance spectroscopy study of the chronic lead effect on the basal ganglion and frontal and occipital lobes in middle-age adults. Environ Health Perspect 117(6):941–945. 10.1289/ehp.0800187.19590687
Hsu PC, Chang HY, Guo YL, . 2009. Effect of smoking on blood lead levels in workers and role of reactive oxygen species in lead-induced sperm chromatin DNA damage. Fertil Steril 91(4):1096–1103. 10.1016/j.fertnstert.2008.01.005.18342860
Hu X, Ding Z. 2009. Lead/cadmium contamination and lead isotopic ratios in vegetables grown in peri-urban and mining/smelting contaminated sites in Nanjing, China. Bull Environ Contam Toxicol 82(1):80–84. 10.1007/s00128-008-9562-y.18795215
Hu H, Hashimoto D, Besser M. 1996b. Levels of lead in blood and bone of women giving birth in a Boston Hospital. Arch Environ Health 51(1):52–58.8629865
Hu H, Rabinowitz M, Smith D. 1998. Bone lead as a biological marker in epidemiologic studies of chronic toxicity: Conceptual paradigms. Environ Health Perspect 106(1):1–8. 10.1289/ehp.981061.9417769
Hu H, Aro A, Payton M, . 1996a. The relationship of bone and blood lead to hypertension. The normative aging study. J Am Med Assoc 275(15):1171–1176.
Hu J, Little J, Xu T, . 1999. Risk factors for meningioma in adults: A case-control study in northeast China. Int J Cancer 83:299–304.10495419
Hu H, Wu MT, Cheng Y, . 2001. The a-aminolevulinic acid dehydratase (ALAD) polymorphism and bone and blood lead levels in community-exposed men: The Normative Aging Study. Environ Health Perspect 109:827–832.
Hu H, Tellez-Rojo MM, Bellinger D, . 2006. Fetal lead exposure at each stage of pregnancy as a predictor of infant mental development. Environ Health Perspect 114(11):1730–1735. 10.1289/ehp.9067.17107860
Hu H, Shih R, Rothenberg S, . 2007. The epidemiology of lead toxicity in adults: Measuring dose and consideration of other methodologic issues. Environ Health Perspect 115(3):455–462. 10.1289/ehp.9783.17431499
Huang XP, Feng ZY, Zhai WL, . 1988. Chromosomal aberrations and sister chromatid exchanges in workers exposed to lead. Biomed Environ Sci 1:382–387.3268122
Huang J, Wu J, Li T, . 2011. Effect of exposure to trace elements in the soil on the prevalence of neural tube defects in a high-risk area of China. Biomed Environ Sci 24(2):94–101. 10.3967/0895-3988.2011.02.002.21565679
Huang S, Hu H, Sanchez BN, . 2016. Childhood blood lead levels and symptoms of Attention Deficit Hyperactivity Disorder (ADHD): A cross-sectional study of Mexican children. Environ Health Perspect 124(6):868–874. 10.1289/ehp.1510067.26645203
HUD. 2011. American health homes survey. Lead and arsenic findings. U.S. Department of Housing and Urban Development. https://portal.hud.gov/hudportal/documents/huddoc%3Fid=AHHS_Report.pdf. July 12, 2017.
HUD. 2017. Revised dust-lead action levels for risk assessment and clearance; clearance of porch floors. Washington, DC: U.S. Department of Housing and Urban Development. https://portal.hud.gov/hudportal/documents/huddoc?id=leaddustclearance.pdf. August 25, 2017.
Huel G, Sahuquillo J, Debotte G, . 2008. Hair mercury negatively correlates with calcium pump activity in human term newborns and their mothers at delivery. Environ Health Perspect 116(2):263–267. 10.1289/ehp.10381.18288328
Huh DA, Choi YH, Ji MS, . 2018. Comparison of pure-tone average methods for estimation of hearing loss caused by environmental exposure to lead and cadmium: Does the pure-tone average method which uses low-frequency ranges underestimate the actual hearing loss caused by environmental lead and cadmium exposure? Audiol Neurotol 23(5):259–269. 10.1159/000494049.
Hui CA. 2002. Lead distribution throughout soil, flora, and an invertebrate at a wetland skeet range. J Toxicol Environ Health A 65:1093–1107. 10.1080/152873902760125246.12167221
Hunt A, Johnson DL, Thornton I, . 1993. Apportioning the sources of lead in house dusts in the London borough of Richmond, England. Sci Total Environ 138(1–3):183–206.8259488
Huo X, Peng L, Qiu B, . 2014. ALAD genotypes and blood lead levels of neonates and children from e-waste exposure in Guiyu, China. Environ Sci Pollut Res Int 21(10):6744–6750. 10.1007/s11356-014-2596-2.24522397
Hursh JB, Suomela J. 1968. Absorption of 212Pb from the gastrointestinal tract of man. Acta Radiol Ther Phys Biol 7(2):108–120. 10.3109/02841866809133184.5710367
Hursh J, Mercer T. 1970. Measurement of 212Pb loss rate from human lungs. J Appl Physiol 28(3):268–274.5414756
Hursh JB, Schraub A, Sattler EL, . 1969. Fate of 212Pb inhaled by human subjects. Health Phys 16:257–267.5787740
Hursh JB, Clarkson TW, Miles EF, . 1989. Percutaneous absorption of mercury vapor by man. Arch Environ Health 44(2):120–127.2494955
Hwang YH, Chiang HY, Yen-Jean MC, . 2009. The association between low levels of lead in blood and occupational noise-induced hearing loss in steel workers. Sci Total Environ 408(1):43–49. 10.1016/j.scitotenv.2009.09.016.19818992
Hytten F. 1985. Blood volume changes in normal pregnancy. Clin Haematol 14(3):601–612.
IARC. 1987. Lead and lead compounds. In: IARC monographs on the evaluation of carcinogenic risks to humans. Supplement 7. Overall evaluations of carcinogenicity: An updating of IARC monographs volumes 1 to 42. Lyon, France: International Agency for Research on Cancer, 230–232. http://monographs.iarc.fr/ENG/Monographs/suppl7/Suppl7-95.pdf. May 4, 2017.
IARC. 2006. IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 87. Inorganic and organic lead compounds. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Monographs/vol87/mono87.pdf. May 4, 2017.
IARC. 2019. Agents classified by the IARC Monographs, Volumes 1–124. Lyon, France: International Agency for Research on Cancer. https://monographs.iarc.fr/list-of-classifications. September 2, 2019.
ICRP. 1994. Human respiratory tract model for radiological protection. International Commission on Radiological Protection. 36–53; 72–77; Annex F 415-432.
Ignasiak Z, Slawinska T, Rozek K, . 2006. Lead and growth status of schoolchildren living in the copper basin of south-western Poland: Differential effects on bone growth. Ann Hum Biol 33(4):401–414. 10.1080/03014460600730752.17060065
Iijima K, Otake T, Yoshinaga J, . 2007. Cadmium, lead, and selenium in cord blood and thyroid hormone status of newborns. Biol Trace Elem Res 119(1):10–18. 10.1007/s12011-007-0057-1.17914214
Inskip MJ, Franklin CA, Baccanale CL, . 1996. Measurement of the flux of lead from bone to blood in a nonhuman primate (Macaca fascicularis) by sequential administration of stable lead isotopes. Fundam Appl Toxicol 33:235–245.8921342
Ionescu JG, Novotny J, Stejskal V, . 2007. Breast tumours strongly accumulate transition metals. Maedica 2(1):5–9.
Irgens A, Kruger K, Skorve AH, . 1998. Reproductive outcome in offspring of parents occupationally exposed to lead in Norway. Am J Ind Med 34(5):431–437. 10.1002/(sici)1097-0274(199811)34:5<431::aid-ajim3>3.0.co;2-t.9787846
IRIS. 2002. Tetraethyl lead; CASRN 78-00-2. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0109_summary.pdf. May 4, 2017.
IRIS. 2004. Lead and compounds (inorganic); CASRN 7439-92-1. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0277_summary.pdf. May 4, 2017.
Irvine G, Doyle JR, White PA, . 2014. Soil ingestion rate determination in a rural population of Alberta, Canada practicing a wilderness lifestyle. Sci Total Environ 470–471:138–146. 10.1016/j.scitotenv.2013.09.037.
Irwinda R, Wibowo N, Putri AS. 2019. The concentration of micronutrients and heavy metals in maternal serum, placenta, and cord blood: A cross-sectional study in preterm birth. J Pregnancy 2019:5062365. 10.1155/2019/5062365.30693107
Iwata T, Yano E, Karita K, . 2005. Critical dose of lead affecting postural balance in workers. Am J Ind Med 48(5):319–325. 10.1002/ajim.20220.16216016
Jackson LW, Cromer BA, Panneerrselvamm A. 2010. Association between bone turnover, micronutrient intake, and blood lead levels in pre- and postmenopausal women, NHANES 1999-2002. Environ Health Perspect 118(11):1590–1596.20688594
Jackson LW, Howards PP, Wactawski-Wende J, . 2011. The association between cadmium, lead and mercury blood levels and reproductive hormones among healthy, premenopausal women. Hum Reprod 26(10):2887–2895. 10.1093/humrep/der250.21778284
Jacobs DE. 2012. Lead. In: Patty’s toxicology. John Wiley & Sons, Inc., 381–426. 10.1002/0471435139.tox034.pub2.
Jaeger RJ, Weiss AL, Manton WI. 1998. Isotopic ratio analysis in residential lead-based paint and associated surficial dust. J Toxicol Clin Toxicol 36(7):691–703.9865237
Jaffe EK, Volin M, Bronson-Mullins CR, . 2000. An artificial gene for human porphobilinogen synthase allows comparison of an allelic variation implicated in susceptibility to lead poisoning. J Biol Chem 275(4):2619–2626.10644722
Jaffe EK, Martins J, Li J, . 2001. The molecular mechanism of lead inhibition of human porphobilinogen synthase. J Biol Chem 276(2):1531–1537. 10.1074/jbc.M007663200.11032836
Jain RB. 2013a. Effect of pregnancy on the levels of blood cadmium, lead, and mercury for females aged 17-39 years old: Data from National Health and Nutrition Examination Survey 2003-2010. J Toxicol Environ Health A 76(1):58–69. 10.1080/15287394.2012.722524.23151210
Jain RB. 2013b. Effect of pregnancy on the levels of urinary metals for females aged 17-39 years old: Data from National Health and Nutrition Examination Survey 2003-2010. J Toxicol Environ Health A 76(2):86–97.23294297
Jain NB, Potula V, Schwartz J, . 2007. Lead levels and ischemic heart disease in a prospective study of middle-aged and elderly men: The VA Normative Aging Study. Environ Health Perspect 115(6):871–875. 10.1289/ehp.9629.17589593
James HM, Hilburn ME, Blair JA. 1985. Effects of meals and meal times on uptake of lead from the gastrointestinal tract in humans. Hum Toxicol 4:401–407.4018820
James AC, Stahlhofen W, Rudolf G, . 1994. Deposition of inhaled particles. Ann ICRP 24(1–3):231–299.
Janakiraman V, Ettinger A, Mercado-Garcia A, . 2003. Calcium supplements and bone resorption in pregnancy: A randomized crossover trial. Am J Prev Med 24(3):260–264.12657345
Janin Y, Couinaud C, Stone A, . 1985. The “Lead-induced colic” syndrome in lead intoxication. Surg Annu 17:287–307.3156432
Jannuzzi AT, Alpertunga B. 2016. Evaluation of DNA damage and DNA repair capacity in occupationally lead-exposed workers. Toxicol Ind Health 32(11):1859–1865. 10.1177/0748233715590919.26149192
Jasso-Pineda Y, Diaz-Barriga F, Calderon J, . 2012. DNA damage and decreased DNA repair in individuals exposed to arsenic and lead in a mining site. Biol Trace Elem Res 146(2):141–149.22016027
Jedrychowski W, Perera FP, Jankowski J, . 2009. Very low prenatal exposure to lead and mental development of children in infancy and early childhood: Krakow prospective cohort study. Neuroepidemiology 32(4):270–278. 10.1159/000203075.19223686
Jedrychowski W, Perera F, Maugeri U, . 2011. Intrauterine exposure to lead may enhance sensitization to common inhalant allergens in early childhood: A prospective prebirth cohort study. Environ Res 111(1):119–124. 10.1016/j.envres.2010.11.002.21094490
Jelliffe-Pawlowski LL, Miles SQ, Courtney JG, . 2006. Effect of magnitude and timing of maternal pregnancy blood lead (Pb) levels on birth outcomes. J Perinatol 26(3):154–162. 10.1038/sj.jp.7211453.16453008
Jemal A, Graubard BI, Devesa SS, . 2002. The association of blood lead level and cancer mortality among whites in the United States. Environ Health Perspect 110(4):325–329.11940448
Jhun MA, Hu H, Schwartz J, . 2015. Effect modification by vitamin D receptor genetic polymorphisms in the association between cumulative lead exposure and pulse pressure: A longitudinal study. Environ Health 14:5. 10.1186/1476-069x-14-5.25582168
Ji JS, Elbaz A, Weisskopf MG. 2013. Association between blood lead and walking speed in the National Health and Nutrition Examination Survey (NHANES 1999-2002). Environ Health Perspect 121(6):711–716. 10.1289/ehp.1205918.23603014
Ji JS, Schwartz J, Sparrow D, . 2014. Occupational determinants of cumulative lead exposure: Analysis of bone lead among men in the VA normative aging study. J Occup Environ Med 56(4):435–440. 10.1097/jom.0000000000000127.24709766
Ji JS, Power MC, Sparrow D, . 2015. Lead exposure and tremor among older men: The VA normative aging study. Environ Health Perspect 123(5):445–450. 10.1289/ehp.1408535.25633720
Ji Y, Hong X, Wang G, . 2018. A prospective birth cohort study on early childhood lead levels and attention deficit hyperactivity disorder: New insight on sex differences. J Pediatr 199:124–131.e128. 10.1016/j.jpeds.2018.03.076.29752174
Jiang YM, Long LL, Zhu XY, . 2008. Evidence for altered hippocampal volume and brain metabolites in workers occupationally exposed to lead: A study by magnetic resonance imaging and 1H magnetic resonance spectroscopy. Toxicol Lett 181(2):118–125. 10.1016/j.toxlet.2008.07.009.18692119
Jin CW, Zhang SJ, He YF, . 2005. Lead contamination in tea garden soils and factors affecting its bioavailability. Chemosphere 59:1151–1159. 10.1016/j.chemosphere.2004.11.058.15833489
Jin YP, Liao YJ, Lu CW, . 2006. Health effects in children aged 3-6 years induced by environmental lead exposure. Ecotoxicol Environ Saf 63(2):313–317. 10.1016/j.ecoenv.2005.05.011.16045986
Jin C, Li Y, Li YL, . 2008. Blood lead: Its effect on trace element levels and iron structure in hemoglobin. Nucl Instrum Methods Phys Res B 266(16):3607–3613. 10.1016/j.nimb.2008.05.087.
Jing J, Thapa S, Delhey L, . 2019. The relation of blood lead and QRS-T angle in American adults. Arch Environ Occup Health 74(5):287–291. 10.1080/19338244.2018.1488674.29920162
Johansen P, Pedersen HS, Asmund G, . 2006. Lead shot from hunting as a source of lead in human blood. Environ Pollut 142:93–97.16280190
Johnson DL, Bretsch JK. 2002. Soil lead and children’s blood lead levels in Syracuse, NY, USA. Environ Geochem Health 24:375–385.
Johnson DL, McDade K, Griffith D. 1996. Seasonal variation in paediatric blood lead levels in Syracuse, NY, USA. Environ Geochem Health 18(2):81–88. 10.1007/bf01771136.24194379
Jones SR, Atkin P, Holroyd C, . 2007. Lung cancer mortality at a UK tin smelter. Occup Med (Lond) 57(4):238–245. 10.1093/occmed/kql153.17437956
Joo H, Lim MH, Ha M, . 2017. Secondhand smoke exposure and low blood lead levels in association with attention-deficit hyperactivity disorder and its symptom domain in children: A community-based case-control study. Nicotine Tob Res 19(1):94–101. 10.1093/ntr/ntw152.27613950
Joo H, Choi JH, Burm E, . 2018. Gender difference in the effects of lead exposure at different time windows on neurobehavioral development in 5-year-old children. Sci Total Environ 615:1086–1092. 10.1016/j.scitotenv.2017.10.007.29751412
Jorgensen S, Willems M. 1987. The fate of lead of soil: The transformation of lead pellets in shooting-range soils. Ambio 16(1):11–15.
Jorgensen TH, De Backer O, Gerds TA, . 2018. Immediate post-procedural 12-lead electrocardiography as predictor of late conduction defects after transcatheter aortic valve replacement. JACC Cardiovasc Interv 11(15):1509–1518. 10.1016/j.jcin.2018.04.011.30093055
Joseph CLM, Havstad S, Ownby DR, . 2005. Blood lead level and risk of asthma. Environ Health Perspect 113(7):900–904. 10.1289/ehp.7453.16002380
Juhasz AL, Weber J, Smith E. 2011. Impact of soil particle size and bioaccessibility on children and adult lead exposure in peri-urban contaminated soil. J Hazard Mater 186(2–3):1870–1879. 10.1016/j.jhazmat.2010.12.095.21247691
Juhasz AL, Weber J, Smith E, . 2009. Evaluation of SBRC-gastric and SBRC-intestinal methods for the prediction of in vivo relative lead bioavailability in contaminated soils. Environ Sci Technol 43(12):4503–4509. 10.1021/es803238u.19603669
Juhasz AL, Scheckel KG, Betts AR, . 2016. Predictive capabilities of in vitro assays for estimating Pb relative bioavailability in phosphate amended soils. Environ Sci Technol 50(23):13086–13094. 10.1021/acs.est.6b04059.27934280
Jurgens BC, Parkhurst DL, Belitz K. 2019. Assessing the lead solubility potential of untreated groundwater of the United States. Environ Sci Technol 53(6):3095–3103. 10.1021/acs.est.8b04475.30835445
Jusko TA, Lockhart DW, Sampson PD, . 2006. Response to: “What is the meaning of non-linear dose-response relationships between blood lead concentrations and IQ?”. Neurotoxicology 27(6):1123–1125. 10.1016/j.neuro.2006.09.004.
Jusko TA, Henderson CR, Lanphear BP, . 2008. Blood lead concentrations <10 µg/dL and child intelligence at 6 years of age. Environ Health Perspect 116(2):243–248. 10.1289/ehp.10424.18288325
Kahn LG, Liu X, Rajovic B, . 2014. Blood lead concentration and thyroid function during pregnancy: Results from the Yugoslavia prospective study of environmental lead exposure. Environ Health Perspect 122(10):1134–1140. 10.1289/ehp.1307669.24866691
Kalahasthi R, Barman T. 2016. Effect of lead exposure on the status of reticulocyte count indices among workers from lead battery manufacturing plant. Toxicol Res 32(4):281–287. 10.5487/tr.2016.32.4.281.27818730
Kamel F, Umbach DM, Munsat TL, . 2002. Lead exposure and amyotrophic lateral sclerosis. Epidemiology 13:311–319.11964933
Kang HG, Jeong SH, Cho MR, . 2009. Time-dependent changes in lead and delta-aminolevulinic acid after subchronic lead exposure in rats. Hum Exp Toxicol 28(10):647–654. 10.1177/0960327109107046.19755440
Kang GH, Uhm JY, Choi YG, . 2018. Environmental exposure of heavy metal (lead and cadmium) and hearing loss: Data from the Korea National Health and Nutrition Examination Survey (KNHANES 2010-2013). Ann Occup Environ Med 30:22. 10.1186/s40557-018-0237-9.29692915
Kapuku GK, Harshfield GA, Davis HC, . 2006. Early markers of cardiovascular disease. Vascul Pharmacol 45(5):277–280. 10.1016/j.vph.2006.08.009.17011834
Karakulak UN, Yilmaz OH, Tutkun E, . 2017. Evaluation of the ambulatory arterial stiffness index in lead-exposed workers. Anatol J Cardiol 18(1):10–14. 10.14744/AnatolJCardiol.2017.7170.28554985
Karakulak UN, Okutucu S, Lokman U, . 2019. Evaluation of erectile dysfunction and left ventricular diastolic parameters in lead exposed workers. Acta Cardiol Sin 35(1):75–84. 10.6515/acs.201901_35(1).20180716a.30713402
Karimooy HN, Mood MB, Hosseini M, . 2010. Effects of occupational lead exposure on renal and nervous system of workers of traditional tile factories in Mashhad (northeast of Iran). Toxicol Ind Health 26(9):633–638. 10.1177/0748233710377774.20630982
Karita K, Yano E, Dakeishi M, . 2005. Benchmark dose of lead inducing anemia at the workplace. Risk Anal 25(4):957–962. 10.1111/j.1539-6924.2005.00652.x.16268943
Karmaus W, Brooks KR, Nebe T, . 2005. Immune function biomarkers in children exposed to lead and organochlorine compounds: A cross-sectional study. Environ Health 4(1):5. 10.1186/1476-069X-4-5.15831097
Kasperczyk A, Kasperczyk S, Horak S, . 2008. Assessment of semen function and lipid peroxidation among lead exposed men. Toxicol Appl Pharmacol 228(3):378–384. 10.1016/j.taap.2007.12.024.18252257
Kasperczyk S, Blaszczyk I, Dobrakowski M, . 2013. Exposure to lead affects male biothiols metabolism. Ann Agric Environ Med 20(4):721–725.24364442
Kasperczyk A, Dobrakowski M, Czuba ZP, . 2015. Environmental exposure to lead induces oxidative stress and modulates the function of the antioxidant defense system and the immune system in the semen of males with normal semen profile. Toxicol Appl Pharmacol 284(3):339–344. 10.1016/j.taap.2015.03.001.25771126
Kasprzak KS, Hoover KL, Poirier LA. 1985. Effects of dietary calcium acetate on lead subacetate carcinogenicity in kidneys of male Sprague-Dawley rats. Carcinogenesis 6(2):279–282.3971492
Kasuba V, Rozgaj R, Milic M, . 2012. Evaluation of genotoxic effects of lead in pottery-glaze workers using micronucleus assay, alkaline comet assay and DNA diffusion assay. Int Arch Occup Environ Health 85(7):807–818. 10.1007/s00420-011-0726-4.22160131
Kauppinen T, Riala R, Seitsamo J, . 1992. Primary liver cancer and occupational exposure. Scand J Work Environ Health 18(1):18–25.
Kayaalti Z, Yavuz I, Soylemez E, . 2015a. Evaluation of DNA damage using 3 comet assay parameters in workers occupationally exposed to lead. Arch Environ Occup Health 70(3):120–125. 10.1080/19338244.2013.787964.24965324
Kayaalti Z, Kaya-Akyuzlu D, Soylemez E, . 2015b. Maternal hemochromatosis gene H63D single-nucleotide polymorphism and placental lead levels. Environ Res 140:456–461.25981872
Kayaalti Z, Sert S, Kaya-Akyuzlu D, . 2016. Association between delta-aminolevulinic acid dehydratase polymorphism and placental lead levels. Environ Toxicol Pharmacol 41:147–151. 10.1016/j.etap.2015.11.017.26701682
Kaye WE, Novotny TE, Tucker M. 1987. New ceramics-related industry implicated in elevated blood lead levels in children. Arch Environ Health 42(2):161–164.3606214
Kazi TG, Shah F, Shaikh HR, . 2014. Exposure of lead to mothers and their new born infants, residents of industrial and domestic areas of Pakistan. Environ Sci Pollut Res Int 21(4):3021–3030. 10.1007/s11356-013-2223-7.24174313
Kehoe RA. 1987. Studies of lead administration and elimination in adult volunteers under natural and experimentally induced condition over extended periods of time. Food Chem Toxicol 25(6):425–494.
Kehoe RA, Thamann F. 1931. The behavior of lead in the animal organism, II. Tetraethyl lead. Am J Hyg 13:478–498.
Kelly RS, Lundh T, Porta M, . 2013. Blood erythrocyte concentrations of cadmium and lead and the risk of B-cell non-Hodgkin’s lymphoma and multiple myeloma: A nested case-control study. PLoS ONE 8(11):e81892. 10.1371/journal.pone.0081892.24312375
Kemp FW, Neti PVSV, Howell RW, . 2007. Elevated blood lead concentrations and vitamin D deficiency in winter and summer in young urban children. Environ Health Perspect 115(4):630–635. 10.1289/ehp.9389.17450235
Kerper LE, Hinkle PM. 1997a. Lead uptake in brain capillary endothelial cells: Activation by calcium store depletion. Toxicol Appl Pharmacol 146(1):127–133.9299604
Kerper LE, Hinkle PM. 1997b. Cellular uptake of lead is activated by depletion of intracellular calcium stores. J Biol Chem 272(13):8346–8352.9079658
Kerr BT, Ochs-Balcom HM, Lopez P, . 2019. Effects of ALAD genotype on the relationship between lead exposure and anthropometry in a Cohort of Mexican children. Environ Res 170:65–72. 10.1016/j.envres.2018.12.003.30557693
Khalil N. 2010. Re: Blood lead mortality study: Khalil et al., 2009. Integrated science assessment for lead: Supporting documents: Supplemental data from Dr. Khalil. Docket ID: EPA-HQ-ORD-2011-00511. http://www.regulations.gov/#!documentDetail;D=EPA-HQ-ORD-2011-0051-0006. February 25, 2020.
Khalil N, Cauley JA, Wilson JW, . 2008. Relationship of blood lead levels to incident nonspine fractures and falls in older women: The Study of Osteoporotic Fractures. J Bone Miner Res 23(9):1417–1425. 10.1359/jbmr.080404.18410230
Khalil N, Wilson JW, Talbott EO, . 2009. Association of blood lead concentrations with mortality in older women: A prospective cohort study. Environmental Health: A Global Access Science Source 8:15. 10.1186/1476-069x-8-15.19344498
Khan DH, Frankland B. 1983. Chemical forms of cadmium and lead in some contaminated soils. Environ Pollut Ser B 6:15–31.
Khan DA, Qayyum S, Saleem S, . 2008. Lead-induced oxidative stress adversely affects health of the occupational workers. Toxicol Ind Health 24(9):611–618. 10.1177/0748233708098127.19106128
Khan D, Qayyum S, Saleem S, . 2010a. Lead exposure and its adverse health effects among occupational worker’s children. Toxicol Ind Health 26(8):497. 10.1177/0748233710373085.20538706
Khan MI, Ahmad I, Mahdi AA, . 2010b. Elevated blood lead levels and cytogenetic markers in buccal epithelial cells of painters in India: Genotoxicity in painters exposed to lead containing paints. Environ Sci Pollut Res Int 17(7):1347–1354. 10.1007/s11356-010-0319-x.20300868
Kieltucki J, Dobrakowski M, Pawlas N, . 2017. The analysis of QT interval and repolarization morphology of the heart in chronic exposure to lead. Hum Exp Toxicol 36(10):1081–1086. 10.1177/0960327116680277.27903879
Kim KN, Kwon HJ, Hong YC. 2016. Low-level lead exposure and autistic behaviors in school-age children. Neurotoxicology 53:193–200. 10.1016/j.neuro.2016.02.004.26877220
Kim R, Hu H, Rotnitzky A, . 1995. A longitudinal study of chronic lead exposure and physical growth in Boston children. Environ Health Perspect 103(10):952–957.8529592
Kim R, Rotnitzky A, Sparrow D, . 1996a. A longitudinal study of low-level lead exposure and impairment of renal function: The normative aging study. J Am Med Assoc 275(15):1177–1181.
Kim R, Hu H, Rotnitzky A, . 1996b. Longitudinal relationship between dentin lead levels in childhood and bone lead levels in young adulthood. Arch Environ Health 51(5):375–382.8896387
Kim R, Landrigan C, Mossmann P, . 1997. Age and secular trends in bone lead levels in middle-aged and elderly men: Three-year longitudinal follow-up in the normative aging study. Am J Epidemiol 146(4):586–591.9326437
Kim HS, Lee SS, Lee GS, . 2004. The protective effect of delta-aminolevulinic acid dehydratase 1-2 and 2-2 isozymes against blood lead with higher hematologic parameters. Environ Health Perspect 112:538–541.15064157
Kim JH, Lee KH, Yoo DH, . 2007. GSTM1 and TNF-alpha gene polymorphisms and relations between blood lead and inflammatory markers in a non-occupational population. Mutat Res 629(1):32–39. 10.1016/j.mrgentox.2007.01.004.17298885
Kim S, Arora M, Fernandez C, . 2013a. Lead, mercury, and cadmium exposure and attention deficit hyperactivity disorder in children. Environ Res 126:105–110.24034783
Kim Y, Ha EH, Park H, . 2013b. Prenatal lead and cadmium co-exposure and infant neurodevelopment at 6 months of age: The Mothers and Children’s Environmental Health (MOCEH) study. Neurotoxicology 35:15–22. 10.1016/j.neuro.2012.11.006.23220728
Kim MG, Ryoo JH, Chang SJ, . 2015. Blood Lead levels and cause-specific mortality of inorganic lead-exposed workers in South Korea. PLoS ONE 10(10):e0140360. 10.1371/journal.pone.0140360.26469177
Kim YS, Ha M, Kwon HJ, . 2017a. Association between low blood lead levels and increased risk of dental caries in children: A cross-sectional study. BMC Oral Health 17(1):42. 10.1186/s12903-017-0335-z.28086936
Kim JH, Park Y, Kim SK, . 2017b. Timing of an accelerated body mass increase in children exposed to lead in early life: A longitudinal study. Sci Total Environ 584–585:72–77. 10.1016/j.scitotenv.2017.01.122.
Kimber I, Stonard MD, Gidlow DA, . 1986. Influence of chronic low-level exposure to lead on plasma immunoglobulin concentration and cellular immune function in man. Int Arch Occup Environ Health 57:117–125.3949395
King M, Ramachandran V, Prengaman RD, . 2014. Lead and lead alloys. In: Kirk-Othmer encyclopedia of chemical technology. Hoboken, NJ: Wiley-Blackwell. 10.1002/0471238961.1205010411091407.a01.pub3.
Kirkby H, Gyntelberg F. 1985. Blood pressure and other cardiovascular risk factors of long-term exposure to lead. Scand J Work Environ Health 11(1):15–19. 10.5271/sjweh.2259.3992216
Klaassen C. 2001. Heavy metals and heavy metal antagonists. In: Hardman JG, Limbard LE, eds. Goodman and Gilman’s The pharmacological basis of therapeutics. 10th ed. New York, NY: McGraw-Hill Companies, 1851–1875.
Klaassen CD, Shoeman DW. 1974. Biliary excretion of lead in rats, rabbits and dogs. Toxicol Appl Pharmacol 29:434–446.4283706
Koh DS, Koh GC. 2007. The use of salivary biomarkers in occupational and environmental medicine. Occup Environ Med 64:202–210. 10.1136/oem.2006.026567.17339296
Koller LD, Kerkvliet NI, Exon JH. 1985. Neoplasia induced in male rats fed lead acetate, ethyl urea, and sodium nitrite. Toxicol Pathol 13(1):50–57.4035262
Kordas K, Canfield RL, Lopez P, . 2006. Deficits in cognitive function and achievement in Mexican first-graders with low blood lead concentrations. Environ Res 100(3):371–386. 10.1016/j.envres.2005.07.007.16169549
Kordas K, Ettinger AS, Lamadrid-Figueroa H, . 2009. Methylenetetrahydrofolate reductase (MTHFR) C677T, A1298C and G1793A genotypes, and the relationship between maternal folate intake, tibia lead and infant size at birth. Br J Nutr 102(6):907–914. 10.1017/s0007114509318280.19338708
Kordas K, Queirolo EL, Ettinger AS, . 2010. Prevalence and predictors of exposure to multiple metals in preschool children from Monetvideo, Uraguay. Sci Total Environ 408:4488–4494.20619443
Kordas K, Ettinger AS, Bellinger DC, . 2011. A dopamine receptor (DRD2) but not dopamine transporter (DAT1) gene polymorphism is associated with neurocognitive development of Mexican preschool children with lead exposure. J Pediatr 159(4):638–643. 10.1016/j.jpeds.2011.03.043.21592505
Korrick SA, Hunter DJ, Rotnitzky A, . 1999. Lead and hypertension in a sample of middle-aged women. Am J Public Health 89(3):330–335.10076481
Korrick SA, Schwartz J, Tsaih SW, . 2002. Correlates of bone and blood lead levels among middle-aged and elderly women. Am J Epidemiol 156(4):335–343.12181103
Kosnett MJ. 2001. Lead. In: Ford M, Delaney KA, Ling L, ., eds. Clinical toxicology. St. Louis, MO: WB Saunders, 723–736.
Kosnett MJ. 2005. Lead. In: Brent J, Wallace KL, Burkhart KK, ., eds. Critical care toxicology: Diagnosis and management of the critically poisoned patient. Philadelphia, PA: Elsevier Mosby, 821–836.
Kosnett MJ, Becker CE, Osterloh JD, . 1994. Factors influencing bone lead concentration in a suburban community assessed by noninvasive K x-ray fluorescence. J Am Med Assoc 271(3):197–203.
Kosnett MJ, Wedeen RP, Rothenberg SJ, . 2007. Recommendations for medical management of adult lead exposure. Environ Health Perspect 115(3):463–471. 10.1289/ehp.9784.17431500
Kostial K, Kello D, Jugo S, . 1978. Influence of age on metal metabolism and toxicity. Environ Health Perspect 25:81–86.720306
Koyashiki GAK, Paoliello MMB, Matsuo T, . 2010. Lead levels in milk and blood from donors to the breast milk bank in southern Brazil. Environ Res 110:265–271.20079491
Kresovich JK, Argos M, Turyk ME. 2015. Associations of lead and cadmium with sex hormones in adult males. Environ Res 142:25–33. 10.1016/j.envres.2015.05.026.26093239
Krieg EF. 2007. The relationships between blood lead levels and serum follicle stimulating hormone and luteinizing hormone in the third national health and nutrition examination survey. Environ Res 104(3):374–382. 10.1016/j.envres.2006.09.009.17084837
Krieg EF, Chrislip DW, Crespo CJ, . 2005. The relationship between blood lead levels and neurobehavioral test performance in NHANES III and related occupational studies. Public Health Rep 120(3):240–251.16134563
Krieg EF, Butler MA, Chang M, . 2009. Lead and cognitive function in ALAD genotypes in the Third National Health and Nutrition Examination Survey. Neurotoxicol Teratol 31(6):364–371. 10.1016/j.ntt.2009.08.003.19686844
Krieg EF, Butler MA, Chang M, . 2010. Lead and cognitive function in VDR genotypes in the Third National Health and Nutrition Examination Survey. Neurotoxicol Teratol 32(2):262–272. 10.1016/j.ntt.2009.12.004.20006704
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kristal-Boneh E, Coller D, Froom P, . 1999. The association between occupational lead exposure and serum cholesterol and lipoprotein levels. Am J Public Health 89(7):1083–1087.10394320
Kromhout D. 1988. Blood lead and coronary heart disease risk among elderly men in Zutphen, The Netherlands. Environ Health Perspect 78:43–46.3203644
Kromhout D, Wibowo A, Herber R, . 1985. Trace metals and coronary heart disease risk indicators in 152 elderly men (the Zutphen Study). Am J Epidemiol 122(3):378–385.4025288
Krueger WS, Wade TJ. 2016. Elevated blood lead and cadmium levels associated with chronic infections among non-smokers in a cross-sectional analysis of NHANES data. Environ Health 15(1):16. 10.1186/s12940-016-0113-4.26864738
Kumar BD, Krishnaswamy K. 1995. Detection of occupational lead nephropathy using early renal markers. J Toxicol Clin Toxicol 33(4):331–335.7629899
Kuruvilla A, Pillay VV, Adhikari P, . 2006. Clinical manifestations of lead workers of Mangalore, India. Toxicol Ind Health 22(9):405–413.17533812
Lagerkvist BJ, Ekesrydh S, Englyst V, . 1996. Increased blood lead and decreased calcium levels during pregnancy: A prospective study of Swedish women living near a smelter. Am J Public Health 86(9):1247–1252.8806376
LaGoy PK. 1987. Estimated soil ingestion rates for use in risk assessment. Risk Anal 7(3):355–359.3317565
Laidlaw MAS, Filippelli GM. 2008. Resuspension of urban soils as a persistent source of lead poisoning in children: A review and new directions. Appl Geochem 23(8):2021–2039. 10.1016/j.apgeochem.2008.05.009.
Laidlaw MA, Mielke HW, Filippelli GM, . 2005. Seasonality and children’s blood lead levels: Developing a predictive model using climatic variables and blood lead data from Indianapolis, Indiana, Syracuse, New York, and New Orleans, Louisiana (USA). Environ Health Perspect 113(6):793–800.15929906
Laidlaw MAS, Zahran S, Mielke HW, . 2012. Re-suspension of lead contaminated urban soil as a dominant source of atmospheric lead in Birmingham, Chicago, Detroit and Pittsburgh, USA. Atmos Environ 49:302–310. 10.1016/j.atmosenv.2011.11.030.
La-Llave-Leon O, Mendez-Hernandez EM, Castellanos-Juarez FX, . 2017. Association between blood lead levels and delta-aminolevulinic acid dehydratase in pregnant women. Int J Environ Res Public Health 14(4):432. 10.3390/ijerph14040432.28420209
Lamadrid-Figueroa H, Téllez-Rojo MM, Hernández-Cadena L, . 2006. Biological markers of fetal lead exposure at each stage of pregnancy. J Toxicol Environ Health A 69(19):1781–1796. 10.1080/15287390600630195.16905508
Lamadrid-Figueroa H, Téllez-Rojo MM, Hernández-Avila M, . 2007. Association between the plasma/whole blood lead ratio and history of spontaneous abortion: A nested cross-sectional study. BMC Pregnancy Childbirth 7:22. 10.1186/1471-2393-7-22.17900368
Lamb MR, Janevic T, Liu X, . 2008. Environmental lead exposure, maternal thyroid function, and childhood growth. Environ Res 106(2):195–202. 10.1016/j.envres.2007.09.012.17988663
Lancranjan I, Popescu HI, Gavanescu O, . 1975. Reproductive ability of workmen occupationally exposed to lead. Arch Environ Health 30:396–401.1155972
Landrigan PJ. 1989. Toxicity of lead at low dose - Editorial. Br J Ind Med 46:593–596.2675956
Landrigan PJ, Baker EL, Feldman RG, . 1976. Increased lead absorption with anemia and slowed nerve conduction in children near a lead smelter. J Pediatr 89(6; 6):904–910.993916
Langlois P, Smith L, Fleming S, . 1996. Blood lead levels in Toronto children and abatement of lead-contaminated soil and house dust. Arch Environ Health 51(1):59–67.8629866
Lanphear BP, Roghmann KJ. 1997. Pathways of lead exposure in urban children. Environ Res 74:67–73.9339217
Lanphear BP, Weitzman M, Eberly S. 1996a. Racial differences in urban children’s environmental exposures to lead. Am J Public Health 86:1460–1463.8876521
Lanphear BP, Eberly S, Howard CR. 2000b. Long-term effect of dust control on blood lead concentrations. Pediatrics 106(4):1–4.10878140
Lanphear BP, Weitzman M, Winter NL, . 1996b. Lead-contaminated house dust and urban children’s blood lead levels. Am J Public Health 86:1416–1421.8876511
Lanphear BP, Burgoon DA, Rust SW, . 1998a. Environmental exposures to lead and urban children’s blood lead levels. Environ Res Section A 76:120–130.
Lanphear BP, Byrd RS, Auinger P, . 1998b. Community characteristics associated with elevated blood lead levels in children. Pediatrics 101(2):264–271.9445502
Lanphear BP, Dietrich K, Auinger P, . 2000a. Cognitive deficits associated with blood lead concentrations< 10 microg/dL in US children and adolescents. Public Health Rep 115(6):521–529.11354334
Lanphear BP, Hornung R, Khoury J, . 2005. Low-level environmental lead exposure and children’s intellectual function: An international pooled analysis. Environ Health Perspect 113(7):894–899.16002379
Lanphear BP, Rauch S, Auinger P, . 2018. Low-level lead exposure and mortality in US adults: A population-based cohort study. Lancet Public Health 3(4):e177–e184. 10.1016/S2468-2667(18)30025-2.29544878
Lanphear BP, Hornung R, Khoury J, . 2019. Erratum: “Low-level environmental lead exposure and children’s intellectual function: An international pooled analysis”. Environ Health Perspect 127(9):99001. 10.1289/ehp5685.31526192
Larrañaga MD, Lewis RJ, Sr., Lewis RA, eds. 2016. Lead and lead compounds. In: Hawley’s condensed chemical dictionary. Sixteenth ed. Hoboken, NJ: John Wiley & Sons, Inc., 817–824.
Lasley SM, Gilbert ME. 2000. Glutamatergic components underlying lead-induced impairments in hippocampal synaptic plasticity. Neurotoxicology 21(6):1057–1068.11233752
Laug EP, Kunze FM. 1948. The penetration of lead through the skin. J Ind Hyg Toxicol 30(4; 4):256–259.18873568
Lauwerys R, Buchet JP, Roels H, . 1978. Placental transfer of lead, mercury, cadmium, and carbon monoxide in women. I. Comparison of the frequency distributions of the biological indices in maternal and umbilical cord blood. Environ Res 15:278–289.668658
Lee HS, Park T. 2018. Nuclear receptor and VEGF pathways for gene-blood lead interactions, on bone mineral density, in Korean smokers. PLoS ONE 13(3):e0193323. 10.1371/journal.pone.0193323.29518117
Lee BK, Lee GS, Stewart WF, . 2001. Associations of blood pressure and hypertension with lead dose measures and polymorphisms in the vitamin D receptor and delta-aminolevulinic acid dehydratase genes. Environ Health Perspect 109(4):383–389.11335187
Lee TH, Tseng MC, Chen CJ, . 2009. Association of high body lead store with severe intracranial carotid atherosclerosis. Neurotoxicology 30(6):876–880. 10.1016/j.neuro.2009.07.004.19616024
Lee BK, Ahn J, Kim NS, . 2016a. Association of blood pressure with exposure to lead and cadmium: Analysis of data from the 2008-2013 Korean National Health and Nutrition Examination Survey. Biol Trace Elem Res 174(1):40–51. 10.1007/s12011-016-0699-y.27087554
Lee W, Yoon JH, Roh J, . 2016b. The association between low blood lead levels and the prevalence of prehypertension among nonhypertensive adults in Korea. Am J Hum Biol 28(5):729–735. 10.1002/ajhb.22857.27121332
Leem AY, Kim SK, Chang J, . 2015. Relationship between blood levels of heavy metals and lung function based on the Korean National Health and Nutrition Examination Survey IV-V. Int J Chron Obstruct Pulmon Dis 10:1559–1570. 10.2147/copd.s86182.26345298
Legare ME, Barhoumi R, Hebert E, . 1998. Analysis of Pb2+ entry into cultured astroglia. Toxicol Sci 46:90–100.9928672
Leggett RW. 1993. An age-specific kinetic model of lead metabolism in humans. Environ Health Perspect 101(7):598–616.8143593
Leikin JB, Paloucek FP. 2008. Lead. In: Poisoning and toxicology handbook. Fourth ed. Boca Raton, FL: CRC Press, 807–811.
Lerda D. 1992. Study of sperm characteristics in persons occupationally exposed to lead. Am J Ind Med 22:567–571.1442789
Lévesque B, Duchesne JF, Gariepy C, . 2003. Monitoring of umbilical cord blood lead levels and sources assessment among the Inuit. Occup Environ Med 60(9):693–695.12937194
Levey AS, Bosch JP, Lewis JB, . 1999. A more accurate method to estimate glomerular filtration rate from serum creatinine: A new prediction equation. Ann Intern Med 130(6):461–479.10075613
Levey AS, Stevens LA, Schmid CH, . 2009. A new equation to estimate glomerular filtration rate. Ann Intern Med 150:604–612.19414839
Lewin MD, Sarasua S, Jones PA. 1999. A multivariate linear regression model for predicting children’s blood lead levels based on soil lead levels: A study at four Superfund sites. Environ Res 81(Section A):52–61.10361026
Lewis RJ. 2012. Lead and lead compounds. In: Sax’s dangerous properties of industrial materials. Vol. 4. 12th ed. John Wiley & Sons, Inc., 2711–2725.
Lewis RC, Meeker JD. 2015. Biomarkers of exposure to molybdenum and other metals in relations to testosterone among men from the United States National Health and Nutrition Examination Survey 2011-2012. Fertil Steril 103:172–178.25439796
Lewis J, Sjostrom J, Skyllberg U, . 2010. Distribution, chemical speciation, and mobility of lead and antimony originating from small arms ammunition in a coarse-grained unsaturated surface sand. J Environ Qual 39:863–870.20400582
Li CJ, Yeh CY, Chen RY, . 2015. Biomonitoring of blood heavy metals and reproductive hormone level related to low semen quality. J Hazard Mater 300:815–822. 10.1016/j.jhazmat.2015.08.027.26340548
Li Y, Hu J, Wu W, . 2016a. Application of IEUBK model in lead risk assessment of children aged 61-84 months old in central China. Sci Total Environ 541:673–682. 10.1016/j.scitotenv.2015.09.103.26433329
Li Y, Xie C, Murphy SK, . 2016b. Lead exposure during early human development and DNA methylation of imprinted gene regulatory elements in adulthood. Environ Health Perspect 124(5):666–673. 10.1289/ehp.1408577.26115033
Li S, Xu J, Liu Z, . 2017a. The non-linear association between low-level lead exposure and maternal stress among pregnant women. Neurotoxicology 59:191–196. 10.1016/j.neuro.2016.07.005.27397901
Li J, Wang H, Hao JH, . 2017b. Maternal serum lead level during pregnancy is positively correlated with risk of preterm birth in a Chinese population. Environ Pollut 227:484–489. 10.1016/j.envpol.2017.05.009.28494400
Li C, Ni ZM, Ye LX, . 2018. Dose-response relationship between blood lead levels and hematological parameters in children from central China. Environ Res 164:501–506. 10.1016/j.envres.2018.03.018.29602094
Liebelt EL, Schonfeld DJ, Gallagher P. 1999. Elevated blood lead levels in children are associated with lower erythropoietin concentrations. J Pediatr 134:107–109.9880459
Lilis R, Gavrilescu N, Nestorescu B, . 1968. Nephropathy in chronic lead poisoning. Br J Ind Med 25:196–202.5663423
Lilis R, Eisinger J, Blumberg W, . 1978. Hemoglobin, serum iron, and zinc protoporphyrin in lead-exposed workers. Environ Health Perspect 25:97–102.720309
Lilis R, Fischbein A, Valciukas JA, . 1980. Kidney function and lead: Relationships in several occupational groups with different levels of exposure. Am J Ind Med 1(3–4):405–412.7342779
Lilley SG, Florence TM, Stauber JL. 1988. The use of sweat to monitor lead absorption through the skin. Sci Total Environ 76:267–278.3238426
Lin TA, Tai-Yi J. 2007. Benchmark dose approach for renal dysfunction in workers exposed to lead. Environ Toxicol 22(3):229–233. 10.1002/tox.20260.17497640
Lin CN, Wang LH, Shen KH. 2009. Determining urinary trace elements (Cu, Zn, Pb, As, and Se) in patients with bladder cancer. J Clin Lab Anal 23(3):192–195. 10.1002/jcla.20318.19455638
Lin Z, Comet B, Qvarfort U, . 1995. The chemical and mineralogical behaviour of PB in shooting range soils from central Sweden. Environ Pollut 89(3):303–309.15091520
Lin JL, Tan DT, Hsu KH, . 2001. Environmental lead exposure and progressive renal insufficiency. Arch Intern Med 161:264–271.11176742
Lin J, Lin-Tan D, Hsu K, . 2003. Environmental lead exposure and progression of chronic renal diseases in patients without diabetes. N Engl J Med 348(4):277–286.12540640
Lin JL, Lin-Tan DT, Li YJ, . 2006a. Low-level environmental exposure to lead and progressive chronic kidney diseases. Am J Med 119(8):1–9. 10.1016/j.amjmed.2006.01.005.
Lin JL, Lin-Tan DT, Yu CC, . 2006b. Environmental exposure to lead and progressive diabetic nephropathy in patients with type II diabetes. Kidney Int 69(11):2049–2056.16641918
Lin CG, Schaider LA, Brabander DJ, . 2010. Pediatric lead exposure from imported Indian spice and cultural powders. Pediatrics 125(4):e828–e835. 10.1542/peds.2009-1396.20231190
Lin CC, Chen YC, Su FC, . 2013. In utero exposure to environmental lead and manganese and neurodevelopment at 2 years of age. Environ Res 123:52–57. 10.1016/j.envres.2013.03.003.23578827
Lin Y, Huang L, Xu J, . 2019. Blood lead, bone lead and child attention-deficit-hyperactivity-disorder-like behavior. Sci Total Environ 659:161–167. 10.1016/j.scitotenv.2018.12.219.30597466
Lin-Tan DT, Lin JL, Yen TH, . 2007. Long-term outcome of repeated lead chelation therapy in progressive non-diabetic chronic kidney diseases. Nephrol Dial Transplant 22(10):2924–2931. 10.1093/ndt/gfm342.17556414
Little BB, Spalding S, Walsh B, . 2009. Blood lead levels and growth status among African-American and Hispanic children in Dallas, Texas-1980 and 2002: Dallas Lead Project II. Ann Hum Biol 36(3):331–341. 10.1080/03014460902806615.19381987
Little BB, Ignasiak Z, Slawinska T, . 2017. Blood lead levels, pulmonary function and agility in Polish schoolchildren. Ann Hum Biol 44(8):723–728. 10.1080/03014460.2017.1387284.29082756
Liu J, McCauley L, Compher C, . 2011. Regular breakfast and blood lead levels among preschool children. Environ Health 10:28. 10.1186/1476-069X-10-28.21457535
Liu R, Gress J, Gao J, . 2013. Impacts of two best management practices on Pb weathering and leachability in shooting range soils. Environ Monit Assess 185:6477–6484. 10.1007/s10661-012-3039-5.23264058
Liu J, Gao D, Chen Y, . 2014a. Lead exposure at each stage of pregnancy and neurobehavioral development of neonates. Neurotoxicology 44:1–7. 10.1016/j.neuro.2014.03.003.24704588
Liu J, Chen Y, Gao D, . 2014b. Prenatal and postnatal lead exposure and cognitive development of infants followed over the first three years of life: A prospective birth study in the Pearl River Delta region, China. Neurotoxicology 44:326–334. 10.1016/j.neuro.2014.07.001.25124739
Liu C, Huo X, Lin P, . 2015a. Association between blood erythrocyte lead concentrations and hemoglobin levels in preschool children. Environ Sci Pollut Res Int 22(12):9233–9240. 10.1007/s11356-014-3992-3.25588596
Liu J, Liu X, Pak V, . 2015b. Early blood lead levels and sleep disturbance in preadolescence. Sleep 38(12):1869–1874. 10.5665/sleep.5230.26194570
Liu Z, He C, Chen M, . 2018a. The effects of lead and aluminum exposure on congenital heart disease and the mechanism of oxidative stress. Reprod Toxicol 81:93–98. 10.1016/j.reprotox.2018.07.081.30031113
Liu Y, Huo X, Xu L, . 2018b. Hearing loss in children with e-waste lead and cadmium exposure. Sci Total Environ 624:621–627. 10.1016/j.scitotenv.2017.12.091.29272831
Liu Y, Peterson KE, Montgomery K, . 2019a. Early lead exposure and childhood adiposity in Mexico city. Int J Hyg Environ Health 222(6):965–970. 10.1016/j.ijheh.2019.06.003.31257186
Liu Y, Tellez-Rojo MM, Sanchez BN, . 2019b. Early lead exposure and pubertal development in a Mexico City population. Environ Int 125:445–451. 10.1016/j.envint.2019.02.021.30763831
Lloyd RD, Mays CW, Atherton DR, . 1975. 210Pb studies in beagles. Health Phys 28:575–583.1158699
Lockett CJ, Arbuckle D. 1987. Lead, ferritin, zinc, and hypertension. Bull Environ Contam Toxicol 38:975–980.3580622
Loghman-Adham M. 1997. Renal effects of environmental and occupational lead exposure. Environ Health Perspect 105(9):928–939.9300927
Long DT, Angino EE. 1977. Chemical speciation of Cd, Cu, Pb, and Zn in mixed freshwater, seawater, and brine solutions. Geochim Cosmochim Acta 41:1183–1191.
Lopez CM, Pineiro AE, Nunez N, . 2000. Thyroid hormone changes in males exposed to lead in the Buenos Aires area (Argentina). Pharmacol Res Commun 42(6):599–602.
Lu Y, Yin W, Huang L, . 2011. Assessment of bioaccessibility and exposure risk of arsenic and lead in urban soils of Guangzhou City, China. Environ Geochem Health 33(2):93–102. 10.1007/s10653-010-9324-8.20524051
Lucas JP, Bellanger L, Le Strat Y, . 2014. Source contributions of lead in residential floor dust and within-home variability of dust lead loading. Sci Total Environ 470–471:768–779. 10.1016/j.scitotenv.2013.10.028.
Lucchini R, Albini E, Cortesi I, . 2000. Assessment of neurobehavioral performance as a function of current and cumulative occupational lead exposure. Neurotoxicology 21(5):805–812.11130286
Lundstrom NG, Nordberg G, Englyst V, . 1997. Cumulative lead exposure in relation to mortality and lung cancer morbidity in a cohort of primary smelter workers. Scand J Work Environ Health 23:24–30.9098908
Lundstrom NG, Englyst V, Gerhardsson L, . 2006. Lung cancer development in primary smelter workers: A nested case-referent study. J Occup Environ Med 48(4):376–380. 10.1097/01.jom.0000201556.95982.95.16607191
Luo J, Hendryx M. 2014. Relationship between blood cadmium, lead, and serum thyroid measures in US adults - The National Health and Nutrition Examination Survey (NHANES) 2007-2010. Int J Environ Health Res 24(2):125–136. 10.1080/09603123.2013.800962.23782348
Lustberg M, Silbergeld E. 2002. Blood lead levels and mortality. Arch Intern Med 162(21):2443–2449.12437403
Lutz PM, Wilson TJ, Ireland J, . 1999. Elevated immunoglobulin E (IgE) levels in children with exposure to environmental lead. Toxicology 134(1):63–78. 10.1016/S0300-483X(99)00036-0.10413189
Lyngbye T, Jorgensen J, Grandjean P, . 1990. Validity and interpretation of blood lead levels: A study on Danish school children. Scand J Clin Lab Invest 50:441–449.2392655
Maas RP, Patch SC, Pandolfo TJ, . 2005. Lead content and exposure from children’s and adult’s jewelry products. Bull Environ Contam Toxicol 74:437–444.15903176
Machida M, Sun SJ, Oguma E, . 2009. High bone matrix turnover predicts blood levels of lead among perimenopausal women. Environ Res 109(7):880–886. 10.1016/j.envres.2009.06.005.19595303
MacMillan JW, Behinaein S, Chettle DR, . 2015. Physiologically based modeling of lead kinetics: A pilot study using data from a Canadian population. Environ Sci Process Impacts 17(12):2122–2133. 10.1039/c5em00517e.26565959
Maddaloni M, Lolacono N, Manton W, . 1998. Bioavailability of soilborne lead in adults, by stable isotope dilution. Environ Health Perspect 106(Suppl 6):1589–1594.9860919
Maddaloni M, Ballew M, Diamond G, . 2005. Assessing lead risks at non-residential hazardous waste sites. Hum Ecol Risk Assess 11:967–1003.
Magzamen S, Imm P, Amato MS, . 2013. Moderate lead exposure and elementary school end-of-grade examination performance. Ann Epidemiol 23(11):700–707. 10.1016/j.annepidem.2013.08.007.24095655
Magzamen S, Amato MS, Imm P, . 2015. Quantile regression in environmental health: Early life lead exposure and end-of-grade exams. Environ Res 137:108–119. 10.1016/j.envres.2014.12.004.25531815
Mahaffey KR, Annest JL. 1986. Association of erythrocyte protoporphyrin with blood lead level and iron status in the second National Health and Nutrition Examination Survey, 1976–1980. Environ Res 41(1):327–338.3489614
Mahaffey KR, Gartside PS, Glueck CJ. 1986. Blood lead levels and dietary calcium intake in 1-to 11-year-old children: The Second National Health and Nutrition Examination Survey, 1976 to 1980. Pediatrics 78(2):257–262.3488536
Mahaffey KR, Rosen JF, Chesney RW, . 1982. Association between age, blood lead concentration, and serum 1,25-dihydroxycholecalciferol levels in children. Am J Clin Nutr 35:1327–1331.6896257
Maheswaran R, Gill JS, Beevers DG. 1993. Blood pressure and industrial lead exposure. Am J Epidemiol 137(6):645–653.8470666
Maizlish NA, Parra G, Feo O. 1995. Neurobehavioural evaluation of Venezuelan workers exposed to inorganic lead. Occup Environ Med 52:408–414.7627319
Maki-Paakkanen J, Sorsa M, Vainio H. 1981. Chromosome aberrations and sister chromatid exchanges in lead-exposed workers. Hereditas 94:269–275.7298357
Malcoe LH, Lynch RA, Keger MC, . 2002. Lead sources, behaviors, and socioeconomic factors in relation to blood lead of native and white children: A community-based assessment of a former mining area. Environ Health Perspect 110(Suppl 2):221–231.
Malcolm D, Barnett HAR. 1982. A mortality study of lead workers 1925-76. Br J Ind Med 39:404–410.7138801
Maldonado-Vega M, Cerbon-Solorzano J, Albores-Medina A, . 1996. Lead: Intestinal absorption and bone mobilization during lactation. Hum Exp Toxicol 15(11):872–877.8938481
Malekirad AA, Kalantari-Dehaghi R, Abdollahi M. 2013. Clinical, haematological, and neurocognitive findings in lead-exposed workers of a battery plant in Iran. Arh Hig Rada Toksikol 64(4):497–503. 10.2478/10004-1254-64-2013-2385.24384755
Mannino DM, Albalak R, Grosse S, . 2003. Second-hand smoke exposure and blood lead levels in U.S. children. Epidemiology 14(6):719–727.14569189
Mantere P, Hänninen H, Hernberg S. 1982. Subclinical neurotoxic lead effects: Two-year follow-up studies with psychological test methods. Neurobehav Toxicol Teratol 4:725–727.7170035
Manton WI. 1977. Sources of lead in blood. Identification by stable isotopes. Arch Environ Health 32(4):149–159. 10.1080/00039896.1977.10667273.889353
Manton WI. 1998. Isotope ratios and the source of lead in lead poisoning. J Toxicol Clin Toxicol 36(7):705–706. 10.3109/15563659809162618.9865238
Manton WI, Malloy CR. 1983. Distribution of lead in body fluids after ingestion of soft solder. Br J Ind Med 40(1):51–57.6402004
Manton WI, Cook JD. 1984. High accuracy (stable isotope dilution) measurements of lead in serum and cerebrospinal fluid. Br J Ind Med 41:313–319.6378251
Manton WI, Rothenberg SJ, Manalo M. 2001. The lead content of blood serum. Environ Res 86(Section A):263–273.11453677
Manton WI, Angle CR, Stanek KL, . 2000. Acquisition and retention of lead by young children. Environ Res 82:60–80.10677147
Manton W, Angle C, Stanek K, . 2003. Release of lead from bone in pregnancy and lactation. Environ Res 92(2):139–151.12854694
Marcus AH. 1985a. Multicompartment kinetic model for lead. I. Bone diffusion models for long-term retention. Environ Res 36:441–458.3979363
Marcus AH. 1985b. Multicompartment kinetic model for lead. II. Linear kinetics and variable absorption in humans without excessive lead exposure. Environ Res 36:459–472.3979364
Marcus AH. 1985c. Multicompartment kinetic model for lead. III. Lead in blood plasma and erythrocytes. Environ Res 36:473–489.3979365
Marcus AH, Schwartz J. 1987. Dose-response curves for erythrocyte protoporphyrin vs blood lead: Effects of iron status. Environ Res 44(2):221–227.3691443
Marcus DK, Fulton JJ, Clarke EJ. 2010. Lead and conduct problems: A meta-analysis. J Clin Child Psychol 39(2):234–241. 10.1080/15374411003591455.
Mari M, Nadal M, Schuhmacher M, . 2014. Human exposure to metals: Levels in autopsy tissues of individuals living near a hazardous waste incinerator. Biol Trace Elem Res 159(1–3):15–21.24728924
Markowitz ME, Rosen JF. 1981. Zinc (Zn) and copper (Cu) metabolism in CaNa-2 EDTA-treated children with plumbism. Pediatr Res 15:635.
Markowitz ME, Weinberger HL. 1990. Immobilization-related lead toxicity in previously lead-poisoned children. Pediatrics 86:455–457.2117743
Marques RC, Bernardi JV, Dorea JG, . 2014. Perinatal multiple exposure to neurotoxic (lead, methylmercury, ethylmercury, and aluminum) substances and neurodevelopment at six and 24 months of age. Environ Pollut 187:130–135. 10.1016/j.envpol.2014.01.004.24486466
Marsden PA. 2003. Increased body lead burden - Cause or consequence of chronic renal insufficiency? N Engl J Med 348(4):345–347. 10.1056/NEJMe020164.12540649
Marsh J, Birchall A. 1999. Determination of lung-to-blood absorption rates for lead and bismuth which are appropriate for radon progeny. Radiat Prot Dosimetry 83(4):331–337.
Martin D, Glass TA, Bandeen-Roche K, . 2006. Association of blood lead and tibia lead with blood pressure and hypertension in a community sample of older adults. Am J Epidemiol 163(5):467–478. 10.1093/aje/kwj060.16421242
Marx SK, Kamber BS, McGowan HA. 2008. Scavenging of atmospheric trace metal pollutants by mineral dusts: Inter-regional transport of Australian trace metal pollution to New Zealand. Atmos Environ 42(10):2460–2478. 10.1016/j.atmosenv.2007.12.014.
Matte TD, Figueroa JP, Burr G, . 1989. Lead exposure among lead-acid battery workers in Jamaica. Am J Ind Med 16:167–177.2773946
Mazumdar M, Bellinger DC, Gregas M, . 2011. Low-level environmental lead exposure in childhood and adult intellectual function: A follow-up study. Environ Health 10(1):24. 10.1186/1476-069X-10-24.21450073
McClure LF, Niles JK, Kaufman HW. 2016. Blood lead levels in young children: US, 2009-2015. J Pediatr 175:173–181. 10.1016/j.jpeds.2016.05.005.27297207
McDonald JA, Potter NU. 1996. Lead’s legacy? Early and late mortality of 454 lead-poisoned children. Arch Environ Health 51(2):116–121.8638961
McElroy JA, Shafer MM, Gangnon RE, . 2008. Urinary lead exposure and breast cancer risk in a population-based case-control study. Cancer Epidemiol Biomarkers Prev 17(9):2311–2317. 10.1158/1055-9965.epi-08-0263.18768499
McElvenny DM, Miller BG, MacCalman LA, . 2015. Mortality of a cohort of workers in Great Britain with blood lead measurements. Occup Environ Med 72(9):625–632. 10.1136/oemed-2014-102637.25872777
McFarlane AC, Searle AK, Van Hooff M, . 2013. Prospective associations between childhood low-level lead exposure and adult mental health problems: The Port Pirie cohort study. Neurotoxicology 39:11–17. 10.1016/j.neuro.2013.08.003.23958641
McGregor AJ, Mason HJ. 1990. Chronic occupational lead exposure and testicular endocrine function. Hum Exp Toxicol 9:371–376.2125430
McLaine P, Navas-Acien A, Lee R, . 2013. Elevated blood lead levels and reading readiness at the start of kindergarten. Pediatrics 131(6):1081–1089. 10.1542/peds.2012-2277.23669514
McMichael AJ, Vimpani GV, Robertson EF, . 1986. The Port Pirie cohort study: Maternal blood lead and pregnancy outcome. J Epidemiol Community Health 40(1):18–25.3711766
McMichael AJ, Baghurst PA, Wigg NR, . 1988. Port Pirie cohort study: Environmental exposure to lead and children’s abilities at the age of four years. N Engl J Med 319(8):468–475.3405253
McNeill FE, Stokes L, Brito JA, . 2000. 109Cd K x-ray fluorescence measurements of tibial lead content in young adults exposed to lead in early childhood. Occup Environ Med 57(7):465–471. 10.1136/oem.57.7.465.10854499
Meeker JD, Rossano MG, Protas B, . 2008. Cadmium, lead, and other metals in relation to semen quality: Human evidence for molybdenum as a male reproductive toxicant. Environ Health Perspect 116(11):1473–1479. 10.1289/ehp.11490.19057699
Meeker JD, Rossano MG, Protas B, . 2010. Environmental exposure to metals and male reproductive hormones: Circulating testosterone is inversely associated with blood molybdenum. Fertil Steril 93(1):130–140. 10.1016/j.fertnstert.2008.09.044.18990371
Meirer F, Pemmer B, Pepponi G, . 2011. Assessment of chemical species of lead accumulated in tidemarks of human articular cartilage by X-ray absorption near-edge structure analysis. J Synchrotron Radiat 18(Pt 2):238–244. 10.1107/S0909049510052040.21335911
Mellem JJ, Baijnath H, Odhav B. 2009. Translocation and accumulation of Cr, Hg, As, Pb, Cu and Ni by Amaranthus dubius (Amaranthaceae) from contaminated sites. J Environ Sci Health A Tox Hazard Subst Environ Eng 44(6):568–575. 10.1080/10934520902784583.19337919
Méndez-Gómez J, García-Vargas GG, López-Carrillo L, . 2008. Genotoxic effects of environmental exposure to arsenic and lead on children in region Lagunera, Mexico. Ann N Y Acad Sci 1140:358–367. 10.1196/annals.1454.027.18991935
Mendiola J, Moreno JM, Roca M, . 2011. Relationships between heavy metal concentrations in three different body fluids and male reproductive parameters: A pilot study. Environ Health 10(1):6. 10.1186/1476-069X-10-6.21247448
Menditto A, Morisi G, Spagnolo A, . 1994. Association of blood lead to blood pressure in men aged 55 to 75 years: Effect of selected social and biochemical confounders. NFR Study Group. Environ Health Perspect 102 Suppl 9:107–111.
Mendola P, Brett K, Dibari JN, . 2013. Menopause and lead body burden among US women aged 45-55, NHANES 1999-2010. Environ Res 121:110–113. 10.1016/j.envres.2012.12.009.23352036
Mendy A, Gasana J, Vieira ER. 2012. Urinary heavy metals and associated medical conditions in the US adult population. Int J Environ Health Res 22(2):105–118. 10.1080/09603123.2011.605877.21854105
Mendy A, Gasana J, Vieira ER. 2013. Low blood lead concentrations and thyroid function of American adults. Int J Environ Health Res 23(6):461–473. 10.1080/09603123.2012.755155.23323812
Menke A, Muntner P, Batuman V, . 2006. Blood lead below 0.48 micromol/L (10 microg/dL) and mortality among US adults. Circulation 114(13):1388–1394. 10.1161/circulationaha.106.628321.16982939
Meredith PA, Moore MR, Campbell BC, . 1978. delta-Aminolaevulinic acid metabolism in normal and lead-exposed humans. Toxicology 9:1–9.653730
Meyer-Baron M, Seeber A. 2000. A meta-analysis for neurobehavioural results due to occupational lead exposure with blood lead concentrations <70 ug/100 ml. Arch Toxicol 73:510–518.10663381
Michaels D, Zoloth SR, Stern FB. 1991. Does low-level lead exposure increase risk of death? A mortality study of newspaper printers. Int J Epidemiol 20(4):978–983.1800439
Mielke HW. 1991. Lead in residential soils: Background and preliminary results of New Orleans. Water Air Soil Pollut 57(1):111–119.
Mielke HW. 1993. Lead dust contaminated U.S.A. communities: Comparison of Louisiana and Minnesota. Appl Geochem Suppl(2):257–261.
Mielke HW, Gonzales C. 2008. Mercury (Hg) and lead (Pb) in interior and exterior New Orleans house paint films. Chemosphere 72(6):882–885. 10.1016/j.chemosphere.2008.03.061.18485443
Mielke HW, Laidlaw MA, Gonzales C. 2010. Lead (Pb) legacy from vehicle traffic in eight California urbanized areas: Continuing influence of lead dust on children’s health. Sci Total Environ 408(19):3965–3975. 10.1016/j.scitotenv.2010.05.017.20542539
Mielke HW, Anderson JC, Berry KJ, . 1983. Lead concentrations in inner-city soils as a factor in the child lead problem. Am J Public Health 73(12; 12):1366–1369.6638229
Mielke HW, Burroughs S, Wade R, . 1984. Urban lead in Minnesota: Soil transect results of four cities. J Minn Acad Sci 50(1):19–24.
Mielke HW, Adams JL, Reagan PL, . 1989. Soil-dust lead and childhood lead exposure as a function of city size and community traffic flow: The case for lead abatement in Minnesota. In: Lead in soil: Issues and guidelines. CRC Press, 253–271.
Mielke HW, Dugas D, Mielke PW, . 1997. Associations between soil lead and childhood blood lead in urban New Orleans and rural Lafourche Parish of Louisiana. Environ Health Perspect 105:950–954.9300928
Mielke HW, Powell ET, Shah A, . 2001. Multiple metal contamination from house paints: Consequences of power sanding and paint scraping in New Orleans. Environ Health Perspect 109(9):973–978.11673129
Mielke HW, Gonzales CR, Powell E, . 2007. Nonlinear association between soil lead and blood lead of children in metropolitan New Orleans, Louisiana: 2000-2005. Sci Total Environ 388(1–3):43–53. 10.1016/j.scitotenv.2007.08.012.17884147
Mielke HW, Gonzales C, Powell E, . 2008. Urban soil-lead (Pb) footprint: Retrospective comparison of public and private properties in New Orleans. Environ Geochem Health 30(3):231–242. 10.1007/s10653-007-9111-3.17687626
Mielzyńska D, Siwińska E, Kapka L, . 2006. The influence of environmental exposure to complex mixtures including PAHs and lead on genotoxic effects in children living in Upper Silesia, Poland. Mutagenesis 21(5):295–304. 10.1093/mutage/gel037.16891332
Miller EK, Friedland AJ. 1994. Lead migration in forest soils: Response to changing atmospheric inputs. Environ Sci Technol 28(4):662–669.22196550
Min KB, Min JY. 2015. Environmental lead exposure and increased risk for total and allergen-specific IgE in US adults. J Allergy Clin Immunol 135(1):275–277. 10.1016/j.jaci.2014.08.052.25441290
Min YS, Ahn YS. 2017. The association between blood lead levels and cardiovascular diseases among lead-exposed male workers. Scand J Work Environ Health 43(4):385–390. 10.5271/sjweh.3631.28306758
Min JY, Min KB, Kim R, . 2008a. Blood lead levels and increased bronchial responsiveness. Biol Trace Elem Res 123(1–3):41–46. 10.1007/s12011-008-8099-6.18286239
Min KB, Min JY, Cho SI, . 2008b. Relationship between low blood lead levels and growth in children of white-collar civil servants in Korea. Int J Hyg Environ Health 211(1–2):82–87. 10.1016/j.ijheh.2007.03.003.17588495
Min MYO, Singer LT, Kirchner HL, . 2009. Cognitive development and low-level lead exposure in poly-drug exposed children. Neurotoxicol Teratol 31(4):225–231. 10.1016/j.ntt.2009.03.002.19345261
Mindak WR, Cheng J, Canas BJ, . 2008. Lead in women’s and children’s vitamins. J Agric Food Chem 56:6892–6896.18646762
Minozzo R, Deimling LI, Gigante LP, . 2004. Micronuclei in peripheral blood lymphocytes of workers exposed to lead. Mutat Res 565(1):53–60. 10.1016/j.mrgentox.2004.09.003.15576239
Miranda ML, Kim D, Reiter J, . 2009. Environmental contributors to the achievement gap. Neurotoxicology 30(6):1019–1024. 10.1016/j.neuro.2009.07.012.19643133
Miranda ML, Edwards SE, Swamy GK, . 2010. Blood lead levels among pregnant women: Historical versus contemporaneous exposures. Int J Environ Res Public Health 7(4):1508–1519. 10.3390/ijerph7041508.20617043
Mishra KP, Singh VK, Rani R, . 2003. Effect of lead exposure on the immune response of some occupationally exposed individuals. Toxicology 188(2–3):251–259. 10.1016/s0300-483x(03)00091-x.12767695
Mishra KP, Rani R, Yadav VS, . 2010. Effect of lead exposure on lymphocyte subsets and activation markers. Immunopharmacol Immunotoxicol 32(3):446–449. 10.3109/08923970903503668.20109038
Mistry P, Lucier GW, Fowler BA. 1985. High affinity lead binding proteins from rat kidney cytosol mediate cell-free nuclear translocation of lead. J Pharmacol Exp Ther 232:462–469.3968645
Mistry P, Mastri C, Fowler BA. 1986. Influence of metal ions on renal cytosolic lead-binding proteins and nuclear uptake of lead in the kidney. Biochem Pharmacol 35:711–713.3947401
Mitra P, Sharma S, Purohit P, . 2017. Clinical and molecular aspects of lead toxicity: An update. Crit Rev Clin Lab Sci 54(7–8):506–528. 10.1080/10408363.2017.1408562.29214886
Miyake M. 1986. Structure refinements of Pb2+ ion-exchanged apatites by x-ray powder pattern-fitting. Journal of Solid State Chemistry 61(2):230–235. 10.1016/0022-4596(86)90026-5.
Mohammad IK, Mahdi AA, Raviraja A, . 2008. Oxidative stress in painters exposed to low lead levels. Arh Hig Rada Toksikol 59(3):161–169. 10.2478/10004-1254-59-2008-1883.18796383
Møller L, Kristensen TS. 1992. Blood lead as a cardiovascular risk factor. Am J Epidemiol 136(9):1091–1100.1462969
Montenegro MF, Barbosa F, Tanus-Santos JE. 2008. Assessment of how pregnancy modifies plasma lead and plasma/whole blood lead ratio in ALAD 1-1 genotype women. Basic Clin Pharmacol Toxicol 102(4):347–351. 10.1111/j.1742-7843.2007.00205.x.18282196
Moon SS. 2013. Association of lead, mercury and cadmium with diabetes in the Korean population: The Korea National Health and Nutrition Examination Survey (KNHANES) 2009-2010. Diabet Med 30(4):e143–148. 10.1111/dme.12103.23278294
Moore MR, Goldberg A. 1985. Health implications of the hematopoietic effects of lead. In: Dietary and environmental lead: Human health effects. Elsevier, 261–314.
Moore MR, Meredith PA, Watson WS, . 1980. The percutaneous absorption of lead-203 in humans from cosmetic preparations containing lead acetate, as assessed by whole-body counting and other techniques. Food Chem Toxicol 18:399–405.
Moran-Martinez J, Carranza-Rosales P, Morales-Vallarta M, . 2013. Chronic environmental exposure to lead affects semen quality in a Mexican men population. Iran J Reprod Med 11(4):267–274.24639755
Moreau T, Orssaud G, Juguet B, . 1982. [Blood lead levels and arterial pressure. Initial results of a cross sectional study of 431 male subjects]. Rev Epidemiol Sante Publique 30(3):395–397. (French)6984522
Moreau T, Hannaert P, Orssaud G, . 1988. Influence of membrane sodium transport upon the relation between blood lead and blood pressure in a general male population. Environ Health Perspect 78:47–51.3203645
Morgan A, Holmes A. 1978. The fate of lead in petrol-engine exhaust particulates inhaled by the rat. Environ Res 15:44–56.74332
Morgan B, Parramore C. 2001. Elevated blood lead levels associated with the consumption of illicitly distilled moonshine. J Toxicol Clin Toxicol 39(5):551.
Morita Y, Sakai T, Araki S, . 1997. Nicotinamide adenine dinucleotide synthetase activity in erythrocytes as a tool for the biological monitoring of lead exposure. Int Arch Occup Environ Health 70:195–198.9298402
Morris V, Markowitz ME, Rosen JF. 1988. Serial measurements of aminolevulinic acid dehydratase in children with lead toxicity. J Pediatr 112(6):916–919.3131512
Morris C, McCarron DA, Bennett WM. 1990. Low-level lead exposure, blood pressure, and calcium metabolism. Am J Kidney Dis 15:568–574.2368697
Morrison JN, Quarterman J. 1987. The relationship between iron status and lead absorption in rats. Biol Trace Elem Res 14(1–2):115–126. 10.1007/bf02795602.24254765
Morrison NA, Yeoman R, Kelly PJ, . 1992. Contribution of trans-acting factor alleles to normal physiological variability: Vitamin D receptor gene polymorphism and circulating osteocalcin. Proc Natl Acad Sci U S A 89(15):6665–6669.1353882
Morrow P, Beiter H, Amato F, . 1980. Pulmonary retention of lead: an experimental study in man. Environ Res 21(2):373–384.7408808
Mortada WI, Sobh MA, El-Defrawy MM, . 2001. Study of lead exposure from automobile exhaust as a risk for nephrotoxicity among traffic policemen. Am J Nephrol 21:274–279.11509798
Moss ME, Lanphear BP, Auinger P. 1999. Association of dental caries and blood lead levels. JAMA 281(24):2294–2298.10386553
Mujaj B, Yang WY, Zhang ZY, . 2019. Renal function in relation to low-level environmental lead exposure. Nephrol Dial Transplant 34(6):941–946. 10.1093/ndt/gfy279.30165570
Muldoon SB, Cauley JA, Kuller LH, . 1996. Effects of blood lead levels on cognitive function of older women. Neuroepidemiology 15:62–72.8684585
Muntner P, He J, Vupputuri S, . 2003. Blood lead and chronic kidney disease in the general United States population: Results from NHANES III. Kidney Int 63(3):1044–1050.12631086
Muntner P, Menke A, DeSalvo KB, . 2005. Continued decline in blood lead levels among adults in the United States - The National Health and Nutrition Examination Surveys. Arch Intern Med 165(18):2155–2161. 10.1001/archinte.165.18.2155.16217007
Muntner P, Menke A, Batuman V, . 2007. Association of tibia lead and blood lead with end-stage renal disease: A pilot study of African-Americans. Environ Res 104(3):396–401. 10.1016/j.envres.2007.04.001.17511982
Murata K, Iwata T, Dakeishi M, . 2009. Lead toxicity: Does the critical level of lead resulting in adverse effects differ between adults and children? J Occup Health 51(1):1–12. 10.1539/joh.K8003.18987427
Murphy MJ, Graziano JH, Popovac D, . 1990. Past pregnancy outcomes among women living in the vicinity of a lead smelter in Kosova, Yugoslavia. Am J Public Health 80:33–35.2293800
Murphy DM, Capps SL, Daniel JS, . 2008. Weekly patterns of aerosol in the United States. Atmos Chem Phys 8(10):2729–2739. 10.5194/acp-8-2729-2008.
Murray H, Thompson K, Macfie SM. 2009. Site- and species-specific patterns of metal bioavailability in edible plants. Botany 87(7):702–711.
Mushak P. 1991. Gastro-intestinal absorption of lead in children and adults: Overview of biological and biophysico-chemical aspects. Chem Spec Bioavailab 3(3–4):87–104.
Mykkanen HM, Wasserman RH. 1981. Gastrointestinal absorption of lead (203Pb) in chicks: Influence of lead, calcium, and age. J Nutr 111:1757–1765.7288498
Mykkanen HM, Wasserman RH. 1982. Effect of vitamin D on the intestinal absorption of 203Pb and 47Ca in chicks. J Nutr 112:520–527.6895913
Naha N, Chowdhury AR. 2006. Inorganic lead exposure in battery and paint factory: Effect on human sperm structure and functional activity. J UOEH 28(2):157–171.16780224
Naicker N, Norris SA, Mathee A, . 2010. Lead exposure is associated with a delay in the onset of puberty in South African adolescent females: Findings from the birth to twenty cohort. Sci Total Environ 408(21):4949–4954. 10.1016/j.scitotenv.2010.07.037.20692685
Nan Z, Cheng G. 2001. Accumulation of Cd and Pb in spring wheat (Triticum aestivum L.) grown in calcareous soil irrigated with wastewater. Bull Environ Contam Toxicol 66(6):748–754.11353377
Narayana K, Al-Bader M. 2011. Ultrastructural and DNA damaging effects of lead nitrate in the liver. Exp Toxicol Pathol 63(1–2):43–51. 10.1016/j.etp.2009.09.007.19804962
Narayana K, Raghupathy R. 2012. DNA damage in lead-exposed hepatocytes: Coexistence of apoptosis and necrosis? Drug Chem Toxicol 35(2):208–217. 10.3109/01480545.2011.589849.21988076
NAS. 1972. Lead: Airborne lead in perspective. Washington, DC: National Academy of Sciences, 71–177, 281–313.
NAS. 2013. Potential health risks to DOD firing-range personnel from recurrent lead exposure. Washington, DC: National Academy of Sciences, National Research Council. http://nap.edu/18249. February 19, 2020.
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, 15–35.
Nash D, Magder L, Lustberg M, . 2003. Blood lead, blood pressure, and hypertension in perimenopausal and postmenopausal women. JAMA 289(12):1523–1532.12672769
Nash D, Magder LS, Sherwin R, . 2004. Bone density-related predictors of blood lead level among peri-and postmenopausal women in the United States the Third National Health and Nutrition Examination Survey, 1988–1994. Am J Epidemiol 160(9):901–911.15496543
Navas-Acien A, Selvin E, Sharrett AR, . 2004. Lead, cadmium, smoking, and increased risk of peripheral arterial disease. Circulation 109:3196–3201.15184277
Navas-Acien A, Silbergeld EK, Sharrett AR, . 2005. Metals in urine and peripheral arterial disease. Environ Health Perspect 113(2):164–169. 10.1289/ehp.7329.15687053
Navas-Acien A, Guallar E, Silbergeld EK, . 2007. Lead exposure and cardiovascular disease - A systematic review. Environ Health Perspect 115:472–482. 10.1289/ehp.9785.17431501
Navas-Acien A, Schwartz BS, Rothenberg SJ, . 2008. Bone lead levels and blood pressure endpoints: A meta-analysis. Epidemiology 19(3):496–504. 10.1097/EDE.0b013e31816a2400.18414090
Navas-Acien A, Tellez-Plaza M, Guallar E, . 2009. Blood cadmium and lead and chronic kidney disease in US adults: A joint analysis. Am J Epidemiol 170(9):1156–1164. 10.1093/aje/kwp248.19700501
Nawrot TS, Thijs L, Hond EMD, . 2002. An epidemiological re-appraisal of the association between blood pressure and blood lead: A meta-analysis. J Hum Hypertens 16:123–131.11850770
Needleman H. 2004. Lead poisoning. Annu Rev Med 55:209–222.14746518
Needleman HL, Gunnoe C, Leviton A, . 1979. Deficits in psychologic and classroom performance of children with elevated dentine lead levels. N Engl J Med 300(13):689–695.763299
Needleman HL, Rabinowitz M, Leviton A, . 1984. The relationship between prenatal exposure to lead and congenital anomalies. J Am Med Assoc 251(22):2956–2959.
Needleman HL, Schell A, Bellinger D, . 1990. The long-term effects of exposure to low doses of lead in childhood: An 11-year follow-up report. N Engl J Med 322(2):83–88.2294437
Needleman HL, Riess JA, Tobin MJ, . 1996. Bone lead levels and delinquent behavior. J Am Med Assoc 275:363–369.
Needleman HL, McFarland C, Ness RB, . 2002. Bone lead levels in adjudicated delinquents. A case control study. Neurotoxicol Teratol 24:711–717.12460653
Nelson AE, Chaudhary S, Kraus VB, . 2011. Whole blood lead levels are associated with biomarkers of joint tissue metabolism in African American and white men and women: The Johnston County Osteoarthritis Project. Environ Res 111(8):1208–1214. 10.1016/j.envres.2011.08.002.21839992
Neri LC, Hewitt D, Orser B. 1988. Blood lead and blood pressure: Analysis of cross-sectional and longitudinal data from Canada. Environ Health Perspect 78:123–126.3264525
Nerin C, Domeno C, Garcia JI, . 1999. Distribution of Pb, V, Cr, Ni, Cd, Cu and Fe in particles formed from the combustion of waste oils. Chemosphere 38(7):1533–1540.10070733
Neuberger JS, Hu SC, Drake KD, . 2009. Potential health impacts of heavy-metal exposure at the Tar Creek Superfund site, Ottawa County, Oklahoma. Environ Geochem Health 31(1):47–59. 10.1007/s10653-008-9154-0.18306045
Neugebauer J, Wittsiepe J, Kasper-Sonnenberg M, . 2015. The influence of low level pre- and perinatal exposure to PCDD/Fs, PCBs, and lead on attention performance and attention-related behavior among German school-aged children: Results from the Duisburg Birth Cohort Study. Int J Hyg Environ Health 218(1):153–162. 10.1016/j.ijheh.2014.09.005.25456149
Neuman DR, Dollhopf DJ. 1992. Lead levels in blood from cattle residing near a lead smelter. J Environ Qual 21:181–184.
NFPA. 2002. Tetraethyl lead. In: Spencer AB, Colonna GR, eds. Fire protection guide to hazardous materials. Quincy, MA: National Fire Protection Association, 325–106.
Ng TP, Goh HH, Ng YL, . 1991. Male endocrine functions in workers with moderate exposure to lead. Br J Ind Med 48:485–491.1906733
Ngueta G, Verner MA, Fiocco AJ, . 2018. Blood lead levels and hypothalamic-pituitary-adrenal function in middle-aged individuals. Environ Res 160:554–561. 10.1016/j.envres.2017.10.032.29102031
Nie H, Chettle DR, Webber CE, . 2005. The study of age influence on human bone lead metabolism by using a simplified model and X-ray fluorescence data. J Environ Monit 7(11):1069–1073. 10.1039/b507749d.16252055
Nie H, Sanchez BN, Wilker E, . 2009. Bone lead and endogenous exposure in an environmentally exposed elderly population: The Normative Aging Study. J Occup Environ Med 51:848–857.19528829
Nie LH, Wright RO, Bellinger DC, . 2011a. Blood lead levels and cumulative blood lead index (CBLI) as predictors of late neurodevelopment in lead poisoned children. Biomarkers 16(6):517–524. 10.3109/1354750x.2011.604133.21827276
Nie LH, Sanchez S, Newton K, . 2011b. In vivo quantification of lead in bone with a portable x-ray fluorescence system - Methodology and feasibility. Phys Med Biol 56(3):N39–51. 10.1088/0031-9155/56/3/n01.21242629
Nie X, Chen Y, Chen Y, . 2017. Lead and cadmium exposure, higher thyroid antibodies and thyroid dysfunction in Chinese women. Environ Pollut 230:320–328. 10.1016/j.envpol.2017.06.052.28667913
Nielsen T. 1984. Atmospheric occurrence of organolead compounds. In: Grandjean P, ed. Biological effects of organolead compounds. Boca Raton, FL: CRC Press, 44–62.
Nielsen T, Jensen KA, Grandjean P. 1978. Organic lead in normal human brains. Nature 274:602–603.79140
Nielsen OJ, O’Farrell DJ, Treacy JJ, . 1991. Rate constants for the gas-phase reactions of hydroxyl radicals with tetramethyllead and tetraethyllead. Environ Sci Technol 25(6):1098–1103.
Nielson KB, Atkin CL, Winge DR. 1985. Distinct metal-binding configurations in metallothionein. J Biol Chem 260:5342–5350.3988757
Nihei MK, Guilarte TR. 2002. Molecular mechanisms of low-level Pb2 neurotoxicity. In: Massaro EJ, ed. Handbook of neurotoxicology. Totowa, NJ: Humana Press, 107–133.
Nilsson U, Attewell R, Christoffersson JO, . 1991. Kinetics of lead in bone and blood after end of occupational exposure. Pharmacol Toxicol 69:477–484.
NIOSH. 1994a. Method 8005, Issue 2: Elements in blood or tissue. NIOSH manual of analytical methods (NMAM). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2003-154/pdfs/8005.pdf. March 30, 2017.
NIOSH. 1994b. Method 8003: Lead in blood and urine. NIOSH manual of analytical methods (NMAM). Cincinnati, OH: National Institute for Occupational Safety and Health.
NIOSH. 1994c. Method 7105, Issue 2: Lead by GFAAS. NIOSH manual of analytical methods (NMAM). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2003-154/pdfs/7105. March 29, 2017.
NIOSH. 1995. Report to congress on workers’ home contamination study conducted under the Worker’s Family Protection Act (29 U.S.C. 671a). Cincinnati, OH: National Institute for Occupational Safety and Health. DHHS (NIOSH) Publication No. 95-123. PB96192000HEF.
NIOSH. 1996a. Method 9100, Issue 2: Lead in surface wipe samples. NIOSH manual of analytical methods (NMAM). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2003-154/pdfs/9100.pdf. March 30, 2017.
NIOSH. 1996b. NIOSH health hazard evaluation report: HETA 91-0346-2572 FBI academy Quantico, Virginia. Cincinnati, OH: National Institute for Occupational Safety and Health.
NIOSH. 1998. Method 7702, Issue 1: Lead by field portable XRF. NIOSH manual of analytical methods (NMAM). National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/docs/2003-154/pdfs/7702.pdf. March 29, 2017.
NIOSH. 2003a. Method 7301, Issue 1: Elements by ICP (Aqua Regia Ashing). NIOSH manual of analytical methods (NMAM). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2003-154/pdfs/7301.pdf. March 29, 2017.
NIOSH. 2003b. Method 7303, Issue 1: Elements by ICP (Hot Block/HCl/HNO3 Ashing). NIOSH manual of analytical methods (NMAM). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2003-154/pdfs/7303.pdf. February 18, 2020.
NIOSH. 2003c. Method 7300, Issue 3: Elements by (ICP). NIOSH manual of analytical methods (NMAM). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2003-154/pdfs/7300.pdf. March 29, 2017.
NIOSH. 2003d. Method 9102, Issue 1: Elements on wipes methods. NIOSH manual of analytical methods (NMAM). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2003-154/pdfs/9102.pdf. March 30, 2017.
NIOSH. 2003e. Method 9105, Issue 1: Lead in dust wipes. NIOSH manual of analytical methods (NMAM). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2003-154/pdfs/9105.pdf. March 30, 2017.
NIOSH. 2014a. Method 7302, Issue 1: Elements by ICP (microwave digestion). NIOSH manual of analytical methods (NMAM). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2014-151/pdfs/methods/7302.pdf. March 29, 2017.
NIOSH. 2014b. Method 7304, Issue 1: Elements by ICP (microwave digestion). NIOSH manual of analytical methods (NMAM). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2014-151/pdfs/methods/7304.pdf. March 29, 2017.
NIOSH. 2015. Method 7306, Issue 1: Elements by cellulosic internal capsule sampler. NIOSH manual of analytical methods (NMAM). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2014-151/pdfs/methods/7306.pdf. March 29, 2017.
NIOSH. 2016a. Method 7701, Issue 3: Lead by portable ultrasonic extraction/ASV. NIOSH manual of analytical methods (NMAM). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2014-151/pdfs/methods/7701.pdf. March 29, 2017.
NIOSH. 2016b. Lead. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0368.html. May 10, 2017.
NIOSH. 2017a. Elevated blood lead levels among employed adults - United States, 2014 Adult blood lead epidemiology and surveillance (ABLES). National Institute for Occupational Safety and Health.
NIOSH. 2017b. Method 7082, Issue 2: Lead by flame AAS NIOSH manual of analytical methods (NMAM). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2014-151/pdfs/methods/7082.pdf. March 13, 2019.
NIOSH. 2019a. Lead. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0368.html. October 25, 2019.
NIOSH. 2019b. Tetraethyl lead (as Pb). NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0601.html. October 25, 2019.
NIOSH. 2019c. Tetramethyl lead (as Pb). NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0603.html. October 25, 2019.
Nishioka E, Yokoyama K, Matsukawa T, . 2014. Evidence that birth weight is decreased by maternal lead levels below 5 ug/dl in male newborns. Reprod Toxicol 47:21–26. 10.1016/j.reprotox.2014.05.007.24878230
Niu Y, Yu W, Fang S, . 2015. Lead poisoning influences TCR-related gene expression patterns in peripheral blood T-lymphocytes of exposed workers. J Immunotoxicol 12(1):92–97. 10.3109/1547691x.2014.899412.24720682
Nkomo P, Mathee A, Naicker N, . 2017. The association between elevated blood lead levels and violent behavior during late adolescence: The South African Birth to Twenty Plus cohort. Environ Int 109:136–145. 10.1016/j.envint.2017.09.004.28916132
NLM. 2020. ChemIDplus: Lead tetroxide (CASRN: 1314-41-6). U.S. National Library of Medicine. https://chem.nlm.nih.gov/chemidplus/name/lead%20tetraoxide. January 23, 2020.
NOAA. 1998. Sampling and analytical methods of the National Status and Trends Program Mussel Watch Project: 1993-1996 Update. Silver Spring, MD: National Oceanic and Atmospheric Administration. NOS ORCA 130. http://aquaticcommons.org/2201/. March 30, 2017.
Nordberg GF, Gerhardsson L, Mumtaz MM, . 2015. Interactions and mixtures in metal toxicology. In: Nordberg GF, Fowler BA, Nordberg M, eds. Handbook on the toxicology of metals. 4th ed. Elsevier, 213–238.
Nordenson I, Beckman G, Beckman L, . 1978. Occupational and environmental risks in and around a smelter in northern Sweden. IV. Chromosomal aberrations in workers exposed to lead. Hereditas 88:263–267.689896
NRC. 2005. Superfund and mining megasites. Lessons from Coeur d’Alene River Basin. National Research Council. http://dels.nas.edu/Report/Superfund-Mining-Megasites-Lessons-from/11359. February 18, 2020.
Nriagu J, Burt B, Linder A, . 2006. Lead levels in blood and saliva in a low-income population of Detroit, Michigan. Int J Hyg Environ Health 209(2):109–121. 10.1016/j.ijheh.2005.11.005.16443391
NTP. 2003. Report on carcinogens background document for lead and lead compounds Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/ntp/newhomeroc/roc11/lead-public_508.pdf. January 23, 2020.
NTP. 2012. NTP monograph on health effects of low-level lead. National Toxicology Program. xiii, xv–148. https://ntp.niehs.nih.gov/ntp/ohat/lead/final/monographhealtheffectslowlevellead_newissn_508.pdf. May 31, 2017.
NTP. 2016. Lead and lead compounds, CAS No. 7439-92-1 (lead). Report on carcinogens. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/lead.pdf. May 4, 2017.
Nwosu JU, Harding AK, Linder G. 1995. Cadmium and lead uptake by edible crops grown in a silt loam soil. Bull Environ Contam Toxicol 54:570–578.7767034
Obeng-Gyasi E, Obeng-Gyasi B. 2018. Blood pressure and oxidative stress among U.S. adults exposed to lead in military environments - A preliminary study. Diseases 6(4):97. 10.3390/diseases6040097.30373250
Odland JO, Nieboer E, Romanova N, . 1999. Blood lead and cadmium and birth weight among sub-arctic and arctic populations of Norway and Russia. Acta Obstet Gynecol Scand 78:852–860.10577613
O’Flaherty EJ. 1987. Modeling: An introduction. In: Pharmacokinetics in risk assessment: Drinking water and health. Vol. 8. Washington, DC: National Academy Press, National Academy of Sciences, 27–33.
O’Flaherty EJ. 1991a. Physiologically based models for bone-seeking elements. II. Kinetics of lead disposition in rats. Toxicol Appl Pharmacol 111:313–331.1957315
O’Flaherty EJ. 1991b. Physiologically based models for bone-seeking elements: III. Human skeletal and bone growth. Toxicol Appl Pharmacol 111(2):332–341.1957316
O’Flaherty EJ. 1993. Physiologically based models for bone-seeking elements. IV. Kinetics of lead disposition in humans. Toxicol Appl Pharmacol 118(1):16–29.8430422
O’Flaherty EJ. 1995a. Physiologically based models for bone-seeking elements. V. Lead absorption and disposition in childhood. Toxicol Appl Pharmacol 131:297–308.7716770
O’Flaherty EJ. 1995b. PBK modeling for metals. Examples with lead, uranium, and chromium. Toxicol Lett 82/83:367–372.8597078
O’Flaherty EJ. 1998. A physiologically based kinetic model for lead in children and adults. Environ Health Perspect 106(Suppl 6):1495–1503.9860908
O’Flaherty EJ. 2000. Modeling normal aging bone loss, with consideration of bone loss in osteoporosis. Toxicol Sci 55:171–188.10788572
O’Flaherty EJ, Hammond PB, Lerner SI. 1982. Dependence of apparent blood lead half-life on the length of previous lead exposure in humans. Fundam Appl Toxicol 2:49–55.7185602
Oldereid NB, Thomassen Y, Attramadal A, . 1993. Concentrations of lead, cadmium and zinc in the tissues of reproductive organs of men. J Reprod Fertil 99:421–425.8107024
Olivero-Verbel J, Duarte D, Echenique M, . 2007. Blood lead levels in children aged 5-9 years living in Cartagena, Colombia. Sci Total Environ 372(2–3):707–716. 10.1016/j.scitotenv.2006.10.025.17157895
Olmedo P, Goessler W, Tanda S, . 2018. Metal concentrations in e-cigarette liquid and aerosol samples: The contribution of metallic coils. Environ Health Perspect 126(2):027010. 10.1289/EHP2175.29467105
Olson KW, Skogerboe RK. 1975. Identification of soil lead compounds from automobile sources. Environ Sci Technol 9:227–230.
Omae K, Sakurai H, Higashi T, . 1990. No adverse effects of lead on renal function in lead-exposed workers. Ind Health 28(2):77–83.2376529
Omar M, Ibrahim M, Assem H, . 2001. Teeth and blood lead levels in Egyptian schoolchildren: Relationship to health effects. J Appl Toxicol 21(4):349–352. 10.1002/jat.771.11481670
Omokhodion FO, Crockford GW. 1991. Lead in sweat and its relationship to salivary and urinary levels in normal healthy subjects. Sci Total Environ 103(2–3):113–122.1882227
Onalaja AO, Claudio L. 2000. Genetic susceptibility to lead poisoning. Environ Health Perspect 108(Suppl 1):23–28.10698721
O’Neil MJ, Heckelman PE, Dobbelaar PH, . 2013. Lead and lead compounds. In: The Merck index. London, England: The Royal Society of Chemistry, 1004–1007, 1706.
Ong CN, Lee WR. 1980. Distribution of lead-203 in human peripheral blood in vitro. Br J Ind Med 37:78–84.7370196
Ong C, Kong Y, Ong H, . 1990. The in vitro and in vivo effects of lead on δ-aminolevulinic acid dehydratase and pyrimidine 5′-nucleotidase. Pharmacol Toxicol 66(1):23–26.2308903
Onuegbu AJ, Olisekodiaka MJ, Nwaba EI, . 2011. Assessment of some renal indices in people occupationally exposed to lead. Toxicol Ind Health 27(5):475–479. 10.1177/0748233710390020.21310779
Oomen AG, Tolls J, Sips AJAM, . 2003a. Lead speciation in artificial human digestive fluid. Arch Environ Contam Toxicol 44:107–115.12434225
Oomen AG, Rompelberg CJ, Bruil MA, . 2003b. Development of an in vitro digestion model for estimating the bioaccessibility of soil contaminants. Arch Environ Contam Toxicol 44(3):281–287.12712286
Opler MGA, Brown AS, Graziano J, . 2004. Prenatal lead exposure, delta-aminolevulinic acid, and schizophrenia. Environ Health Perspect 112(5):548–552. 10.1289/ehp.10464.15064159
Opler MGA, Buka SL, Groeger J, . 2008. Prenatal exposure to lead, delta-aminolevulinic acid, and schizophrenia: Further evidence. Environ Health Perspect 116(11):1586–1590. 10.1289/ehp.10464.19057716
Orisakwe OE, Nwachukwu E, Osadolor HB, . 2007. Liver and kidney function tests amongst paint factory workers in Nkpor, Nigeria. Toxicol Ind Health 23(3):161–165.18220158
Orssaud G, Claude JR, Moreau T, . 1985. Blood lead concentration and blood pressure. Br Med J 290:244.3917774
OSHA. 1995. Subpart Z - Toxic and hazardous substances. Lead-general. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1025. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1025. February 19, 2020.
OSHA. 2002a. Metal & metalloid particulates in workplace atmospheres (atomic absorption). Occupational Safety and Health Administration. https://www.osha.gov/dts/sltc/methods/inorganic/id121/id121.pdf. January 13, 2020.
OSHA. 2002b. Metal and metalloid particulates in workplace atmospheres (ICP analysis). Occupational Safety and Health Administration. https://www.osha.gov/dts/sltc/methods/inorganic/id125g/id125g.pdf. January 13, 2020.
OSHA. 2016a. Subpart Z - Toxic and hazardous substances. Lead - general. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1025. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol6/pdf/CFR-2016-title29-vol6-sec1910-1025.pdf. May 4, 2017.
OSHA. 2016b. Subpart Z - Toxic and hazardous substances. Air contaminants - general industry. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol6/pdf/CFR-2016-title29-vol6-sec1910-1000.pdf. March 6, 2017.
OSHA. 2019a. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Lead. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1025. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1025. October 25, 2019.
OSHA. 2019b. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. October 25, 2019.
OSHA. 2019c. Safety and health regulations for construction. Lead. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.62. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.62. October 25, 2019.
OSHA. 2019d. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55 Appendix A. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. October 25, 2019.
OSHA. 2019e. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. October 25, 2019.
OSHA. 2019f. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Lead. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1025. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1025. October 25, 2019.
Oskarsson A, Jorhem L, Sundberg J, . 1992. Lead poisoning in cattle - Transfer of lead to milk. Sci Total Environ 111:83–94.1539131
Osman K, Pawlas K, Schutz A, . 1999. Lead exposure and hearing effects in children in Katowice, Poland. Environ Res 80 Section A:1–8.9931221
Osterberg E, Mayewski P, Kreutz K, . 2008. Ice core record of rising lead pollution in the North Pacific atmosphere. Geophys Res Lett 35(5):L05810. 10.1029/2007gl032680.
Osterode W, Barnas U, Geissler K. 1999. Dose dependent reduction of erythroid progenitor cells and inappropriate erythropoietin response in exposure to lead: New aspects of anaemia induced by lead. Occup Environ Med 56:106–109.10448314
Otto D, Robinson G, Baumann S, . 1985. 5-Year follow-up study of children with low-to-moderate lead absorption: Electrophysiological evaluation. Environ Res 38(1):168–186.4076105
Ou LT, Thomas JE, Jing W. 1994. Biological and chemical degradation of tetraethyl lead in soil. Bull Environ Contam Toxicol 52:238–245.8123984
Ou LT, Jing W, Thomas JE. 1995. Biological and chemical degradation of ionic ethyllead compounds in soil. Environ Toxicol Chem 14(4):545–551.
Ozkaynak H, Xue J, Zartarian VG, . 2011. Modeled estimates of soil and dust ingestion rates for children. Risk Anal 31(4):592–608. 10.1111/j.1539-6924.2010.01524.x.21039709
Padilla MA, Elobeid M, Ruden DM, . 2010. An examination of the association of selected toxic metals with total and central obesity indices: NHANES 99-02. Int J Environ Res Public Health 7:3332–3347. 10.3390/ijerph7093332.20948927
Paglia DE, N VW, Dahlgren JG. 1975. Effects of low-level lead exposure on pyrimidine 5’-nucleotidase and other erythrocyte enzymes. Possible role of pyrimidine 5’-nucleotidase in the pathogenesis of lead-induced anemia. J Clin Invest 56:1164–1169.1184742
Paglia D, Valentine W, Fink K. 1977. Lead poisoning. Further observations on erythrocyte pyrimidine-nucleotidase deficiency and intracellular accumulation of pyrimidine nucleotides. J Clin Invest 60(6):1362–1366.915002
Pagliuca A, Mufti GJ, Baldwin D, . 1990. Lead poisoning: Clinical, biochemical, and haematological aspects of a recent outbreak. J Clin Pathol 43:277–281.2341563
Palaniappan K, Roy A, Balakrishnan K, . 2011. Lead exposure and visual-motor abilities in children from Chennai, India. Neurotoxicology 32(4):465–470. 10.1016/j.neuro.2011.03.011.21510976
Palmer KT, Kucera CL. 1980. Lead contamination of sycamore and soil from lead mining and smelting operations in eastern Missouri. J Environ Qual 9(1):106–111.
Pan SY, Morrison H, Gibbons L, . 2011. Breast cancer risk associated with residential proximity to industrial plants in Canada. J Occup Environ Med 53(5):522–529. 10.1097/JOM.0b013e318216d0b3.21494158
P’An AYS. 1981. Lead levels in saliva and in blood. J Toxicol Environ Health 7(2):273–280. 10.1080/15287398109529978.7230275
PAN Pesticides Database. 2004. Chemical names that begin with: Lead. PAN Pesticides Database-chemicals. Pesticide Action Network. http://www.pesticideinfo.org/. February 22, 2005.
Parajuli RP, Fujiwara T, Umezaki M, . 2013. Association of cord blood levels of lead, arsenic, and zinc with neurodevelopmental indicators in newborns: A birth cohort study in Chitwan Valley, Nepal. Environ Res 121:45–51. 10.1016/j.envres.2012.10.010.23164520
Pardo R, Barrado E, Perez L, . 1990. Determination and speciation of heavy metals in sediments of the Pisuerga River. Water Res 24(3):373–379.
Park SK, Schwartz J, Weisskopf M, . 2006. Low-level lead exposure, metabolic syndrome, and heart rate variability: The VA normative aging study. Environ Health Perspect 114:1718–1724.17107858
Park SK, Hu H, Wright RO, . 2009a. Iron metabolism genes, low-level lead exposure, and QT interval. Environ Health Perspect 117(1):80–85.19165391
Park SK, Mukherjee B, Xia X, . 2009b. Bone lead level prediction models and their application to examine the relationship of lead exposure and hypertension in the third National Health and Nutrition Examination Survey. J Occup Environ Med 51(12):1422–1436. 10.1097/JOM.0b013e3181bf6c8d.19952788
Park SK, Elmarsafawy S, Mukherjee B, . 2010. Cumulative lead exposure and age-related hearing loss: The VA Normative Aging Study. Hear Res 269(1–2):48–55. 10.1016/j.heares.2010.07.004.20638461
Park SJ, Lee JH, Woo SJ, . 2015. Five heavy metallic elements and age-related macular degeneration: Korean National Health and Nutrition Examination Survey, 2008-2011. Ophthalmology 122(1):129–137. 10.1016/j.ophtha.2014.07.039.25225109
Park JH, Seo JH, Hong YS, . 2016. Blood lead concentrations and attention deficit hyperactivity disorder in Korean children: A hospital-based case control study. BMC pediatrics 16(1):156. 10.1186/s12887-016-0696-5.27659349
Park WJ, Kim SH, Kang W, . 2019. Blood lead level and Helicobacter pylori infection in a healthy population: A cross-sectional study. Arch Environ Occup Health 74:1–6. 10.1080/19338244.2019.1654969.30932794
Parkinson DK, Ryan C, Bromet EJ, . 1986. A psychiatric epidemiologic study of occupational lead exposure. Am J Epidemiol 123(2; 2):261–269.3946375
Parkinson DK, Hodgson MJ, Bromet EJ, . 1987. Occupational lead exposure and blood pressure. Br J Ind Med 44(11):744–748.3689706
Parramore CS, Morgan BW, Ethridge MW. 2001. Lead contaminated moonshine: A report of ATF analyzed samples. J Toxicol Clin Toxicol 39(5):520.
Partanen T, Heikkila P, Hernberg S, . 1991. Renal cell cancer and occupational exposure to chemical agents. Scand J Work Environ Health 17(4):231–239.1925434
Pasternak MD, Becker CE, Lash A, . 1989. Cross-sectional neurotoxicology study of lead-exposed cohort. Clin Toxicol 27(1 and 2):37–51.
Patel AB, Prabhu AS. 2009. Determinants of lead level in umbilical cord blood. Indian Pediatr 46(9):791–793.19213980
Patil AJ, Bhagwat VR, Patil JA, . 2006. Effect of lead (Pb) exposure on the activity of superoxide dismutase and catalase in battery manufacturing workers (BMW) of Western Maharashtra (India) with reference to heme biosynthesis. Int J Environ Res Public Health 3(4):329–337.17159274
Patil AJ, Bhagwat VR, Patil JA, . 2007. Occupational lead exposure in battery manufacturing workers, silver jewelry workers, and spray painters in western Maharashtra (India): Effect on liver and kidney function. J Basic Clin Physiol Pharmacol 18(2):87–100. 10.1515/JBCPP.2007.18.2.87.17715565
Pawlas N, Broberg K, Olewinska E, . 2012. Modification by the genes ALAD and VDR of lead-induced cognitive effects in children. Neurotoxicology 33:37–43.22101007
Pawlas N, Broberg K, Olewinska E, . 2015. Genetic modification of ALAD and VDR on lead-induced impairment of hearing in children. Environ Toxicol Pharmacol 39(3):1091–1098. 10.1016/j.etap.2015.03.008.25899472
Pawlas N, Plachetka A, Kozlowska A, . 2016. Telomere length, telomerase expression, and oxidative stress in lead smelters. Toxicol Ind Health 32(12):1961–1970. 10.1177/0748233715601758.26381690
Pawlas N, Olewinska E, Markiewicz-Gorka I, . 2017. Oxidative damage of DNA in subjects occupationally exposed to lead. Adv Clin Exp Med 26(6):939–945. 10.17219/acem/64682.29068594
Payton M, Hu H, Sparrow D, . 1994. Low-level lead exposure and renal function in the normative aging study. Am J Epidemiol 140(9):821–829.7977292
Payton M, Riggs KM, Sprio A, . 1998. Relations of bone and blood lead to cognitive function: The VA normative aging study. Neurotoxicol Teratol 20(1):19–27.9511166
PEHSU. 2013. Recommendations on medical management of childhood lead exposure and poisoning. Pediatric Environmental Health Specialty Units. American Academy of Pediatrics. https://www.pehsu.net/_Library/facts/medical-mgmnt-childhood-lead-exposure-June-2013.pdf. February 19, 2020.
Pekcici R, Kavlakoğlu B, Yilmaz S, . 2010. Effects of lead on thyroid functions in lead-exposed workers. Cent Eur J Med 5(2):215–218. 10.2478/s11536-009-0092-8.
Pellizzari ED, Perritt RL, Clayton CA. 1999. National human exposure assessment survey (NHEXAS): Exploratory survey of exposure among population subgroups in EPA Region V. J Expo Anal Environ Epidemiol 9:49–55.10189626
Peralta-Videa JR, Lopez ML, Narayan M, . 2009. The biochemistry of environmental heavy metal uptake by plants: Implications for the food chain. Int J Biochem Cell Biol 41(8–9):1665–1677. 10.1016/j.biocel.2009.03.005.19433308
Pergande M, Jung K, Precht S, . 1994. Changed excretion or urinary proteins and enzymes by chronic exposure to lead. Nephrol Dial Transplant 9:613–618.7526273
Perkins M, Wright RO, Amarasiriwardena CJ, . 2014. Very low maternal lead level in pregnancy and birth outcomes in an eastern Massachusetts population. Ann Epidemiol 24(12):915–919. 10.1016/j.annepidem.2014.09.007.25444892
Perlstein T, Weuve J, Schwartz J, . 2007. Cumulative community-level lead exposure and pulse pressure: The Normative Aging Study. Environ Health Perspect 115(12):1696–1700. 10.1289/ehp.10350.18087585
Perneger TV, Nieto FJ, Whelton PK, . 1993. A prospective study of blood pressure and serum creatinine: Results from the ‘Clue’ Study and the ARIC Study. J Am Med Assoc 269:488–493.
Perroy RL, Belby CS, Mertens CJ. 2014. Mapping and modeling three dimensional lead contamination in the wetland sediments of a former trap-shooting range. Sci Total Environ 487:72–81. 10.1016/j.scitotenv.2014.03.102.24776973
Peryea FJ. 1998. Historical use of lead arsenate insecticides, resulting soil contamination and implications for soil remediation. In: Proceedings. 16th World Congress of Soil Science (CD rom), Montpellier, France, 20-26 Aug. 1998. Vol. Scientific registration no: 274. Washington State University. http://soils.tfrec.wsu.edu/leadhistory.htm. March 4, 2005.
Pesch B, Haerting J, Ranft U, . 2000. Occupational risk factors for renal cell carcinoma: Agent-specific results from a case-control study in Germany. Int J Epidemiol 29:1014–1024.11101542
Peters JL, Kubzansky L, McNeely E, . 2007. Stress as a potential modifier of the impact of lead levels on blood pressure: The Normative Aging Study. Environ Health Perspect 115(8):1154–1159. 10.1289/ehp.10002.17687441
Petrucci R, Leonardi A, Battistuzzi G. 1982. The genetic polymorphism of delta-aminolevulinate dehydrase in Italy. Hum Genet 60(3):289–290.7106762
Pieper KJ, Martin R, Tang M, . 2018. Evaluating water lead levels during the Flint water crisis. Environ Sci Technol 52(15):8124–8132. 10.1021/acs.est.8b00791.29932326
Pierzynski GM, Schwab AP. 1993. Heavy metals in the environment. Bioavailability of zinc, cadmium, and lead in a metal-contaminated alluvial soil. J Environ Qual 22:247–254.
Pilsner JR, Hu H, Ettinger A, . 2009. Influence of prenatal lead exposure on genomic methylation of cord blood DNA. Environ Health Perspect 117(9):1466–1471. 10.1289/ehp.0800497.19750115
Pineda-Zavaleta AP, García-Vargas G, Borja-Aburto VH, . 2004. Nitric oxide and superoxide anion production in monocytes from children exposed to arsenic and lead in region Lagunera, Mexico. Toxicol Appl Pharmacol 198(3):283–290. 10.1016/j.taap.2003.10.034.15276407
Pingitore NE, Clague JW, Amaya MA, . 2009. Urban airborne lead: X-ray absorption spectroscopy establishes soil as dominant source. PLoS ONE 4(4):e5019. 10.1371/journal.pone.0005019.19340295
Pinkerton LE, Biagini RE, Ward EM, . 1998. Immunologic findings among lead-exposed workers. Am J Ind Med 33(4):400–408. 10.1002/(SICI)1097-0274(199804)33:4<400::AID-AJIM11>3.0.CO;2-2.9513648
Pinto D, Ceballos JM, Garcıa G, . 2000. Increased cytogenetic damage in outdoor painters. Mutat ´ Res Genet Toxicol Environ Mutagen 467(2):105–111. 10.1016/S1383-5718(00)00024-3.
Pinto de Almeida AR, Carvalho FM, Spinola AG, . 1987. Renal dysfunction in Brazilian lead workers. Am J Nephrol 7(6):455–458. 10.1159/000167519.3439554
Pirkle JL, Schwartz J, Landis JR, . 1985. The relationship between blood lead levels and blood pressure and its cardiovascular risk implications. Am J Epidemiol 121(2):246–258.4014119
Pirkle JL, Brody DJ, Gunter EW, . 1994. The decline in blood lead levels in the United States. The National Health and Nutrition Examination Surveys (NHANES). J Am Med Assoc 272(4):284–291.
Pirkle JL, Kaufmann RB, Brody DJ, . 1998. Exposure of the U.S. population to lead, 1991-1994. Environ Health Perspect 106(11):745–750.9799191
Pizent A, Macan J, Jurasović J, . 2008. Association of toxic and essential metals with atopy markers and ventilatory lung function in women and men. Sci Total Environ 390(2–3):369–376. 10.1016/j.scitotenv.2007.10.049.18045657
Pocock SJ, Shaper AG, Walker M, . 1983. Effects of tap water lead, water hardness, alcohol, and cigarettes on blood lead concentrations. J Epidemiol Community Health 37:1–7.6875437
Pocock SJ, Shaper AG, Ashby D, . 1984. Blood lead concentration, blood pressure, and renal function. Br Med J 289:872–874.6434118
Pocock SJ, Shaper AG, Ashby D, . 1988. The relationship between blood lead, blood pressure, stroke, and heart attacks in middle-aged British men. Environ Health Perspect 78:23–30.3203640
Polanska K, Hanke W, Pawlas N, . 2018. Sex-dependent impact of low-level lead exposure during prenatal period on child psychomotor functions. Int J Environ Res Public Health 15(10):2263. 10.3390/ijerph15102263.30332762
Pollack AZ, Schisterman EF, Goldman LR, . 2011. Cadmium, lead, and mercury in relation to reproductive hormones and anovulation in premenopausal women. Environ Health Perspect 119(8):1156–1161. 10.1289/ehp.1003284.21543284
Pollack AZ, Mumford SL, Wactawski-Wende J, . 2013. Bone mineral density and blood metals in premenopausal women. Environ Res 120:76–81.23122770
Pollack AZ, Mumford SL, Mendola P, . 2015. Kidney biomarkers associated with blood lead, mercury, and cadmium in premenopausal women: A prospective cohort study. J Toxicol Environ Health A 78(2):119–131. 10.1080/15287394.2014.944680.25424620
Popovic M, McNeill FE, Chettle DR, . 2005. Impact of occupational exposure on lead levels in women. Environ Health Perspect 113(4):478–484.15811839
Poreba R, Poreba M, Gać P, . 2011. Ambulatory blood pressure monitoring and structural changes in carotid arteries in normotensive workers occupationally exposed to lead. Hum Exp Toxicol 30(9):1174–1180. 10.1177/0960327110391383.21148199
Poreba R, Gac P, Poreba M, . 2012. Assessment of cardiovascular risk in workers occupationally exposed to lead without clinical presentation of cardiac involvement. Environ Toxicol Pharmacol 34(2):351–357. 10.1016/j.etap.2012.05.008.22717663
Poreba R, Gac P, Poreba M, . 2013. Echocardiographic assessment of myocardial function in workers occupationally exposed to lead without clinically evident heart disease. Environ Toxicol Pharmacol 36(2):522–528. 10.1016/j.etap.2013.05.010.23811109
Pounds JG, Leggett RW. 1998. The ICRP age-specific biokinetic model for lead: Validations, empirical comparisons, and explorations. Environ Health Perspect 106(Suppl 6):1505–1511.9860909
Pounds JG, Marlar RJ, Allen JR. 1978. Metabolism of lead-210 in juvenile and adult rhesus monkeys (Macaca mulatta). Bull Environ Contam Toxicol 19(1):684–691.98188
Power MC, Korrick S, Tchetgen Tchetgen EJ, . 2014. Lead exposure and rate of change in cognitive function in older women. Environ Res 129:69–75. 10.1016/j.envres.2013.12.010.24529005
Presley SM, Abel MT, Austin GP, . 2010. Metal concentrations in schoolyard soils from New Orleans, Louisiana before and after hurricanes Katrina and Rita. Chemosphere 80(1):67–73. 10.1016/j.chemosphere.2010.03.031.20385401
Proctor SP, Rotnitzky A, Sparrow D, . 1996. The relationship of blood lead and dietary calcium to blood pressure in the normative aging study. Int J Epidemiol 25(3):528–536.8671553
Przybyla J, Houseman EA, Smit E, . 2017. A path analysis of multiple neurotoxic chemicals and cognitive functioning in older US adults (NHANES 1999-2002). Environ Health 16(1):19. 10.1186/s12940-017-0227-3.28270159
Pugh Smith P, Nriagu JO. 2011. Lead poisoning and asthma among low-income and African American children in Saginaw, Michigan. Environ Res 111(1):81–86. 10.1016/j.envres.2010.11.007.21144501
Purchase NG, Fergusson JE. 1986. Lead in teeth: The influence of the tooth type and the sample within a tooth on lead levels. Sci Total Environ 52(3):239–250. 10.1016/0048-9697(86)90124-5.3738503
Queirolo EI, Ettinger AS, Stoltzfus RJ, . 2010. Association of anemia, child and family characteristics with elevated blood lead concentrations in preschool children from Montevideo, Uruguay. Arch Environ Occup Health 65(2):94–100. 10.1080/19338240903390313.20439228
Queiroz MLS, Almeida M, Gallão MI, . 1993. Defective neutrophil function in workers occupationally exposed to lead. Pharmacol Toxicol 72(2):73–77. 10.1111/j.1600-0773.1993.tb00293.x.8474967
Queiroz MLS, Costa FF, Bincoletto C, . 1994a. Engulfment and killing capabilities of neutrophils and phagocytic splenic function in persons occupationally exposed to lead. Int J Immunopharmacol 16(3):239–244. 10.1016/0192-0561(94)90018-3.8206690
Queiroz MLS, Perlingeiro RCR, Bincoletto C, . 1994b. Immunoglobulin levels and cellular immune function in lead exposed workers. Immunopharmacol Immunotoxicol 16(1):115–128. 10.3109/08923979409029904.8169320
Rabinowitz MB. 1995. Relating tooth and blood lead levels in children. Bull Environ Contam Toxicol 55:853–857.8601064
Rabinowitz MB, Wetherill GW, Kopple JD. 1976. Kinetic analysis of lead metabolism in healthy humans. J Clin Invest 58:260–270.783195
Rabinowitz MB, Kopple JD, Wetherill GW. 1980. Effect of food intake and fasting on gastrointestinal lead absorption in humans. Am J Clin Nutr 33:1784–1788.7405881
Rabinowitz M, Leviton A, Bellinger D. 1985. Home refinishing, lead paint and infant blood lead levels. Am J Public Health 75(4):403–404.3976969
Rabinowitz MB, Leviton A, Bellinger DC. 1989. Blood lead-tooth lead relationship among Boston children. Bull Environ Contam Toxicol 43(4):485–492. 10.1007/bf01701924.2804388
Rabinowitz MB, Leviton A, Bellinger D. 1993. Relationships between serial blood lead levels and exfoliated tooth dentin lead levels: Models of tooth lead kinetics. Calcif Tissue Int 53(5):338–341. 10.1007/bf01351840.8287322
Rabinowitz M, Bellinger D, Leviton A, . 1987. Pregnancy hypertension, blood pressure during labor, and blood lead levels. Hypertension 10:447–451.3653974
Rabinowitz MB, Allred EN, Bellinger DC, . 1990. Lead and childhood propensity to infectious and allergic disorders: Is there an association? Bull Environ Contam Toxicol 44(5):657–660. 10.1007/BF01701784.2344471
Rabito FA, Kocak M, Werthmann DW, . 2014. Changes in low levels of lead over the course of pregnancy and the association with birth outcomes. Reprod Toxicol 50:138–144. 10.1016/j.reprotox.2014.10.006.25461912
Raihan MJ, Briskin E, Mahfuz M, . 2018. Examining the relationship between blood lead level and stunting, wasting and underweight - A cross-sectional study of children under 2 years-of-age in a Bangladeshi slum. PLoS ONE 13(5):e0197856. 10.1371/journal.pone.0197856.29795643
Rajan P, Kelsey KT, Schwartz JD, . 2007. Lead burden and psychiatric symptoms and the modifying influence of the delta-aminolevulinic acid dehydratase (ALAD) polymorphism: The VA Normative Aging Study. Am J Epidemiol 166(12):1400–1408. 10.1093/aje/kwm220.17823382
Rajan P, Kelsey KT, Schwartz JD, . 2008. Interaction of the delta-aminolevulinic acid dehydratase polymorphism and lead burden on cognitive function: The VA Normative Aging Study. J Occup Environ Med 50(9):1053–1061. 10.1097/JOM.0b013e3181792463.18784554
Rajaraman P, Stewart PA, Samet JM, . 2006. Lead, genetic susceptibility, and risk of adult brain tumors. Cancer Epidemiol Biomarkers Prev 15(12):2514–2520. 10.1158/1055-9965.EPI-06-0482.17164378
Rapisarda V, Ledda C, Ferrante M, . 2016. Blood pressure and occupational exposure to noise and lead (Pb): A cross-sectional study. Toxicol Ind Health 32(10):1729–1736. 10.1177/0748233715576616.25883097
Ravnskov U. 1992. Cholesterol lowering trials in coronary heart disease: Frequency of citation and outcome. Br Med J 305:15–19.1638188
Raymond J, Brown MJ. 2015a. Childhood blood lead levels - United States, 2007-2012 [Erratum: MMWR 64(45): 1277]. MMWR Morb Mortal Wkly Rep 62(54):76–80. 10.15585/mmwr.mm6254a5.26505220
Raymond J, Brown MJ. 2015b. Childhood blood lead levels - United States, 2007-2012 [Erratum to: MMWR 62(54): 76-80]. MMWR Morb Mortal Wkly Rep 64(45):1277. https://www.cdc.gov/mmwr/pdf/wk/mm6445.pdf. June 29, 2017.26584256
Raymond J, Brown MJ. 2017. Childhood blood lead levels in children aged <5 years - United States, 2009–2014. MMWR Morb Mortal Wkly Rep 66(3):1–7. https://www.cdc.gov/mmwr/volumes/66/ss/pdfs/ss6603.pdf. June 29, 2017.28081055
Reddy KJ, Wang L, Gloss SP. 1995. Solubility and mobility of copper, zinc, and lead in acidic environments. Plant Soil 171:53–58.
Reddy YS, Aparna Y, Ramalaksmi BA, . 2014. Lead and trace element levels in placenta, maternal and cord blood: A cross-sectional pilot study. J Obstet Gynaecol Res 40(12):2184–2190. 10.1111/jog.12469.25132559
Reed BE, Moore RE, Cline SR. 1995. Soil flushing of a sandy loam contaminated with Pb(II), PbSO4 (s), PbCo3 (3) or Pb-naphthalene: Column results. J Soil Contam 4(3):243–267.
Rees DC, Duley JA, Marinaki AM. 2003. Pyrimidine 5′ nucleotidase deficiency. Br J Haematol 120(3):375–383.12580951
Reimer W, Tittelbach U. 1989. [Verhalten von herzfrequenz, blutdruck und systolischen zeitintervallen in ruhe und wahrend einhandarbeit bei bleiexponierten und kontrollpersonen]. Z Gesamte Hyg 35:491–492. (German)2815878
Rentschler G, Broberg K, Lundh T, . 2012. Long-term lead elimination from plasma and whole blood after poisoning. Int Arch Occup Environ Health 85(3):311–316. 10.1007/s00420-011-0673-0.21701834
Renzetti S, Just AC, Burris HH, . 2017. The association of lead exposure during pregnancy and childhood anthropometry in the Mexican PROGRESS cohort. Environ Res 152:226–232. 10.1016/j.envres.2016.10.014.27810680
RePORTER. 2020. Lead. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. January 7, 2020.
Reuben A, Caspi A, Belsky DW, . 2017. Association of childhood blood lead levels with cognitive function and socioeconomic status at age 38 years and with IQ change and socioeconomic mobility between childhood and adulthood. JAMA 317(12):1244–1251. 10.1001/jama.2017.1712.28350927
Rezende VB, Barbosa F, Montenegro MF, . 2008. Haplotypes of vitamin D receptor modulate the circulating levels of lead in exposed subjects. Arch Toxicol 82:29–36.17701399
Rhoads GG, Ettinger AS, Weisel CP, . 1999. The effect of dust lead control on blood lead in toddlers: A randomized trial. Pediatrics 103(3):551–555.10049955
Rhodes D, Spiro III A, Aro A, . 2003. Relationship of bone and blood lead levels to psychiatric symptoms: The normative aging study. J Occup Environ Med 45(11):1144–1151.14610395
Richter PA, Bishop EE, Wang J, . 2013. Trends in tobacco smoke exposure and blood lead levels among youths and adults in the United States: The National Health and Nutrition Examination Survey, 1999-2008. Preventing chronic disease 10:E213. 10.5888/pcd10.130056.24355106
Riddell TJ, Solon O, Quimbo SA, . 2007. Elevated blood-lead levels among children living in the rural Philippines. Bull World Health Organ 85(9):674–680.18026623
Riedt CS, Buckley BT, Brolin RE, . 2009. Blood lead levels and bone turnover with weight reduction in women. J Expo Sci Environ Epidemiol 19:90–96.18322449
Ris MD, Dietrich KN, Succop PA, . 2004. Early exposure to lead and neuropsychological outcome in adolescence. J Int Neuropsychol Soc 10(2):261–270. 10.1017/S1355617704102154.15012846
Risch HA, Burch JD, Miller AB, . 1988. Occupational factors and the incidence of cancer of the bladder in Canada. Br J Ind Med 45:361–367.3395572
Robbins N, Zhang ZF, Sun J, . 2010. Childhood lead exposure and uptake in teeth in the Cleveland area during the era of leaded gasoline. Sci Total Environ 408(19):4118–4127. 10.1016/j.scitotenv.2010.04.060.20627360
Robins JM, Cullen MR, Connors BB, . 1983. Depressed thyroid indexes associated with occupational exposure to inorganic lead. Arch Intern Med 143:220–224.6600605
Robinson G, Baumann S, Kleinbaum D, . 1985. Effects of low to moderate lead exposure on brainstem auditory evoked potentials in children. In: Environmental health, Document 3: Neurobehavioral methods in occupational and environmental health. Copenhagen, Denmark: World Health Organization, 177–182.
Rodamilans M, Osaba MJ, To-Figueras J, . 1988. Lead toxicity on endocrine testicular function in a occupationally exposed population. Hum Toxicol 7:125–128.3132417
Rodosthenous RS, Burris HH, Svensson K, . 2017. Prenatal lead exposure and fetal growth: Smaller infants have heightened susceptibility. Environ Int 99:228–233. 10.1016/j.envint.2016.11.023.27923585
Rodrigues JL, Batista BL, Nunes JA, . 2008. Evaluation of the use of human hair for biomonitoring the deficiency of essential and exposure to toxic elements. Sci Total Environ 405(1–3):370–376. 10.1016/j.scitotenv.2008.06.002.18632136
Rodrigues EG, Bellinger DC, Valeri L, . 2016. Neurodevelopmental outcomes among 2- to 3-year-old children in Bangladesh with elevated blood lead and exposure to arsenic and manganese in drinking water. Environ Health 15:44. 10.1186/s12940-016-0127-y.26968381
Roels H, Lauwerys R. 1987. Evaluation of dose-effect and dose-response relationships for lead exposure in different Belgian population groups (fetus, child, adult men and women). Trace Elem Med 4(2):80–87.
Roels H, Lauwerys R, Buchet J, . 1975. Response of free erythrocyte porphyrin and urinary δ-aminolevulinic acid in men and women moderately exposed to lead. Int Arch Occup Environ Health 34(2):97–108.
Roels H, Buchet JP, Lauwerys R, . 1976. Impact of air pollution by lead on the heme biosynthetic pathway in school-age children. Arch Environ Health Nov/Dec:310–315.999344
Roels HA, Balis-Jacques MN, Buchet J-P, . 1979. The influence of sex and of chelation therapy on erythrocyte protoporphyrin and urinary [delta]-aminolevulinic acid in lead-exposed workers. J Occup Environ Med 21(8):527–539.
Roels H, Lauwerys R, Konings J, . 1994. Renal function and hyperfiltration capacity in lead smelter workers with high bone lead. Occup Environ Med 51:505–512.7951773
Roels H, Konings J, Green S, . 1995. Time-integrated blood lead concentration is a valid surrogate for estimating the cumulative lead dose assessed by tibial lead measurement. Environ Res 69(2):75–82.8608773
Rokadia H, Agarwal S. 2013. Serum heavy metals and obstructive lung disease: Results from the National Health and Nutrition Examination Survey. Chest 143(2):388–397. 10.1378/chest.12-0595.22911427
Romeo R, Aprea C, Boccalon P, . 1996. Serum erythropoietin and blood lead concentrations. Int Arch Occup Environ Health 69:73–75.9017439
Ronco AM, Gutierrez Y, Gras N, . 2010. Lead and arsenic levels in women with different body mass composition. Biol Trace Elem Res 136:269–278. 10.1007/s12011-009-8546-z.19851721
Rooney CP, McLaren RG, Condron LM. 2007. Control of lead solubility in soil contaminated with lead shot: Effect of soil pH. Environ Pollut 149:149–157. 10.1016/j.envpol.2007.01.009.17360092
Rooney JPK, Woods NF, Martin MD, . 2018. Genetic polymorphisms of GRIN2A and GRIN2B modify the neurobehavioral effects of low-level lead exposure in children. Environ Res 165:1–10. 10.1016/j.envres.2018.04.001.29655037
Root RA. 2000. Lead loading of urban streets by motor vehicle wheel weights. Environ Health Perspect 108(10):937–940.11049812
Roscoe RJ, Gittleman JL, Deddens JA, . 1999. Blood lead levels among children of lead-exposed workers: A meta-analysis. Am J Med 36(4):475–481.
Rosen JF, Chesney RW, Hamstra A, . 1980. Reduction in 1,25-dihydroxyvitamin D in children with increased lead absorption. N Engl J Med 302(20):1128–1131.7366636
Rosenman KD, Sims A, Luo Z, . 2003. Occurrence of lead-related symptoms below the current occupational safety and health act allowable blood lead levels. J Occup Environ Med 45(5):546–555.12762080
Rothenberg SJ, Schnaas L, Cansino-Ortiz S, . 1989. Neurobehavioral deficits after low level lead exposure in neonates: The Mexico City pilot study. Neurotoxicol Teratol 11:85–93.2733657
Rothenberg SJ, Karchmer S, Schnaas L, . 1994a. Changes in serial blood lead levels during pregnancy. Environ Health Perspect 102(10):876–880. 10.1289/ehp.94102876.9644197
Rothenberg SJ, Manalo M, Jiang J, . 1999a. Blood lead level and blood pressure during pregnancy in South Central Los Angeles. Arch Environ Health 54(6):382–389. 10.1080/00039899909603369.10634227
Rothenberg SJ, Manalo M, Jiang J, . 1999b. Maternal blood lead level during pregnancy in South Central Los Angeles. Arch Environ Health 54(3):151–157. 10.1080/00039899909602253.10444035
Rothenberg SJ, Kondrashov V, Manalo M, . 2002. Increases in hypertension and blood pressure during pregnancy with increased bone lead levels. Am J Epidemiol 156(12):1079–1087.12480651
Rousseau MC, Parent ME, Nadon L, . 2007. Occupational exposure to lead compounds and risk of cancer among men: A population-based case-control study. Am J Epidemiol 166(9):1005–1014. 10.1093/aje/kwm183.17690218
Roussel H, Waterlot C, Pelfrene A, . 2010. Cd, Pb and Zn oral bioaccessibility of urban soils contaminated in the past by atmospheric emissions from two lead and zinc smelters. Arch Environ Contam Toxicol 58(4):945–954. 10.1007/s00244-009-9425-5.20016887
Roy MM, Gordon CL, Beaumont LF, . 1997. Further experience with bone lead content measurements in residents of southern Ontario. Appl Radiat Isot 48(3):391–396. 10.1016/s0969-8043(96)00223-0.9116655
Roy A, Bellinger D, Hu H, . 2009. Lead exposure and behavior among young children in Chennai, India. Environ Health Perspect 117(10):1607–1611. 10.1289/ehp.0900625.20019913
Roy A, Hu H, Bellinger DC, . 2011. Hemoglobin, lead exposure, and intelligence quotient: Effect modification by the DRD2 Taq IA polymorphism. Environ Health Perspect 119(1):144–149. 10.1289/ehp.0901878.21205584
Ruby MV, Schoof R, Brattin W, . 1999. Advances in evaluating the oral bioavailability of inorganics in soil for use in human health risk assessment. Environ Sci Technol 33(21):3697–3705.
Ruebner RL, Hooper SR, Parrish C, . 2019. Environmental lead exposure is associated with neurocognitive dysfunction in children with chronic kidney disease. Pediatr Nephrol 34(11):2371–2379. 10.1007/s00467-019-04306-7.31327061
Ryan JA, Scheckel KG, Berti WR, . 2004. Reducing children’s risk from lead in soil. Environ Sci Technol 38:19A–24A.14740712
Ryu JE, Ziegler EE, Nelson SE, . 1983. Dietary intake of lead and blood lead concentration in early infancy. Am J Dis Child 137:886–891.6613955
Sabin LD, Schiff KC. 2008. Dry atmospheric deposition rates of metals along a coastal transect in southern California. Atmos Environ 42(27):6606–6613. 10.1016/j.atmosenv.2008.04.042.
Sabin LD, Lim JH, Stolzenbach KD, . 2006. Atmospheric dry deposition of trace metals in the coastal region of Los Angeles, California, USA. Environ Toxicol Chem 25(9):2334–2341. 10.1897/05-300r.1.16986787
Sadeghniiat-Haghighi K, Saraie M, Ghasemi M, . 2013. Assessment of peripheral neuropathy in male hospitalized patients with lead toxicity in Iran. J Res Med Sci 18(1):6–9.23901334
Saikat S, Barnes B, Westwood D. 2007. A review of laboratory results for bioaccessibility values of arsenic, lead and nickel in contaminated UK soils. J Environ Sci Health A Tox Hazard Subst Environ En 42(9):1213–1221. 10.1080/10934520701435486.
Sakai T. 2000. Biomarkers of lead exposure. Ind Health 38:127–142.10812836
Sakai T, Morita Y. 1996. delta-Aminolevulinic acid in plasma or whole blood as a sensitive indicator of lead effects, and its relation to the other heme-related parameters. Int Arch Occup Environ Health 68:126–132.8720283
Sakai T, Yanagihara S, Kunugi Y, . 1982. Relationships between distribution of lead in erythrocytes in vivo and in vitro and inhibition of ALA-D. Br J Ind Med 39:382–387.7138797
Sakai T, Yanagihara S, Kunugi Y, . 1983. Mechanisms of ALA-D inhibition by lead and of its restoration by zinc and dithiothreitol. Br J Ind Med 40:61–66.6824601
Sakai T, Morita Y, Araki T, . 2000. Relationship between delta-aminolevulinic acid dehydratase genotypes and heme precursors in lead workers. Am J Ind Med 38:355–360.10940976
Sakata S, Shimizu S, Ogoshi K, . 2007. Inverse relationship between serum erythropoietin and blood lead concentrations in Kathmandu tricycle taxi drivers. Int Arch Occup Environ Health 80(4):342–345. 10.1007/s00420-006-0125-4.16838166
Sallmén M, Lindbohm M-L, Nurminen M. 2000. Paternal exposure to lead and infertility. Epidemiology 11(2):148–152.11021611
Sallmén M, Anttila A, Lindbohm ML, . 1995. Time to pregnancy among women occupationally exposed to lead. J Occup Environ Med 37(8):931–934.8520955
Sanin LH, Gonzalez-Cossio T, Romieu I, . 2001. Effect of maternal lead burden on infant weight and weight gain at one month of age among breastfed infants. Pediatrics 107(5):1016–1023.11331680
Sankila R, Karjalainen A, Pukkala E, . 1990. Cancer risk among glass factory workers: An excess of lung cancer? Br J Ind Med 47:815–818.2271387
Sanna E, Vallascas E. 2011. Hair lead levels to evaluate the subclinical impact of lead on growth in Sardinian children (Italy). Am J Hum Biol 23(6):740–746. 10.1002/ajhb.21203.21858896
Santibanez M, Vioque J, Alguacil J, . 2008. Occupational exposures and risk of oesophageal cancer by histological type: A case-control study in eastern Spain. Occup Environ Med 65(11):774–781. 10.1136/oem.2007.037929.18614460
Sarasua SM, Vogt RF, Henderson LO, . 2000. Serum immunoglobulins and lymphocyte subset distributions in children and adults living in communities assessed for lead and cadmium exposure. J Toxicol Environ Health A 60(1):1–15. 10.1080/009841000156556.10832614
Sata F, Araki S, Tanigawa T, . 1998. Changes in T cell subpopulations in lead workers. Environ Res 76(1):61–64.9466898
Sauve S, McBride MB, Hendershot WH. 1997. Speciation of lead in contaminated soils. Environ Pollut 98(2):149–155.
Schalscha EB, Morales M, Pratt PF. 1987. Lead and molybdenum in soils and forage near an atmospheric source. J Environ Qual 16(4):313–315.
Schaumberg DA, Mendes F, Balaram M, . 2004. Accumulated lead exposure and risk of age-related cataract in men. JAMA 292(22):2750–2754.15585735
Scheckel KG, Diamond GL, Burgess MF, . 2013. Amending soils with phosphate as means to mitigate soil lead hazard: A critical review of the state of the science. J Toxicol Environ Health B Crit Rev 16(6):337–380. 10.1080/10937404.2013.825216.24151967
Schell LM, Denham M, Stark AD, . 2004. Relationship between blood lead concentration and dietary intakes of infants from 3 to 12 months of age. Environ Res 96(3):264–273. 10.1016/j.envres.2004.02.008.15364593
Schell LM, Denham M, Stark AD, . 2009. Growth of infants’ length, weight, head and arm circumferences in relation to low levels of blood lead measured serially. Am J Hum Biol 21(2):180–187. 10.1002/ajhb.20842.18991336
Schmitt MDC, Trippler DJ. 1988. Soil lead concentrations in residential Minnesota as measured by ICP-AES. Water Air Soil Pollut 39:157–168.
Schmitt CJ, Brumbaugh WG. 1990. National contaminant biomonitoring program: Concentrations of arsenic, cadmium, copper, lead, mercury, selenium, and zinc in U.S. freshwater fish, 1976-1984. Arch Environ Contam Toxicol 19:731–747.21318505
Schnaas L, Rothenberg SJ, Perroni E, . 2000. Temporal pattern in the effect of postnatal blood lead level on intellectual development of young children. Neurotoxicol Teratol 22:805–810.11120385
Schnaas L, Rothenberg SJ, Flores MF, . 2004. Blood lead secular trend in a cohort of children in Mexico City (1987-2002). Environ Health Perspect 112(10):1110–1115.15238286
Schnaas L, Rothenberg SJ, Flores MF, . 2006. Reduced intellectual development in children with prenatal lead exposure. Environ Health Perspect 114(5):791–797. 10.1289/ehp.8552.16675439
Schober SE, Mirel LB, Graubard BI, . 2006. Blood lead levels and death from all causes, cardiovascular disease, and cancer: Results from the NHANES III Mortality Study. Environ Health Perspect 114(10):1538–1541.17035139
Schroeder HA, Tipton IH. 1968. The human body burden of lead. Arch Environ Occup Health 17(6):965–978.
Schuhmacher M, Hernandez M, Domingo JL, . 1996. A longitudinal study of lead mobilization during pregnancy: Concentration in maternal and umbilical cord blood. Trace Elem Electrolytes 13:177–181.
Schuhmacher M, Paternain JL, Domingo JL, . 1997. An assessment of some biomonitors indicative of occupational exposure to lead. Trace Elem Electrolytes 14(3):145–149.
Schumacher C, Brodkin CA, Alexander B, . 1998. Thyroid function in lead smelter workers: Absence of subacute or cumulative effects with moderate lead burdens. Int Arch Occup Environ Health 71(7):453–458.9826077
Schütz A, Skerfving S, Ranstam J, . 1987. Kinetics of lead in blood after the end of occupational exposure. Scand J Work Environ Health 13:221–231.3616551
Schütz A, Bergdahl IA, Ekholm A, . 1996. Measurement by ICP-MS of lead in plasma and whole blood of lead workers and controls. Occup Environ Med 53:736–740.9038796
Schwanitz G, Lehnert G, Gebhart E. 1970. Chromosome damage after occupational exposure to lead. Dtsch Med Wochenschr 95(32):1636–1641.5433400
Schwanitz G, Gebhart E, Rott H-D, . 1975. [Chromosomenuntersuchungen bei Personen mit beruflicher Bleiexposition]. Dtsch Med Wochenschr 100(18):1007–1011. (German)
Schwartz J. 1995. Lead, blood pressure, and cardiovascular disease in men. Arch Environ Health 50(1):31–37.7717767
Schwartz J, Otto D. 1987. Blood lead, hearing threshold, and neurobehavioral development in children and youth. Arch Environ Health 42(2; 2):153–160.3606213
Schwartz J, Pitcher H. 1989. The relationship between gasoline lead and blood lead in the United States. J off Stat 5:421–431.
Schwartz J, Otto D. 1991. Lead and minor hearing impairment. Arch Environ Health 46(5):300–305.1953038
Schwartz J, Landrigan PJ, Feldman RG, . 1988. Threshold effect in lead-induced peripheral neuropathy. J Pediatr 112:12–17.2826742
Schwartz J, Landrigan PJ, Baker EL, . 1990. Lead-induced anemia: Dose-response relationships and evidence for a threshold. Am J Public Health 80(2):165–168.2297059
Schwartz BS, Lee BK, Stewart W, . 1995. Associations of delta-aminolevulinic acid dehydratase genotype with plant, exposure duration, and blood lead and zinc protoporphyrin levels in Korean lead workers. Am J Epidemiol 142(7):738–745.7572945
Schwartz BS, Lee BK, Stewart W, . 1997a. Associations of subtypes of hemoglobin with delta-aminolevulinic acid dehydratase genotype and dimercaptosuccinic acid-chelatable lead levels. Arch Environ Health 52(2):97–103.9124882
Schwartz BS, Lee B-K, Stewart W, . 1997b. delta-Aminolevulinic acid dehydratase genotype modifies four hour urinary lead excretion after oral administration of dimercaptosuccinic acid. Occup Environ Med 54(4):241–246.9166129
Schwartz BS, Lee B-K, Lee G-S, . 2000a. Associations of blood lead, dimercaptosuccinic acid-chelatable lead, and tibia lead with polymorphisms in the vitamin D receptor and [delta]-aminolevulinic acid dehydratase genes. Environ Health Perspect 108(10):949–954.
Schwartz BS, Stewart W, Bolla K, . 2000b. Past adult lead exposure is associated with longitudinal decline in cognitive function. Neurology 55(8):1144–1150.11071492
Schwartz BS, Stewart WF, Todd AC, . 2000c. Different associations of blood lead, meso 2,3-dimercaptosuccinic acid (DMSA)-chelatable lead, and tibial lead levels with blood pressure in 543 organolead manufacturing workers. Arch Environ Health 55:85–92.10821507
Schwartz BS, Lee B, Lee G, . 2001. Associations of blood lead, dimercaptosuccinic acid-chelatable lead, and tibia lead with neurobehavioral test scores in South Korean lead workers. Am J Epidemiol 153(5):453–464.11226977
Schwartz BS, Lee BK, Bandeen-Roche K, . 2005. Occupational lead exposure and longitudinal decline in neurobehavioral test scores. Epidemiology 16(1):106–113. 10.1097/01.ede.0000147109.62324.51.15613953
Scinicariello F, Buser MC. 2015. Blood cadmium and depressive symptoms in young adults (aged 20-39 years). Psychol Med 45(4):807–815.25115444
Scinicariello F, Abadin HG, Murray HE. 2011. Association of blood lead and blood pressure in the NHANES 1999-2006. Environ Res 111(8):1249–1257.21907978
Scinicariello F, Murray HE, Moffett DB, . 2007. Lead and delta-aminolevulinic acid dehydratase polymorphism: Where does it lead? A meta-analysis. Environ Health Perspect 115(1):35–41. 10.1289/ehp.9448.
Scinicariello F, Yesupriya A, Chang MH, . 2010. Modification by ALAD of the association between blood lead and blood pressure in the U.S. population: Results from the Third National Health and Nutrition Examination Survey. Environ Health Perspect 118(2):259–264. 10.1289/ehp.0900866.20123609
Scinicariello F, Buser MC, Mevissen M, . 2013. Blood lead level association with lower body weight in NHANES 1999-2006. Toxicol Appl Pharmacol 273(3):516–523. 10.1016/j.taap.2013.09.022.24099784
Sears ME, Kerr KJ, Bray RI. 2012. Arsenic, cadmium, lead, and mercury in sweat: A systematic review. J Environ Public Health 2012:184745. 10.1155/2012/184745.22505948
Secchi GC, Erba L, Cambiaghi G. 1974. delta-Aminolevulinic dehydratase activity of erythrocytes and liver tissue in man. Relationship to lead exposure. Arch Environ Health 28:130–132.4810883
Sedman RM, Mahmood RJ. 1994. Soil ingestion by children and adults reconsidered using the results of recent tracer studies. Air Waste 44(2):141–144. 10.1080/1073161x.1994.10467242.8142089
Seegal RF, Fitzgerald EF, McCaffrey RJ, . 2013. Tibial bone lead, but not serum polychlorinated biphenyl, concentrations are associated with neurocognitive deficits in former capacitor workers. J Occup Environ Med 55(5):552–562. 10.1097/JOM.0b013e318285f3fd.23618890
Selevan SG, Landrigan PJ, Stern FB, . 1985. Mortality of lead smelter workers. Am J Epidemiol 122:673–683.4025307
Selevan SG, Rice DC, Hogan KA, . 2003. Blood lead concentration and delayed puberty in girls. N Engl J Med 348(16):1527–1536. 10.1056/NEJMoa020880.12700372
Selonen S, Liiri M, Strommer R, . 2012. The fate of lead at abandoned and active shooting ranges in a boreal pine forest. Environ Toxicol Chem 31(12):2771–2779. 10.1002/etc.1998.22933087
Seo J, Lee BK, Jin SU, . 2014. Lead-induced impairments in the neural processes related to working memory function. PLoS ONE 9(8):e105308. 10.1371/journal.pone.0105308.25141213
Seto DSY, Freeman JM. 1964. Lead neuropathy in childhood. Am J Dis Child 107:337–342.14109491
Shadbegian R, Guignet D, Klemick H, . 2019. Early childhood lead exposure and the persistence of educational consequences into adolescence. Environ Res 178:108643. 10.1016/j.envres.2019.108643.31473504
Shah F, Kazi TG, Afridi HI, . 2010. Environmental exposure of lead and iron deficit anemia in children age ranged 1-5 years: A cross sectional study. Sci Total Environ 408(22):5325–5330. 10.1016/j.scitotenv.2010.07.091.20801490
Shah F, Kazi TG, Afridi HI, . 2011. The influence of environmental exposure on lead concentrations in scalp hair of children in Pakistan. Ecotoxicol Environ Saf 74(4):727–732. 10.1016/j.ecoenv.2010.10.036.21071086
Shaheen SM, Tsadilas CD. 2009. Concentration of lead in soils and some vegetable plants in north Nile Delta as affected by soil type and irrigation water. Commun Soil Sci Plant Anal 40(1–6):327–344.
Shaik AP, Jamil K. 2009. Individual susceptibility and genotoxicity in workers exposed to hazardous materials like lead. J Hazard Mater 168(2–3):918–924. 10.1016/j.jhazmat.2009.02.129.19327888
Shao W, Liu Q, He X, . 2017. Association between level of urinary trace heavy metals and obesity among children aged 6-19 years: NHANES 1999-2011. Environ Sci Pollut Res Int 24:11573–11581. 10.1007/s11356-017-8803-1.28321702
Shaper AG, Pocock SJ, Walker M, . 1981. British regional heart study: Cardiovascular risk factors in middle-aged men in 24 towns. Br Med J 283:179–186.6789956
Sharp DS, Osterloh J, Becker CE, . 1988. Blood pressure and blood lead concentration in bus drivers. Environ Health Perspect 78:131–137.3203632
Sharp DS, Smith AH, Holman BL, . 1989. Elevated blood pressure in treated hypertensives with low-level lead accumulation. Arch Environ Health 44:18–22.2563647
Sharp DS, Benowitz NL, Osterloh JD, . 1990. Influence of race, tobacco use, and caffeine use on the relation between blood pressure and blood lead concentration. Am J Epidemiol 131(5):845–854.2321627
Sheffet A, Thind I, Miller AM, . 1982. Cancer mortality in a pigment plant utilizing lead and zinc chromates. Arch Environ Health 37(1):44–52.7059230
Shen XM, Yan CH, Guo D, . 1998. Low-level prenatal lead exposure and neurobehavioral development of children in the first year of life: A prospective study in Shanghai. Environ Res 79:1–8.9756675
Shen X, Wu S, Yan C, . 2001. delta-Aminolevulinate dehydratase polymorphism and blood lead levels in Chinese children. Environ Res 85(3):185–190.11237505
Shepherd TJ, Dirks W, Roberts NM, . 2016. Tracing fetal and childhood exposure to lead using isotope analysis of deciduous teeth. Environ Res 146:145–153. 10.1016/j.envres.2015.12.017.26752082
Sherlock J, Quinn M. 1986. Relationship between blood lead concentrations and dietary lead intake in infants: The Glasgow Duplicate Diet Study 1979–1980. Food Addit Contam 3(2):167–176.3709889
Sherlock J, Smart G, Forbes GI, . 1982. Assessment of lead intakes and dose-response for a population in Ayr exposed to a plumbosolvent water supply. Hum Toxicol 1:115–122.7173892
Sherlock JC, Ashby D, Delves HT, . 1984. Reduction in exposure to lead from drinking water and its effect on blood lead concentrations. Hum Toxicol 3:383–392.6490022
Shiau C, Wang J, Chen P. 2004. Decreased fecundity among male lead workers. Occup Environ Med 61(11):915–923.15477285
Shih RA, Glass TA, Bandeen-Roche K, . 2006. Environmental lead exposure and cognitive function in community-dwelling older adults. Neurology 67(9):1556–1562. 10.1212/01.wnl.0000239836.26142.c5.16971698
Shih RA, Hu H, Weisskopf MG, . 2007. Cumulative lead dose and cognitive function in adults: A review of studies that measured both blood lead and bone lead. Environ Health Perspect 115:483–492. 10.1289/ehp.9786.17431502
Shiue I. 2014. Higher urinary heavy metal, phthalate, and arsenic but not parabens concentrations in people with high blood pressure, U.S. NHANES, 2011-2012. Int J Environ Res Public Health 11:5989–5999. 10.3390/ijerph110605989.24905244
Siciliano SD, James K, Zhang G, . 2009. Adhesion and enrichment of metals on human hands from contaminated soil at an Arctic urban brownfield. Environ Sci Technol 43(16):6385–6390.19746741
Siegel M, Forsyth B, Siegel L, . 1989. The effect of lead on thyroid function in children. Environ Res 49:190–196.2753005
Siemiatycki J. 1991. Exposure assessment. In: Risk factors for cancer in the workplace. Boca Raton, FL: CRC Press, 45–49, 84, 141–145, 198–199, 210, 215.
Silbergeld EK, Schwartz J, Mahaffey K. 1988. Lead and osteoporosis: Mobilization of lead from bone in postmenopausal women. Environ Res 47(1):79–94.3168967
Silberstein T, Saphier O, Paz-Tal O, . 2006. Lead concentrates in ovarian follicle compromises pregnancy. J Trace Elem Med Biol 20(3):205–207. 10.1016/j.jtemb.2006.05.001.16959598
Silver MK, Li X, Liu Y, . 2016. Low-level prenatal lead exposure and infant sensory function. Environ Health 15(1):65. 10.1186/s12940-016-0148-6.27266277
Simon DL, Maynard EJ, Thomas KD. 2007. Living in a sea of lead - Changes in blood- and hand-lead of infants living near a smelter. J Expo Sci Environ Epidemiol 17(3):248–259. 10.1038/sj.jes.7500512.16823398
Simons TJB. 1985. Influence of lead ions on cation permeability in human red cell ghosts. J Membr Biol 84:61–71.3999125
Simons TJB. 1986a. The role of anion transport in the passive movement of lead across the human red cell membrane. J Physiol 378:287–312.3025431
Simons TJB. 1986b. Passive transport and binding of lead by human red blood cells. J Physiol 378:267–286.3795106
Simons TJB. 1988. Active transport of lead by the calcium pump in human red cell ghosts. J Physiol 405:105–113.2855638
Simons TJ. 1993. Lead transport and binding by human erythrocytes in vitro. Toxicol Lett 423:307–313.
Simons TJB, Pocock G. 1987. Lead enters bovine adrenal medullary cells through calcium channels. J Neurochem 48:383–389.2432178
Singh Z, Chadha P, Sharma S. 2013. Evaluation of oxidative stress and genotoxicity in battery manufacturing workers occupationally exposed to lead. Toxicol Int 20(1):95–100. 10.4103/0971-6580.111550.23833444
Singh B, Chandran V, Bandhu HK, . 2000. Impact of lead exposure on pituitary-thyroid axis in humans. Biometals 13:187–192.11016408
Sioen I, Den Hond E, Nelen V, . 2013. Prenatal exposure to environmental contaminants and behavioural problems at age 7-8 years. Environ Int 59:225–231. 10.1016/j.envint.2013.06.014.23845936
Sirivarasai J, Wananukul W, Kaojarern S, . 2013. Association between inflammatory marker, environmental lead exposure, and glutathione S-transferase gene. Biomed Res Int 2013:474963. 10.1155/2013/474963.23484121
Sithisarankul P, Schwartz BS, Lee BK, . 1997. Aminolevulinic acid dehydratase genotype mediates plasma levels of the neurotoxin, 5-aminolevulinic acid, in lead-exposed workers. Am J Ind Med 32(1):15–20. 10.1002/(sici)1097-0274(199707)32:1<15::aid-ajim2>3.0.co;2-q.9131207
Skerfving S. 1988. Biological monitoring of exposure to inorganic lead. In: Clarkson TW, Friberg L, Nordberg G, ., eds. Biological monitoring of toxic metals. New York, NY: Plenum Press, 169–197.
Skerfving S, Bergdahl IA. 2015. Lead. In: Nordberg GF, Fowler BA, eds. Handbook of toxicology of metals. Specific metals, Volume II. 4th ed. Boston, MA: Academic Press, 911–967.
Skerfving S, Ahlgren L, Christoffersson JO, . 1985. Metabolism of inorganic lead in man. Nutr Res Suppl 1:601–607.
Slivkova J, Popelkova M, Massanyi P, . 2009. Concentration of trace elements in human semen and relation to spermatozoa quality. J Environ Sci Health A Tox Hazard Subst Environ Eng 44(4):370–375. 10.1080/10934520802659729.19184704
Smith GR. 1995. Lead. Minerals yearbook: Volume I. Metals and minerals. U.S. Geological Survey. http://minerals.usgs.gov/minerals/pubs/commodity/lead/380495.pdf. October 5, 2007.
Smith FL, Rathmell TK, Marcil GE. 1938. The early diagnosis of acute and latent plumbism. Am J Clin Pathol 8:471–508.
Smith DR, Osterloh JD, Flegal AR. 1996. Use of endogenous, stable lead isotopes to determine release of lead from the skeleton. Environ Health Perspect 104(1):60–66.8834863
Smith DR, Ilustre RP, Osterloh JD. 1998a. Methodological considerations for the accurate determination of lead in human plasma and serum. Am J Ind Med 33:430–438.9557166
Smith DR, Kahng MW, Quintanilla-Vega B, . 1998b. High-affinity renal lead-binding proteins in environmentally-exposed humans. Toxicol Appl Pharmacol 115:39–52.
Smith D, Hernandez-Avila M, Tellez-Rojo MM, . 2002. The relationship between lead in plasma and whole blood in women. Environ Health Perspect 110(3):263–268.11882477
Smith E, Weber J, Naidu R, . 2011. Assessment of lead bioaccessibility in peri-urban contaminated soil. J Hazard Mater 186(1):300–305. 10.1016/j.jhazmat.2010.10.111.21115224
Sobin C, Gutierrez M, Alterio H. 2009. Polymorphisms of delta-aminolevulinic acid dehydratase (ALAD) and peptide transporter 2 (PEPT2) genes in children with low-level lead exposure. Neurotoxicology 30(6):881–887. 10.1016/j.neuro.2009.08.006.19723536
Sobin C, Flores-Montoya MG, Gutierrez M, . 2015. delta-Aminolevulinic acid dehydratase single nucleotide polymorphism 2 (ALAD2) and peptide transporter 2*2 haplotype (hPEPT2*2) differently influence neurobehavior in low-level lead exposed children. Neurotoxicol Teratol 47:137–145. 10.1016/j.ntt.2014.12.001.25514583
Sokas RK, Simmens S, Sophar K, . 1997. Lead levels in Maryland construction workers. Am J Ind Med 31:188–194.9028435
Soldin OP, Pezzullo JC, Hanak B, . 2003. Changing trends in the epidemiology of pediatric lead exposure: Interrelationship of blood lead and ZPP concentrations and a comparison to the US population. Ther Drug Monit 25(4):415–420.12883223
Solliway BM, Schaffer A, Pratt H, . 1996. Effects of exposure to lead on selected biochemical and haematological variables. Pharmacol Toxicol 78:18–22.8685081
Somashekaraiah BV, Venkaiah B, Prasad ARK. 1990. Biochemical diagnosis of occupational exposure to lead toxicity. Bull Environ Contam Toxicol 44:268–275.2322668
Songdej N, Winters PC, McCabe MJ, . 2010. A population-based assessment of blood lead levels in relation to inflammation. Environ Res 110(3):272–277. 10.1016/j.envres.2009.12.008.20116055
Sonmez O, Bukun B, Kaya C, . 2008. The assessment of tolerance to heavy metals (Cd, Pb and Zn) and their accumulation in three weed species. Pak J Bot 40(2):747–754.
Sönmez F, Dönmez O, Keskınoğlu A, . 2002. Lead exposure and urinary N-acetyl β D glucosaminidase activity in adolescent workers in auto repair workshops. J Adolesc Health 30(3):213–216.11869929
Soto-Jiménez MF, Flegal AR. 2009. Origin of lead in the Gulf of California Ecoregion using stable isotope analysis. J Geochem Explor 101(3):209–217. 10.1016/j.gexplo.2008.07.003.
Spear TM, Svee W, Vincent JH, . 1998. Chemical speciation of lead dust associated with primary lead smelting. Environ Health Perspect 106(9):565–571.9721256
Specht AJ, Weisskopf M, Nie LH. 2018. Childhood lead biokinetics and associations with age among a group of lead-poisoned children in China. J Expo Sci Environ Epidemiol 29(3):416–423. 10.1038/s41370-018-0036-y.29706621
Specht AJ, Lin Y, Weisskopf M, . 2016. XRF-measured bone lead (Pb) as a biomarker for Pb exposure and toxicity among children diagnosed with Pb poisoning. Biomarkers 21(4):347–352. 10.3109/1354750x.2016.1139183.26856822
Spector JT, Navas-Acien A, Fadrowski J, . 2011. Associations of blood lead with estimated glomerular filtration rate using MDRD, CKD-EPI and serum cystatin C-based equations. Nephrol Dial Transplant 26(9):2786–2792. 10.1093/ndt/gfq773.21248295
Staessen JA, Roels H, Fagard R. 1996b. Lead exposure and conventional and ambulatory blood pressure. A prospective population study. J Am Med Assoc 275(20):1563–1570.
Staessen J, Bulpitt C, Roels H, . 1984. Urinary cadmium and lead concentrations and their relation to blood pressure in a population with low exposure. Br J Ind Med 41(2):241–248.6372852
Staessen J, Yeoman WB, Fletcher AE, . 1990. Blood lead concentration, renal function, and blood pressure in London civil servants. Br J Ind Med 47:442–447.1974456
Staessen JA, Lauwerys RR, Buchet JP, . 1992. Impairment of renal function with increasing blood lead concentrations in the general population. N Engl J Med 327:151–156.1608406
Staessen JA, Lauwerys RR, Bulpitt CJ, . 1994. Is a positive association between lead exposure and blood pressure supported by animal experiments? Curr Opin Nephrol Hypertens 3(3):257–263.7922250
Staessen JA, Buchet J-P, Ginucchio G, . 1996a. Public health implications of environmental exposure to cadmium and lead: An overview of epidemiological studies in Belgium. J Cardiovasc Risk 3(1):26–41.8783028
Staessen JA, T O’Brien E, Thijs L, . 2000. Modern approaches to blood pressure measurement. Occup Environ Med 57(8):510–520.10896957
Staessen JA, Nawrot T, Den Hond E, . 2001. Renal function, cytogenetic measurements, and sexual development in adolescents in relation to environmental pollutants: A feasibility study of biomarkers. Lancet 357(9269):1660–1669.11425371
Stanek EJ, Calabrese EJ, Xu B. 2012. Meta-analysis of mass-balance studies of soil ingestion in children. Risk Anal 32(3):433–447. 10.1111/j.1539-6924.2011.01673.x.21883335
Stanek EJ, Calabrese EJ, Barnes R, . 1997. Soil ingestion in adults - Results of a second pilot study. Ecotoxicol Environ Saf 36(3):249–257. 10.1006/eesa.1996.1510.9143453
Stauber JL, Florence TM. 1988. A comparative study of copper, lead, cadmium and zinc in human sweat and blood. Sci Total Environ 74:235–247.3222694
Stauber JL, Florence TM, Gulson BL, . 1994. Percutaneous absorption of inorganic lead compounds. Sci Total Environ 145:55–70.8016629
Steenhout A. 1982. Kinetics of lead storage in teeth and bones: An epidemiologic approach. Arch Environ Health 37(4):224–231. 10.1080/00039896.1982.10667569.7114903
Steenhout A, Pourtois M. 1981. Lead accumulation in teeth as a function of age with different exposures. Br J Ind Med 38(3):297–303. 10.1136/oem.38.3.297.7272245
Steenhout A, Pourtois M. 1987. Age-related lead kinetics in children. In: Trace elements in human health and disease. Second Nordic symposium, Odense, Denmark. Copenhagen, Denmark: World Health Organization, 144–147.
Steenland K, Boffetta P. 2000. Lead and cancer in humans: Where are we now? Am J Ind Med 38:295–299.10940967
Steenland K, Selevan S, Landrigan P. 1992. The mortality of lead smelter workers: An update. Am J Public Health 82(12):1641–1644.1456339
Steenland K, Barry V, Anttila A, . 2017. A cohort mortality study of lead-exposed workers in the USA, Finland and the UK. Occup Environ Med 74(11):785–791. 10.1136/oemed-2017-104311.28546320
Steenland K, Barry V, Anttila A, . 2019. Cancer incidence among workers with blood lead measurements in two countries. Occup Environ Med 76(9):603–610. 10.1136/oemed-2019-105786.31296664
Stern AH. 1994. Derivation of a target level of lead in soil at residential sites corresponding to a de minimis contribution to blood lead concentration. Risk Anal 14(6):1049–1056.7846312
Stern AH. 1996. Derivation of a target concentration of Pb in soil based on elevation of adult blood pressure. Risk Anal 16(2):201–210.8638039
Stewart WF, Schwartz BS, Simon D, . 2002. ApoE genotype, past adult lead exposure, and neurobehavioral function. Environ Health Perspect 110(5):501–505.
Stollery BT, Banks HA, Broadbent DE, . 1989. Cognitive functioning in lead workers. Br J Ind Med 46:698–707.2818958
Stollery BT, Broadbent DE, Banks HA, . 1991. Short term prospective study of cognitive functioning in lead workers. Br J Ind Med 48:739–749.1954152
Stroustrup A, Hsu HH, Svensson K, . 2016. Toddler temperament and prenatal exposure to lead and maternal depression. Environ Health 15(1):71. 10.1186/s12940-016-0147-7.27312840
Stuik EJ. 1974. Biological response of male and female volunteers to inorganic lead. Int Arch Arbeitsmed 33:83–97.4850778
Succop P, Bornschein R, Brown K, . 1998. An empirical comparison of lead exposure pathway models. Environ Health Perspect 106 Suppl 6:1577–1583.9860917
Succop P, Clark S, Tseng CY, . 2001. Evaluation of public housing lead risk assessment data. Environ Geochem Health 23:1–15.
Sun CC, Wong TT, Hwang YH, . 2002. Percutaneous absorption of inorganic lead compounds. AIHA J (Fairfax, Va) 63(5):641–646. 10.1080/15428110208984751.12529920
Sun L, Hu J, Zhao Z, . 2003. Influence of exposure to environmental lead on serum immunoglobulin in preschool children. Environ Res 92(2):124–128. 10.1016/S0013-9351(02)00090-7.12854692
Sun Y, Sun D, Zhou Z, . 2008a. Osteoporosis in a Chinese population due to occupational exposure to lead. Am J Ind Med 51(6):436–442. 10.1002/ajim.20567.18381596
Sun Y, Sun DH, Zhou ZJ, . 2008b. Estimation of benchmark dose for bone damage and renal dysfunction in a Chinese male population occupationally exposed to lead. Ann Occup Hyg 52(6):527–533. 10.1093/annhyg/men031.18567606
Suszkiw JB. 2004. Presynaptic disruption of transmitter release by lead. Neurotoxicology 25(4):599–604.15183013
Süzen HS, Duydu Y, Aydın A, . 2003. Influence of the delta-aminolevulinic acid dehydratase (ALAD) polymorphism on biomarkers of lead exposure in Turkish storage battery manufacturing workers. Am J Ind Med 43(2):165–171.12541271
Sweeney MH, Beaumont JJ, Waxweiler RJ, . 1986. An investigation of mortality from cancer and other causes of death among workers employed at an east Texas chemical plant. Arch Environ Health 41(1):23–28.3963883
Swenberg JA, Short B, Borghoff S, . 1989. The comparative pathobiology of α2u-globulin nephropathy. Toxicol Appl Pharmacol 97(1):35–46.2464861
Symanski E, Hertz-Picciotto I. 1995. Blood lead levels in relation to menopause, smoking, and pregnancy history. Am J Epidemiol 141(11):1047–1058.7771441
Szymanska-Chabowska A, Laczmanski L, Jedrychowska I, . 2015. The relationship between selected VDR, HFE and ALAD gene polymorphisms and several basic toxicological parameters among persons occupationally exposed to lead. Toxicology 334:12–21. 10.1016/j.tox.2015.05.002.25963508
Taha EA, Sayed SK, Ghandour NM, . 2013. Correlation between seminal lead and cadmium and seminal parameters in idiopathic oligoasthenozoospermic males. Cent European J Urol 66(1):84–92. 10.5173/ceju.2013.01.art28.
Takamatsu T, Murata T, Koshikawa MK, . 2010. Weathering and dissolution rates among Pb shot pellets at differing elemental compositions exposed to various aqueous and soil conditions. Arch Environ Contam Toxicol 59:91–99. 10.1007/s00244-009-9449-x.20039167
Tamura H, Honda M, Sato T, . 2005. Pb hyperaccumulation and tolerance in common buckwheat (Fagopyrum esculentum Moench). J Plant Res 118(5):355–359. 10.1007/s10265-005-0229-z.16177838
Tasmin S, Furusawa H, Ahmad SA, . 2015. delta-Aminolevulinic acid dehydratase (ALAD) polymorphism in lead exposed Bangladeshi children and its effect on urinary aminolevulinic acid (ALA). Environ Res 136:318–323. 10.1016/j.envres.2014.08.045.25460652
Taylor CM, Golding J, Emond AM. 2015. Adverse effects of maternal lead levels on birth outcomes in the ALSPAC study: A prospective birth cohort study. BJOG 122(3):322–328. 10.1111/1471-0528.12756.24824048
Taylor CM, Golding J, Hibbeln J, . 2013. Environmental factors predicting blood lead levels in pregnant women in the UK: The ALSPAC study. PLoS ONE 8(9):e72371. 10.1371/journal.pone.0072371.24039753
Taylor CM, Kordas K, Golding J, . 2017. Effects of low-level prenatal lead exposure on child IQ at 4 and 8 years in a UK birth cohort study. Neurotoxicology 62:162–169. 10.1016/j.neuro.2017.07.003.28687448
Taylor CM, Emond AM, Lingam R, . 2018. Prenatal lead, cadmium and mercury exposure and associations with motor skills at age 7 years in a UK observational birth cohort. Environ Int 117:40–47. 10.1016/j.envint.2018.04.032.29723752
Teichmann R, Stremmel W. 1990. Iron uptake by human upper small intestine microvillous membrane vesicles. Indication for a facilitated transport mechanism mediated by a membrane iron-binding protein. J Clin Invest 86(6):2145–2153.2254464
Telisman S, Cvitkovic P, Jurasovic J, . 2000. Semen quality and reproductive endocrine function in relation to biomarkers of lead, cadmium, zinc, and copper in men. Environ Health Perspect 108(1):45–53.10620523
Telisman S, Colak B, Pizent A, . 2007. Reproductive toxicity of low-level lead exposure in men. Environ Res 105(2):256–266. 10.1016/j.envres.2007.05.011.17632096
Tellez-Rojo MM, Hernandez-Avila M, Gonzalez-Cossio T, . 2002. Impact of breastfeeding on the mobilization of lead from bone. Am J Epidemiol 155(5):420–428.11867353
Tellez-Rojo MM, Hernandez-Avila M, Lamadrid-Figueroa H, . 2004. Impact of bone lead and bone resorption on plasma and whole blood lead levels during pregnancy. Am J Epidemiol 160(7):668–678.15383411
Téllez-Rojo MM, Bellinger DC, Arroyo-Quiroz C, . 2006. Longitudinal associations between blood lead concentrations lower than 10 microg/dL and neurobehavioral development in environmentally exposed children in Mexico City. Pediatrics 118(2):e323–e330. 10.1542/peds.2005-3123.16882776
Ter Haar GL, Bayard MA. 1971. Composition of airborne lead particles. Nature 232:553–554.4106136
Ter Haar G, Aronow R. 1974. New information on lead in dirt and dust as related to the childhood lead problem. Environ Health Perspect 7:83–89.4831152
Theppeang K, Schwartz BS, Lee B-K, . 2004. Associations of patella lead with polymorphisms in the vitamin D receptor, δ-aminolevulinic acid dehydratase and endothelial nitric oxide synthase genes. J Occup Environ Med 46(6):528–537.15213514
Theppeang K, Glass TA, Bandeen-Roche K, . 2008. Associations of bone mineral density and lead levels in blood, tibia, and patella in urban-dwelling women. Environ Health Perspect 116(6):784–790. 10.1289/ehp.10977.18560535
Thomas S, Arbuckle TE, Fisher M, . 2015. Metals exposure and risk of small-for-gestational age birth in a Canadian birth cohort: The MIREC study. Environ Res 140:430–439. 10.1016/j.envres.2015.04.018.25967284
Thompson GN, Robertson EF, Fitzgerald S. 1985. Lead mobilization during pregnancy. Med J Aust 143:131.
Tian L, Zheng G, Sommar JN, . 2013. Lead concentration in plasma as a biomarker of exposure and risk, and modification of toxicity by delta-aminolevulinic acid dehydratase gene polymorphism. Toxicol Lett 221(2):102–109. 10.1016/j.toxlet.2013.06.214.23792432
Timchalk C, Lin Y, Weitz KK, . 2006. Disposition of lead (Pb) in saliva and blood of Sprague-Dawley rats following a single or repeated oral exposure to Pb-acetate. Toxicology 222(1):86–94.16510233
Todd AC, Carroll S, Godbold JH, . 2000. Variability in XRF-measured tibia lead levels. Phys Med Biol 45(12):3737–3748.11131196
Todd AC, Buchanan R, Carroll S, . 2001. Tibia lead levels and methodological uncertainty in 12-year-old children. Environ Res 86:60–65.11386742
Todd AC, Carroll S, Geraghty C, . 2002. L-shell x-ray fluorescence measurements of lead in bone: Accuracy and precision. Phys Med Biol 47:1399–1419.12030563
Tola S, Hernberg S, Asp S, . 1973. Parameters indicative of absorption and biological effect in new lead exposure: A prospective study. Br J Ind Med 30(2):134–141.4703084
Tomoum HY, Mostafa GA, Ismail NA, . 2010. Lead exposure and its association with pubertal development in school-age Egyptian children: Pilot study. Pediatr Int 52(1):89–93. 10.1111/j.1442-200X.2009.02893.x.19496973
Tomsig J, Suszkiw JB. 1991. Permeation of Pb2+ through calcium channels: Fura-2 measurements of voltage-and dihydropyridine-sensitive Pb2+ entry in isolated bovine chromaffin cells. Biochim Biophys Acta Biomembr 1069(2):197–200.
Tong S, McMichael AJ, Baghurst PA. 2000. Interactions between environmental lead exposure and sociodemographic factors on cognitive development. Arch Environ Health 55(5):330–335. 10.1080/00039890009604025.11063408
Toscano CD, Guilarte TR. 2005. Lead neurotoxicity: From exposure to molecular effects. Brain Res Brain Res Rev 49(3):529–554. 10.1016/j.brainresrev.2005.02.004.16269318
Treble RG, Thompson RS. 1997. Preliminary results of a survey of lead levels in human liver tissue. Bull Environ Contam Toxicol 59:688–695.9323215
TRI18. 2020. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Toxics Release Inventory. U.S. Environmental Protection Agency. http://www.epa.gov/triexplorer/. February 18, 2020.
Triebig G, Weltle D, Valentin H. 1984. Investigations on neurotoxicity of chemical substances at the workplace. Int Arch Occup Environ Health 53:189–204.6323322
Tripathi RK, Llewellyn GC. 1990. Deterioration of air quality in firing ranges: A review of airborne lead exposures. In: Llewellyn GC, O’Rear CE, eds. Biodeterioration research 3: Mycotoxins, biotoxins, wood decay, air quality, cultural properties, general biodeterioration, and degradation. New York, NY: Plenum Press, 445–457.
Tripathi R, Raghunath R, Kumar AV, . 2001. Atmospheric and children’s blood lead as indicators of vehicular traffic and other emission sources in Mumbai, India. Sci Total Environ 267(1):101–108.11286206
Tsaih SW, Korrick S, Schwartz J, . 2004. Lead, diabetes, hypertension, and renal function: The normative aging study. Environ Health Perspect 112(11):1178–1182. 10.1289/ehp.7024.15289163
Tsoi MF, Cheung CL, Cheung TT, . 2016. Continual decrease in blood lead level in Americans: United States National Health Nutrition and Examination Survey 1999-2014. Am J Med 129(11):1213–1218. 10.1016/j.amjmed.2016.05.042.27341956
Tulasi SJ, Reddy PUM, Rao JVR. 1992. Accumulation of lead and effects on total lipids and lipid derivatives in the freshwater fish Anabas testudineus (Bloch). Ecotoxicol Environ Saf 23(1):33–38.1375146
Tuppurainen M, Wagar G, Kurppa K, . 1988. Thyroid function as assessed by routine laboratory tests of workers with long-term lead exposure. Scand J Work Environ Health 14:175–180.3393853
Turlakiewicz Z, Chmielnicka J. 1985. Diethyllead as a specific indicator of occupational exposure to tetraethyllead. Br J Ind Med 42:682–685.4041386
Tuthill RW. 1996. Hair lead levels related to children’s classroom attention-deficit behavior. Arch Environ Health 51(3):214–220.8687242
Tvinnereim HM, Eide R, Riise T, . 1997. Lead in primary teeth from Norway: Changes in lead levels from the 1970s to the 1990s. Sci Total Environ 207(2–3):165–177. 10.1016/s0048-9697(97)00263-5.9447746
Ukaejiofo EO, Thomas N, Ike SO. 2009. Haematological assessment of occupational exposure to lead handlers in Enugu urban, Enugu State, Nigeria. Niger J Clin Pract 12(1):58–64.19562924
Ulmer DD, Vallee BL. 1969. Effects of lead on biochemical systems. In: Hemphill DD, ed. Trace substances in environmental health. Columbia, MO: University of Missouri Press, 7–27.
Undeger U, Basaran N, Canpinar H, . 1996. Immune alterations in lead-exposed workers. Toxicology 109:167–172.8658547
USAF. 1995. The fate and behavior of lead alkyls in the subsurface environment. Tyndall Air Force Base, FL: U.S. Air Force. AL/EQ-TR-1994-0026.
USGS. 1989. Techniques of Water-Resources Investigations of the United States Geological Survey: Chapter A1: Methods for the determination of inorganic substances in water and fluvial sediments. U.S. Geological Survey. https://pubs.er.usgs.gov/publication/twri05A1. March 30, 2017.
USGS. 1993. Methods of analysis by the U.S. Geological Survey National Water Quality Laboratory. Determination of inorganic and organic constituents in water and fluvial sediments. Denver, CO: U.S. Geological Survey. Open-File Report 93-125. https://pubs.usgs.gov/of/1993/0125/report.pdfUSGS. March 30, 2017.
USGS. 2014. Comparison of the U.S. lead recycling industry in 1998 and 2011. U.S. Geological Survey. Scientific Investigations Report 2014–5086. https://pubs.usgs.gov/sir/2014/5086/pdf/sir2014-5086.pdf. June 26, 2017.
USGS. 2016. 2014 Mineral yearbook. Lead [advance release]. U.S. Geological Survey. https://minerals.usgs.gov/minerals/pubs/commodity/lead/myb1-2014-lead.pdf. June 26, 2017.
USGS. 2019. Mineral commodity summaries 2019. Reston, VA: U.S. Geological Survey. 10.3133/70202434.
Vaglenov A, Carbonell E, Marcos R. 1998. Biomonitoring of workers exposed to lead. Genotoxic effects, its modulation by polyvitamin treatment and evaluation of induced radioresistance. Mutat Res 418:79–92.9757002
Vaglenov A, Creus A, Laltchev S, . 2001. Occupational exposure to lead and induction of genetic damage. Environ Health Perspect 109(3):295–298.11333192
Valciukas JA, Lilis R, Eisinger J, . 1978. Behavioral indicators of lead neurotoxicity: Results of a clinical field survey. Int Arch Occup Environ Health 41(4):217–236.355147
Valentino M, Governa M, Marchiseppe I, . 1991. Effects of lead on polymorphonuclear leukocyte (PMN) functions in occupationally exposed workers. Arch Toxicol 65(8):685–688.1660709
Valentino M, Rapisarda V, Santarelli L, . 2007. Effect of lead on the levels of some immunoregulatory cytokines in occupationally exposed workers. Hum Exp Toxicol 26(7):551–556. 10.1177/0960327107073817.17884957
Van de Wiele TR, Oomen AG, Wragg J, . 2007. Comparison of five in vitro digestion models to in vivo experimental results: Lead bioaccessibility in the human gastrointestinal tract. J Environ Sci Health A Tox Hazard Subst Environ Eng 42(9):1203–1211. 10.1080/10934520701434919.17654140
Van Esch GJ, Kroes R. 1969. The induction of renal tumours by feeding basic lead acetate to mice and hamsters. Br J Cancer 23(4):765–771.5367336
Van Larebeke N, Koppen G, Nelen V, . 2004. Differences in HPRT mutant frequency among middle-aged Flemish women in association with area of residence and blood lead levels. Biomarkers 9(1):71–84. 10.1080/13547500310001652160.15204312
van Wijngaarden E, Dosemeci M. 2006. Brain cancer mortality and potential occupational exposure to lead: Findings from the National Longitudinal Mortality Study, 1979-1989. Int J Cancer 119(5):1136–1144. 10.1002/ijc.21947.16570286
van Wijngaarden E, Campbell JR, Cory-Slechta DA. 2009. Bone lead levels are associated with measures of memory impairment in older adults. Neurotoxicology 30(4):572–580. 10.1016/j.neuro.2009.05.007.19477197
Vander AJ, Taylor DL, Kalitis K, . 1977. Renal handling of lead in dogs: Clearance studies. Am J Physiol 233(6):F532–F538.596452
Vantelon D, Lanzirotti A, Scheinost AC, . 2005. Spatial distribution and speciation of lead around corroding bullets in a shooting range soil studies by micro-x-ray fluorescence and absorption spectroscopy. Environ Sci Technol 39(13):4808–4815.16053078
Verbeeck RMH, Lassuyt CJ, Heijligers HJM, . 1981. Lattice parameters and cation distribution of solid solutions of calcium and lead hydroxyapatite. Calcif Tissue Int 33(1):243–247. 10.1007/BF02409444.6268259
Verberk MM, Willems TEP, Verplanke AJW, . 1996. Environmental lead and renal effects in children. Arch Environ Health 51(1):83–87.8629869
Verschoor M, Wibowo A, Herber R, . 1987. Influence of occupational low-level lead exposure on renal parameters. Am J Ind Med 12(4):341–351.3499817
Vesper SJ, Donovan-Brand R, Paris KP, . 1996. Microbial removal of lead from solid media and soil. Water Air Soil Pollut 86:207–219.
Victery W, Vander AJ, Mouw DR. 1979. Effect of acid-base status on renal excretion and accumulation of lead in dogs and rats. Am J Physiol 237(5):F398–F407.495756
Vigeh M, Yokoyama K, Kitamura F, . 2010. Early pregnancy blood lead and spontaneous abortion. Women Health 50(8):756–766.21170817
Vigeh M, Yokoyama K, Seyedaghamiri Z, . 2011. Blood lead at currently acceptable levels may cause preterm labour. Occup Environ Med 68(3):231–234. 10.1136/oem.2009.050419.20798002
Vigeh M, Yokoyama K, Matsukawa T, . 2014. Low level prenatal blood lead adversely affects early childhood mental development. J Child Neurol 29(10):1305–1311. 10.1177/0883073813516999.24532811
Viverette L, Mielke HW, Brisco M, . 1996. Environmental health in minority and other underserved populations: Benign methods for identifying lead hazards at day care centres of New Orleans. Environ Geochem Health 18(1):41–45. 10.1007/bf01757218.24194368
Vlasak T, Jordakieva G, Gnambs T, . 2019. Blood lead levels and cognitive functioning: A meta-analysis. Sci Total Environ 668:678–684. 10.1016/j.scitotenv.2019.03.052.30856576
von Lindern I, Spalinger S, Petroysan V, . 2003. Assessing remedial effectiveness through the blood lead:soil/dust lead relationship at the Bunker Hill Superfund Site in the Silver Valley of Idaho. Sci Total Environ 303(1–2):139–170.12568769
von Lindern I, Spalinger S, Stifelman ML, . 2016. Estimating children’s soil/dust ingestion rates through retrospective analyses of blood lead biomonitoring from the Bunker Hill Superfund Site in Idaho. Environ Health Perspect 124:1462–1470. 10.1289/ehp.1510144.26745545
Vupputuri S, He J, Muntner P, . 2003. Blood lead level is associated with elevated blood pressure in blacks. Hypertension 41(3):463–468.12623944
Vural N, Duydu Y. 1995. Biological monitoring of lead in workers exposed to tetraethyllead. Sci Total Environ 171:183–187.7481745
Waalkes MP, Klaassen CD. 1985. Concentration of metallothionein in major organs of rats after administration of various metals. Fundam Appl Toxicol 5:473–477.4007305
Waalkes MP, Harvey MJ, Klaassen CD. 1984. Relative in vitro affinity of hepatic metallothionein for metals. Toxicol Lett 20:33–39.6695394
Waalkes MP, Diwan BA, Ward JM, . 1995. Renal tubular tumors and atypical hyperplasias in B6C3F1. Cancer Res 55:5265–5271.7585586
Wang EX, Bormann FH, Benoit G. 1995. Evidence of complete retention of atmospheric lead in the soils of northern hardwood forested ecosystems. Environ Sci Technol 29:735–739.22200283
Wang Y, Allen AG, Harrison RM. 1996. Determination of octanol-water partition coefficients, water solubility and vapour pressures of alkyl-lead compounds. Appl Organomet Chem 10(10):773–778.
Wang IJ, Karmaus WJJ, Yang CC. 2017a. Lead exposure, IgE, and the risk of asthma in children. J Expo Sci Environ Epidemiol 27(5):478–483. 10.1038/jes.2017.5.28401896
Wang G, Su MY, Chen YH, . 2006. Transfer characteristics of cadmium and lead from soil to the edible parts of six vegetable species in southeastern China. Environ Pollut 144(1):127–135. 10.1016/j.envpol.2005.12.023.16516364
Wang FT, Hu H, Schwartz J, . 2007. Modifying effects of the HFE polymorphisms on the association between lead burden and cognitive decline. Environ Health Perspect 115(8):1210–1215. 10.1289/ehp.9855.17687449
Wang HL, Chen XT, Yang B, . 2008. Case-control study of blood lead levels and attention deficit hyperactivity disorder in Chinese children. Environ Health Perspect 116(10):1401–1406. 10.1289/ehp.11400.18941585
Wang Q, Zhao HH, Chen JW, . 2010. delta-Aminolevulinic acid dehydratase activity, urinary delta-aminolevulinic acid concentration and zinc protoporphyrin level among people with low level of lead exposure. Int J Hyg Environ Health 213(1):52–58. 10.1016/j.ijheh.2009.08.003.19733117
Wang ZW, Nan ZR, Wang SL, . 2011. Accumulation and distribution of cadmium and lead in wheat (Triticum aestivum L.) grown in contaminated soils from the oasis, north-west China. J Sci Food Agric 91(2):377–384. 10.1002/jsfa.4196.21086461
Wang N, Chen C, Nie X, . 2015. Blood lead level and its association with body mass index and obesity in China - Results from SPECT-China study. Scientific reports 5:18299. 10.1038/srep18299.26658662
Wang H, Li J, Hao JH, . 2017b. High serum lead concentration in the first trimester is associated with an elevated risk of small-for-gestational-age infants. Toxicol Appl Pharmacol 332:75–80. 10.1016/j.taap.2017.07.020.28755861
Wang J, Gao ZY, Yan J, . 2017c. Sex differences in the effects of prenatal lead exposure on birth outcomes. Environ Pollut 225:193–200. 10.1016/j.envpol.2017.03.031.28371734
Wang W, Moroi S, Bakulski K, . 2018. Bone lead levels and risk of incident primary open-angle glaucoma: The VA Normative Aging Study. Environ Health Perspect 126(8):087002. 10.1289/ehp3442.30102601
Wang M, Hossain F, Sulaiman R, . 2019. Exposure to inorganic arsenic and lead and autism spectrum disorder in children: A systematic review and meta-analysis. Chem Res Toxicol 32(10):1904–1919. 10.1021/acs.chemrestox.9b00134.31549506
Warrington NM, Zhu G, Dy V, . 2015. Genome-wide association study of blood lead shows multiple associations near ALAD. Hum Mol Genet 24(13):3871–3879. 10.1093/hmg/ddv112.25820613
Wasserman GA, Graziano JH, Factor-Litvak P, . 1994. Consequences of lead exposure and iron supplementation on childhood development at age 4 years. Neurotoxicol Teratol 16(3):233–240.7523846
Wasserman GA, Liu X, Lolacono NJ, . 1997. Lead exposure and intelligence in 7-year-old children: The Yugoslavia Prospective Study. Environ Health Perspect 105(9):956–962.9410739
Wasserman GA, Liu X, Popovac D, . 2000. The Yugoslavia prospective lead study: Contributions of prenatal and postnatal lead exposure to early intelligence. Neurotoxicol Teratol 22:811–818.11120386
Wasserman GA, Factor-Litvak P, Liu X, . 2003. The relationship between blood lead, bone lead and child intelligence. Child Neuropsychol 9(1):22–34.12815520
Watanabe H, Hu H, Rotnitzky A. 1994. Correlates of bone and blood lead levels in carpenters. Am J Ind Med 26(2):255–264. 10.1002/ajim.4700260211.7977400
Watson WS, Morrison J, Bethel MIF, . 1986. Food iron and lead absorption in humans. Am J Clin Nutr 44:248–256.3728362
Weaver V, Lee B, Ahn K, . 2003a. Associations of lead biomarkers with renal function in Korean lead workers. Occup Environ Med 60(8):551–562.12883015
Weaver VM, Schwartz BS, Ahn KD, . 2003b. Associations of renal function with polymorphisms in the delta-aminolevulinic acid dehydratase, vitamin D receptor, and nitric oxide synthase genes in Korean lead workers. Environ Health Perspect 111(13):1613–1619.14527840
Weaver VM, Jaar BG, Schwartz BS, . 2005a. Associations among lead dose biomarkers, uric acid, and renal function in Korean lead workers. Environ Health Perspect 113(1):36–42.15626645
Weaver VM, Schwartz BS, Jaar BG, . 2005b. Associations of uric acid with polymorphisms in the “delta”-aminolevulinic acid dehydratase, vitamin D receptor, and nitric oxide synthase genes in Korean lead workers. Environ Health Perspect 113(11):1509–1515. 10.1289/ehp.7927.16263504
Weaver VM, Lee BK, Todd AC, . 2006. Effect modification by delta-aminolevulinic acid dehydratase, vitamin D receptor, and nitric oxide synthase gene polymorphisms on associations between patella lead and renal function in lead workers. Environ Res 102(1):61–69. 10.1016/j.envres.2006.01.001.16487505
Weaver VM, Ellis LR, Lee BK, . 2008. Associations between patella lead and blood pressure in lead workers. Am J Ind Med 51(5):336–343. 10.1002/ajim.20573.18320594
Weaver VM, Griswold M, Todd AC, . 2009. Longitudinal associations between lead dose and renal function in lead workers. Environ Res 109(1):101–107. 10.1016/j.envres.2008.09.005.19038382
Wedeen RP. 1992. Removing lead from bone: Clinical implications of bone lead stores. Neurotoxicology 13:843–852.1302310
Wedeen RP, Mallik DK, Batuman V. 1979. Detection and treatment of occupational lead nephropathy. Arch Intern Med 139:53–57.760684
Wedeen RP, Maesaka JK, Weiner B, . 1975. Occupational lead nephropathy. Am J Med 59:630–641.1200035
Weis CP, LaVelle JM. 1991. Characteristics to consider when choosing an animal model for the study of lead bioavailability. Chem Spec Bioavailab 3(3–4):113–119.
Weisel C, Demak M, Marcus S, . 1991. Soft plastic bread packaging: Lead content and reuse by families. Am J Public Health 81(6):756–758.2029047
Weiss ST, Munoz A, Stein A, . 1986. The relationship of blood lead to blood pressure in a longitudinal study of working men. Am J Epidemiol 123(5):800–808.3485920
Weiss ST, Munoz A, Stein A, . 1988. The relationship of blood lead to systolic blood pressure in a longitudinal study of policemen. Environ Health Perspect 78:53–56.3203646
Weiss AL, Caravanos J, Blaise MJ, . 2006. Distribution of lead in urban roadway grit and its association with elevated steel structures. Chemosphere 65(10):1762–1771. 10.1016/j.chemosphere.2006.04.079.16793117
Weisskopf MG, Wright RO, Schwartz J, . 2004. Cumulative lead exposure and prospective change in cognition among elderly men. The VA Normative Aging Study. Am J Epidemiol 160(12):1184–1193. 10.1093/aje/kwh333.15583371
Weisskopf MG, Proctor SP, Wright RO, . 2007. Cumulative lead exposure and cognitive performance among elderly men. Epidemiology 18(1):59–66. 10.1097/01.ede.0000248237.35363.29.17130688
Weisskopf MG, Nitin J, Nie H, . 2009. A prospective study of bone lead concentration and death from all causes, cardiovascular diseases, and cancer in the department of veterans affairs normative aging study. Circulation 120(12):1056–1064. 10.1161/circulationaha.108.827121.19738141
Weitzman M, Aschengrau A, Bellinger D, . 1993. Lead-contaminated soil abatement and urban children’s blood lead levels. J Am Med Assoc 269(13):1647–1654.
Wells A, Venn J, Heard M. 1975. Deposition in the lung and uptake to blood of motor exhaust labelled with 203Pb. Inhaled Part 4:175–189.70403
Wells EM, Navas-Acien A, Herbstman JB, . 2011. Low-level lead exposure and elevations in blood pressure during pregnancy. Environ Health Perspect 119:664–669.21292600
Wells EM, Bonfield TL, Dearborn DG, . 2014. The relationship of blood lead with immunoglobulin E, eosinophils, and asthma among children: NHANES 2005-2006. Int J Hyg Environ Health 217(2–3):196–204. 10.1016/j.ijheh.2013.04.010.23726529
Were FH, Moturi MC, Gottesfeld P, . 2014. Lead exposure and blood pressure among workers in diverse industrial plants in Kenya. J Occup Environ Hyg 11(11):706–715. 10.1080/15459624.2014.908258.24690073
Wetmur JG, Lehnert G, Desnick RJ. 1991b. The delta-aminolevulinate dehydratase polymorphism: Higher blood lead levels in lead workers and environmentally exposed children with 1-2 and 2-2 isozymes. Environ Res 56:109–119.1769358
Wetmur JG, Kaya AH, Plewinska M, . 1991a. Molecular characterization of the human delta-aminolevulinate dehydratase 2 (ALAD2) allele: Implications for molecular screening of individuals for genetic susceptibility to lead poisoning. Am J Hum Genet 49(4):757–763.1716854
Weuve J, Kelsey KT, Schwartz J, . 2006. delta-Aminolevulinic acid dehydratase polymorphism and the relation between low level lead exposure and the Mini-Mental Status Examination in older men: The Normative Aging Study. Occup Environ Med 63(11):746–753. 10.1136/oem.2006.027417.16757504
Weuve J, Korrick SA, Weisskopf MA, . 2009. Cumulative exposure to lead in relation to cognitive function in older women. Environ Health Perspect 117(4):574–580. 10.1289/ehp.11846.19440496
Weuve J, Press DZ, Grodstein F, . 2013. Cumulative exposure to lead and cognition in persons with Parkinson’s disease. Mov Disord 28(2):176–182. 10.1002/mds.25247.23143985
Whelan EA, Piacitelli GM, Gerwel B, . 1997. Elevated blood lead levels in children of construction workers. Am J Public Health 87(8):1352–1355.9279275
White PD, Van LP, Davis BD, . 1998. The conceptual structure of the integrated exposure uptake biokinetic model for lead in children. Environ Health Perspect 106(Suppl 6):1513–1530.9860910
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. January 08, 2014.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Wildt K, Eliasson R, Berlin M. 1983. Effects of occupational exposure to lead on sperm and semen. In: Clarkson TW, Nordberg GF, Sager PR, eds. Reproductive and developmental toxicity of metals. Boston, MA: Springer-Verlag, 279–300. 10.1007/978-1-4615-9346-1_10.
Wildt K, Berlin M, Isberg PE. 1987. Monitoring of zinc protoporphyrin levels in blood following occupational lead exposure. Am J Ind Med 12(4):385–398.3674027
Wilhelm M, Lombeck I, Hafner D, . 1989. Hair lead levels in young children from the FRG. J Trace Elem Electrolytes Health Dis 3:165–170.2535336
Wilker E, Korrick S, Nie LH, . 2011. Longitudinal changes in bone lead levels: The VA Normative Aging Study. J Occup Environ Med 53(8):850–855. 10.1097/JOM.0b013e31822589a9.21788910
Williams PL, Sergeyev O, Lee MM, . 2010. Blood lead levels and delayed onset of puberty in a longitudinal study of Russian boys. Pediatrics 125(5):1088–1096. 10.1542/peds.2009-2575.20421257
Williams PL, Bellavia A, Korrick SA, . 2019. Blood lead levels and timing of male sexual maturity: A longitudinal study of Russian boys. Environ Int 125:470–477. 10.1016/j.envint.2019.01.070.30769180
Williamson AM, Teo RKC. 1986. Neurobehavioral and memory of occupational lead workers. Br J Ind Med 43:373–380.
Wilson R, Jones-Otazo H, Petrovic S, . 2013. Revisiting dust and soil ingestion rates based on hand-to-mouth transfer. Hum Ecol Risk Assess 19(1):158–188.
Wingren G, Englander V. 1990. Mortality and cancer morbidity in a cohort of Swedish glassworkers. Int Arch Occup Environ Health 62:253–257.2347650
Winter AS, Sampson RJ. 2017. From lead exposure in early childhood to adolescent health: A Chicago birth cohort. Am J Public Health 107(9):1496–1501. 10.2105/ajph.2017.303903.28727523
Wisconsin DHS. 2002. Lead arsenate pesticides. Madison, WI: Wisconsin Department of Health Services. P-45007.
Wiwanitkit V, Suwansaksri J, Soogarun S. 2008. White blood cell sister chromatid exchange among a sample of Thai subjects exposed to lead: Lead-induced genotoxicity. Toxicol Environ Chem 90(4):765–768. 10.1080/02772240701712758.
Wolf C, Wallnofer A, Waldhor T, . 1995. Effect of lead on blood pressure in occupationally nonexposed men. Am J Ind Med 27(6):897–903.7645582
Wolff MS, Britton JA, Boguski L, . 2008. Environmental exposures and puberty in inner-city girls. Environ Res 107(3):393–400. 10.1016/j.envres.2008.03.006.18479682
Wong O, Harris F. 2000. Cancer mortality study of employees at lead battery plants and lead smelters, 1947-1995. Am J Ind Med 38:255–270.10940963
Wright RO, Hu H, Silverman EK, . 2003a. Apolipoprotein E genotype predicts 24-month Bayley scales infant development score. Pediatr Res 54(6):819–825.12930912
Wright RO, Tsaih SW, Schwartz J, . 2003b. Lead exposure biomarkers and mini-mental status exam scores in older men. Epidemiology 14(6):713–718.14569188
Wright RO, Silverman EK, Schwartz J, . 2004. Association between hemochromatosis genotype and lead exposure among elderly men: The Normative Aging Study. Environ Health Perspect 112(6):746–750.15121519
Wu T, Buck GM, Mendola P. 2003b. Blood lead levels and sexual maturation in U.S. girls: The Third National Health and Nutrition Examination Survey, 1988-1994. Environ Health Perspect 111(5):737–741. 10.1289/ehp.6008.12727603
Wu TN, Yang KC, Wang CM, . 1996. Lead poisoning caused by contaminated Cordyceps, a Chinese herbal medicine: Two case reports. Sci Total Environ 182:193–195.8854946
Wu F, Chang P, Wu C, . 2002. Correlations of blood lead with DNA-protein cross-links and sister chromatid exchanges in lead workers. Cancer Epidemiol Biomarkers Prev 11(3):287–290.11895879
Wu M, Kelsey K, Schwartz J, . 2003a. A delta-aminolevulinic acid dehydratase (ALAD) polymorphism may modify the relationship of low-level lead exposure to uricemia and renal function: The normative aging study. Environ Health Perspect 111(3):335–340.12611663
Wu HM, Lin-Tan DT, Wang ML, . 2012. Lead level in seminal plasma may affect semen quality for men without occupational exposure to lead. Reprod Biol Endocrinol 10:91.23137356
Wu S, Hivert MF, Cardenas A, . 2017. Exposure to low levels of lead in utero and umbilical cord blood DNA methylation in project viva: An epigenome-wide association study. Environ Health Perspect 125(8):087019. 10.1289/ehp1246.28858830
Wu Y, Sun J, Wang M, . 2018. The relationship of children’s intelligence quotient and blood lead and zinc levels: A meta-analysis and system review. Biol Trace Elem Res 182(2):185–195. 10.1007/s12011-017-1093-0.28710590
Xian X. 1989. Response of kidney bean to concentration and chemical form of cadmium, zinc, and lead in polluted soils. Environ Pollut 57:127–137.15092458
Xie Y, Chiba M, Shinohara A, . 1998. Studies on lead-binding protein and interaction between lead and selenium in the human erythrocytes. Ind Health 36:234–239.9701901
Xie X, Ding G, Cui C, . 2013. The effects of low-level prenatal lead exposure on birth outcomes. Environ Pollut 175:30–34. 10.1016/j.envpol.2012.12.013.23321271
Xu X, Chen X, Zhang J, . 2015. Decreased blood hepatitis B surface antibody levels linked to e-waste lead exposure in preschool children. J Hazard Mater 298:122–128. 10.1016/j.jhazmat.2015.05.020.26022852
Yamamoto N, Takahashi Y, Yoshinaga J, . 2006. Size distributions of soil particles adhered to children’s hands. Arch Environ Contam Toxicol 51(2):157–163. 10.1007/s00244-005-7012-y.16583253
Yang H, Huo X, Yekeen TA, . 2013a. Effects of lead and cadmium exposure from electronic waste on child physical growth. Environ Sci Pollut Res Int 20(7):4441–4447. 10.1007/s11356-012-1366-2.23247522
Yang CC, Chen HI, Chiu YW, . 2013b. Metallothionein 1A polymorphisms may influence urine uric acid and N-acetyl-beta-D-glucosaminidase (NAG) excretion in chronic lead-exposed workers. Toxicology 306:68–73. 10.1016/j.tox.2013.02.007.23429061
Yang WY, Zhang ZY, Thijs L, . 2017. Left ventricular structure and function in relation to environmental exposure to lead and cadmium. Journal of the American Heart Association 6(2):e004692. 10.1161/jaha.116.004692.28151401
Yang WY, Efremov L, Mujaj B, . 2018. Association of office and ambulatory blood pressure with blood lead in workers before occupational exposure. J Am Soc Hypertens 12(1):14–24. 10.1016/j.jash.2017.10.010.29195913
Yazbeck C, Thiebaugeorges O, Moreau T, . 2009. Maternal blood lead levels and the risk of pregnancy-induced hypertension: The EDEN cohort study. Environ Health Perspect 117(10):1526–1530. 10.1289/ehp.0800488.20019901
Yesilonis ID, Pouyat RV, Neerchal NK. 2008. Spatial distribution of metals in soils in Baltimore, Maryland: Role of native parent material, proximity to major roads, housing age and screening guidelines. Environ Pollut 156(3):723–731. 10.1016/j.envpol.2008.06.010.18656291
Yiin LM, Rhoads GG, Lioy PJ. 2000. Seasonal influences on childhood lead exposure. Environ Health Perspect 108(2):177–182.
Yin Y, Zhang T, Dai Y, . 2008. The effect of plasma lead on anembryonic pregnancy. Ann N Y Acad Sci 1140:184–189. 10.1196/annals.1454.042.18991916
Yokoyama K, Araki S, Murata K, . 1997. Subclinical vestibulo-cerebellar, anterior cerebellar lobe and spinocerebellar effects in lead workers in relation to concurrent and past exposure. Neurotoxicology 18(2):371–380.9291487
Yoon JH, Ahn YS. 2016. The association between blood lead level and clinical mental disorders in fifty thousand lead-exposed male workers. J Affect Disord 190:41–46. 10.1016/j.jad.2015.09.030.26480210
Yorita Christensen KL. 2013. Metals in blood and urine, and thyroid function among adults in the United States 2007-2008. Int J Hyg Environ Health 216(6):624–632.23044211
Youravong N, Teanpaisan R. 2015. The periodontal health of lead-exposed children living in a shipyard industrial area. Toxicol Ind Health 31(5):459–466. 10.1177/0748233712472529.23406954
Yu C, Lin J, Lin-Tan D. 2004. Environmental exposure to lead and progression of chronic renal diseases: A four-year prospective longitudinal study. J Am Soc Nephrol 15(4):1016–1022.15034104
Yu CJ, Du JC, Chiou HC, . 2016. Attention deficit/hyperactivity disorder and urinary nonylphenol levels: A case-control study in Taiwanese children. PLoS ONE 11(2):e0149558. 10.1371/journal.pone.0149558.26890918
Yu CG, Wei FF, Yang WY, . 2019a. Heart rate variability and peripheral nerve conduction velocity in relation to blood lead in newly hired lead workers. Occup Environ Med 76(6):382–388. 10.1136/oemed-2018-105379.30928907
Yu CG, Yang WY, Saenen N, . 2019b. Neurocognitive function in relation to blood lead among young men prior to chronic occupational exposure. Scand J Work Environ Health 45(3):298–307. 10.5271/sjweh.3798.30631878
Yücesoy B, Turhan A, Üre M, . 1997. Simultaneous effects of lead and cadmium on NK cell activity and some phenotypic parameters. Immunopharmacol Immunotoxicol 19(3):339–348. 10.3109/08923979709046980.9248862
Zahran S, Mielke HW, Gonzales CR, . 2010. New Orleans before and after hurricanes Katrina/Rita: A quasi-experiment of the association between soil lead and children’s blood lead. Environ Sci Technol 44(12):4433–4440. 10.1021/es100572s.20405935
Zak K, Rohovec J, Navratil T. 2009. Fluxes of heavy metals from a highly polluted watershed during flood events: A case study of the Litavka River, Czech Republic. Water Air Soil Pollut 203(1–4):343–358. 10.1007/s11270-009-0017-9.
Zaprjanova P, Dospatliev L, Angelova V, . 2010. Correlation between soil characteristics and lead and cadmium content in the aboveground biomass of Virginia tobacco. Environ Monit Assess 163(1–4):253–261. 10.1007/s10661-009-0831-y.19277884
Zaragoza L, Hogan K. 1998. The integrated exposure uptake biokinetic model for lead in children: Independent validation and verification. Environ Health Perspect 106(Suppl 6):1551–1556.9860914
Zartarian V, Xue J, Tornero-Velez R, . 2017. Children’s lead exposure: A multimedia modeling analysis to guide public health decision-making. Environ Health Perspect 125(9):e97009. 10.1289/EHP1605.
Zawia NH, Crumpton T, Brydie M, . 2000. Disruption of the zinc finger domain: A common target that underlies many of the effects of lead. Neurotoxicology 21(6):1069–1080.11233753
Zawirska B. 1981. The role of the kidneys in disorders of porphyrin metabolism during carcinogenesis induced with lead acetate. Environ Res 24:391–408.
Zawirska B, Medraś K. 1972. The role of the kidneys in disorders of porphyrin metabolism during carcinogenesis induced with lead acetate. Arch Immunol Ther Exp (Warsz) 20(2):257–272.5024632
Zeng X, Xu X, Zheng X, . 2016. Heavy metals in PM2.5 and in blood, and children’s respiratory symptoms and asthma from an e-waste recycling area. Environ Pollut 210:346–353. 10.1016/j.envpol.2016.01.025.26803791
Zeng X, Xu X, Boezen HM, . 2017. Decreased lung function with mediation of blood parameters linked to e-waste lead and cadmium exposure in preschool children. Environ Pollut 230:838–848. 10.1016/j.envpol.2017.07.014.28734265
Zentner LE, Rondó PH, Mastroeni SS. 2006. Lead contamination and anthropometry of the newborn baby. J Trop Pediatr 52(5):369–371. 10.1093/tropej/fml009.16554339
Zeyrek D, Soran M, Cakmak A, . 2009. Serum copper and zinc levels in mothers and cord blood of their newborn infants with neural tube defects: A case-control study. Indian Pediatr 46(8):675–680.19430086
Zhai H, Chen C, Wang N, . 2017. Blood lead level is associated with non-alcoholic fatty liver disease in the Yangtze River Delta region of China in the context of rapid urbanization. Environ Health 16(1):93. 10.1186/s12940-017-0304-7.28859656
Zhang W, Zhang GG, He HZ, . 1994. Early health effects and biological monitoring in persons occupationally exposed to tetraethyl lead. Int Arch Occup Environ Health 65:395–399.7518422
Zhang N, Baker HW, Tufts M, . 2013. Early childhood lead exposure and academic achievement: Evidence from Detroit public schools, 2008-2010. Am J Public Health 103(3):e72–77. 10.2105/ajph.2012.301164.23327265
Zhang XL, Guariglia SR, McGothan JL, . 2015. Presynaptic mechanisms of lead neurotoxicity: Effects on vesicular release, vesicle clustering and mitochondria number. PLoS ONE 10(5):e0127461.26011056
Zhang A, Park SK, Wright RO, . 2010. HFE H63D polymorphism as a modifier of the effect of cumulative lead exposure on pulse pressure: The Normative Aging Study. Environ Health Perspect 118(9):1261–1266. 10.1289/ehp.1002251.20478760
Zhang A, Hu H, Sánchez BN, . 2011. Association between prenatal lead exposure and blood pressure in female offspring. Environ Health Perspect 120(3):445–450. 10.1289/ehp.1103736.21947582
Zhao ZY, Li R, Sun L, . 2004. Effect of lead exposure on the immune function of lymphocytes and erythrocytes in preschool children. J Zhejiang Univ Sci 5(8):1001–1004. 10.1007/BF02947614.15236489
Zheng G, Tian L, Liang Y, . 2011. delta-Aminolevulinic acid dehydratase genotype predicts toxic effects of lead on workers’ peripheral nervous system. Neurotoxicology 32:374–382.21439310
Zhou L, Xu J, Zhang J, . 2017. Prenatal maternal stress in relation to the effects of prenatal lead exposure on toddler cognitive development. Neurotoxicology 59:71–78. 10.1016/j.neuro.2017.01.008.
Zhu M, Fitzgerald EF, Gelberg KH, . 2010. Maternal low-level lead exposure and fetal growth. Environ Health Perspect 118(10):1471–1475. 10.1289/ehp.0901561.20562053
Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12(1):29–34.643372
Zimmermann-Tansella C, Campara P, Andrea FD, . 1983. Psychological and physical complaints of subjects with low exposure to lead. Hum Toxicol 2:615–623.6642518
Zollinger HU. 1953. Durch chronische bleivergiftung erzeugte nierenadenome und-carcinome bei ratten und ihre beziechungen zu den entsprehenden neubildungen menschen. Virchows Arch 323:694–710.13102931
Zota AR, Shenassa ED, Morello-Frosch R. 2013. Allostatic load amplifies the effect of blood lead levels on elevated blood pressure among middle-aged U.S. adults: A cross-sectional study. Environ Health 12(1):64. 10.1186/1476-069x-12-64.23953669
Zota AR, Needham BL, Blackburn EH, . 2015. Associations of cadmium and lead exposure with leukocyte telomere length: Findings from National Health and Nutrition Examination Survey, 1999-2002. Am J Epidemiol 181(2):127–136. 10.1093/aje/kwu293.25504027