# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding lead in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for Pb. As discussed in Appendix A, no MRLs were derived for Pb.

Table 7-1 Regulations and Guidelines Applicable to Lead (Pb)

Agency | Description | Information | Reference
Air
EPA | RfC | Not evaluated | IRIS 2002, 2004
EPA | NAAQS | 0.15 µg/m^3a^ | EPA 2019b
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | No data | EPA 2018c
EPA | National primary drinking water regulations for inorganic lead | | EPA 2009
EPA | MCL or TT | TT^b^
EPA | Action level | 0.015 mg/L
EPA | Public health goal | zero
EPA | Lead and copper rule proposal | | EPA 2019a
EPA | Trigger level (proposed) | 10 µg/L^c^
EPA | RfD
EPA | Tetraethyl lead | 1x10^−7^ mg/kg/day | IRIS 2002
WHO | Drinking water quality guidelines | | WHO 2017
WHO | Provisional guideline value, lead | 0.01 mg/L (10 μg/L)^d^
FDA | Substances Added to Food^e^ | Not listed | FDA 2019a
FDA | Allowable level of lead in bottled water | 0.005 mg/L | FDA 2019b
Cancer
HHS | Carcinogenicity classification | | NTP 2016
HHS | Lead and lead compounds | Reasonably anticipated to be human carcinogens
EPA | Carcinogenicity classification | | IRIS 2004
EPA | Lead and compounds (inorganic) | B2^f^
IARC | Carcinogenicity classification
IARC | Lead | Group 2B^g^ | IARC 1987, 2019
IARC | Lead compounds, inorganic | Group 2A^h^ | IARC 2006, 2019
IARC | Lead compounds, organic | Group 3^i^ | IARC 2006, 2019
Occupational
OSHA | PEL (8-hour TWA) for general industry
OSHA | Lead (elemental, inorganic and organic soaps) | 50 µg/m^3^ | OSHA 2019a
OSHA | Tetraethyl lead and tetramethyl lead | 0.075 mg/m^3j^ | OSHA 2019b
OSHA | PEL (8-hour TWA) for construction and shipyards
OSHA | Lead (elemental, inorganic and organic soaps) | 50 µg/m^3^ | OSHA 2019c, 2019a
OSHA | Tetraethyl lead | 0.1 mg/m^3j^ | OSHA 2019d, 2019e
OSHA | Tetramethyl lead | 0.15 mg/m^3j^ | OSHA 2019d, 2019f
OSHA | Action level (8-hour TWA) for general industry, construction
OSHA | Lead (elemental, inorganic and organic soaps) | 30 µg/m^3^ | OSHA 2019a, 2019c
OSHA | Medical removal protection for general industry | | OSHA 2019a
OSHA | Temporary removal blood lead level | ≥60 µg/100 g
OSHA | Return to work blood lead level | <40 µg/100 g
OSHA | Medical removal protection for construction and shipyards | | OSHA 2019c
OSHA | Temporary removal blood lead level | ≥50 µg/dL
OSHA | Return to work blood lead level | <40 µg/dL
NIOSH | REL (8-hour TWA)
NIOSH | Lead and compounds (as Pb) | 0.05 mg/m^3^ | NIOSH 2019a
NIOSH | Tetraethyl lead (as Pb) and tetramethyl lead (as Pb) | 0.075 mg/m^3j^ | NIOSH 2019b, 2019c
NIOSH | IDLH
NIOSH | Lead and compounds (as Pb) | 100 mg/m^3^ | NIOSH 2019a
NIOSH | Tetraethyl lead (as Pb) and tetramethyl lead (as Pb) | 40 mg/m^3^ | NIOSH 2019b, 2019c
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2018c
DOE | PACs-air^k^ | | DOE 2018a
DOE | Lead
DOE | PAC-1 | 0.15 mg/m^3^
DOE | PAC-2 | 120 mg/m^3^
DOE | PAC-3 | 700 mg/m^3^
DOE | Tetraethyl lead
DOE | PAC-1 | 0.3 mg/m^3^
DOE | PAC-2 | 4 mg/m^3^
DOE | PAC-3 | 40 mg/m^3^
DOE | Tetramethyl lead
DOE | PAC-1 | 0.45 mg/m^3^
DOE | PAC-2 | 4 mg/m^3^
DOE | PAC-3 | 40 mg/m^3^
DOE | Lead acetate
DOE | PAC-1 | 5 mg/m^3^
DOE | PAC-2 | 55 mg/m^3^
DOE | PAC-3 | 330 mg/m^3^
DOE | Lead carbonate
DOE | PAC-1 | 0.19 mg/m^3^
DOE | PAC-2 | 24 mg/m^3^
DOE | PAC-3 | 900 mg/m^3^
DOE | Lead dioxide and lead sulfide
DOE | PAC-1 | 0.17 mg/m^3^
DOE | PAC-2 | 140 mg/m^3^
DOE | PAC-3 | 810 mg/m^3^
DOE | Lead tetroxide
DOE | PAC-1 | 0.17 mg/m^3^
DOE | PAC-2 | 130 mg/m^3^
DOE | PAC-3 | 770 mg/m^3^
DOE | Lead sulfide
DOE | PAC-1 | 0.17 mg/m^3^
DOE | PAC-2 | 140 mg/m^3^
DOE | PAC-3 | 810 mg/m^3^
DOE | Lead oxide
DOE | PAC-1 | 0.16 mg/m^3^
DOE | PAC-2 | 130 mg/m^3^
DOE | PAC-3 | 750 mg/m^3^
DOE | Lead sulfate
DOE | PAC-1 | 0.22 mg/m^3^
DOE | PAC-2 | 170 mg/m^3^
DOE | PAC-3 | 1,000 mg/m^3^
DOE | Lead phosphate
DOE | PAC-1 | 0.2 mg/m^3^
DOE | PAC-2 | 150 mg/m^3^
DOE | PAC-3 | 910 mg/m^3^
DOE | Lead chloride
DOE | PAC-1 | 0.2 mg/m^3^
DOE | PAC-2 | 160 mg/m^3^
DOE | PAC-3 | 940 mg/m^3^
DOE | Lead chromate
DOE | PAC-1 | 0.036 mg/m^3^
DOE | PAC-2 | 16 mg/m^3^
DOE | PAC-3 | 97 mg/m^3^
DOE | Lead bromide
DOE | PAC-1 | 0.27 mg/m^3^
DOE | PAC-2 | 200 mg/m^3^
DOE | PAC-3 | 1,200 mg/m^3^
DOE | Lead nitrate
DOE | PAC-1 | 0.24 mg/m^3^
DOE | PAC-2 | 180 mg/m^3^
DOE | PAC-3 | 1,100 mg/m^3^
DOE | Lead iodide
DOE | PAC-1 | 0.33 mg/m^3^
DOE | PAC-2 | 270 mg/m^3^
DOE | PAC-3 | 1,600 mg/m^3^
DOE | Lead fluoroborate
DOE | PAC-1 | 0.28 mg/m^3^
DOE | PAC-2 | 220 mg/m^3^
DOE | PAC-3 | 1,300 mg/m^3^
Miscellaneous Federal Guidance
CDC | PbB reference value | 5 µg/dL | CDC 2012d, 2012e
EPA | Dust-lead hazard standards | | EPA 2019c
EPA | Floors | 10 µg/ft^2^
EPA | Window sills | 100 µg/ft^2^
EPA | Soil screening level | 400 ppm | EPA 1994e, 1998; 2016d
HUD | Dust lead hazard action levels | | HUD 2017
HUD | Floors | ≥10 µg/ft^2^
HUD | Window sills | ≥100 µg/ft^2^
HUD | Dust lead clearance action levels
HUD | Interior floors | <10 µg/ft^2^
HUD | Porch floors | <40 µg/ft^2^
HUD | Window sills | <100 µg/ft^2^
HUD | Window troughs | <100 µg/ft^2^

a Not-to-exceed air Pb concentration of 0.15 µg/m^3^ in total suspended solids for a 3-month rolling average, evaluated over a 3-year period (i.e., the 3-month rolling average cannot exceed 0.15 µg/m^3^ over a 3-year period).

b If >10% of tap water samples exceed the action level, a water system must take additional steps to control the corrosiveness of its water.

c Exceedance would trigger additional planning, monitoring, and treatment requirements, which vary depending on the characteristics of the water system.

d The guideline value is designated as provisional on the basis of treatment performance and analytical achievability because it is extremely difficult to achieve a lower concentration by central conditioning, such as phosphate dosing.

e The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited in food, delisted color additives, and some substances “no longer FEMA GRAS.”

f Group B2: probable human carcinogen.

g Group 2B: possibly carcinogenic to humans.

h Group 2A: probably carcinogenic to humans.

i Group 3: not classifiable as to carcinogenicity to humans.

j Skin designation.

k Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

AEGL = acute exposure guideline levels; CDC = Centers for Disease Control and Prevention; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; HUD = Housing and Urban Development; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health concentration; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; MCL = maximum contaminant level; NAAQS = National Ambient Air Quality Standard; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PbB = blood lead concentration; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TT = treatment technique; TWA = time-weighted average; WHO = World Health Organization