# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Pb is a naturally occurring element with an abundance of 0.0016% in the earth’s crust (Davidson et al. 2014). It is a member of Group 14 (IVA) of the periodic table. Natural Pb is a mixture of four stable isotopes: ^204^Pb (1.4%), ^206^Pb (24.1%), ^207^Pb (22.1%), and ^208^Pb (52.4%). The Pb isotopes ^206^Pb, ^207^Pb, and ^208^Pb are the stable decay product of the naturally occurring decay series of uranium, actinium, and thorium, respectively (Haynes 2014).

Pb is found in concentrated and easily accessible Pb ore deposits that are widely distributed throughout the world (King et al. 2014). Its properties, such as corrosion resistance, density, and low melting point, make it a familiar metal in pipes, solder, weights, and storage batteries. The chemical identities of Pb and several of its compounds are provided in Table 4-1.

Table 4-1 Chemical Identity of Lead and Compounds

Characteristic | Lead | Lead(II) acetate | Lead(II) azide | Lead(II) bromide
Synonym(s) and registered trade name(s) | C.I. 77575; C.I. Pigment metal 4; Glover; Lead flake; Lead S2; Omaha; Omaha & Grant; SI; SO^a^ | Acetic acid lead(2+) salt (2:1); neutral lead acetate; plumbous acetate; normal lead acetate; sugar of lead; salt of Saturn^b^ | Lead azide^b^ | Lead bromide (PbBr_2_); plumbous bromide^b^
Chemical formula | Pb^b^ | Pb(CH_3_CO_2_)_2_^b^ | Pb(N_3_)_2_^b^ | PbBr_2_^b^
Chemical structure | Not applicable | Not applicable | Not applicable | Not applicable
CAS Registry Number | 7439-92-1^b^ | 301-04-2^b^ | 13424-46-9^b^ | 10031-22-8^b^

Characteristic | Lead(II) chloride | Lead(II) chromate | Lead(II) tetrafluoroboratec | Lead(II) iodide
Synonym(s) and registered trade name(s) | Lead chloride (PbCl_2_); Lead(2+) chloride; Plumbous chloride^b^ | Chromic acid (H_2_CrO_4_ lead(2+) salt (1:1); Chrome yellow; Cologne yellow; King’s yellow; Leipzig yellow; Paris yellow; C.I. Pigment Yellow 34; lead chromium oxide (PbCrO_4_); plumbous chromate; C.I. 77600^b^ | Tetrafluoro borate(1-) Lead(2+)^a^ | Lead iodide (PbI_2_); Plumbous iodide^b^
Chemical formula | PbCl_2_^b^ | PbCrO_4_^b^ | Pb(BF_4_)_2_^a^ | PbI_2_^b^
Chemical structure | Not applicable | Not applicable | Not applicable | Not applicable
CAS Registry Number | 7758-95-4^b^ | 7758-97-6^b^ | 13814-96-5^a^ | 10101-63-0^b^

Characteristic | Lead molybdenum chromate | Lead(II) nitrate | Lead(II) oxide | Lead(II,II,IV) oxide
Synonym(s) and registered trade name(s) | Chromic acid, lead and molybdenum salt; chromic acid lead salt with lead molybdate; C.I. Pigment Red 104; Lead chromate, Molybdenum-Lead chromate; Molybdenum Orange^a^ | Nitric acid lead(2+) salt (2:1); Plumbous nitrate^b^ | C.I. 77577; C.I. Pigment Yellow 46; Lead oxide; Lead oxide yellow; Lead protoxide; Litharge; Litharge Yellow L-28; Massicot; Massicotite; Plumbous oxide; Yellow lead ocher^a^ | Lead tetraoxide; Lead tetroxide; Lead oxide red; C.I. Pigment Red 105; C.I. 77578; Gold satinobre; Lead orthoplumbate; Lead Orange; Mineral Red; Paris Red; Saturn Red; Minium; Plumboplumbic oxide; Red Lead; Red Lead oxide; Trilead tetraoxide^d,e^
Chemical formula | No data | Pb(NO_3_)_2_^b^ | PbO^a^ | Pb_3_O_4_^e^
Chemical structure | Not applicable | Not applicable | Not applicable | [image]
CAS Registry Number | 12709-98-7^a^ | 10099-74-8^b^ | 1317-36-8^a^ | 1314-41-6^d^

Characteristic | Lead(II) phosphate | Lead(II) styphnate | Lead(II) sulfate
Synonym(s) and registered trade name(s) | C.I. 77622; Lead orthophosphate; Lead phosphate (3:2); Lead(2+) phosphate; normal lead orthophosphate; Phosphoric acid, lead(2+) salt (2:3); Plumbous phosphate; Trilead phosphate^a^ | Lead trinitroresorcinate^f^ | Anglesite; C.I. 77630; C.I. Pigment White 3; Fast White; Freemans White Lead; Lead bottoms; Milk white; Mulhouse White; Sulfuric acid, lead(2+) salt (1:1)^a^
Chemical formul^a^ | Pb_3_(PO_4_)_2_^a^ | Pb(C_6_HN_3_O_8_)_2_^f^ | PbSO_4_^b^
Chemical structure | Not applicable | Not applicable | Not applicable
CAS Registry Number | 7446-27-7^a^ | 15245-44-0^f^ | 7446-14-2^b^

Characteristic | Lead(II) sulfide | Tetraethyl lead | Lead(II) carbonate
Synonym(s) and registered trade name(s) | C.I. 77640; Galena; Natural lead sulfide; Plumbous sulfide^a^ | Tetraethylplumbane; Lead tetraethyl; TEL^b^ | Carbonic acid, lead(2+) salt (1:1); Cerussite; Dibasic lead carbonate; Lead(2+) carbonate; White lead^a^
Chemical formula | PbS^a^ | Pb(C_2_H_5_)_4_^a^ | PbCO_3_^a^
Chemical structure | Not applicable | [image] | Not applicable
CAS Registry Number | 1314-87-0^a^ | 78-00-2^b^ | 598-63-0^a^

a Lewis 2012.

b O’Neil et al. 2013.

c Stable only in aqueous solution (Haynes 2014).

d NLM 2020.

e Haynes 2014.

f Boileau et al. 2012.

CAS = Chemical Abstracts Services

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Pb, a blueish-white metal with bright luster, is very soft, highly malleable, ductile, a poor conductor of electricity, and is very resistant to corrosion (Haynes 2014). A clean Pb surface will not be attacked by dry air; however, in moist air, the surface will react and become coated with a layer of lead(II) oxide (PbO). This coating may be hydrated and combine with carbon dioxide to form lead(II) carbonate (PbCO_3_) (Carr et al. 2004). This protective coating of insoluble Pb compounds slows or halts corrosion of the underlying metal. Pb is rarely found in its metallic form in nature and commonly occurs as a mineral with sulfur or oxygen. The most important Pb mineral is galena (PbS). Other common Pb-containing minerals include anglesite (PbSO_4_), cerussite (PbCO_3_), and minium (Pb_3_O_4_) (Carr et al. 2004; Davidson et al. 2014; Haynes 2014).

Pb can exist in the 0 oxidation state in metallic Pb and in compounds as the +2 or +4 oxidation states. In the environment, Pb is primarily found in the +2 state in inorganic compounds. The chemistry of inorganic Pb compounds is generally similar to that of the Group 2(II) or alkaline earth metals. There are three common oxides of Pb: lead(II) oxide (PbO); lead(II,IV) oxide or lead tetroxide (Pb_3_O_4_); and lead(IV) oxide or lead dioxide (PbO_2_). The +4 state is only formed under strongly oxidizing conditions. Inorganic Pb(+4) compounds are relatively unstable and would not be expected to be found under ordinary environmental conditions. Pb is amphoteric, meaning that it can react with acids and bases. In acid, Pb forms Pb(+2) (plumbous) and Pb(+4) (plumbic) salts and in basic solution, it forms plumbites (PbO_2_^2−^) and plumbates (Pb(OH)_6_^2−^) (Carr et al. 2004). In organolead compounds, Pb is typically in the tetravalent (+4) oxidation state (Carr et al. 2004; Haynes 2014).

Data on the physical and chemical properties of Pb and several of its compounds are provided in Table 4-2.

Table 4-2 Physical and Chemical Properties of Lead and Compounds

Property | Lead | Lead(II) acetate | Lead(II) azide | Lead(II) bromide
Molecular weight | 207.2^a^ | 325.3^b^ | 291.24^a^ | 367.0^b^
Color | Bluish-white, silvery, gray metal^a^ | White crystals^b^ | Needles or white powder^a^ | White orthorhombic crystals^b^
Physical state | Solid | Solid | Solid | Solid
Melting point | 327.4°C^a^ | 280°C^b^ | Decomposes at 190°C^c^ | 371°C^b^
Boiling point | 1,740°C^a^ | Decomposes^b^ | No data | 892°C^b^
Density | 11.34 g/cm^3^ at 20°C^a^ | 3.25 g/cm^3b^ | 4.17 g/cm^3^ at 20°C^c^ | 6.69 g/cm^3b^
Odor | No data | Slightly acetic odor (trihydrate)^a^ | No data | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water | Insoluble^d^ | 443,000 mg/L at 20°C^b^ | 230 mg/L at 18°C^a^ | 9,750 mg/L at 25°C^b^
Acids | Soluble in dilute nitric acid^d^; reacts with sulfuric acid^a^ | Soluble in acid^e^ | Freely soluble in acetic acid^a^ | No data
Bases | No data | Soluble in alkali^e^ | No data | No data
Organic solvents | Soluble in glycerin; slightly soluble in alcohol^e^ | Slightly soluble in alcohol; freely soluble in glycerol^d^ | No data | Insoluble in alcohol^b^
Partition coefficients:
Log K_ow_ | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data
Vapor pressure | 1.77 mmHg at 1,000°C^a^ | No data | No data | 0.0075 mmHg at 374°C^b^
Henry’s law constant | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data
Conversion factors | Not relevant^f^ | Not relevant^f^ | Not relevant^f^ | Not relevant^f^
Explosive limits | No data | No data | Explodes at 350°C^a^ | No data
Valence state | 0 | +2 | +2 | +2

Property | Lead(II) chloride | Lead(II) chromate | Lead(II) tetrafluoroborate | Lead iodide
Molecular weight | 278.1^g^ | 323.19^a^ | 380.8^b^ | 461.05^g^
Color | White, orthorhombic needles^g^ | Yellow or orange-yellow powder^a^ | No data | Yellow hexagonal crystals^g^
Physical state | Solid | Solid | Stable only in aqueous solution^b^ | Solid
Melting point | 501°C^g^ | 844°C^a^ | No data | 402°C^g^
Boiling point | 950°C^g^ | No data | No data | 954°C^g^
Density | 5.85 g/cm^3g^ | 6.12 g/cm^3b^ | No data | 6.16 g/cm^3g^
Odor | No data | No data | No data | No data
Odor threshold | No data | No data | No data | No data
Solubility:
Water | 9,900 mg/L at 20°C^g^ | 0.2 mg/L^a^ | Soluble^b^ | 630 mg/L at 20°C^g^
Acids | Slightly soluble in dilute hydrochloric acid^g^ | Soluble in dilute nitric acid; insoluble in acetic acid^a^ | No data | No data
Bases | Slightly soluble in dilute ammonia^g^ | No data | No data | No data
Organic solvents | Insoluble in alcohol^g^ | No data | No data | Insoluble in alcohol^g^
Partition coefficients:
Log K_ow_ | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data
Vapor pressure | 7.5 mmHg at 637°C^b^ | No data | No data | 0.75 mmHg at 470°C^b^
Henry’s law constant | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data
Conversion factors | Not relevant^f^ | Not relevant^f^ | Not relevant^f^ | Not relevant^f^
Explosive limits | No data | No data | No data | No data
Valence state | +2 | +2 | +2 | +2

Property | Lead molybdenum chromate | Lead(II) nitrate | Lead(II) oxide | Lead(II,II,IV) oxide
Molecular weight | No data | 331.23^g^ | 223.21^g^ | 685.57^e^
Color | No data | Cubic or monoclinic colorless crystals^g^ | Reddish-yellow; yellow (above 489°C)^g^ | Bright red heavy powder^a^; red tetrahedral crystals^b^
Physical state | No data | Solid | Solid | Solid
Melting point | No data | Begins to decompose above 205°C^g^ | 897°C (begins to sublime before melting)^g^ | 830°C^b^; 500°C^e^
Boiling point | No data | No data | Decomposes at 1,472°C^g^ | Decomposes between 500-530°C^d^
Density | No data | 4.53 g/cm^3g^ | 9.53 g/cm^3^ (Litharge)^g^; 9.6 g/cm^3^ (Massicot)^g^ | 8.92 g/cm^3b^; 9.1 g/cm^3e^
Odor | No data | No data | No data | No data
Odor threshold: | No data | No data | No data | No data
Solubility:
Water | No data | 56:5 g/100 mL at 20°C^g^ | 50.4 mg/L at 25°C (Litharge)^g^; 106.5 mg/L at 25°C (Massicot)^g^ | Insoluble in water^d^
Acid | No data | Insoluble in concentrated nitric acid^a^ | Soluble^g^ | Dissolves in acetic acid or hot hydrochloric acid^b,g^
Base | No data | Soluble in alkali and ammonia^g^ | Soluble^g^ | No data
Organic solvents | No data | 87.7 mg/L (43% aqueous ethanol) at 22°C^g^ | Insoluble in alcohol^a^ | Insoluble in alcohol^g^
Partition coefficients:
Log K_ow_ | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data
Vapor pressure | No data | No data | 0.0075 mmHg at 724°C^b^ | No data
Henry’s law constant | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data
Conversion factors | Not relevant^f^ | Not relevant^f^ | Not relevant^f^ | Not relevant^f^
Explosive limits | No data | No data | No data | No data
Valence state | +2 | +2 | +2 | +2, +2, +4

Property | Lead(II) phosphate | Lead(II) styphnate | Lead(II) sulfate
Molecular weight | 811.54^a^ | 450.29^h^ | 303.25^g^
Color | White powder^a^ | Monoclinic orange-yellow crystal (monohydrate)^b^ | White, heavy, crystalline powder^a^
Physical state | Solid | Solid | Solid
Melting point | 1,014°C^a^ | No data | 1,170°C^g^
Boiling point | No data | No data | No data
Density | 6.9 g/cm^3a^ | 3.1 g/cm^3^ (monohydrate); 2.9 g/cm^3^ (anhydrous)^b^ | 6.2 g/cm^3g^
Odor | No data | No data | No data
Odor threshold: | No data | No data | No data
Solubility:
Water | Insoluble^b^ | Insoluble^b^ | 42.5 mg/L at 25°C^g^
Acid | Soluble in nitric acid^a^ | No data | Soluble in concentrated acids^g^
Base | Soluble in fixed alkali hydroxides^a^ | No data | Soluble in alkalies^g^
Organic solvents | Insoluble in alcohol^a^ | No data | Insoluble in alcohol^a^
Partition coefficients:
Log K_ow_ | No data | No data | No data
Log K_oc_ | No data | No data | No data
Vapor pressure | No data | No data | No data
Henry’s law constant | No data | No data | No data
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | No data | No data | No data
Conversion factors | Not relevant^f^ | Not relevant^f^ | Not relevant^f^
Explosive limits | No data | Detonates at 260°C^b^ | No data
Valence state | +2 | +2 | +2

Property | Lead(II) sulfide | Tetraethyl lead | Lead(II) carbonate
Molecular weight | 239.25^g^ | 323.45^a^ | 267.22^g^
Color | Metallic black cubic crystals^g^ | Colorless^a^ | Colorless rhombic crystals^g^
Physical state | Solid | Liquid^a^ | Solid
Melting point | 1,114°C^d^ | No data | 315°C (decomposes)^g^
Boiling point | Sublimes at 1,281°C^d^ | 200 °C; 227.7°C (with decomposition)^a^ | No data
Density | 7.57–7.59 g/cm^3g^ | 1.653 g/cm^3a^ | 6.6 g/cm^3g^
Odor | No data | No data | No data
Odor threshold: | No data | No data | No data
Solubility:
Water | 124.4 mg/L 20°C^g^ | 0.29 mg/L^i^ | 1.1 mg/L at 20°C^g^
Acid | Soluble in nitric acid^g^ | No data | Soluble^g^
Base | Insoluble in alkalies^d^ | No data | Soluble in alkalies; insoluble in ammonia^g^
Organic solvents | Insoluble in alcohol^a^ | Soluble in benzene, petroleum ether, gasoline; slightly soluble in alcohol^a^ | Insoluble in alcohol^g^
Partition coefficients:
Log K_ow_ | No data | 4.15^j^ | No data
Log K_oc_ | No data | No data | No data
Vapor pressure | 0.0075 mmHg at 705°C^b^ | 0.26 mmHg at 25°C^j^ | No data
Henry’s law constant | No data | No data | No data
Autoignition temperature | No data | No data | No data
Flashpoint | No data | 200°F (93°C) (closed cup)^k^ | No data
Flammability limits | No data | Lower flammable limit: 1.8% by volume^k^ | No data
Conversion factors | Not relevant^f^ | No data | Not relevant^f^
Explosive limits | No data | No data | No data
Valence state | +2 | +4 | +2

a O’Neil et al. 2013.

b Haynes 2014.

c Akhavan 2004.

d Larrañaga et al. 2016.

e Jacob 2012.

f Since these compounds exist in the atmosphere in the particulate state, their concentrations are expressed as μg/m^3^ only.

g Carr et al. 2004.

h Molecular weight calculated from atomic weights.

i Feldhake and Stevens 1963.

j Wang et al. 1996.

k NFPA 2002.