# APPENDIX C INGESTION OF LEAD DEBRIS

The main focus of this ATSDR Toxicological Profile for Lead is on health effects of chronic low-level environmental exposures. The profile also provides information on the clinical presentation of acute Pb toxicity, which occurs when large amounts of Pb are ingested. In children, this often occurs through ingestion of paint chips containing Pb, Pb-contaminated soils, or other non-solid forms of Pb. Ingestion of solid forms of Pb (Pb debris) is a unique exposure scenario in which there is accidental or purposeful ingestion of visible debris containing Pb. This exposure may be acute (debris is expelled or removed from the body soon after ingestion) or chronic (Pb debris is retained within the body, leading to continued elevation in PbB). There are several sources of Pb debris, including Pb shot or other debris found at firing or artillery ranges, or Pb shot found in wild game meats. The information presented below reviews toxicokinetics and adverse health effects of ingested Pb debris. Information regarding the chemistry, fate, and transport of Pb debris is reviewed in Chapter 5. It should also be noted that in addition to ingestion of Pb debris, retained Pb shot or shrapnel, especially in military personnel, could contribute to elevated PbB (Gerhardsson et al. 2002; McQuirter et al. 2004); this possibility should be considered in individuals as appropriate.

Overview. No controlled studies in humans have evaluated bioavailability or toxicity of ingested Pb debris (e.g., Pb shot and other Pb-containing debris from artillery or shooting ranges). Available information is anecdotal, obtained from case reports. Thus, data are not sufficient to determine the bioavailability of ingested Pb debris or to develop dose-response relationships for toxicity. Case reports of acute exposures from ingestion of Pb debris are summarized in Table C-1; these reports demonstrate the following:

- PbB rises rapidly (within hours to a few days) following ingestion of Pb debris.
- The clinical presentation of toxicity following ingestion of Pb debris is the same as that observed for acute Pb poisoning from ingestion of other forms of Pb (see Section 2.2).
- Severity of toxicity of ingested Pb debris will depend upon how much Pb is absorbed (e.g., toxicity is related to PbB; see Section 2.2).
- The onset of toxicity can be rapid (within hours to a few days).
- Following removal of Pb debris from the body, PbBs decrease; however, applying clinical protocols for chelation therapy results in a more rapid decrease in PbB.
- Ingested Pb debris can be retained in the appendix of some individuals and continue to contribute to elevated PbB.

Table C-1 Selected Case Studies of Ingestion of Solid Lead (Pb) Debris or Pb Retained in Gunshot Wounds

Reference and exposure | Blood lead concentration (PbB) (µg/dL) | Effects | Treatment
Banner et al. 2012; A 15-year-old boy ingested a “handful” of Pb shot. He was admitted to the hospital for treatment 14 days after exposure. | - Post-ingestion; ○ 8 days: 54; ○ 14 days: 41; - Post-treatment (2 weeks): <5 | - Most Pb was located in the appendix (14 days post-ingestion); - Abdominal pain; - Elevated free erythrocyte protoporphyrin | - Whole bowel irrigation; - Appendectomy; - Chelation
CDC 2006; A 4-year-old boy with previously diagnosed microcephaly and mental delays ingested a metallic charm containing Pb. Time from exposure to first medical visit was not reported. | At death: 180 | - Charm was retained in the stomach (was not removed); - Intractable vomiting; - Cerebral edema; - Seizures; - Death | Supportive therapy
Clifton et al. 2002; A 21-month-old girl ingested Pb BB pellets. She was taken to the hospital approximately 6 hours post-ingestion. | - Pre-ingestion (routine): 12; - Post-ingestion (6 hours): 47; - Post-removal of pellets: 25; - Post-treatment (10 days): 16 | - Hyperactivity; - No signs of neurological or gastrointestinal toxicity | - Bowel irrigation; - Colonoscopy for removal of pellets; - Chelation
Cox and Pesola 2005; A 73-year-old woman ingested Pb shot in game over decades. | Not reported | - Pb shot accumulated in the appendix; - No information on adverse health effects was reported | Not reported
Durlach et al. 1986; A 30-year-old man ingested Pb shot in game regularly over an unspecified period of time. | - At initial examination: 67.4; - Post-treatment; ○ 10 days: 52.2; ○ 13 days: 24.5; ○ 1 month: 36.8; ○ 1.5 months: 31.6 | - Pb shot accumulated in the appendix; - Acute abdominal pain | - Bowel irritation; - Chelation; - Appendectomy
Fergusson et al. 1997; A 4-year-old girl ingested a Pb fishing sinker. She was evaluated in the emergency room within 1 hour of ingestion. | - Day of ingestion: 4; - Day after ingestion: 16 | No signs of toxicity observed | Endoscopy
Gerhardsson et al. 2002; A man in his “late 40s” had retained Pb shot following a gunshot wound to the shoulder. Reconstructive surgery occurred 54 days post-accident. Some, but not all, of the Pb shot was removed during surgery. | Approximate (data presented graphically), time after accident:; - 25 days: 28; - 50 days: 41; - 54 days (day of surgery): 55; - ~60 days: 31; - 75 days: 48; - 200 days: 36; - 375 days: 30 | - No signs of toxicity observed; - Not all of the Pb shot could be removed during surgery | Surgical removal of Pb pellets
Guillard et al. 2006; A 2-year-old boy ingested toy money made from pure metallic Pb. | Time post-ingestion; - 1 day: 31.3; - 8 days: 61.1; - 1 month: 30.0; - 4 months: 24.9; - 10 months: 9.9 | - Development of microcytic anemia and increased blood zinc protoporphyrin; - No signs of toxicity observed | - Removal of object; - Chelation (8 days post-ingestion)
Gustavsson and Gerhardsson 2005; A 45-year-old woman with elevated PbB was found to have Pb shot in her intestine from ingestion of game. The Pb shot was spontaneously eliminated. Time from ingestion was estimated to be sometime between 1993 and 2001. | Time of assessment:; - January 2002: 55.0; - April 2003 (2 months post-elimination): 34.5; - November 2003: 7.2 | - Malaise and fatigue; - “Diffuse gastrointestinal symptoms” | No treatment (object was spontaneously eliminated)
Hatten et al. 2013; - Case 1: A 15-year-old boy ingested rifle cartridges approximately 1 month prior to evaluation.; - Case 2: A 65-year-old woman ingested several handfuls of bullets. | Case 1; - Initial assessment: 146; - 19 days post-treatment: 53; - 3 months post-treatment: 38 | Case 1; - Decreased activity level; - Vomiting, diarrhea, anorexia; - Hyperactive patellar and brachioradialis reflexes | Case 1; - Cartridges removed by endoscopy; - Chelation
Hatten et al. 2013; - Case 1: A 15-year-old boy ingested rifle cartridges approximately 1 month prior to evaluation.; - Case 2: A 65-year-old woman ingested several handfuls of bullets. | Case 2: Days after ingestion; - Day 1: 9.7; - Day 2: 25.7; - Day 3: 40.5; - Day 60: 17.2 | Case 2; - No signs of toxicity were observed | Case 2; - Endoscopy
Larsen and Blanton 2000; A 9-year-old boy ingested Pb shot in game; the Pb shot was retained in the appendix. | Not reported | - Abdominal pain and anorexia | Appendectomy
Lyons and Filston 1994; A 4-year-old boy ingested Pb shot, which was lodged in his appendix. | - Peak (time of assessment not reported): 23; - Prior to surgery (1.5 months after ingestion): 12 | - Abdominal discomfort, nausea, vomiting, diarrhea; - Headache | Appendectomy
Madsen et al. 1988; Seven patients with Pb shot retained in the appendix. | Range: 4.6–18.2 | Not reported | Not reported
McKinney and McKinney 2000; A 5.5-year-old girl ingested several Pb pellets. | Time after ingestion; - 13 hours: 57; - 36 hours: 79; After treatment:; - 14 days: 14.3; - 6 months: 25 | - Vomiting and abdominal pain; - Decreased blood hemoglobin and hematocrit; - “Mild” speech and language delays noted post-treatment | - Whole bowel irrigation; - Chelation
McNutt et al. 2001; A 45-year-old male ingested 206 Pb bullets. Medical evaluation occurred 5 days after ingestion. Bullets were spontaneously eliminated over 4–47 days after first medical evaluation. | Time after ingestion:; - 5 days: 391; - 10 days: 171; - 25 days: 41; - 6 weeks: 24 | - Abdominal pain and gastrointestinal bleeding; - Anemia | Chelation started at initial medical visit
McQuirter et al. 2004; Subjects (n=451) 1-year following gunshot wound with retained bullets. | - PbB at time after injury: 1.9; - % with PbB ≥10 (days after injury); ○ 0 days: 2.1; ○ 3 days: 7.6; ○ 18 days: 25.1; ○ 3 months: 38.1; ○ 6 months: 28.5; ○ 12 months: 15.8 | Not reported | Not reported
CDC 2004a; A 4-year-old boy ingested a Pb medallion. | - 2–3 weeks after ingestion: 123; - After treatment: 57 | - Abdominal pain, vomiting, diarrhea; - Normocytic anemia, elevated protoporphyrin | - Endoscopy; - Chelation
Mowad et al. 1998; An 8-year-old boy ingested several Pb fishing sinkers. Medical assessment was within 1 days of ingestion. | Time after ingestion:; - 1 day: 53; - 6 days: 45 (start of chelation); - 1 month: 3 | No signs of toxicity observed | - Bowel irrigation; - Colonoscopy; - Chelation
Rosenberg and Haynes 2019; A 3-year-old ingested Pb pellets. | Time after ingestion:; - 7 days: 27; - Post-surgical removal: 14 | Not reported | Laproscopic removal of pellets
Rozier and Liebelt 2019; A 2-year-old boy, a 10-year-old boy, and a 16-year old girl ingested Pb pellets. | 2-year-old boy, PbB measurement:; - Day 0: 65; - 5 days post-chelation: 25.2 | 2-year-old boy: asymptomatic | 2-year-old boy; - Bowel irrigation; - Chelation
Rozier and Liebelt 2019; A 2-year-old boy, a 10-year-old boy, and a 16-year old girl ingested Pb pellets. | 10-year-old boy, PbB measurement:; - 3 days post-ingestion: 70; - 7 months post-chelation: 9.5 | 10-year-old boy: not reported | 10-year-old boy; - Bowel irrigation; - Chelation
Rozier and Liebelt 2019; A 2-year-old boy, a 10-year-old boy, and a 16-year old girl ingested Pb pellets. | 16-year old girl, PbB measurement:; - 9 days post-ingestion: 53; - 13 days post-treatment: 3; - 5 weeks post-treatment: 13 | 16-year old girl:; - abdominal pain; - shortness of breath | 16-year old girl; - Bowel irrigation; - Chelation; - Colonoscopy
Treble and Thompson 2002; A 2.5-year-old girl ingested Pb pellets. | Time after ingestion; - 1.5 hours: 56; - 29 hours: 35; - 94 hours: 35 | No signs of toxicity observed | Laxatives
Zardawi and Siriweera 2013; An 8-year-old boy ingested Pb pellets in game over a 2-year period. | Elevated PbB (17.4–27.4) over 2 years; Pellets observed in appendix | Hyperactivity | - Bowel irrigation; - Appendectomy

Confounding Factors. There are several uncertainties from case reports on ingestion of Pb debris. Therefore, it is not possible to determine dose, bioavailability, or accurate plasma-time concentration curves. Uncertainties include:

- Baseline PbB data are rarely available. Thus, it is difficult to determine the contribution of ingested Pb debris to measured PbB following ingestion.
- Time from ingestion of Pb debris to first clinical evaluation and PbB assessment is often unknown.
- No quantitative data on the dose of Pb ingested in debris are reported.
- No quantitative data on fecal excretion of ingested Pb are reported.
- Information on the chemical composition of Pb debris often is not reported.
- No information on potential differences in the bioavailability of different types of Pb debris is available

Bioavailability of Pb Debris. No quantitative estimates on the bioavailability of Pb debris in humans are available. Several case reports show increased PbB following ingestion of Pb debris, demonstrating that ingested Pb is absorbed (CDC 2006; Clifton et al. 2002; Durlach et al. 1986; Fergusson et al. 1997; Greensher et al. 1974; Guillard et al. 2006; Hatten et al. 2013; McKinney and McKinney 2000; McNutt et al. 2001; CDC 2004a; Mowad et al. 1998; Treble and Thompson 2002); see Table C-1 for details. However, due to lack of information on ingested dose, quantitative estimates of absorption cannot be determined. No information on bioavailability of Pb debris in animals was identified. Lead debris retained within the body will continue to contribute to elevated PbB until it is removed from the body, either spontaneously or by medical intervention (Banner et al. 2012; Clifton et al. 2002; Durlach et al. 1986; Gerhardsson et al. 2002; Guillard et al. 2006; McQuirter et al. 2004).

Lead debris must become bioaccessible (i.e., soluble) in the gastrointestinal tract in order for it to be absorbed. It is likely that processes thought to contribute to rendering ingested soil Pb bioaccessible also are important in rendering ingested Pb debris bioaccessible (see Section 3.1.1). IVBA assays that measure extractable Pb have not been evaluated for predicting bioavailability or RBA of ingested Pb debris, although one study found that IVBA measured at gastric pH predicted the relatively high in vivo RBA (100%) of firing range soils (Bannon et al. 2009; see Section 3.1.1).

Although dose-PbB relationships and bioavailability cannot be reliably established from the published case history of Pb debris ingestion, it is possible to use exposure-biokinetics models to reconstruct the time course of PbB expected for a given acute dose of soluble Pb and, from this, estimate the relative bioavailability of Pb from ingested Pb shot that would result in a given peak PbB. This scenario assumes that Pb debris is not retained in the body. The AALM-LG (EPA 2014a) can simulate the internal biokinetics of Pb associated with daily doses of Pb. This model predicts that a child 30 months of age who has a baseline PbB of 1 µg/dL would experience a 10 µg/dL increase in PbB in response to ingestion of approximately 1 mg of soluble Pb (Figure C-1). The peak PbB would occur during the day of ingestion and PbB would return to approximately 120% of baseline in approximately 35 days following the dose. If this prediction is extrapolated to the ingestion of Pb shot or other debris, the 1 mg dose of soluble Pb could occur in association with a dose of 100 mg of debris having an RBA of 1%, or 1 g of debris having an RBA of 0.1% (see Section 3.1.5.4 EPA All Ages Lead Model [AALM] for more information). Figure C-1 also shows the predicted PbB pattern for six repeated, weekly events in which the child ingested 1 mg of soluble PbB. This would result in periodic increases in PbB, with the maximum following each exposure event increasing until a pseudo-steady-state PbB was reached at approximately 14.5 µg/dL (13.5 µg/dL above baseline). The PbB would return to approximately 120% of baseline in approximately 570 days after the last exposure event. This longer time to baseline following multiple exposures reflects the accrual of Pb in bone with multiple dosing and the relatively slow transfer of Pb from bone to blood after exposure ceases (see Section 3.1).

Ingestion of soil from firing ranges may also contribute to PbB. A study in juvenile swine of eight soils (sieved to <250 µm) from small arms firing ranges showed a relative bioavailability range of 77–140%, with a mean of 108 % (SD or SE [not specified]: 18%). Soil from this site largely consisted of highly bioavailable Pb carbonate. However, this study did not provide information on bioavailability of Pb debris.

Figure C-1 PbB Predicted from AALM-LG for a 0.9 mg Dose of Soluble Pb Ingested by a Child 30 Months of Age

Retention of Pb Debris in the Appendix. Case reports show that Pb debris can be retained within the appendix (Banner et al. 2012; Cox and Pesola 2005; Durlach et al. 1986; Larsen and Blanton 2000; Lyons and Filston 1994; Madsen et al. 1988; Reddy 1985; Zardawi and Siriweera 2013); see Table C-1 for details. For this to occur, the appendix must be oriented with respect to the cecum in such a way to allow objects to pass through the appendiceal-cecal orifice; approximately 45% of the population have appendices with this orientation. However, approximately 65% of the population have appendices that might hinder foreign body access into the appendiceal lumen due to atypical anatomic position, adhesions, or kinks (Klingler et al. 1998). In addition to orientation of the appendix, the physical size and shape of the debris likely contribute to retention. Although it is not possible to determine the incidence of Pb debris lodged in the gastrointestinal tract or the appendix because not all cases of ingestion of Pb debris are reported in the published literature, approximately 45% of the population is predisposed to retention of Pb debris on orientation of the appendix.

Toxicity of Ingested Pb Debris. Regardless of the source of Pb (e.g., ingested Pb debris, Pb paint, Pb-contaminated soil, occupational exposure), once Pb is absorbed into the body, toxicity will be related to PbB; thus, bioavailability and duration of elevated PbB, rather than the form of Pb ingested, will determine adverse health outcomes. If ingested Pb debris is not retained by the body, toxicity of PbB would be consistent with that described for acute Pb toxicity. A summary of peak PbBs and associated toxicity following exposure of ingested Pb debris is shown in Table C-2. Severity of toxicity increases with PbB. At PbB ≤47 µg/dL, the only adverse health effect observed was a single report of headache at a PbB of 12 µg/dL. With increased PbB, effects were observed in several organ systems and severity of effects increased. At a PbB range of 54–146 µg/dL, abdominal colic, vomiting, hematological effects, and neurological effects were observed, and at a PbB of 180 µg/dL, severe effects (seizure and cerebral edema) leading to death were observed. In most cases, the onset of toxicity occurs within hours or days of ingestion. If PbB remains elevated, either due to inadequate medical intervention or Pb that is retained within the body (i.e., appendix, gastrointestinal tract, etc.) adverse health effects associated with chronically elevated PbB would be expected to occur (see Chapter 2, Health Effects). As reviewed in Chapter 2, PbBs ≤10 µg/dL are associated with adverse health effects to numerous organ systems, including developmental and neurological effects, with severity exhibiting dose-dependence. Given the many factors that can affect development of Pb-induced toxicity, case reports of individuals cannot provide generalizations of exposure-response relationships.

Table C-2 Peak Blood Lead Concentration (PbB) and Acute Toxicity Associated with Ingestion of Lead (Pb) Debris

Peak PbB (µg/dL)^a^ | Effects associated with Pb exposure | References
12–16 | No effects observed | Fergusson et al. 1997
12–16 | Headache | Lyons and Filston 1994
40.5–47 | No effects observed | Clifton et al. 2002; Hatten et al. 2013
54–61 | No effects observed | Mowad et al. 1998; Treble and Thompson 2002
54–61 | Abdominal colic; Hematological effects^b^ | Banner et al. 2012
79 | Abdominal colic and vomiting; Hematological effects^c^; Neurological effects^d^ | McKinney and McKinney 2000
123 | Abdominal colic, vomiting, diarrhea; Hematological effects^e^ | CDC 2004a
146 | Vomiting; Neurological signs^f^ | Hatten et al. 2013
180 | Vomiting; Seizures; Cerebral edema; Death | CDC 2006
391 | Abdominal colic, gastrointestinal bleeding; Anemia | McNutt et al. 2001

a Peak blood Pb reported.

b Elevated free erythrocyte protoporphyrin or microcytic anemia and increased blood zinc protoporphyrin.

c Decreased blood hemoglobin and hematocrit.

d “Mild” speech and language delays.

e Normocytic anemia, elevated protoporphyrin

f Decreased activity level and hyperactive patellar and brachioradialis reflexes.

## REFERENCES

Banner B, Schaeffer S, Badillo RB, . 2012. Multiple lead appendoliths following ingestion of lead shot: Time course and removal by laporoscopic appendectomy. Clin Toxicol 50(4):266–267. 10.3109/15563650.2012.658473.
Bannon DI, Drexler JW, Fent GM, . 2009. Evaluation of small arms range soils for metal contamination and lead bioavailability. Environ Sci Technol 43(24):9071–9076. 10.1021/es901834h.20000496
CDC. 2004a. Brief report: Lead poisoning from ingestion of a toy necklace- Oregon, 2003. Centers for Disease Control and Prevention. MMWR Morb Mortal Wkly Rep 53(23):509–511. https://www.cdc.gov/mmwr/preview/mmwrhtml/mm5323a5.htm.
CDC. 2006. Death of a child after ingestion of a metallic charm - Minnesota, 2006. MMWR Morb Mortal Wkly Rep 55(12):340–341. https://www.cdc.gov/mmwr/pdf/wk/mm5512.pdf. May 23, 2017.16572103
Clifton JC, Sigg T, Burda AM, . 2002. Acute pediatric lead poisoning: Combined whole bowel irrigation, succimer therapy, and endoscopic removal of ingested lead pellets. Pediatr Emerg Care 18(3):200–202. 10.1097/00006565-200206000-00013.12066009
Cox WM, Pesola GR. 2005. Buckshot ingestion. N Engl J Med 353(26):e23.16382055
Durlach V, Lisovoski F, Gross A, . 1986. Appendicectomy in an unusual case of lead poisoning. Lancet 1(8482):687–688.
EPA. 2014a. Development and evaluation of the all ages lead model (AALM). U.S. Environmental Protection Agency.
Fergusson J, Malecky G, Simpson E. 1997. Lead foreign body ingestion in children. J Paediatr Child Health 33:542–544.9484690
Gerhardsson L, Dahlin L, Knebel R, . 2002. Blood lead concentration after a shotgun accident. Environ Health Perspect 110:115–117.11781173
Greensher J, Mofenson HC, Balakrishnan C, . 1974. Leading poisoning from ingestion of lead shot. Pediatrics 54(5):641–643.4453468
Guillard O, Flamen P, Fauconneau B. 2006. A case of acute lead poisoning in a 2-year-old child. Br J Clin Pharmacol 62(2):247–247. 10.1111/j.1365-2125.2006.02603.x.
Gustavsson P, Gerhardsson L. 2005. Intoxication from an accidentally ingested lead shot retained in the gastrointestinal tract. Environ Health Perspect 113:491–493.15811841
Hatten BW, Bueso A, Craven P, . 2013. Lead toxicity and endoscopic removal of ingested firearm cartridges. Clin Toxicol (Phila) 51(5):448–450. 10.3109/15563650.2013.792114.23641934
Klingler PJ, Seelig MH, DeVault KR, . 1998. Ingested foreign bodies within the appendix: A 100-year review of the literature. Dig Dis 16(5):308–314.9892790
Larsen AR, Blanton RH. 2000. Appendicitis due to bird shot ingestion: A case study. Am Surg 66(6):589–591.10888137
Lyons JD, Filston HC. 1994. Lead intoxication from a pellet entrapped in the appendix of a child: Treatment considerations. J Pediatr Surg 29(12):1618–1620.7877052
Madsen HH, Skjodt T, Jorgensen PJ, . 1988. Blood lead levels in patients with lead shot retained in the appendix. Acta Radiol 29(6):745–746. 10.1080/02841858809171977.3190952
McNutt TK, Chambers-Emerson J, Dethlefsen M, . 2001. Bite the bullet: Lead poisoning after ingestion of 206 lead bullets. Vet Hum Toxicol 43(5):288–289.11577935
McQuirter JL, Rothenberg SJ, Dinkins GA, . 2004. Change in blood lead concentration up to 1 year after a gunshot wound with a retained bullet. Am J Epidemiol 159(7):683–692. 10.1093/aje/kwh074.15033646
Mowad E, Haddad I, Gemmel DJ. 1998. Management of lead poisoning from ingested fishing sinkers. Arch Pediatr Adolesc Med 152(5):485–488.9605033
Reddy ER. 1985. Retained lead shot in the appendix. J Can Assoc Radiol 36(1):47–48.3980552
Rosenberg A, Haynes J. 2019. Management of ingested lead pellets with elevated blood lead levels in a pediatric patient. J Pediatr Gastroenterol Nutr 69(6):e159–e160. 10.1097/mpg.0000000000002438.31436710
Rozier B, Liebelt E. 2019. Lead pellet ingestion in 3 children: Another source for lead toxicity. Pediatr Emerg Care 35(5):385–388. 10.1097/pec.0000000000001469.30095594
Treble RG, Thompson TS. 2002. Elevated blood lead levels resulting from the ingestion of air rifle pellets. J Anal Toxicol 26:370–373.12220020
Zardawi I, Siriweera E. 2013. Images in clinical medicine. Pellets in the appendix. N Engl J Med 369(6):e7. 10.1056/NEJMicm1214754.23924027