# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR LEAD

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to Pb.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen were conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for Pb. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of Pb have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of Pb are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

- Health Effects; - Species; - Human; - Laboratory mammals; - Route of exposure; - Inhalation; - Oral; - Dermal (or ocular); - Parenteral (these studies will be considered supporting data); - Health outcome; - Death; - Systemic effects; - Body weight effects; - Respiratory effects; - Cardiovascular effects; - Gastrointestinal effects; - Hematological effects; - Musculoskeletal effects; - Hepatic effects; - Renal effects; - Dermal effects; - Ocular effects; - Endocrine effects; - Immunological effects; - Neurological effects; - Reproductive effects; - Developmental effects; - Other noncancer effects; - Cancer
- Toxicokinetics; - Absorption; - Distribution; - Metabolism; - Excretion; - PBPK models; - Biomarkers; - Biomarkers of exposure; - Biomarkers of effect; - Interactions with other chemicals; - Potential for human exposure; - Releases to the environment; - Air; - Water; - Soil; - Environmental fate; - Transport and partitioning; - Transformation and degradation; - Environmental monitoring; - Air; - Water; - Sediment and soil; - Other media; - Biomonitoring; - General populations; - Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the draft toxicological profile for Pb released for public comment in 2019; thus, the literature search was restricted to studies published between February 2015 and September 2019. The following main databases were searched in September 2019:

- PubMed
- National Library of Medicine’s TOXLINE
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for Pb. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to Pb were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
09/2019 | ((((10031-22-8[rn] OR 10099-74-8[rn] OR 10101-63-0[rn] OR 11119-70-3[rn] OR 12709-98-7[rn] OR 1309-60-0[rn] OR 1314-41-6[rn] OR 1314-87-0[rn] OR 1317-36-8[rn] [ 13424-46-9[rn] OR 13814-96-5[rn] OR 15245-44-0[rn] OR 16040-38-3[rn] OR 39377-56-5[rn] OR 598-63-0[rn] OR 7439-92-1[rn] OR 7446-14-2[rn] OR 7446-27-7[rn] OR 7758-95-4[rn] OR 7758-97-6[rn] OR 78-00-2[rn] OR 301-04-2[rn] ) AND (((“Lead/toxicity”[mh] OR “Lead/adverse effects”[mh] OR “Lead/poisoning”[mh] OR “Lead/pharmacokinetics”[mh]) OR (“Lead”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Lead”[mh] AND toxicokinetics[mh:noexp]) OR (“Lead/blood”[mh] OR “Lead/cerebrospinal fluid”[mh] OR “Lead/urine”[mh]) OR (“Lead”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Lead”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Lead/antagonists and inhibitors”[mh]) OR (“Lead/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Lead”[majr] AND cancer[sb]) OR (“Lead/pharmacology”[majr])) AND (2016/02/01 : 3000[mhda] OR 2016/02/01 : 3000[crdt] OR 2016/02/01 : 3000[edat] OR 2015/02/01 : 3000[dp]))) OR (“lead poisoning”[mh] AND (2016/02/01 : 3000[mhda] OR 2016/02/01 : 3000[crdt] OR 2016/02/01 : 3000[edat] OR 2015/02/01 : 3000[dp])) OR (((“Tetraethyl Lead/toxicity”[mh] OR “Tetraethyl Lead/adverse effects”[mh] OR “Tetraethyl Lead/poisoning”[mh] OR “Tetraethyl Lead/pharmacokinetics”[mh]) OR (“Tetraethyl Lead”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Tetraethyl Lead”[mh] AND toxicokinetics[mh:noexp]) OR (“Tetraethyl Lead/blood”[mh] OR “Tetraethyl Lead/cerebrospinal fluid”[mh] OR “Tetraethyl Lead/urine”[mh]) OR (“Tetraethyl Lead”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Tetraethyl Lead”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Tetraethyl Lead/antagonists and inhibitors”[mh]) OR (“Tetraethyl Lead/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Tetraethyl Lead”[majr] AND cancer[sb]) OR (“Tetraethyl Lead/pharmacology”[majr])) AND (2016/02/01 : 3000[mhda] OR 2016/02/01 : 3000[crdt] OR 2016/02/01 : 3000[edat] OR 2015/02/01 : 3000[dp])) OR ((301-04-2[rn] AND ((“Organometallic Compounds/toxicity”[mh] OR “Organometallic Compounds/adverse effects”[mh] OR “Organometallic Compounds/poisoning”[mh] OR “Organometallic Compounds/pharmacokinetics”[mh]) OR (“Organometallic Compounds”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Organometallic Compounds”[mh] AND toxicokinetics[mh:noexp]) OR (“Organometallic Compounds/blood”[mh] OR “Organometallic Compounds/cerebrospinal fluid”[mh] OR “Organometallic Compounds/urine”[mh]) OR (“Organometallic Compounds”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Organometallic Compounds”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Organometallic Compounds/antagonists and inhibitors”[mh]) OR (“Organometallic Compounds/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Organometallic Compounds”[majr] AND cancer[sb]) OR (“Organometallic Compounds/pharmacology”[majr]))) AND (2016/02/01 : 3000[mhda] OR 2016/02/01 : 3000[crdt] OR 2016/02/01 : 3000[edat] OR 2015/02/01 : 3000[dp])) OR (((“1,3-Benzenediol, 2,4,6-trinitro-, lead(2+) salt”[tw] OR “Borate(1-), tetrafluoro-, lead (2+)”[tw] OR “Borate(1-), tetrafluoro-, lead(2+)”[tw] OR “Chromic acid lead salt with lead molybdate”[tw] OR “Chromic acid, lead and molybdenum salt”[tw] OR “Chromium lead molybdenum oxide”[tw] OR “Lead (II) iodide”[tw] OR “Lead 2,4,6-trinitro-m-phenylene dioxide”[tw] OR “Lead bis(tetrafluoroborate)”[tw] OR “Lead borofluoride”[tw] OR “Lead boron fluoride”[tw] OR “Lead Brown”[tw] OR “Lead chromate molybdate”[tw] OR “lead diiodide”[tw] OR “Lead dioxide”[tw] OR “Lead fluoborate”[tw] OR “Lead fluoroborate”[tw] OR “Lead iodide”[tw] OR “Lead molybdate chromate”[tw] OR “Lead molybdenum chromate”[tw] OR “Lead oxide”[tw] OR “Lead peroxide”[tw] OR “Lead styphnate”[tw] OR “Lead superoxide”[tw] OR “Lead tetrafluoroborate”[tw] OR “Lead tricinate”[tw] OR “Lead trinitroresorcinate”[tw] OR “Lead(II) iodide”[tw] OR “Lead(II) styphnate”[tw] OR “Lead(II) tetrafluoroborate”[tw] OR “Lead(IV) oxide”[tw] OR “Lead-molybdenum chromate”[tw] OR “Molybdenum-lead chromate”[tw] OR “Plumbic oxide”[tw] OR “Plumbous iodide”[tw] OR “Plumbum jodatum”[tw] OR “Resorcinol, 2,4,6-trinitro-, lead(2+) salt”[tw] OR “Thiolead A”[tw] OR “Tricinat”[tw]) AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR ai[sh] OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh] OR “pharmacology”[sh:noexp] OR “environmental exposure”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR “Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic ”[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh] OR cancer[sb] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])))) AND (2016/02/01 : 3000[mhda] OR 2016/02/01 : 3000[crdt] OR 2016/02/01 : 3000[edat] OR 2015/02/01 : 3000[dp])) OR ((“Plumbism”[tw] OR “saturnism”[tw] OR “colica pictorum”[tw] OR “Devon colic”[tw] OR “painter’s colic”[tw]) NOT “lead poisoning”[mh]) OR (((“1,3-Benzenediol, 2,4,6-trinitro-, lead(2+) salt (1:1)”[tw] OR “Acetic acid lead(2+) salt”[tw] OR “Acetic acid, lead salt”[tw] OR “Acetic acid, lead(2 +) salt”[tw] OR “Acetic acid, lead(2+) salt”[tw] OR “Anglislite”[tw] OR “Azarcon”[tw] OR “Borate(1-), tetrafluoro-, lead (2+)”[tw] OR “Borate(1-), tetrafluoro-, lead(2+) (2:1)”[tw] OR “C.I. Pigment Metal 4”[tw] OR “C.I. Pigment Yellow 46”[tw] OR “CARBONIC ACID, LEAD SALT (1:1)”[tw] OR “Carbonic acid, lead salt (2+) (1:1) ”[tw] OR “Carbonic acid, lead(2+) salt”[tw] OR “Cerussete”[tw] OR “Cerussite”[tw] OR “Chrome Orange”[tw] OR “Chrome Yellow”[tw] OR “Chromic acid (H2CrO4), lead(2+) salt (1:1)”[tw] OR “Chromic acid lead salt ”[tw] OR “CHROMIC ACID, LEAD (2+) SALT (1:1)”[tw] OR “Chromic Acid, Lead (II) Salt (1:1)”[tw] OR “Chromic acid, lead and molybdenum salt”[tw] OR “Chromic acid, lead salt”[tw] OR “Chromic acid, lead(2+) salt (1:1)”[tw] OR “Chromium lead molybdenum oxide”[tw] OR “Chromium lead oxide”[tw] OR “CI pigment metal 4”[tw] OR “CI Pigment Yellow 46”[tw] OR “Collodial lead phosphate”[tw] OR “Dibasic lead acetate”[tw] OR “Dibasic lead carbonate”[tw] OR “Dibasic lead sulfate”[tw] OR “Entan”[tw] OR “Fast White”[tw] OR “Flowsperse R 12”[tw] OR “Freemans White Lead”[tw] OR “Galena”[tw] OR “Glover”[tw] OR “Gold Satinobre”[tw] OR “Heuconin 5”[tw] OR “Lead (II) carbonate”[tw] OR “Lead (II) chloride”[tw] OR “Lead (II) chromate”[tw] OR “Lead (II) iodide”[tw] OR “Lead (II) nitrate”[tw] OR “Lead (II) oxide”[tw] OR “Lead (II) sulfate”[tw] OR “Lead (II) sulfide”[tw] OR “Lead (II, IV) oxide”[tw] OR “Lead (IV) oxide ”[tw] OR “Lead 2,4,6-trinitro-m-phenylene dioxide”[tw] OR “Lead acetate”[tw] OR “Lead azide”[tw] OR “Lead bis(tetrafluoroborate)”[tw] OR “Lead borofluoride”[tw] OR “Lead boron fluoride”[tw] OR “Lead Bottoms”[tw] OR “Lead bromide”[tw] OR “Lead brown”[tw] OR “Lead carbonate”[tw] OR “Lead chloride”[tw] OR “Lead chromate”[tw] OR “Lead chromate(VI)”[tw] OR “Lead chromium oxide (PbCrO4)”[tw] OR “Lead di(acetate)”[tw] OR “Lead diacetate”[tw] OR “Lead diazide”[tw] OR “Lead dibasic acetate”[tw] OR “Lead dibromide”[tw] OR “Lead dichloride”[tw] OR “Lead diiodide”[tw] OR “Lead dinitrate”[tw] OR “Lead dioxide”[tw] OR “Lead element”[tw] OR “Lead flake”[tw] OR “Lead fluoborate”[tw] OR “Lead fluoroborate”[tw] OR “Lead iodide”[tw] OR “Lead metal”[tw] OR “Lead molybdate chromate”[tw] OR “Lead molybdenum chromate”[tw] OR “Lead monooxide”[tw] OR “Lead monosulfate”[tw] OR “Lead monosulfide”[tw] OR “Lead monoxide”[tw] OR “Lead nitrate”[tw] OR “Lead orthophosphate”[tw] OR “Lead orthoplumbate”[tw] OR “Lead oxide”[tw] OR “Lead peroxide”[tw] OR “Lead phosphate”[tw] OR “Lead protoxide”[tw] OR “Lead S 2”[tw] OR “Lead S2”[tw] OR “Lead styphnate”[tw] OR “Lead sulfate”[tw] OR “Lead sulfide”[tw] OR “Lead sulphate”[tw] OR “Lead sulphide”[tw] OR “Lead superoxide”[tw] OR “Lead tetraethide”[tw] OR “Lead tetraethyl”[tw] OR “Lead tetrafluoroborate”[tw] OR “Lead tetraoxide”[tw] OR “Lead tetroxide”[tw] OR “Lead tricinate”[tw] OR “Lead trinitroresorcinate”[tw] OR “Lead(+2) sulfate”[tw] OR “Lead(2+) acetate”[tw] OR “Lead(2+) azide”[tw] OR “Lead(2+) bis(nitrate)”[tw] OR “Lead(2+) bromide”[tw] OR “Lead(2+) carbonate”[tw] OR “Lead(2+) chloride”[tw] OR “Lead(2+) nitrate”[tw] OR “Lead(2+) oxide”[tw] OR “Lead(2+) phosphate”[tw] OR “Lead(2+) phosphate (Pb3(PO4)2)”[tw] OR “Lead(2+) salt carbamic acid (1:1) ”[tw] OR “Lead(2+) sulfate”[tw] OR “Lead(2+) sulfide”[tw] OR “Lead(II) acetate”[tw] OR “Lead(II) azide”[tw] OR “Lead(II) bromide”[tw] OR “Lead(II) carbonate”[tw] OR “Lead(II) chloride”[tw] OR “Lead(II) chromate”[tw] OR “Lead(II) dinitrate”[tw] OR “Lead(II) iodide”[tw] OR “Lead(II) nitrate”[tw] OR “Lead(II) oxide”[tw] OR “Lead(II) phosphate”[tw] OR “Lead(II) phosphate (3:2)”[tw] OR “Lead(II) styphnate”[tw] OR “Lead(II) sulfate”[tw] OR “Lead(II) sulfide”[tw] OR “Lead(II) tetrafluoroborate”[tw] OR “Lead(IV) oxide”[tw] OR “Lead, elemental”[tw] OR “Lead, inorganic”[tw] OR “Lead, tetraethyl”[tw] OR “Lead, tetraethyl-”[tw] OR “Lead-molybdenum chromate”[tw] OR “Litharge”[tw] OR “Massicot”[tw] OR “Massicotite”[tw] OR “Mennige”[tw] OR “Milk White”[tw] OR “mine orange”[tw] OR “Mineral Orange”[tw] OR “Mineral red”[tw] OR “minio anaranjado”[tw] OR “Minium”[tw] OR “Molybdenum-lead chromate”[tw] OR “Mulhouse White”[tw] OR “Nitric acid lead(2+) salt”[tw] OR “Nitric acid, lead(2+) salt”[tw] OR “Orange lead”[tw] OR “Orangemennige”[tw] OR “Paris Red”[tw] OR “PbSO4”[tw] OR “Perlex paste 500”[tw] OR “Perlex paste 600A”[tw] OR “Phoenicochroite”[tw] OR “Phosphoric acid, lead salt”[tw] OR “Phosphoric acid, lead(2+) salt (2:3)”[tw] OR “Pigment Red 105”[tw] OR “Pigment White 3”[tw] OR “Pigment Yellow 34”[tw] OR “Pigment Yellow 46”[tw] OR “Plumbane”[tw] OR “Plumbi”[tw] OR “Plumbic oxide”[tw] OR “Plumboplumbic oxide”[tw] OR “Plumbous”[tw] OR “Plumbum”[tw] OR “Red lead”[tw] OR “Resorcinol, 2,4,6-trinitro-, lead(2+) salt (1:1)”[tw] OR “Rough lead bullion”[tw] OR “Royal Yellow 6000”[tw] OR “Salt of saturn”[tw] OR “Sandix”[tw] OR “Saturn red”[tw] OR “Sugar of lead”[tw] OR “Sulfuric acid, lead(2+) salt”[tw] OR “Tetra Ethylene Lead”[tw] OR “Tetra(methylethyl)lead”[tw] OR “Tetraethyl lead”[tw] OR “Tetraethyl plumbane”[tw] OR “Tetraethyllead”[tw] OR “Tetraethyllead, liquid”[tw] OR “tetraethylplomb”[tw] OR “Tetraethylplombane”[tw] OR “Tetraethylplumbane”[tw] OR “tetraetilplomo”[tw] OR “Thiolead A”[tw] OR “Tricinat”[tw] OR “Trilead bis(orthophosphate)”[tw] OR “Trilead phosphate”[tw] OR “Trilead tetraoxide”[tw] OR “Trilead tetroxide”[tw] OR “Unichem PBA”[tw] OR “Yellow lead ocher”[tw]) NOT medline[sb]) AND (2016/02/01 : 3000[crdt] OR 2016/02/01 : 3000[edat] OR 2015/02/01 : 3000[dp])))) OR ((((“Lead”[ti] NOT “lead to”[ti]) OR “Pb”[ti] OR “PbS”[ti] OR “PbO”[ti]) NOT medline[sb]) AND (2016/02/01 : 3000[crdt] OR 2016/02/01 : 3000[edat] OR 2015/02/01 : 3000[dp]))
Toxline
09/2019 | Date limit: 2015 to present:; (10031-22-8[rn] OR 10099-74-8[rn] OR 10101-63-0[rn] OR 11119-70-3[rn] OR 12709-98-7[rn] OR 1309-60-0[rn] OR 1314-41-6[rn] OR 1314-87-0[rn] OR 1317-36-8[rn] OR 13424-46-9[rn] OR 13814-96-5[rn] OR 15245-44-0[rn] OR 16040-38-3[rn] OR 39377-56-5[rn] OR 598-63-0[rn] OR 7439-92-1[rn] OR 7446-14-2[rn] OR 7446-27-7[rn] OR 7758-95-4[rn] OR 7758-97-6[rn] OR 78-00-2[rn]) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ); (“1,3-Benzenediol, 2,4,6-trinitro-, lead(2+) salt (1:1)” OR “Acetic acid lead(2+) salt” OR “Acetic acid, lead salt” OR “Acetic acid, lead(2 +) salt” OR “Acetic acid, lead(2+) salt” OR “Anglislite” OR “Azarcon” OR “Borate(1-), tetrafluoro-, lead (2+)” OR “Borate(1-), tetrafluoro-, lead(2+) (2:1)” OR “C.I. Pigment Metal 4” OR “C.I. Pigment Yellow 46” OR “CARBONIC ACID, LEAD SALT (1:1)” OR “Carbonic acid, lead salt (2+) (1:1)”) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ); (“Carbonic acid, lead(2+) salt” OR “Cerussete” OR “Cerussite” OR “Chrome Orange” OR “Chrome Yellow” OR “Chromic acid (H2CrO4), lead(2+) salt (1:1)” OR “Chromic acid lead salt ” OR “CHROMIC ACID, LEAD (2+) SALT (1:1)” OR “Chromic Acid, Lead (II) Salt (1:1)” OR “Chromic acid, lead and molybdenum salt” OR “Chromic acid, lead salt” OR “Chromic acid, lead(2+) salt (1:1)” OR “Chromium lead molybdenum oxide”) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ); (“Chromium lead oxide” OR “CI pigment metal 4” OR “CI Pigment Yellow 46” OR “Collodial lead phosphate” OR “Dibasic lead acetate” OR “Dibasic lead carbonate” OR “Dibasic lead sulfate” OR “Entan” OR “Fast White” OR “Flowsperse R 12” OR “Freemans White Lead” OR “Galena” OR “Glover” OR “Gold Satinobre” OR “Heuconin 5” OR “Lead (II) carbonate” OR “Lead (II) chloride” OR “Lead (II) chromate” OR “Lead (II) iodide” OR “Lead (II) nitrate” OR “Lead (II) oxide” OR “Lead (II) sulfate” OR “Lead (II) sulfide”) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ); (“Lead (II,IV) oxide” OR “Lead (IV) oxide ” OR “Lead 2,4,6-trinitro-m-phenylene dioxide” OR “Lead acetate” OR “Lead azide” OR “Lead bis(tetrafluoroborate)” OR “Lead borofluoride” OR “Lead boron fluoride” OR “Lead Bottoms” OR “Lead bromide” OR “Lead brown” OR “Lead carbonate” OR “Lead chloride” OR “Lead chromate” OR “Lead chromate(VI)” OR “Lead chromium oxide (PbCrO4)” OR “Lead di(acetate)”) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ); (“Lead diacetate” OR “Lead diazide” OR “Lead dibasic acetate” OR “Lead dibromide” OR “Lead dichloride” OR “Lead diiodide” OR “Lead dinitrate” OR “Lead dioxide” OR “Lead element” OR “Lead flake” OR “Lead fluoborate” OR “Lead fluoroborate” OR “Lead iodide” OR “Lead metal” OR “Lead molybdate chromate” OR “Lead molybdenum chromate” OR “Lead monooxide” OR “Lead monosulfate” OR “Lead monosulfide”) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ); (“Lead monoxide” OR “Lead nitrate” OR “Lead orthophosphate” OR “Lead orthoplumbate” OR “Lead oxide” OR “Lead peroxide” OR “Lead phosphate” OR “Lead protoxide” OR “Lead S 2” OR “Lead S2” OR “Lead styphnate” OR “Lead sulfate” OR “Lead sulfide” OR “Lead sulphate” OR “Lead sulphide” OR “Lead superoxide” OR “Lead tetraethide” OR “Lead tetraethyl” OR “Lead tetrafluoroborate” OR “Lead tetraoxide”) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ); (“Lead tetroxide” OR “Lead tricinate” OR “Lead trinitroresorcinate” OR “Lead(+2) sulfate” OR “Lead(2+) acetate” OR “Lead(2+) azide” OR “Lead(2+) bis(nitrate)” OR “Lead(2+) bromide” OR “Lead(2+) carbonate” OR “Lead(2+) chloride” OR “Lead(2+) nitrate” OR “Lead(2+) oxide” OR “Lead(2+) phosphate” OR “Lead(2+) phosphate (Pb3(PO4)2)” OR “Lead(2+) salt carbamic acid (1:1) ” OR “Lead(2+) sulfate”) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ); (“Lead(2+) sulfide” OR “Lead(II) acetate” OR “Lead(II) azide” OR “Lead(II) bromide” OR “Lead(II) carbonate” OR “Lead(II) chloride” OR “Lead(II) chromate” OR “Lead(II) dinitrate” OR “Lead(II) iodide” OR “Lead(II) nitrate” OR “Lead(II) oxide” OR “Lead(II) phosphate” OR “Lead(II) phosphate (3:2)” OR “Lead(II) styphnate” OR “Lead(II) sulfate” OR “Lead(II) sulfide” OR “Lead(II) tetrafluoroborate” OR “Lead(IV) oxide”) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ); (“Lead, elemental” OR “Lead, inorganic” OR “Lead, tetraethyl” OR “Lead, tetraethyl-” OR “Lead-molybdenum chromate” OR “Litharge” OR “Massicot” OR “Massicotite” OR “Mennige” OR “Milk White” OR “mine orange” OR “Mineral Orange” OR “Mineral red” OR “minio anaranjado” OR “Minium” OR “Molybdenum-lead chromate” OR “Mulhouse White” OR “Nitric acid lead(2+) salt” OR “Nitric acid, lead(2+) salt”) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ); (“Orange lead” OR “Orangemennige” OR “Paris Red” OR “PbSO4” OR “Perlex paste 500” OR “Perlex paste 600A” OR “Phoenicochroite” OR “Phosphoric acid, lead salt” OR “Phosphoric acid, lead(2+) salt (2:3)” OR “Pigment Red 105” OR “Pigment White 3” OR “Pigment Yellow 34” OR “Pigment Yellow 46” OR “Plumbane” OR “Plumbi” OR “Plumbic oxide” OR “Plumboplumbic oxide” OR “Plumbous” OR “Plumbum”) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ); (“Red lead” OR “Resorcinol, 2,4,6-trinitro-, lead(2+) salt (1:1)” OR “Rough lead bullion” OR “Royal Yellow 6000” OR “Salt of saturn” OR “Sandix” OR “Saturn red” OR “Sugar of lead” OR “Sulfuric acid, lead(2+) salt” OR “Tetra Ethylene Lead” OR “Tetra(methylethyl)lead” OR “Tetraethyl lead” OR “Tetraethyl plumbane” OR “Tetraethyllead” OR “Tetraethyllead, liquid” OR “tetraethylplomb”) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ); (“Tetraethylplombane” OR “Tetraethylplumbane” OR “tetraetilplomo” OR “Thiolead A” OR “Tricinat” OR “Trilead bis(orthophosphate)” OR “Trilead phosphate” OR “Trilead tetraoxide” OR “Trilead tetroxide” OR “Unichem PBA” OR “Yellow lead ocher”) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ); Term searched as exact words:; “lead” AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ); Date limit: 2013 to present:; “Plumbism” OR “saturnism” OR “colica pictorum” OR “Devon colic” OR “painter’s colic”
Toxcenter
09/2019 | L1 8918 SEA 10031-22-8 OR 10099-74-8 OR 10101-63-0 OR 11119-70-3 OR 12709-98-7 OR 1309-60-0 OR 1314-41-6 OR 1314-87-0 OR 1317-36-8 OR 13424-46-9; L2 239150 SEA 13814-96-5 OR 15245-44-0 OR 16040-38-3 OR 301-04-2 OR 39377-56-5 OR 598-63-0 OR 7439-92-1 OR 7446-14-2 OR 7446-27-7 OR 7758-95-4 OR 7758-97-6 OR 78-00-2; L3 244612 SEA L1 OR L2; L4 244408 SEA L3 NOT TSCATS/FS; L5 225905 SEA L4 NOT PATENT/DT; L6 26519 SEA L5 AND ED>=20160201; ACT TOXQUERY/Q; -------; L7 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L8 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L9 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L10 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L11 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L12 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L13 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L14 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L15 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L16 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L17 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L18 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L19 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L20 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L21 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L22 QUE (ENDOCRIN? AND DISRUPT?); L23 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L24 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L25 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L26 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L27 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L28 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L29 QUE (NEPHROTOX? OR HEPATOTOX?); L30 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L31 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L32 QUE L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31; L33 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L34 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L35 QUE L32 OR L33 OR L34; L36 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L37 QUE L35 OR L36; -------; L38 14067 SEA L6 AND L37; L39 2663 SEA L38 AND MEDLINE/FS; L40 4980 SEA L38 AND BIOSIS/FS; L41 6411 SEA L38 AND CAPLUS/FS; L42 13 SEA L38 NOT (L39 OR L40 OR L41); L43 11438 DUP REM L39 L40 L42 L41 (2629 DUPLICATES REMOVED) ANSWERS ‘1-11438’ FROM FILE TOXCENTER; L*** DEL 2663 S L38 AND MEDLINE/FS; L*** DEL 2663 S L38 AND MEDLINE/FS; L44 2663 SEA L43; L*** DEL 4980 S L38 AND BIOSIS/FS; L*** DEL 4980 S L38 AND BIOSIS/FS; L45 3952 SEA L43; L*** DEL 6411 S L38 AND CAPLUS/FS; L*** DEL 6411 S L38 AND CAPLUS/FS; L46 4810 SEA L43; L*** DEL 13 S L38 NOT (L39 OR L40 OR L41); L*** DEL 13 S L38 NOT (L39 OR L40 OR L41); L47 13 SEA L43; L48 8775 SEA (L44 OR L45 OR L46 OR L47) NOT MEDLINE/FS SAVE TEMP L48 LEAD/A

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
09/2019 | Compounds searched: 10031-22-8; 10099-74-8; 10101-63-0; 11119-70-3; 12709-98-7; 1309-60-0; 1314-41-6; 1314-87-0; 1317-36-8; 13424-46-9; 13814-96-5; 15245-44-0; 16040-38-3; 301-04-2; 39377-56-5; 598-63-0; 7439-92-1; 7446-14-2; 7446-27-7; 7758-95-4; 7758-97-6; 78-00-2
NTP
09/2019 | NTP Site Search (http://ntpsearch.niehs.nih.gov/home), date limit 2015 to present:; “10031-22-8” “10099-74-8” “10101-63-0” “11119-70-3” “12709-98-7” “1309-60-0” “1314-41-6” “1314-87-0” “1317-36-8” “13424-46-9” “13814-96-5” “15245-44-0” “16040-38-3” “301-04-2” “39377-56-5” “598-63-0” “7439-92-1” “7446-14-2” “7446-27-7” “7758-95-4” “7758-97-6” “78-00-2”; Limited to content types reports & publications; systematic reviews; ROC profiles, reviews, or candidates; or testing status, date limit 2015 to present: “lead”
Regulations.gov
10/2019 | Compounds searched: 10031-22-8; 10099-74-8; 10101-63-0; 11119-70-3; 12709-98-7; 1309-60-0; 1314-41-6; 1314-87-0; 1317-36-8; 13424-46-9; 13814-96-5; 15245-44-0; 16040-38-3; 301-04-2; 39377-56-5; 598-63-0; 7439-92-1; 7446-14-2; 7446-27-7; 7758-95-4; 7758-97-6; 78-00-2
NIH RePORTER
01/2020 | Search in: Projects AdminIC: All, Fiscal Year: Active Projects Text Search (Advanced):; “1,3-Benzenediol, 2,4,6-trinitro-, lead” OR “Acetic acid lead ” OR “Acetic acid, lead salt” OR “Acetic acid, lead ” OR “Acetic acid, lead ” OR “Anglislite” OR “Azarcon” OR “Borate(1-), tetrafluoro-, lead” OR “Borate(1-), tetrafluoro-, lead” OR “C.I. Pigment Metal 4” OR “C.I. Pigment Yellow 46” OR “CARBONIC ACID, LEAD SALT” OR “Carbonic acid, lead salt” OR “Carbonic acid, lead” OR “Cerussete” OR “Cerussite” OR “Chrome Orange” OR “Chrome Yellow” OR “Chromic acid (H2CrO4), lead” OR “Chromic acid lead salt ” OR “CHROMIC ACID, LEAD” OR “Chromic Acid, Lead (II) Salt” OR “Chromic acid, lead and molybdenum salt” OR “Chromic acid, lead salt” OR “Chromic acid, lead” OR “Chromium lead molybdenum oxide” OR “Chromium lead oxide” OR “CI pigment metal 4” OR “CI Pigment Yellow 46” OR “Collodial lead phosphate” OR “Dibasic lead acetate” OR “Dibasic lead carbonate” OR “Dibasic lead sulfate” OR “Entan” OR “Fast White” OR “Flowsperse R 12” OR “Freemans White Lead” OR “Galena” OR “Glover” OR “Gold Satinobre” OR “Heuconin 5” OR “Lead (II) carbonate” OR “Lead (II) chloride” OR “Lead (II) chromate” OR “Lead (II) iodide” OR “Lead (II) nitrate” OR “Lead (II) oxide” OR “Lead (II) sulfate” OR “Lead (II) sulfide” OR “Lead (II, IV) oxide” OR “Lead (IV) oxide ” OR “Lead 2,4,6-trinitro-m-phenylene dioxide” OR “Lead acetate” OR “Lead azide” OR “Lead bis(tetrafluoroborate)” OR “Lead borofluoride” OR “Lead boron fluoride” OR “Lead Bottoms” OR “Lead bromide” OR “Lead brown” OR “Lead carbonate” OR “Lead chloride” OR “Lead chromate” OR “Lead chromate(VI)” OR “Lead chromium oxide (PbCrO4)” OR “Lead di(acetate)” OR “Lead diacetate” OR “Lead diazide” OR “Lead dibasic acetate” OR “Lead dibromide” OR “Lead dichloride” OR “Lead diiodide” OR “Lead dinitrate” OR “Lead dioxide” OR “Lead element” OR “Lead flake” OR “Lead fluoborate” OR “Lead fluoroborate” OR “Lead iodide” OR “Lead metal” OR “Lead molybdate chromate” OR “Lead molybdenum chromate” OR “Lead monooxide” OR “Lead monosulfate” OR “Lead monosulfide” OR “Lead monoxide” OR “Lead nitrate” OR “Lead orthophosphate” OR “Lead orthoplumbate” OR “Lead oxide” OR “Lead peroxide” OR “Lead phosphate” OR “Lead protoxide” OR “Lead S 2” OR “Lead S2” OR “Lead styphnate” OR “Lead sulfate” OR “Lead sulfide” OR “Lead sulphate” OR “Lead sulphide” OR “Lead superoxide” OR “Lead tetraethide” OR “Lead tetraethyl”; “Lead tetrafluoroborate” OR “Lead tetraoxide” OR “Lead tetroxide” OR “Lead tricinate” OR “Lead trinitroresorcinate” OR “Lead(II) acetate” OR “Lead(II) azide” OR “Lead(II) bromide” OR “Lead(II) carbonate” OR “Lead(II) chloride” OR “Lead(II) chromate” OR “Lead(II) dinitrate” OR “Lead(II) iodide” OR “Lead(II) nitrate” OR “Lead(II) oxide” OR “Lead(II) phosphate” OR “Lead(II) phosphate” OR “Lead(II) styphnate” OR “Lead(II) sulfate” OR “Lead(II) sulfide” OR “Lead(II) tetrafluoroborate” OR “Lead(IV) oxide” OR “Lead, elemental” OR “Lead, inorganic” OR “Lead, tetraethyl” OR “Lead, tetraethyl-” OR “Lead-molybdenum chromate” OR “Litharge” OR “Massicot” OR “Massicotite” OR “Mennige” OR “Milk White” OR “mine orange” OR “Mineral Orange” OR “Mineral red” OR “minio anaranjado” OR “Minium” OR “Molybdenum-lead chromate” OR “Mulhouse White” OR “Nitric acid lead” OR “Nitric acid, lead” OR “Orange lead” OR “Orangemennige” OR “Paris Red” OR “PbSO4” OR “Perlex paste 500” OR “Perlex paste 600A” OR “Phoenicochroite” OR “Phosphoric acid, lead salt” OR “Phosphoric acid, lead” OR “Pigment Red 105” OR “Pigment White 3” OR “Pigment Yellow 34” OR “Pigment Yellow 46” OR “Plumbane” OR “Plumbi” OR “Plumbic oxide” OR “Plumboplumbic oxide” OR “Plumbous” OR “Plumbum” OR “Red lead” OR “Resorcinol, 2,4,6-trinitro-, lead” OR “Rough lead bullion” OR “Royal Yellow 6000” OR “Salt of saturn” OR “Sandix” OR “Saturn red” OR “Sugar of lead” OR “Sulfuric acid, lead” OR “Tetra Ethylene Lead” OR “Tetra(methylethyl)lead” OR “Tetraethyl lead” OR “Tetraethyl plumbane” OR “Tetraethyllead” OR “Tetraethyllead, liquid” OR “tetraethylplomb” OR “Tetraethylplombane” OR “Tetraethylplumbane” OR “tetraetilplomo” OR “Thiolead A” OR “Tricinat” OR “Trilead bis(orthophosphate)” OR “Trilead phosphate” OR “Trilead tetraoxide” OR “Trilead tetroxide” OR “Unichem PBA” OR “Yellow lead ocher” OR “Lead(2) sulfate” OR “Lead(2) acetate” OR “Lead(2) azide” OR “Lead(2) bis(nitrate)” OR “Lead(2) bromide” OR “Lead(2) carbonate” OR “Lead(2) chloride” OR “Lead(2) nitrate” OR “Lead(2) oxide” OR “Lead(2) phosphate” OR “Lead(2) phosphate (Pb3(PO4)2)” OR “Lead(2) salt carbamic acid” OR “Lead(2) sulfate” OR “Lead(2) sulfide”; “lead poisoning” OR “Plumbism” OR “saturnism” OR “colica pictorum” OR “Devon colic” OR “painter’s colic”; “blood lead”; Search in: Projects Limit to: Project Title, AdminIC: All, Fiscal Year: Active Projects Text Search (Advanced):; “lead” not (“lead academic” or “lead optimization”)
Other | Identified throughout the assessment process

The 2019 results were:

- Number of records identified from PubMed, TOXLINE, and TOXCENTER (after duplicate removal): 15,240
- Number of records identified from other strategies: 107
- Total number of records to undergo literature screening: 15,347

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on Pb:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 388
- Number of studies considered relevant and moved to the next step: 388

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 388
- Number of studies cited in the pre-public draft of the toxicological profile: 1,589
- Total number of studies cited in the profile: 1,803

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 September 2019 Literature Search Results and Screen for Lead (Pb)

Figure B-1 description