# SUPPORTING DOCUMENT FOR EPIDEMIOLOGICAL STUDIES FOR LEAD

Table 1 Epidemiology Studies Evaluating Effects on Body Weight at Mean Blood Lead Concentrations (PbB) ≤10 µg/dL

Reference and study population | PbB (µg/dL) and analysis | Outcomes
Burns et al. 2017; Prospective cohort of 481 Russian boys enrolled at age 8–9 years (2003–2005) and followed until age 18 years (2012–2015) | PbB:; Median (range):; - All: 3.0 (0.5–31.0); - Low (<5 μg/dL) (n=347): 3.0 (0.5–4.0); - High (≥5 μg/dL) (n=134): 6.0 (5.0–31.0); Analysis: Height was analyzed using linear regression and adjusted for birth weight, preterm birth, percent calories from protein at baseline, and age (years). BMI was adjusted using linear regression for birth weight, no biological father in home, percent calories from fat at baseline, and age (years). | Adjusted mean difference (95% CI) for HT-Z score and BMI-Z score for higher versus lower PbB (≥5 versus <5 µg/dL) in boys followed for up to 10 years:; - HT-Z: −0.43 (−0.60, −0.25); p<0.001; - BMI-Z: −0.22 (−1.45, 0.006); p=0.06; Adjusted β (95% CI) for HT-Z and BMI-Z (z-score per unit lnPbB):; - HT-Z: −0.26 (−0.40, −0.13); p<0.001; - BMI-Z: −0.14 (−0.31, 0.04); p=0.12
Cassidy-Bushrow et al. 2016; Birth cohort of 299 children (aged 2–3 years) from mothers who participated in a WHEALS study (2003–2007), Western Wayne Country, Michigan; 131 children had detectable PbB (≥1.0 µg/dL) | PbB:; Mean (SD), n=131: 2.45 (2.53); Analysis: Obesity at age 2 years was defined as BMI ≥85^th^ percentile. BMI was analyzed using linear regression and adjusted for race, sex, and birth weight Z-score. | PbB was negatively associated with body size.; - Adjusted RR (95% CI) for BMI ≥85^th^ percentile 0.57 (0.33, 0.98); p=0.041; - Adjusted β (95% CI) for BMI Z-score: −0.35 (−0.60, −0.10); p=0.012
Hauser et al. 2008; Cross-sectional study of 489 boys (aged 8–9 years); Chapaevsk, Russia (2003–2005) | PbB:; - Mean: 3; - Range: 2–5; - PbB >10: 3%; Analysis: PbB were log-transformed. Height, weight, and BMI were analyzed using multivariate logistic regression, adjusted for birth weight, gestational age, and age at exam. Birth weight was adjusted for height, BMI, penile length, and gestational age. | A negative association was observed between PbB and height and birth weight, but not BMI. Adjusted β (95% CI), per unit log-PbB:; - Height: −1.439 (−2.25, −0.63); p<0.001; - Weight: −0.761 (−1.54, 0.02); p=0.067; - BMI: −0.107 (−0.44, 0.23); p=0.53
Ronco et al. 2010; Cross-sectional study of 107 women of childbearing age (median age: 27 years) from Chile; data collection period not reported | PbB:; Median (interquartile range); - All: 1.0 (1.0–4.8); - Low weight: 1.7 (1.0–3.8); - Normal weight: 2.3 (1.0–6.5); - Overweight: 1.0 (1.0–3.8); Analysis: Women were classified into three groups based on BMI: low weight (BMI <18.5 kg/m^2^), normal weight (BMI >19–<24.9 kg/m^2^), and overweight (BMI >25 kg/m^2^). Data were analyzed using the nonparametric Kruskal-Wallis test. | No differences in PbB were observed between BMI categories.
Scinicariello et al. 2013; Cross sectional study of children and adolescents (n=10,693; age 3–19 years) adults (n=15,899, age ≥20) using NHANES data (1999–2006) | PbB:; Gmean (SE); - Children/adolescents: 1.12 (0.02); - Adults: 1.59 (0.02); - Quartiles (all):; ○ Q1: ≤0.70; ○ Q2: 0.71–1.09; ○ Q3: 1.10–1.60; ○ Q4: ≥1.61; Analysis: Linear regression of BMI Z-scores and PbB quartile. Multiple logit regression of overweight (BMI 25–29.9 kg/m^2^, ≥85^th^–95^th^ percentile) or obese (BMI ≥30 kg/m^2^, ≥95^th^ percentile) and PbB quartile; adjusted for age, sex, race/ethnicity, hematocrit, calorie intake, television and video game use, serum cotinine, and poverty income ratio. BMI data in adults were analyzed using multiple linear and logit regression, adjusted for race/ethnicity, sex, age, hematocrit, smoking status, serum cotinine, alcohol consumption, education, calorie intake, and moderate and vigorous activity. | A negative association was observed between PbB and BMI-z score in children and adolescents. Adjusted β (SE) (BMI-Z per quartile):; - Q1: reference; - Q2: −0.06 (0.04); p=0.20; - Q3: −0.15 (0.06); p=0.01; - Q4: −0.33 (0.07); p ≤ 0.01; - p-trend: ≤0.01; A negative association was observed between PbB and overweight and obesity in children and adolescents. Adjusted OR (95% CI) for:; Overweight; - Q1: reference; - Q2: 0.93 (0.77, 1.13); - Q3: 0.87 (0.67, 1.11); - Q4: 0.67 (0.52, 0.88); Obese; - Q1: reference; - Q2: 0.82 (0.67, 1.00); - Q3: 0.70 (0.54, 0.90); - Q4: 0.42 (0.30, 0.59); A negative association was observed between PbB and BMI in adults. Adjusted β (SE) (BMI per quartile):; - Q1: reference; - Q2: −0.90 (0.20); p ≤ 0.01; - Q3: −1.41 (0.22); p ≤0.01; - Q4: −2.58 (0.25); p ≤0.01; - p-trend: ≤0.01; PbB was negatively associated with overweight and obesity. Adjusted OR (95% CI):; Overweight; - Q1: reference; - Q2: 1.04 (0.87, 1.25); - Q3: 1.02 (0.87, 1.19); - Q4: 0.79 (0.65, 0.95); Obese; - Q1: reference; - Q2: 0.76 (0.66, 0.87); - Q3: 0.66 (0.56, 0.77); - Q4: 0.42 (0.35, 0.40)
Wang et al. 2015; Cross-sectional study of 5,558 adults (men: 2,235, ages 39–65 years; women: 3,323, ages 40–65 years) from 16 locations in China | PbB:; Men; - Median (interquartile range): 4.400 (2.900–6.216); - Quartiles:; ○ Q1: ≤2.900; ○ Q2: 2.901–4.400; ○ Q3: 4.401–6.216; ○ Q4: ≥6.216; Women:; - Median (interquartile range): 3.779 (2.513–5.435); - Quartiles:; ○ Q1: ≤2.513; ○ Q2: 2.514–3.779; ○ Q3: 3.780–5.435; ○ Q4: ≥5.435; Analysis: Overweight adults were defined as a BMI of 25–29.9 kg/m^2^; obesity was defined as BMI ≥30 kg/m^2^. Data were analyzed by multiple linear regression and logistic regression adjusted for age, rural/urban residence, economic status, current smoking, diabetes, dyslipidemia, and hypertension. | BMI was positively associated with BMI in women (trend and Q4), but not men. β (SE) per PbB quartile:; - Men; ○ Q1: reference; ○ Q2: −0.06 (0.19); ○ Q3: 0.05 (0.19); ○ Q4: 0.01 (0.20); ○ p-trend: 0.82; - Women; ○ Q1: reference; ○ Q2: −0.12 (0.17); ○ Q3: 0.27 (0.17); ○ Q4: 0.59 (0.17); p<0.05; ○ p-trend: <0.001; Adjusted ORs (95% CI) for obesity for women, but not men, were increased in Q4 compared to Q1.; Men:; - Overweight; ○ Q1: reference; ○ Q2: 1.02 (0.79,1.33); ○ Q3: 1.01 (0.77, 1.32); ○ Q4: 0.95 (0.72,1.26); ○ p-trend: 0.74; - Obesity; ○ Q1: reference; ○ Q2: 0.73 (0.40, 1.33); ○ Q3: 1.13 (0.64, 1.97); ○ Q4: 0.88 (0.48, 1.61); ○ p-trend: 0.99; Women:; - Overweight; ○ Q1: reference; ○ Q2: 0.82 (0.65, 1.04); ○ Q3: 1.07 (0.85, 1.35); ○ Q4: 1.16 (0.92, 1.46); ○ p-trend: 0.07; - Obesity; ○ Q1: reference; ○ Q2: 1.16 (0.70, 1.90); ○ Q3: 1.31 (0.80, 2.14); ○ Q4: 1.86 (1.16, 2.98); ○ p-trend: <0.01

BMI = body mass index; BMI-Z = BMI z-scores; CI = confidence interval; Gmean = geometric mean; HT-Z = height z-scores; NHANES = National Health and Nutrition Examination Survey; OR = odds ratio; RR = relative risk; SD = standard deviation; SE = standard error; WHEALS = Wayne County Health, Environment, Allergy and Asthma Longitudinal Study

Table 2 Epidemiology Studies Evaluating Effects on the Respiratory System at Mean Blood Lead Concentrations (PbB) ≤10 µg/dL

Reference and study population | PbB (µg/dL) and analysis | Outcomes
Changes in lung function
Chung et al. 2015; Cross-sectional study of 870 adults (mean at 54.0 years) from the 5^th^ Korea National Health and Nutrition Examination Survey, 2011 | PbB:; - Mean (SD): 2.50 (0.87); - Range: 0.66–5.14; - Tertiles:; ○ T1: <2.03; ○ T2: 2.03–2.81; ○ T3: >2.81; Analysis: Pulmonary function tests (FVC, FVC%, FEV_1_, FEV_1_%, FEV_1_/FVC ratio) were administered by spirometry. Data were analyzed by logistic multiple regression and adjusted for age, gender, BMI, smoking status, physical activity, types of residential area, types of occupation, education status, and SES. | A negative correlation was observed between PbB and FEV_1_/FVC ratio, but not FVC% or FEV_1_%. Results are indicative of pulmonary obstructive disease. Correlation coefficient:; - FVC%: 0.070; - FEV_1_%: 0.00; - FEV_1_/FVC: −0.115; p<0.01; Adjusted OR for T3 was decreased compared to T1, with a significant trend over tertiles. Adjusted ORs (95% CI) for FEV_1_/FVC ratio:; - T1: 1 (reference); - T2: 0.409 (0.003, 4.454); - T3: 0.006 (0, 0.286); - p-trend=0.03
Leem et al. 2015; Pooled cross-sectional study of 5,972 adults (≥20 years of age) from the 4^th^ and 5^th^ Korea National Health and Nutrition Examination Surveys, 2007–2009 and 2010–2012 | PbB:; Mean:; - Men: 2.92; - Women: 2.33; Quartiles (men and women); - Q1: ≤1.85; - Q2: 1.86–2.43; - Q3: 2.44–3.16; - Q4: ≥3.17; Analysis: Data were log-transformed and analyzed by analysis of co-variance or multivariate linear regression, adjusted for age, sex, BMI, and smoking status. | FEV_1_/FVC (%) was decreased in Q4 relative to Q1. Mean (SE):; - Q1 (reference): 79.0 (0.2); - Q2: 78.9 (0.2); p=0.753; - Q3: 79.1 (0.2); p=0.771; - Q4: 78.4 (0.2); mean difference (SE): −0.6 (0.3); p=0.025
Little et al. 2017; Cross-sectional study of 184 boys and 189 girls, 10–15 years of age, in Poland; data collection period not specified | Mean (SE):; - Boys: 5.27 (0.19); - Girls: 3.82 (0.10); Analysis: FVC was measured after physical activity (running and agility). Data were log-transformed and analyzed by linear regression, adjusted for height, weight, and run time. | FVC was decreased in girls, but not in boys, following physical exertion; β (SE), per log10 increase in PbB:; - Boys: −5.11 (4.47); p=0.25; - Girls: −12.90 (5.25); p=0.02
Zeng et al. 2017; Cross-sectional study of 200 children (mean age: 5.53 years; age range; 5–7 years; 52% boys) living near an area of electronic waste and 100 controls (mean age: 5.54 years; 63% boys) in China; data collection period: November 2013–December 2013 | PbB:; Median (IQR); - Control: 3.57 (2.68–4.86); - Exposed: 5.53 (3.92–7.04); p<0.001; Analysis: Pulmonary function data were log-transformed and analyzed by linear regression models, adjusted for age, gender, height, RDW, family member daily smoking, family income level, parental education level, daily outdoor play time, and living area. | PbB was negatively associated with FEV_1_: and FVC in children living near the exposed area. Regression coefficient β (95% CI):; - FEV_1_: −0.02 (−0.100, 0.043); - FVC: −0.015 (−0.093, 0.063)
Increased bronchial responsiveness
Min et al. 2008a; Cross-sectional study of 523 adults (mean age 39.8 years) in Seoul, South Korea; data collection period was not reported | PbB:; Mean (SD): 2.96 (1.59); Analysis: Bronchial reactivity was assessed by methacholine provocation test. The bronchial reactivity index was calculated as: log [(% decline in FEV_1_/log of final methacholine concentration) +10]. Multiple regression analysis was performed, with adjustments for age, sex, height, smoking status, baseline FEV_1_, and presence of asthma. | A 1 μg/dL increase in PbB was associated with increased bronchial responsiveness. β (SE): 0.018 (0.007)
Lung disease
Joseph et al. 2005; Prospective study of 4,634 children (ages 3 months to 3 years) in southern Michigan; data collection period: 1995–1998 | PbB:; Mean (SD); - White: 3.2 (2.5); - Black: 5.5 (4.3); Analysis: Following PbB measurement, participants were evaluated for asthma and were followed for up to 12 months for a diagnosis of asthma. The association of PbB to incident asthma by race was evaluated by Cox proportional hazards multivariable analysis. Adjusted for annual income per person, birth weight, and sex. | Adjusted HRs (95% CI) for asthma diagnosis (based on a child having four or more asthma-medication-dispensing events in 12 months, and one or more emergency department visits for asthma, one or more hospitalizations for asthma, or four or more outpatient visits for asthma with at least two asthma-medication-dispensing events):; Incident asthma by race; - White (PbB <5): 1 (reference); - White (PbB ≥5): 2.7 (0.9, 8.1); 0.09; - White (PbB ≥10): 0 incidence (HR not reported); - Black (PbB <5): 1 (reference); - Black (PbB ≥5) 1.1 (0.8, 1.7), p=0.53; - Black (PbB≥10): 1.3 (0.6, 2.6), p=0.54; Incident asthma using one race-exposure reference group; - White (PbB <5): 1 (reference); - White (PbB ≥5): 2.3 (0.8, 6.7); p=0.12; - White (PbB ≥10): not calculated; - Black (PbB <5): 1.8 (1.3, 2.4); p<0.01; - Black (PbB ≥5): 1.5 (1.2, 1.8); p<0.01; - Black (PbB ≥10): 3.0 (1.2, 7.1); p-0.01
Rokadia and Agarwal 2013; Cross-sectional study of pooled data from 9,575 participants from NHANES 2007–2010, including 8,411 participants without obstructive lung disease (OLD) (mean age: 42.3 years) and 1,164 participants with OLD (mean age: 4.4 years); prevalence of OLD was 12.4% | PbB:; Geometric mean (SD); - Non-OLD: 1.18 (1.0; - OLD: 1.73 (1.02); p<0.001 compared to non-OLD; Analysis: Mild OLD defined as FEV_1_ ≥80% predicted; moderate-severe OLD defined as FEV_1_ <80% predicted. Multivariate linear regression analysis was performed, with adjustments for age, sex, race, BMI, chronic kidney disease, diabetes, hyperlipidemia, hypertension, stroke, coronary artery disease, smoking, serum, C-reactive protein concentration, and serum cotinine concentration. Mild OLD defined as FEV_1_ ≥80% predicted; moderate-severe OLD defined as FEV_1_ <80% predicted. | The risk of all OLD and moderate-severe OLD was elevated with increasing concentration of PbB. OR (95% CI); - All OLD: 1.94 (1.10, 3.42); - Mild OLD: 1.21 (0.55, 2.65); - Moderate-severe OLD: 3.49 (1.70, 7.15)
Wang et al. 2017a; Cross-sectional study of 930 children with a mean age of 5.74 years (boys: 469; girls: 461) in Taiwan; data collection period: 2011 | PbB:; Geometric mean (GSD); - All: 1.86 (1.21); - Boys: 1.89 (1.22); - Girls: 1.83 (1.20); Analysis: Data for asthma were dichotomized as <5 and ≥5 µg/dL and analyzed by univariate and multivariate logistic regression with adjustments for age, maternal age, maternal history of atopy, maternal nationality, parental education and occupation, family income, number of siblings, breast feeding, environmental tobacco smoke, incensing at home, dehumidifier at home, new paintings of houses, and residence using groundwater. | The risk of asthma was increased in the total population and in boys, but not in girls. ORs (95% CI), <5 versus ≥5 μg/dL:; - All: 5.50 (1.69, 17.94); p=0.005; - Boys: 6.40 (1.49, 27.42);p=0.012; - Girls: 4.73 (0.44, 50.60); p=0.199
Wells et al. 2014; Cross-sectional study of 1,788 children (ages 2–12 years) from NHANES 2005–2006; asthma analysis was limited to the subset of children aged 4–12 years (n=1,430) | PbB:; Geometric mean (95% CI): 1.07 (0.99–1.17); Analysis: Data were analyzed by logistic regression and adjusted for 6-month season, age, sex, race/ethnicity, parental educational status, prenatal smoke exposure, BMI, presence of cockroaches in the home, and avoidance/removal of pets. | No association was observed between PbB and asthma. Adjusted ORs (95% CI), based on a 1 µg/dL increase of PbB:; - Asthma with atopy: 0.97 (0.61, 1.55); - Asthma with no atopy: 1.07 (0.86, 1.33)
Zeng et al. 2016; Cross-sectional study of 470 children living near an electronic recycling area; Haojiang area (n=170: mean age 4.34 years; age range: 3–8 years; 57% boys, 43% girls; Guiyu area (n=300): mean age 4.66 years, 50% boys, 50% girls; data collection period: December 2012–January 2013 | PbB:; Median (IQR); - Haojiang area: 4.75 (3.98–5.76); - Guiyu area: 6.24 (4.55, 8.00); - p=0.000; Analysis: Comparison of PbB between groups was assessed by t-test on Ln-transformed data. Asthma data were analyzed by logistic regression analysis for PbB stratified by <5 or ≥5 µg/dL, adjusted for age, gender, passive smoking, living in Guiyu, whether use home as workshop, whether home close to e-waste recycling site, and whether child contact with electronic waste. | When stratified by PbB, PbB ≥5 µg/dL was associated with increased risk of asthma, compared to <5 µg/dL. OR (95% CI): 9.50 (1.16, 77.49); p<0.01

BMI = body mass index; CI = confidence interval; FEV_1_: forced expiratory volume in 1 second (L/second); FEV_1_% = percent of predicted FEV_1_; FVC = forced vital capacity (L); FVC% = percent of predicted FVC; Gmean = geometric mean; GSD = geometric standard deviation; HR = hazard ratio; IQR = interquartile ratio; NHANES = National Health and Nutrition Examination Survey; OLD = obstructive lung disease; OR = odds ratio; RDW = red blood cell distribution width; SD = standard deviation; SE = standard error; SES = socio-economic status

Table 3 Selected Epidemiology Studies Evaluating Cardiovascular Effects at Mean Blood Lead Concentrations (PbB) ≤10 µg/dL

Reference and study population | PbB (µg/dL) and analysis | Outcomes
Mortality due to cardiovascular disease
Aoki et al. 2016; Prospective study of 18,602 participants (≥40 years of age at baseline) from NHANES (1999–2001) with mortality follow-up through 2011 | PbB:; Mean (SE): 1.73 (0.02); Analysis: Participants were followed for mortality from baseline to 2011. PbB data were log_10_-transformed. Data were analyzed by Cox proportional hazard regression, adjusted for race/Hispanic origin, sex, and blood cadmium, serum iron, serum CRP, serum calcium, smoking, education, and alcohol intake. | A positive association was observed between PbB and RR of mortality due to cardiovascular disease. RR (95% CI), per 10-fold increase in hematocrit-corrected PbB: 1.44 (1.05, 1.98)
Khalil et al. 2009; Prospective cohort study of 533 women (age range: 65–87) years in Baltimore, Maryland and Monongahela Valley, Pennsylvania | PbB:; Mean (SD): 5.3 (2.3); Range: 1–21; Analysis: Participants were followed for 12 years following baseline. Data were analyzed by Cox proportional hazards regression, adjusted for smoking, alcohol intake, estrogen use, hypertension, total hip bone mineral density, walking for exercise, and diabetes. | Mortality due to coronary heart disease was increased in women with PbB ≥8.0 µg/dL compared to women with PbB <8.0 µg/dL. HR (95% CI): 3.08 (1.23, 7.70); p=0.016.
Lanphear et al. 2018; Longitudinal study of 14,289 adults (age ≥20 years at baseline) from NHANES III (1988–1994), studied through 2011; follow-up to Menke et al. 2006 | PbB:; Geometric mean: 2.71; Analysis: Participants were followed for mortality a median period of 19.3 years. Data were analyzed by Cox proportional hazard regression analysis adjusted for age, race/ethnicity, sex, cigarette smoking, alcohol consumption, physical activity, household income, BMI, total cholesterol, diabetes mellitus, and hypertension. | An increase in PbB from 1.0 to 6.7 µg/dL was associated with increased mortality due to:; - Cardiovascular disease (HR 1.70; 95% CI 1.30, 2.22; - Ischemic heart disease (HR 2.08; 95% CI 1.52, 2.85)
Menke et al. 2006; Longitudinal study of 13,946 adults (age ≥17 years) from NHANES III (1988–1994), studied through 2000 | PbB:; Baseline mean: 2.58; Tertiles:; - T1: <1.94; - T2: 1.94–3.62; - T3: ≥3.63; Analysis: Participants were followed for mortality for 12 years after baseline PbB was obtained. Data were analyzed by Cox proportional hazard regression analysis adjusted for age, race/ethnicity, sex, urban residence, cigarette smoking, alcohol consumption, education, physical activity, household income, menopausal status, BMI, CRP, total cholesterol, diabetes mellitus, hypertension, and GFR. | PbB T3 was associated with increased risk of death due to cardiovascular disease, myocardial infarction, and stroke, with positive trends across tertiles. Adjusted HRs (95% CI):; - Cardiovascular disease mortality; p-trend=0.003; ○ T1: 1 (reference); ○ T2: 1.03 (0.69, 1.55); ○ T3: 1.55 (1.08, 2.24); - Myocardial infarction mortality; p-trend=0.007; ○ T1: 1 (reference); ○ T2: 1.02 (0.55, 1.89); ○ T3: 1.89 (1.04, 3.43); - Stroke mortality; p-trend=0.017; ○ T1: 1 (reference); ○ T2: 2.19 (0.87, 5.53); ○ T3: 2.51 (1.20, 5.26)
Schober et al. 2006; Longitudinal study of 9,686 adults (age ≥40 years) from NHANES III (1988–1994), studied through 2000 | PbB:; Tertiles:; - T1 (n=6,608): <5; - T2 (n=2,532): 5–9; - T3 (n=617): ≥10; Analysis: The median follow-up period following PbB measurement to death was 8.55 years. Data were analyzed by Cox proportional hazard regression analysis adjusted for sex, race/ethnicity, education, and smoking status. | Increased risk of death due to cardiovascular disease was observed in participants with PbB ≥10 µg/dL, compared to participants with PbB <5. µg/dL. No association was observed for participants with PbB 5–9 µg/dL. Adjusted RR (95% CI):; - T1: 1 (reference); - T2: 1.20 (0.93, 1.55); - T3: 1.55 (1.16, 2.07); - p-trend: <0.01
Weisskopf et al. 2009; Longitudinal study of 868 men (age >55 years) enrolled in the Normative Aging Study in Boston, Massachusetts; baseline PbB measurements obtained 1994 (±3 years) | PbB:; Mean (SD): 5.6 (3.4); - Tertiles; ○ T1: <4; ○ T2: 4–6; ○ T3: >6; Analysis: The median follow-up period following PbB and bone Pb measurement to death was 8.9 years (SD 3.9 years). Data were analyzed by Cox proportional hazard regression analysis adjusted for age, smoking status, and education. | No association was observed between PbB and increased risk of death due to cardiovascular disease. HRs (95% CI):; - PbB (p-trend: 0.72); ○ T1: 1 (reference); ○ T2: 1.09 (0.69, 1.72); ○ T3: 1.10 (0.67, 1.80)
Blood pressure and hypertension in adults
Almeida Lopes et al. 2017; Population-based study of 948 adults (421 men and 527 women), aged ≥40 years from an urban area in southern Brazil; data collection period: 2011 | PbB:; Gmean (range):1.97 (0.46–45.62); Quartiles:; - Q1: ≤1.32; - Q2: 1.32–1.93; - Q3: 1.93–2.76; - Q4: >2.76; Analysis: PbB data were log transformed. Data SBP and DBP were analyzed by multiple linear regression, adjusted for sex, age, race, education, income, antihypertensive medication, total cholesterol, triglycerides, glycemia, smoking status, alcohol intake, and BMI. | PbB was positivity associated with DBP and risk of hypertension.; Change (95% CI) of SBP and DBP by PbB quartile:; - SBP; ○ Q1: 0 (reference); ○ Q2: −0.00 (−0.00, −0.00); ○ Q3: −0.00 (−0.00, −0.00); ○ Q4: −0.00 (−0.00, −0.00); ○ p-trend=0.002; - DBP; ○ Q1: 0 (reference); ○ Q2: 0.03 (0.01, 0.05); ○ Q3: 0.02 (0.00, 0.05); ○ Q4: 0.06 (0.04, 0.09); ○ p-trend<0.001; OR (95% CI) for hypertension by PbB quartile:; ○ Q1: 1 (reference); ○ Q2: 0.11 (0.01, 1.59); ○ Q3: 0.40 (0.02, 6.87); ○ Q4: 2.54 (1.17, 5.53); ○ p-trend=0.003
Al-Saleh et al. 2005; Case-control study of 100 women with hypertension (ages 47–93 years) and 85 control subjects (ages 45–82 years) in Saudi Arabia; data collection: 2001–2002 | PbB:; Mean (SD); range; - With hypertension: 4.75 (3.93); 1.45–28.3; - Controls: 4.56 (2.85); 1.19–17.6; Analysis: Data were analyzed using multiple logistic regression, adjusted for menopausal status, time since menopause, physical activity, history of breast feeding, family income, attended school, work status, family history of hypertension, heart diseases, rheumatologic diseases, other diseases, intake of supplements and minerals, age, and creatinine. | For PbB ≥3.86 µg/dL compared to PbB <3.86 µg/dL, the risk of hypertension was increased. OR (95% CI): 5.27 (0.93, 29.86); p=0.06
An et al. 2017; Cross-sectional study of 310 male smelter workers (ages 21–61 years); data collection period: January–December 2014 | PbB:; Gmean (95% CI): 5.839 (5.421, 6.068); Analysis: PbB data were log_2_ transformed. Data were analyzed by linear regression, adjusted for age, BMI, dyslipidemia, diabetes, alcohol consumption, smoking status, exercise, and family history of hypertension. | No association was observed between PbB and SBP or DBP. β (95% CI) per doubling of PbB:; - SBP: −0.636 (−2.661, 1.389); p=0.537; - DBP: −1.182 (−2.763, 0.399); p=0.142
Barry et al. 2019; Cross-sectional study of 211 male Pb workers (mean age: 61.9 years) residing in New York and New Jersey; data collection period: 2016–2017 | PbB:; Median (range): 2.5 (0–34.0); - Quartiles; ○ Q1: <1.6; ○ Q2: 1.6–2.5; ○ Q3: 2.6–4.2; ○ Q4: ≥4.3; Bone Pb (tibia) median, µg/g (range): 13.8 (0–127.3); - Bone Pb quartiles:; ○ Q1: <9.6; ○ Q2: 9.6–13.7; ○ Q3: 13.8–19.5; ○ Q4: ≥19.6; Analysis: Associations between PbB or bone Pb and SBP were analyzed by multivariable linear regression using both continuous and categorical (quartiles) models, adjusted for age, smoking pack years, and BMI. | A positive linear trend was observed between bone Pb and SBP, although no associations were observed for any bone Pb quartiles or for PbB (continuous or quartiles). SBP regression coefficient (SE):; PbB; - Q1: reference; - Q2: 1.21 (4.35); p=0.78; - Q3: 0.49 (4.84); p=0.92; - Q4: 7.33 (4.40); p=0.10; - Continuous: 0.19 (0.30) 0.52; Bone Pb; - Q1: reference; - Q2: −0.44 (4.51); p=0.92; - Q3: 5.45 (4.69); p=0.25; - Q4: 5.32 (5.26); p=0.31; - Continuous: 0.36 (0.15); p=0.02
Bost et al. 1999; Cross-sectional survey study of 2,563 men (mean age 47.5 years) and 2,763 women (mean age 47.7 years) in Great Britain in 1995 | PbB:; - Mean in men: 3.7; - Mean in women: 2.6; Analysis: Three sitting blood pressure measurements were taken on the day of assessment. Data were analyzed using multivariate linear regression (with log-transformed PbB), adjusted for covariates (age and BMI, alcohol consumption and tobacco smoking, SES, and region of residence; subjects who were on AH agents were excluded). | Increasing DBP was significantly associated with increasing PbB in males, but not in females.; Standardized regression coefficients for males:; - Subjects on AH drugs included: 0.061 (p<0.001); - Subjects on AH drugs excluded: 0.055 (p<0.01); Change in DBP (mmHg) in males per doubling of PbB (95% CI):; - Subjects on AH drugs included: 0.78 (0.01, 1.55); - Subjects on AH drugs excluded: 0.88 (0.13, 1.63); No associations were observed for SBP for men or women (regression coefficients not reported).
Bushnik et al. 2014; Population-based survey study of 2,214 men (mean age 49.5 years) and 2,336 women (mean age 50.5 years) using data collected from the Canadian Health Measures Survey (2007–2011) | PbB:; Mean; All participants: 1.64; Non-hypertensive: 1.59; Hypertensive: 1.74; Analysis: Six blood pressure measurements were taken on the day of assessment. Associations between PbB and blood pressure were analyzed by linear regression. Associations between PbB and hypertension were analyzed by logistic regression, with adjustments for age, sex, education, smoking, alcohol, physical activity, BMI, non-HDL cholesterol, diabetes, chronic kidney disease, family history of high blood pressure, and AH medication use. | An association was observed between PbB and increased DBP, but not SBP. No association was observed between PbB and increased prevalence of hypertension. SBP (mmHg) β mmHg per 1 µg/dL (95% CI) for:; - Men and women: 1.85 (−0.20, 3.90); p=0.075; - Men: 2.17 (−0.08, 4.42); p=0.058; - Women: 0.76 (−2.72, 4.24); p=0.656; DBP (mmHg) β mmHg per 1 µg/dL (95% CI) for:; - Men and women: 1.91 (0.75, 3.08); p=0.002; - Men: 2.36 (0.94, 3.79); p=0.002; - Women: 1.43 (−0.51, 3.38); p=0.142; Hypertension risk (SBP ≥140, DBP ≥90) logistic β (95% CI) for:; - Men and women: −3.87 (−7.46, −0.29); p=0.035; - Men: −6.37 (−15.02, 2.29); p=0.142; - Women: −4.18 (−8.78, 0.42); p=0.073
Cheng et al. 2001; Longitudinal study of 833 men (age range: 21–80; mean: 42 years) from the Normative Aging Study in Boston, Massachusetts; data collection: period 1991–1997 | PbB (mean:; - All (range): 6.09 (<1–35); - Normotensive (SD): 5.87 (4.01); - Borderline hypertension (SD): 6.00 (3.69); - Definite hypertension (SD): 6.37 (4.21); Tibia Pb (µg/g); - Normotensive (SD): 20.27 (11.55); - Borderline hypertension (SD): 23.46 (15.02); - Definite hypertension (SD): 22.69 (14.71); Patella Pb (µg/g); - Normotensive (SD): 28.95 (18.01); - Borderline hypertension (SD): 33.73 (21.76); - Definite hypertension (SD): 32.72 (19.55); Analysis: Data were analyzed by Cox’s proportional hazards model for hypertension and by multivariate linear regression for SBP. Models were adjusted for age^2^, BMI, family history of hypertension, race, educational level, pack-years of smoking, alcohol consumption, and dietary intakes of sodium and calcium. | An association between patella Pb (but not PbB or tibia Pb) and hypertension was observed. RR (95% CI), per 1 SD increase in:; - PbB: 1.00 (0.76, 1.33); - Tibia Pb: 1.22 (0.95, 1.57); - Patella Pb: 1.29 (1.04, 1.61); p<0.05; An association between tibia Pb (but not PbB or patella Pb) and SBP was observed. RR (95% CI), per 1 SD increase in:; - PbB: −0.13 (−1.35, 1.09); - Tibia Pb: 1.37 (0.02, 2.73); p<0.05; - Patella Pb: 0.57 (−0.71, 1.84)
Chu et al. 1999; Population-based survey study of 2,800 subjects (1,471 males and 1,329 females) (15–86 years of age) in Taiwan; data collection period: 1993–1994 | PbB:; Mean (SD); range; - All participants: 6.5 (4.7); 0.1–69.1; - Men: 7.3 (5.2); 0.1–69.1); - Women: 5.7 (3.9); 0.1–40.1; Analysis: Two blood pressure measurements were taken on the day of assessment. Data were analyzed using multiple regression analyses with log_10_-transformed PbB, adjusted for age, BMI, milk intake, alcohol consumption, and smoking. | An association was observed between PbB and increased SBP in men, but not in women. No association was observed between PbB and DBP in men or women. Regression coefficient β mmHg per 1 log_10_ µg/dL (SE) for:; - SBP (mmHg); ○ Men: 0.185 (0.076); p=0.015; ○ Women: −0.057 (0.109); p=0.603; - DBP; ○ Men: 0.075 (0.053); p=0.159; ○ Women: −0.083 (0.072); p=0.250
Den Hond et al. 2002; Cross-sectional study of 13,781 adults (age ≥20 years): white (4,685 males; 5,138 females) and black (1,761 males; 2,197 females) from NHANES III (1988–1994) | PbB:; Median (IQR); - White males: 3.6 (2.3–5.3); - White females: 2.1 (1.3–3.4); - Black males: 4.2 (2.7–6.5); - Black females: 2.3 (1.4–3.9); Analysis: Data were analyzed by multivariate linear regression, adjusted for age, BMI, hematocrit, total serum calcium, and protein concentrations, smoking, alcohol and coffee consumption, dietary calcium, potassium, and sodium intakes, diabetes, and use of AH drugs. | SBP and DBP was positively associated with PbB in black males and females, but not in white males or females.; Predicted covariate-adjusted increments in SBP and DBP per doubling of PbB (95% CI):; - SBP:; ○ White males: 0.3 (−0.2, 0.7); p=0.29; ○ White females: 0.1 (−0.4, 0.5); p=0.80; ○ Black males: 0.9 (0.04, 1.8); p=0.04; ○ Black females: 1.2 (0.4, 2.0); p=0.004; - DBP:; ○ White males: −0.6 (−0.9, −0.3); p=0.0003; ○ White females: −0.2 (−0.5, −0.1); p=0.13; ○ Black males: 0.3 (−0.3, 1.0); p=0.28; ○ Black females: 0.5 (0.01, 1.1); p=0.047
Elmarsafawy et al. 2006; Cross-sectional study of 471 men (mean age 67 years) from the Normative Aging Study in Boston, Massachusetts; data collection period: 1991–1994 | PbB:; Mean (SD); - All subjects: 6.6 (4.3); - Low calcium intake: 6.6 (4.0); - High calcium intake: 6.6 (4.6); Analysis: Data were analyzed by logistic regression adjusted for age, BMI, family history of hypertension, smoking, dietary sodium intake, and alcohol ingestion. | In subjects with low calcium intake, PbB was associated with an increased risk of hypertension. Adjusted ORs (95% CI); - Low calcium group (intake ≤800 mg/day): 1.07 (1.00, 1.15); - High calcium group (intake >800 mg/day): 1.03 (0.97, 1.11)
Faramawi et al. 2015; Cross-sectional study of 13,757 adults (mean age 42.74 years) from NHANES III (1988–1994) | PbB:; Mean (SE): 3.44 (0.09); Analysis: Three blood pressure measurements were taken at the initial in-home visit and in the Mobile Examination Center in a follow-up within 1 month of the in-home visit. Data were analyzed by multivariable regression analyses, with adjustments for age, sex, race, smoking, and SES. | An association was observed between PbB and increased SBP variability (SD of multiple blood pressure measurements), but not DBP variability. Regression coefficient β for change in blood pressure SD per µg/dL (SE):; - SBP (mmHg); ○ Mean variability: 3.33 mmHg; ○ β (SE): 0.07 (0.02); p<0.01; - DBP (mmHg); ○ Mean variability: 1.74 mmHg; ○ β (SE): 0.04 (0.03); p=0.08
Gambelunghe et al. 2016; Cross-section study of 4,452 adults (mean age: 57 years; 66% women) residing in Sweden; data collection period 2007–2012 | PbB:; Mean (range): 2.8 (0.15–25.8); Quartiles, mean (range):; - Q1: 0.15 (0.15–1.9); - Q2: 2.2 (1.9–2.5); - Q3: 2.8 (2.5–3.3); - Q4: 4.7 (3.3–28.5); - p (Q4 versus Q1–Q3): <0.001; Analysis: Blood pressure was measured after 10 minutes of supine rest. Hypertension was defined as SBP ≥140 mmHg or DBP ≥90 mmHg and/or current use of hypertension medication. Data for SBP and DBP were analyzed by multiple linear regression and data for hypertension were analyzed by multiple logistic regression. Both models were adjusted for sex, alcohol intake, smoking, waist circumference, education, and blood cadmium concentration. | PbB was positively associated with SBP, DBP, and risk of hypertension.; Regression coefficient, β, for SBP and DBP, Q4 versus Q1–Q3:; - SBP: 1.7; p=0.01; - DBP: 1.3; p<0.001; OR for hypertension (95% CI): 1.3 (1.1, 1.5); p=0.004
Gerr et al. 2002; Cross-sectional study of 508 young adults (92 males and 118 females) ages 19–29 years (born 1965–1975); the study included two cohorts: (1) participants heavily exposed during childhood (near an active Pb smelter in Silver Valley, Idaho), and (2) referents who did not live near the smelter in childhood | PbB:; Current PbB mean (SD) associated with the following bone (tibia) Pb concentrations:; - <1 µg/g: 1.91 (1.58); - 1–5 µg/g: 2.31 (2.06); - 6–10 µg/g: 2.43 (2.36); - >10 µg/g: 3.15 (2.28); Analysis: Sitting blood pressure was measured on the day of assessment (number of measurements not reported). Multiple linear regression models were used to analyze data and were adjusted for age, sex, height, BMI, current smoking status, frequency of alcohol consumption, current use of birth control medication, hemoglobin level, serum albumin, and income. | For the >10 µg/g bone Pb group, SBP and DBP were increased compared to the <1 µg/g bone group. Blood pressure increases, mmHg (SE):; - Systolic: 4.26 (1.48); p=0.004; - Diastolic: 2.80 (1.25); p=0.03
Glenn et al. 2003; Longitudinal study of 496 male workers (mean age 55.8 years) from the eastern United States studied during 1994–1996 | PbB:; Mean (SD): 4.6 (2.6); Range: 1–20; Analysis: Multiple seated blood pressure measurements were taken at each examination (three or four visits). General estimating equation models were used to evaluate associations between PbB and blood pressure. Covariates considered in the analyses included race; age and BMI; diagnosis of diabetes, arthritis, or thyroid disease; education; and blood pressure measurement interval. | SBP was significantly associated with baseline PbB. An increase in PbB of 1 SD was associated with the following increases in blood pressure (mmHg). β (SE; 95% CI):; - SBP (mmHg): 0.64 (0.25; 0.14, 1.14); - DBP (mmHg): 0.09 (0.17; −0.24, 0.43)
Hense et al. 1993; Population survey study of 1,703 men and 1,661 women (ages 28–67 years) from Germany; data collection period: 1987–1988 | PbB:; Mean; - Men: 8.3; - Women: 6.0; Analysis: Three sitting blood pressure measurements were obtained on the assessment day. Data were analyzed by multiple linear regression, adjusted for age, BMI, alcohol use, and hematocrit. | Regression coefficients per 1.0 µg/dL increase in PbB showed associations between PbB and increased SBP in men and increased DBP in women. β mmHg per 1 µg/dL (95% CI):; - SBP:; ○ Men: 0.29 (0.08, 0.49); ○ Women: 0.17 (−0.14, 0.48); - DBP; ○ Men: 0.08 (−0.06, 0.23); ○ Women: 029 (0.09, 0.49)
Hu et al. 1996a; Case-control study of 146 men (mean age 67 years) with hypertension and 444 age-matched controls, from the Normative Aging Study in Boston, Massachusetts; data collection: period 1991–1994 | PbB:; Mean (SD); - Cases: 6.9 (4.3); - Controls: 6.1 (4.0); Bone Pb (µg/g); mean (SD); - Tibia; ○ Cases: 23.7 (14.0); ○ Controls: 20.9 (11.4); - Patella; ○ Cases: 35.1 (19.5); ○ Controls: 31.1 (18.3); Analysis: Physical examinations, including seated blood pressure and medical history follow-ups, were conducted at approximately 3–5-year intervals. Risk of hypertension was assessed using a logistic regression model, adjusted for BMI and family history of hypertension. | Significant associations were observed between increasing tibia Pb and risk of hypertension.; - Logistic β (SE) for 1 µg/g increase in tibia Pb: 0.19 (0.0078); p=0.01; - OR (95% CI) for 1 µg/g change in tibia Pb: 1.019 (1.004, 1.035); - OR (95% CI) for quintile range (8–37 µg/g): 1.5 (1.1, 1.8); No significant associations observed for PbB or patella Pb.
Korrick et al. 1999; Case-control study of women (mean) age 61.1 years) with hypertension (n=89) and controls (n=195) from the National Nurses’ Health Study; data collection period: 1993–1995 | PbB:; Combined cases and controls:; - Mean (SD): 3 (2); - Range: <1–14; Bone Pb (µg/g), mean (SD); - Tibia: 13.3 (9.0); - Patella: 17.3 (11.1); Analysis: Risk of hypertension was assessed using a logistic regression model, adjusted for age, BMI, dietary sodium intake, alcohol consumption, smoking, and family history of hypertension. | Patella Pb was associated with an increased risk of hypertension. ORs (95% CI): 1.03 (1.00, 1.05); p=0.02.; No association was observed for PbB or tibia Pb (ORs not reported).
Lee et al. 2016a; Cross-sectional study of 5,920 men and 6,059 women, age ≥19 years, from the Korean National Health and Nutrition Examination Survey; data collection period: 2008–2013 | PbB:; Gmean (95% CI); - Men: 2.396 (2.362, 2.430); - Women: 1.919 (1.889, 1.949); Tertiles:; - Men; ○ T1: <2.096; ○ T2: 2.096–2.886; ○ T3: >2.886; - Women; ○ T1: <1.516; ○ T2: 1.516–2.147; ○ T3: >2.147; Analysis: PbB levels were log_2_-transformed. The mean difference in SBP and DBP per doubling of PbB was analyzed by regression analysis for continuous and tertial PbB. ORs for hypertension (DBP of at least 90 mmHg or SBP of at least 140 mmHg or self-reported current use of an anti-hypertensive medication) and prehypertension (DBP of at least 80 mmHg but below 90 mmHg or SBP of at least 120 mmHg but below 140 mmHg) were analyzed by logistic regression. All analyses were adjusted for sex, age group, BMI, residence area, smoking status, drinking status, education level, hypertensive status, physical activities, serum creatinine, hemoglobin, and year of examination. | Difference (95% CI) in SBP and DBP, T3 versus T1:; DBP; - Men; ○ Continuous per doubling of PbB: 0.30 (−0.53, 1.14); ○ T1: 0 (reference); ○ T2: −0.34 (−1.38. 0.69); ○ T3: 0.25 (−0.90, 1.41); - Women; ○ Continuous per doubling of PbB: 1.08 (0.26, 1.90); ○ T1: 0 (reference); ○ T2: 0.312 (−0.74, 1.368); ○ T3: 1.48 (0.29, 2.67); SBP; - Men; ○ Continuous per doubling of PbB: 0.59 (0.01, 1.17); ○ T1: 0 (reference); ○ T2: 0.35 (−0.43, 1.14); ○ T3: 0.73 (−0.12, 1.60); - Women; ○ Continuous per doubling of PbB: 0.80 (0.28, 1.33); ○ T1: 0 (reference); ○ T2: 0.182 (−0.51, 0.879); ○ T3: 1.059 (0.308, 1.811); OR (95% CI) for hypertension; - Men; ○ T1: 1 (reference); ○ T2: 0.88 (0.71, 1.09) (n=582); ○ T3: 0.88 (0.72, 1.07) (n=787); - Women; ○ T1: 1 (reference); ○ T2: 1.07 (0.85, 1.34) (n=426); ○ T3: 1.26 (0.999, 1.58) (n=647); OR (95% CI) for prehypertension; - Men; ○ T1: 1 (reference); ○ T2: 0.86 (0.73, 1.02) (n=1,183); ○ T3: 0.95 (0.79, 1.16) (n=1,437); - Women; ○ T1: 1 (reference); ○ T2: 1.13 (0.94, 1.37) (n=838); ○ T3: 1.22 (1.01, 1.48) (n=1,082)
Lee et al. 2016b; Cross-sectional study of 8,493 adults (3,945 men and 4,548 women), age ≥20 years, from the Korean National Health and Nutrition Examination Survey; data collection period: 2007–2013 | PbB:; (study population mean not reported); Quartiles:; - Q1: 0.206–1.539; - Q2: 1.540–2.056; - Q3: 2.057–2.716; - Q4: 2.717–24.532; Analysis: ORs for prehypertension (DBP of at least 80 mmHg but below 90 mmHg or SBP of at least 120 mmHg but below 140 mmHg) were analyzed by logistic regression age, sex, sociodemographic factors (education, occupation, household income, and residence), health behavioral factors (smoking, alcohol drinking, and exercise level), hypertension-associated medical status (anemia and serum creatinine clearance), and chronic disease (central obesity, diabetes, elevated triglycerides, and decreased HDL). | PbB in all quartiles was positively associated with the risk of prehypertension. OR (95% CI):; - Q1: 1 (reference); - Q2: 1.24 (1.04, 1.48); - Q3: 1.27 (1.06, 1.52); - Q4: 1.30 (1.07, 1.60); - p-trend: 0.0152
Martin et al. 2006; Cross-sectional study of 964 men and women (ages 50–70 years) in Baltimore, Maryland; data collection period 2001–2002 | PbB:; Mean (SD): 3.5 (2.3); Bone Pb (µg/g), mean (SD); - Tibia: 18.8 (12.4); Analysis: Three sitting blood pressure measurements were obtained on the day of assessment. Data were analyzed by multiple linear regression adjusted for age, sex, BMI, AH medication use, dietary sodium intake, dietary potassium intake, time of day, testing technician, serum total cholesterol, SES, and race/ethnicity. | PbB was associated with increased SBP and DBP. β (95% CI), mmHg per µg/dL PbB:; - SBP: 0.99 (0.47,1.51); p<0.01; - DBP: 0.51 (0.24, 0.79); p<0.01; - No association was observed for tibia Pb
Muntner et al. 2005; Cross-sectional study of 9,961 men and women (age ≥18 years) from NHANES (1999–2002) | PbB:; - Mean (95% CI): 1.64 (1.59–1.68); - Quartiles:; ○ Q1: <1.06; ○ Q2: 1.06–1.63*; ○ Q3: 1.63–2.47*; ○ Q4: ≥2.47; *Overlap of PbB of 1.63 µg/dL in Q2 and Q3 is as reported in Muntner et al. (2005).; Analysis: Three sitting blood pressure measurements were obtained on the day of assessment. PbB were log-transformed. Race/ethnicity-stratified ORs of hypertension were analyzed by multivariable logistic regressions models adjusted for age, sex, BMI, diabetes mellitus, smoking status, health insurance status, alcohol consumption, and education. | Concurrent PbB was not associated with hypertension across race/ethnicity groups, although a positive trend was observed for Mexican Americans. Adjusted ORs (95% CI):; - Non-Hispanic white: p-trend=0.61; ○ Q1: 1; ○ Q2: 1.12 (0.83, 1.50); ○ Q3: 1.03 (0.78, 1.37); ○ Q4: 1.10 (0.87, 1.41); - Non-Hispanic black: p-trend=0.06; ○ Q1: 1; ○ Q2: 1.03 (0.63, 1.67); ○ Q3: 1.12 (0.77, 1.64); ○ Q4: 1.44 (0.89, 2.32); - Mexican American: p-trend=0.04; ○ Q1: 1; ○ Q2: 1.42 (0.75, 2.71); ○ Q3: 1.48 (0.89, 2.48); ○ Q4: 1.54 (0.99, 2.39)
Nash et al. 2003; Cross-sectional study of 2,165 women (mean age 48.2 years; range 40–59 years) from NHANES III (1988–1994); the population included 1084 and 633 pre- and postmenopausal women, respectively | PbB:; Mean: 2.9; Range: 0.50–31.1; Quartiles; mean (range); - Q1: 1.0 (0.5–1.6); - Q2: 2.1 (1.7–2.5); - Q3: 3.2 (2.6–3.9); - Q4: 6.4 (4.0–31.1); Analysis: Data were analyzed by multiple linear regression; adjusted for race, age, BMI, tobacco smoking, alcohol consumption, and kidney function (based on serum creatinine levels). | PbB was associated with increased SBP and the prevalence of hypertension in all participants. When stratified by menopausal status, DBP was associated with PbB in postmenopausal women.; Distribution of blood pressure variables (all women):; - SBP, mean (SE, mmHg; p-trend<0.001; ○ Q1: 117.2 (0.95); ○ Q2: 117.7 (0.83); ○ Q3: 119.3 (1.10); ○ Q4: 121.2 (0.92); - DBP, mean (SE, mmHg; p-trend=0.79; ○ Q1: 73.7 (0.51); ○ Q2: 74.2 (0.53); ○ Q3: 74.2 (0.62); ○ Q4: 74.3 (0.62); - Hypertension (%); p-trend<0.001; ○ Q1: 19.4; ○ Q2: 20.6; ○ Q3: 25.5; ○ Q4: 28.3; Regression coefficients (SE) for blood pressure (mmHg per 1 µg/dL):; - All women (pre- and postmenopausal); ○ SBP: 0.32 (0.16); p=0.03; ○ DBP: 0.25 (0.09); p=0.009; - Premenopausal women; ○ SBP: 0.14 (0.26); p=0.59; ○ DBP: 0.38 (0.25); p=0.12; - Postmenopausal women; ○ SBP: 0.42 (0.21); p=0.29; ○ DBP: 0.14 (0.13); p=0.04; OR (95% CI) for general hypertension.; - All women (pre- and postmenopausal); ○ Q1: 1.0 (reference); ○ Q2: 1.0 (0.63, 1.6); ○ Q3: 1.3 (0.87, 2.0); ○ Q4: 1.4 (0.92, 2.0); - Premenopausal women; ○ Q1: 1.0 (reference); ○ Q2: 0.78 (0.38, 1.6); ○ Q3: 1.4 (0.82, 2.4); ○ Q4: 1.5 (0.78, 2.8); - Postmenopausal women; ○ Q1: 1.0 (reference); ○ Q2: 0.73 (0.40, 1.3); ○ Q3: 1.3 (0.75, 2.2); ○ Q4: 1.3 (0.68, 2.3)
Park et al. 2009b; Cross-sectional study of 12,500 participants (mean age 49.9 years) from NHANES III (1988–1994) | PbB:; Mean (SE); - Overall: 3.52 (0.10); - White men; ○ <50 years old (n=2,130): 4.02 (0.16); ○ ≥50 years old (n=2,152): 4.92 (0.18); - Black men; ○ <50 years old (n=1,048): 4.55 (0.15); ○ ≥50 years old (n=540): 7.57 (0.22); - White women; ○ <50 years old (n=2,429): 2.09 (0.07); ○ ≥50 years old (n=2,180): 3.53 (0.12); - Black women; ○ <50 years old (n=1,409): 2.52 (0.09); ○ ≥50 years old (n=612): 4.49 (0.16); Analysis: Logistic regression models were adjusted for age, age^2^, education, smoking status, pack-years of cigarettes, BMI, hematocrit, alcohol consumption, physical activity, AH medication use, and diabetes diagnosis. | The risk of hypertension associated with PbB was increased in all participants, men >50 years of age, all white women, all black women, and women <50 years of age. Adjusted ORs (95% CI) for hypertension per SD (0.75 μg/dL) in log blood Pb:; - Overall: 1.12 (1.03, 1.23).; - Men; ○ White: 1.06 (0.92, 1.22); ○ Black: 1.17 (0.98, 1.38); ○ <50 years old: 0.98 (0.80, 1.22); ○ ≥50 years old: 1.20 (1.02, 1.41); - Women; ○ White: 1.16 (1.04, 1.29); ○ Black: 1.19 (1.04, 1.38); ○ <50 years old: 1.23 (1.04, 1.46); ○ ≥50 years old: 1.09 (0.94, 1.26)
Obeng-Gyasi and Obeng-Gyasi 2018; Cross-sectional study of 22,747 adults (43.67% men; mean age: 44.64 years) participating in NHANES 2009–2016. | PbB:; Mean (95% CI): 1.33 (1.27, 1.38); Analysis: PbB data were ln-transformed. Association between PbB and SBP and DBP were evaluated by linear regression, with adjustments for age, alcohol consumption, smoking, gender, ethnicity, and BMI. | Ln PbB was positively associated with SBP and DBP. β (95% CI), increase in blood pressure (mmHg) per unit increased in ln PbB:; SBP: 0.238 (0.122, 0.355); p=0.0001; DBP: 0.132 (0.049, 0.215); p=0.002
Perlstein et al. 2007; Cross-sectional study of 593 elderly men (age >60 years) enrolled in Normative Aging Study in Boston, Massachusetts (1991–1997) | PbB:; Mean (SD); range: 6.12 (4.03); <1–35; Bone Pb (µg/g) mean: 19; Quintiles for tibia Pb, mean (range), and associated PbB mean (SD):; - Q1:; ○ Tibia Pb: 7.4 (−3–11); ○ Associated PbB: 4.9 (2.9); - Q2:; ○ Tibia Pb: 14.1 (12–16); ○ Associated PbB: 5.3 (3.6); - Q3:; ○ Tibia Pb: 18.9 (17–21); ○ Associated PbB: 5.6 (3.5); - Q4:; ○ Tibia Pb: 24.9 (22–29); ○ Associated PbB: 6.7 (3.8); - Q5:; ○ Tibia Pb: 40.9 (30–126); ○ Associated PbB: 8.1 (5.2); Analysis: Adjusted mean difference in pulse pressure was analyzed by multiple linear regression model, with adjustment for age, height, race, heart rate, waist circumference, diabetes, family history of hypertension, education level achieved, smoking, alcohol intake, fasting plasma glucose, and ratio of total cholesterol to HDL cholesterol. | For tibia Pb concentrations >19 µg/g, mean pulse pressure was 4.2 mmHg greater (95% CI 1.9, 6.5) than for men with tibia Pb concentrations <19 µg/g.; No association between PbB or bone Pb quintiles and changes in pulse pressure were observed, although a positive trend was observed for bone Pb. Adjusted mean difference in pulse pressure (95% CI):; PbB: p-trend=0.82; - Q1: 0 (reference); - Q2: −4.37 (−7.88, −0.86); - Q3: −2.56 (−5.78, 0.67); - Q4: −1.39 (−4.94, 2.15); - Q5: −1.49 (−4.93, 1.94); Bone Pb: p-trend=0.02; - Q1: 0 (reference); - Q2: −3.02 (−6.48, 0.44); - Q3: −0.73 (−4.27, 2.82); - Q4: 2.64 (−0.93, 6.21); - Q5: 2.58 (−1.15, 6.33)
Proctor et al. 1996; Cross-sectional study of 798 male participants (mean age: 66.1 years; age range 43–93 years) in the Normative Aging Study in Boston, Massachusetts; data collection period: 1992–1993 | PbB:; Mean (SD); - All participants: 6.5 (4.0); range 0.5–35; - ≤74 years (n=681): 6.5 (4.1); - >74 years (n=117): 6.3 (3.6); Analysis: Sitting blood pressure was measured in each arm, and the average was used in the analysis. Data were analyzed by multiple linear regression with ln-transformed PbB, adjusted for age, BMI, dietary calcium intake, alcohol use, sitting heart rate, exercise, hematocrit, and smoking status. | An association was observed between PbB and increased DBP, but not SBP (mmHg) for all participants and for participants ≤74 years of age. β mmHg per 1 ln µg/dL (95% CI):; - All participants; ○ SBP: 0.85 (−1.1, 2.7); p>0.05; ○ DBP: 1.2 (0.11, 2.2); p≤0.05; - Participants ≤74 years of age (n=681); ○ SBP: 1.2 (−0.86, 3.2); p>0.05; ○ DBP: 1.6 (0.42, 2.7); p≤0.01; After exclusion of persons on anti-hypertensive medication (whole cohort n=575; ≤74 years of age n=494), no association was found between PbB and SBP or DBP.; No association was found for those >74 years old.
Schwartz 1995; Meta-analysis of 15 studies published during the period 1985–1993; number of participants was not reported | PbB:; Reduction of PbB from 10 to 5; Analysis: Meta-analysis of 15 studies. Results of studies were weighted by the inverse of the variances. | A doubling of PbB from 5 to 10 µg/dL was associated with a 1.25 mmHg (95% CI, 0.87–1.63) increase in SBP (DBP not reported).
Scinicariello et al. 2010; Cross-sectional study of 6,016 participants (age ≥17 years) from NHANES III (1988–1994) | PbB:; Mean (SE); - All participants: 2.99 (0.09); - Non-Hispanic whites: 2.87 (0.09); - Non-Hispanic blacks 3.59 (0.20); - Mexican American 3.33 (0.11); Quartiles; - Q1: 0.7–1.4; - Q2: 1.5–2.3; - Q3: 2.4–3.7; - Q4: 3.8–52.9; Analysis: Up to six blood pressure measurements were obtained at the assessment visit. Data were analyzed by multivariable linear regression of ln-transformed blood Pb level, with adjustments for age, sex, education, smoking status, alcohol use, BMI, serum creatinine, serum total calcium, glycosylated hemoglobin, and hematocrit. | PbB was associated with increased SBP in non-Hispanic whites and non-Hispanic blacks and increased DBP in non-Hispanic blacks. β (SE) (mmHg per ln µg/dL-PbB):; - SBP; ○ Non-Hispanic whites: 1.05 (0.37); p=0.01; ○ Non-Hispanic blacks: 2.55 (0.49); p=0.001; ○ Mexican Americans: 0.84 (0.46); p=0.08; - DBP; ○ Non-Hispanic whites: −0.14 (0.49); p=0.77; ○ Non-Hispanic blacks: 1.99 (0.44); p=0.0002; ○ Mexican Americans: 0.74 (0.38); p=0.06; - Adjusted prevalence ORs (95% CI) for hypertension for PbB quartiles; ○ Non-Hispanic whites; ■ Q4: 1.52 (0.80, 2.88); ○ Non-Hispanic blacks:; ■ Q1: reference; ■ Q2: 1.83 (1.08, 3.09); ■ Q3: 2.38 (1.40, 4.06); ■ Q4: 2.92 (1.58, 5.41); ○ Mexican Americans:; ■ Q4: 1.27 (0.59, 2.57); - Interactions with blood Pb and ALAD genotype for SBP were observed in non-Hispanic whites and non-Hispanic blacks.
Scinicariello et al. 2011; Cross-sectional study of 16,222 participants (age ≥20 years) from NHANES (1999–2006) | PbB:; - Mean (SE) All; ○ 1999–2000: 1.75 (0.03); ○ 2005–2006: 1.41 (0.03); ○ % population PbB <10: 100%; - White men (n=4,538): 2.20 (0.03); - White women (n=4,319): 1.55 (0.02); - Black men (n=1,767): 2.44 (0.05); - Black women (n=1,854): 1.81 (0.06); - Mexican-American men (n=1,925): 2.47 (0.06); - Mexican-American women (n=1,819): 1.56 (0.04); Analysis: Multivariable linear regression was used to examine the relationships among blood pressure measures (systolic, diastolic, and pulse pressure) and l mmHg per ln µg/dL PbB-transformed PbB. Logistic regression to calculate adjusted PORs for hypertension. Models were adjusted for age, BMI, self-reported diabetes, alcohol ingestion, smoking status, education, serum creatinine, serum total calcium, sodium, hematocrit, and blood cadmium. | Ln-transformed PbB was associated with: increased SBP in all participants and black men and women; increased DBP in all participants, white men and women, and black men; decreased DBP in Mexican-American men; and increased pulse pressure in Mexican-American men. Regression coefficient (SE) based on ln µg/dL for:; - SBP (mmHg); ○ All: 1.07 (0.35); p<0.05; ○ White men: 0.87 (0.53); p>0.05; ○ White women: 0.89 (0.55); p>0.05; ○ Black men 2.30 (0.71); p<0.05; ○ Black women 2.40 (1.14); p<0.05; ○ Mexican-American men 0.10 (0.70); p>0.05; ○ Mexican-American women −0.03 (0.64); p>0.05; - DBP (mmHg); ○ All: 0.71 (0.27): p<0.05; ○ White men: 0.90 (0.45): p<0.05; ○ White women: 0.95 (0.38): p<0.05; ○ Black men: 2.75 (0.82); p<0.05; ○ Black women: 0.30 (0.81); p>0.05; ○ Mexican-American men: −1.34 (0.66); p<0.05; ○ Mexican-American women: −0.74 (0.44); p>0.05; - Pulse pressure (mmHg); ○ All: 0.37 (0.34); p>0.05; ○ White men: −0.02 (0.55); p>0.05; ○ White women: −0.03 (0.62); p>0.05; ○ Black men: −0.42 (0.93): p>0.05; ○ Black women: 2.21 (1.17); p>0.05; ○ Mexican-American men: 1.42 (0.70); p<0.05; ○ Mexican-American women: 0.70 (0.63); p>0.05; The risk of hypertension was associated with PbB in black men. PORs (95% CI) for hypertension:; - All: 0.99 (0.89, 1.11); p>0.05; - White men: 0.97 (0.84, 1.13); p>0.05; - White women: 0.94 (0.77, 1.14); p>0.05; - Black men: 1.41 (1.05, 1.88); p<0.05; - Black women: 1.04 (0.76, 1.42); p>0.05; - Mexican-American men: 0.91 (0.67, 1.24); p>0.05; - Mexican-American women: 0.89 (0.69, 1.16); p>0.05
Vupputuri et al. 2003; Cross-sectional study of 14,952 subjects (age ≥18 years); white (5,360 males; 5,188 females) or black (2,104 males; 2,300 females) from NHANES III | PbB:; Mean (SE); - White males: 4.4 (0.1); - White females: 3.0 (0.1); - Black males: 5.4 (0.2); - Black females: 3.4 (0.1); Analysis: Data were analyzed by multivariate linear regression and logistic regression, adjusted for age, BMI, alcohol consumption, dietary calorie, potassium, and sodium intakes, and physical activity. | SBP and DBP was positively associated with PbB in black males and females, but not in white males or females. Predicted covariate-adjusted increments in SBP and DBP per 1 SD (3.3 µg/dL) increase of PbB (95% CI):; - SBP:; ○ White males: 0.29 (−0.24, 0.83); p>0.05; ○ White females: 0.34 (−0.49, 1.17, p>0.05; ○ Black males: 0.82 (0.19, 1.44); p<0.05; ○ Black females: 1.55 (0.47, 2.64); p<0.01; - DBP:; ○ White males: 0.01 (−0.38, 0.40); p>0.05; ○ White females: −0.04 (−0.56, 0.47) p>0.05; ○ Black males: 0.64 (0.08, 1.20); p<0.05; ○ Black females: 1.07 (0.37, 1.77); p<0.01); - Adjusted OR for hypertension [SBP ≥140, DBP ≥90 (95% CI)]:; ○ White males: 1.04 (0.93, 1.16); p=0.47; ○ White females: 1.32 (1.14, 1.52) p<0.001; ○ Black males: 1.08 (0.99, 1.99); p=0.08; ○ Black females: 1.39 (1.21, 1.61); p<0.001)
Zota et al. 2013; Cross-sectional study of 8,194 adults (ages 40–65 years) participating in NHANES 1999–2008 | PbB:; Mean (SE): 1.69 (0.02); Quintiles:; - Q1: ≤1.05; - Q2: 1.06–1.44; - Q3: 1.45–1.90; - Q4: 1.91–2.69; - Q5: >2.70; Analysis: Data were analyzed using logistic regression models, adjusted for age, sex, race/ethnicity, education, marital status, smoking status, alcohol consumption, and AH medication use. | Risk elevated DBP was associated with PbB for Q3–Q5. No association was observed for SBP. Adjusted ORs (95% CI):; - Elevated SBP (≥140 mmHg); ○ Q1: 1 (reference); ○ Q2: 0.87 (0.66, 1.15); ○ Q3: 1.00 (0.76, 1.31); ○ Q4: 1.03 (0.78, 1.37); ○ Q5: 1.23 (0.92, 1.65); ○ p-trend: 0.06; - Elevated DBP (≥90 mmHg); ○ Q1: 1 (reference); ○ Q2: 1.22 (0.82, 1.81); ○ Q3: 1.56 (1.11, 2.19); ○ Q4: 1.80 (1.24, 2.60); ○ Q5: 1.77 (1.25, 2.50); ○ p-trend: 0.0002
Blood pressure in children
Ahn et al. 2018; Cross-sectional study of 1,776 adolescents (age: 10–18 years; 917 males and 859 females) from the 2010–2016 Korean National Health and Nutrition Survey | PbB:; Mean (95% CI):; - All: 1.192 (1.165, 1.219); - Males: 1.308 (1.268, 1.348); - Females: 1.073 (1.037, 1.111); Quartiles; - Males; ○ Q1: <1.07; ○ Q2: 1.07–1.341; ○ Q3: 1.342–1.655; ○ Q4: >1.655; - Females; ○ Q1: <0.839; ○ Q2: 0.839–1.076; ○ Q3: 1.077–1.371; ○ Q4: >1.371; Analysis: Adjusted mean differences in DBP and SBP for a doubling of PbB, BP were regressed against log_2_-transformed PbB, with adjustments of covariates for both continuous variable and quartile analysis. ORs for prehypertension (90>DBP≥ 80 mmHg or 140>SBP≥120 mmHg) were calculated for log_2_-transformed PbB by logistic regression analyses. Adjustments were sex, age, residence area, smoking status, drinking status, BMI, year of measurement, physical activities, hemoglobin, and serum creatinine. | No associations were observed between PbB and DBP, SBP, or risk of prehypertension. A significant negative association was observed for DBP in Q3, but not in Q4. Mean differences in DBP (95% CI):; - Continuous variable for doubling of PbB: −0.680 (−1.581, 0.221); - Quartiles:; ○ Q1: 0 (reference); ○ Q2: 0.065 (−2.238, 1.385); ○ Q3: −1.411 (−3.330, −0.017); ○ Q4: −0.511 (−1.363, 0.844); Mean differences in SBP, β (95% CI):; - Continuous variable for doubling of PbB: −0.099 (−1.098, 0.898); - Quartiles:; ○ Q1: 0 (reference); ○ Q2: −0.255 (−1.755, 1.223); ○ Q3: −0.788 (−1.773, 0.651); ○ Q4: −0.304 (−0.682, 1.218); OR (95% CI) for having prehypertension:; - Continuous variable for doubling of PbB: 0.906 (0.629, 1.305); - Quartiles:; ○ Q1: Reference; ○ Q2: 0.943 (0.589, 1.509); ○ Q3: 0.797 (0.495, 1.282); ○ Q4: 1.002 (0.598, 1.678)
Gump et al. 2005; Prospective study of 122 children (62 males; 66 females) at 9 years of age (born 1991–1994) in Oswego, New York | PbB:; - Cord PbB mean (SD): 2.97 (1.75); - Child PbB (measured at 2.6 years of age) mean (SD): 4.62 (2.51); - Quartiles (child PbB):; ○ Q1: 1.5–2.8; ○ Q2: 2.9–4.1; ○ Q3: 4.2–5.4; ○ Q4: 5.5–13.1; Analysis: Cardiovascular endpoints (blood pressure, heart rate, stroke volume, cardiac output, total peripheral resistance) were assessed at rest and following acute pressor stress (arm immersion in ice water) at age 9.5 years. Associations between PbB and endpoints were examined by multivariate linear regression models with log-transformed cord PbB to untransformed child PbB, adjusted for HOME score, SES, birth weight, BMI, and sex. | Increasing cord PbB was associated with increasing covariate-adjusted resting SBP, but not DBP. β mmHg per log µg/dL (SE):; - SBP (mmHg): 12.16 (4.96); p=0.016; - DBP (mmHg): 8.45 (4.54); p=0.066; Under acute pressor stress, child PbB was associated with increased total peripheral resistance and decreased stroke volume, but not blood pressure, heart rate, or cardiac output. The study authors stated that “a negative association between blood lead levels and stroke volume suggests that lead-induced increases in vascular resistance were sufficient to produce cardiac afterload, a situation arising when blood pressure in the aorta makes it difficult for the left ventricle to eject blood.” β per µg/dL (95% CI):; - Total peripheral vascular resistance; - (dyne-s/cm^5^): 0.088 (0.024, 0.152; p=0.007).; - Stroke volume (mL): −0.069 (−0.124,; - -0.015); p=0.013; - SBP (mmHg): −0.009; - (−0.074, 0.055); p=0.773; - DBP (mmHg): 0.069 (−0.001, 0.138); p=0.052; - Heart rate (beat/minute): 0.013 (−0.046, 0.072); p=0.659; - Cardiac output (L/minute): −0.056 (−0.113, 0.001); p=0.054; Positive trend (p-trend: 0.007) for increased vascular resistance under acute pressor stress over quartiles (data presented graphically). Estimated change in vascular resistance from baseline (%):; - Q1: 3.25; - Q2: 13.76; - Q3: 10.1; - Q4: 14.6
Gump et al. 2011; Cross-sectional study of 140 children ages 9–11 years in Oswego, New York | PbB:; Mean:1.01; Quartiles:; - Q1: 0.14–0.68; - Q2: 0.69–0.93; - Q3: 0.94–1.20; - Q4: 1.21–3.76; Analysis: Cardiovascular responses (blood pressure, total peripheral resistance, cardiac output, and heart rate) were measured in response to acute stress (mirror tracing task). Outcomes under stress were compared to baseline measurements. Regression analyses were adjusted for sex, SES, BMI, and age. | PbB was not associated with cardiovascular baseline values. Under acute stress, associations were observed between PbB and total peripheral resistance, cardiac output, and stroke volume, but not blood pressure or heart rate. Changes under acute stress:; - SBP (mmHg): p-trend=0.31; ○ Q1: 5.30; ○ Q2: 7.33; ○ Q3: 7.07; ○ Q4: 7.23; - DBP (mmHg): p-trend=0.29; ○ Q1: 4.02; ○ Q2: 5.64; ○ Q3: 5.09; ○ Q4: 5.53; - Heart rate (beats/minute): p-trend=0.85; ○ Q1: 0.91; ○ Q2: 0.19; ○ Q3: 0.86; ○ Q4: 0.58; - Stroke volume (%): p-trend=0.04; ○ Q1: 2.23; ○ Q2: 0.91; ○ Q3: −3.47; ○ Q4: −0.89; - Cardiac output (%): p-trend=0.05; ○ Q1: 3.26; ○ Q2: 1.19; ○ Q3: −2.31; ○ Q4: −0.20; - Total peripheral resistance (%): p-trend=0.03; ○ Q1: 2.91; ○ Q2: 8.18; ○ Q3: 9.55; ○ Q4: 9.51
Zhang et al. 2011; Prospective longitudinal study of 457 mother-child pairs in a birth cohort born 1994–2003 in Mexico City; evaluation of children was conducted at ages 7–15 years (during 2008–2010) | PbB:; Mean (SD); - Umbilical cord: 5.51 (3.45); - Child (concurrent): 2.96 (1.72); Maternal postpartum bone Pb median (IQR), μg/g:; - Tibia 9.3 (3.3, 16.1); - Patella: 11.6 (4.5, 19.9); Analysis: Data were analyzed using multiple regression models and generalized estimating equations (ln-transformed cord blood, untransformed concurrent blood, and maternal bone), adjusted for maternal education, smoking during pregnancy, pregnancy nutrition, birth weight, BMI, sex, and child concurrent age. | Maternal tibia Pb was associated with increased SBP and DBP in girls, but not boys. No associations were observed between patella Pb and umbilical cord PbB with blood pressure parameters in children. β mmHg per IQ increase (95% CI) in maternal tibia Pb (13 µg/g):; - SBP; ○ Boys: −0.34 (−1.98, 1.30); ○ Girls: 2.11 (0.69, 3.52); p=0.025; - DBP; ○ Boys: −0.83 (−2.05, 0.38); ○ Girls: 1.60 (0.28, 2.91); p=0.007; β mmHg per IQ increase (95% CI) in umbilical PbB (4 µg/dL):; - SBP; ○ Boys: 0.88 (−1.03, 2.80); ○ Girls: 0.74 (−1.18, 2.67); - DBP; ○ Boys: 0.65 (−1.97, 3.27); ○ Girls: 0.84 (−0.40, 2.09)
Blood pressure and hypertension during pregnancy
Disha et al. 2019; Cross-sectional study of 44 healthy pregnant women (mean age: 24.54 years) and 23 pre-eclamptic women (mean age: 27.34); data collection period: February–October 2017 | PbB:; Mean (range); - Control: 2.38 (0.16–10.12); - Pre-eclampsia: 3.42 (1.28–8.6); p=0.013; Analysis: The relationship between PbB and SBP and DBP was analyzed by Pearson correlation. No adjustments were reported. | PbB was positively associated with SBP and DBP in women with pre-eclampsia. Pearson correlation:; - SBP (mmHg): 0.71; p<0.0001; - DBP (mmHg): 0.57; p=0.004
Rothenberg et al. 2002; Longitudinal study of 667 pregnant women (ages 15–44 years) in Los Angeles during the period 1995–2001 | PbB:; Mean (SD); - 3^rd^ trimester: 1.9; - Postpartum: 2.3; Bone Pb (µg/g) mean; - Tibia: 8.0; - Calcaneus: 10.7; Analysis: Measurements of sitting blood pressure and PbB were made during the 3^rd^ trimester and at 10 weeks postpartum. Data were analyzed by multiple regression analysis with ln-transformed PbB and adjusted for age, BMI, parity, postpartum hypertension, tobacco smoking, and education. | An association was observed between calcaneus Pb, but not tibia Pb or PbB, and increased blood pressure and hypertension in the 3^rd^ trimester. β (95% CI) for 3^rd^ trimester measurements:; - Ln-transformed PbB; ○ SBP: −0.04 (−1.26, 1.18); ○ DBP: 0.20 (−0.78, 1.18); ○ Hypertension: 0.75 (0.21, 2.65); - Tibia Pb; ○ SBP: 0.07 (−0.62, 0.77); ○ DBP: 0.18 (−0.38, 0.74); ○ Hypertension: 0.98 (0.92, 1.04); - Calcaneus Pb; ○ SBP: 0.70 (0.04, 1.36); ○ DBP: 0.54 (0.01, 1.08); ○ Hypertension: 1.86 (1.04, 3.32); Associations were observed between ln PbB and blood pressure measures, β (95% CI), for the postpartum period, but not for tibia or calcaneus Pb:; - PbB; ○ SBP: −1.52 (−2.83, −0.20); ○ DBP: −1.67 (−2.85, −0.50)
Wells et al. 2011; Cross-sectional study of 285 pregnant women (mean age 26 years) during labor in Baltimore, Maryland | PbB:; Umbilical cord; - Mean: 0.66; - Quartiles:; ○ Q1: <0.46; ○ Q2: 0.47–0.65; ○ Q3: 0.66–0.95; ○ Q4: 0.96–6.47; Analysis: Blood pressure was measured at admission, throughout labor, and at delivery. Data (blood pressure at admission and maximum blood pressure during labor/delivery) were analyzed by multivariable linear regression, adjusted for maternal age, maternal race, neighborhood median household income, primiparity, smoking during pregnancy, prepregnancy BMI, and anemia. BMD analysis was also conducted to estimate the PbB BMD and the associated lower confidence limit (BMDL) that was associated with 1 SD increase in blood pressure. | SBP and DBP recorded at admission and maximum values reached were elevated in Q1 compared to Q4. Change in blood pressure in mmHg (95% CI):; - Admission SBP:; ○ Q1: reference; ○ Q2: 2.89 (−2.16, 7.94); ○ Q3: 1.05 (−4.04, 6.14); ○ Q4: 6.87 (1.51, 12.21); p<0.05; ○ p-trend: 0.033; - Admission DBP:; ○ Q1: reference; ○ Q2: 0.00 (−3.95, 3.96); ○ Q3: 0.81 (−3.17, 4.80); ○ Q4: 4.40 (0.21, 8.59); p<0.05; ○ p-trend: 0.036; - Maximum SBP:; ○ Q1: reference; ○ Q2: 2.47 (−3.08, 8.02); ○ Q3: −1.76 (−7.36, 3.85); ○ Q4: 7.72 (1.83, 13.60); p<0.05; ○ p-trend: 0.055; - Maximum DBP:; ○ Q1: reference; ○ Q2: 3.93 (−2.86, 10.72); ○ Q3: −0.42 (−7.27, 6.43); ○ Q4: 8.33 (1.14, 15.53); p<0.05; ○ p-trend: 0.086; BMDL (µg/dL) associated with 1 SD increase in blood pressure:; - Admission SBP: 1.42; - Admission DBP: 1.43; - Maximum SBP: 1.41; - Maximum DBP: 1.43
Yazbeck et al. 2009; Cross-sectional study of 971 pregnant women (ages 18–45 years) in France; data collection: 2003–2005 | PbB:; Mean (SD); - Participants with PIH (n=106): 2.2 (1.4); - Participants without PIH (n=865): 1.9 (1.2); p=0.02 (compared to PIH group); Analysis: PbB was obtained at 24–28 weeks of gestation. Data were analyzed using multivariable logistic regression, with PIH as the dependent variable, using log_10_-transformed PbB. Models were adjusted for maternal age, cadmium, manganese, and selenium blood levels, hematocrit, parity, BMI, gestational diabetes, education, SES, geographic residence, and smoking status during pregnancy. | PbB was associated with an increased risk of PIH. Adjusted OR (95% CI) for PIH for:; - Increase of 1 log_10_ μg/dL in PbB; 3.29 (1.11, 9.74); p=0.03.; - >2.30 µg/dL (<1.20 reference): 2.56 (1.05, 6.22), p=0.09
Atherosclerosis
Ari et al. 2011; Clinical study of 50 adult male and female non-diabetic hemodialysis patients and 48 age- and sex-matched controls (location and data collection period not reported); participants did not have known atherosclerotic disease | PbB:; Mean (SD):; - Hemodialysis patients: 0.41 (0.38); - Controls: 0.10 (0.05); p<0.001 (compared to hemodialysis patients); Analysis: Carotid artery intima-media thickness was assessed by carotid artery ultrasonography. Data were analyzed by multiple linear regression. | A positive association was observed between PbB concentration and greater carotid artery intima-media thickness. β mm per µg/dL (SE): 0.101 (0.040); p=0.013
Muntner et al. 2005; Cross-sectional study of 9,961 men and women (age ≥18 years) from NHANES (1999–2002) | PbB:; - Mean (95% CI): 1.64 (1.59–1.68); - Quartiles:; ○ Q1: <1.06; ○ Q2: 1.06–1.63; ○ Q3: 1.63–2.47; ○ Q4: ≥2.47; Analysis: Peripheral artery disease was assessed by ankle-brachial blood pressure. PbB were log-transformed and adjusted for age, sex, race/ethnicity, BMI, diabetes mellitus, smoking status, alcohol consumption, health insurance status, and education. | A positive trend over quartiles was observed for prevalence (%) of peripheral artery disease. Prevalence (SE):; - Q1: 2.6 (0.6); - Q2: 3.0 (0.5); - Q3: 4.8 (0.6); - Q4: 7.7 (0.6); - p-trend: <0.001; Adjusted ORs showed a positive trend for increased risk of peripheral artery disease across quartiles and increased risk of peripheral artery disease in Q4 compared to Q1. Adjusted ORs (95% CI):; - Q1: 1 (reference); - Q2: 1.00 (0.45–2.22); - Q3: 1.21 (0.66–2.23); - Q4: 1.92 (1.02–3.61); - p-trend: <0.001
Navas-Acien et al. 2004; Cross-sectional study of 2,125 participants (≥40) from NHANES (1999–2000). | PbB:; Mean (25^th^, 75^th^ percentile): 2.07 (1.45, 2.90); Quartiles:; - Q1: <1.45; - Q2: 1.45–2.07; - Q3: 2.07–2.90; - Q4: >2.90; Analysis: Peripheral artery disease was assessed by ankle-brachial blood pressure index. Regression models were adjusted for age, sex, race, education, BMI, alcohol intake, hypertension, diabetes, hypercholesterolemia, GFR, CRP, smoking status, and serum cotinine. | A positive trend (p=0.02) was observed across PbB quartiles for increased risk of peripheral artery disease. Adjusted ORs (95% CI); p-trend 0.02:; - Q1: 1 (reference); - Q2: 1.63 (0.51, 5.15); - Q3: 1.92 (0.62, 9.47); - Q4: 2.88 (0.87, 9.47)
Heart disease and cardiac function
Chen et al. 2017; Cross-sectional study of 5,348 adults (men: 2,163; women: 3,185) aged ≥18 years (mean age 52 years) from East China; data collection period: February–June 2014 | PbB:; Median (IQR); - Men; ○ With cardiovascular disease: 4.333 (2.900–6.867); ○ No cardiovascular disease: 4.402 (2.900–6.216); ○ p=0.63; - Women; ○ With cardiovascular disease: 4.806 (3.407–7.1019); ○ No cardiovascular disease: 3.700 (2.500–5.383); ○ p<0.01; Quartiles:; - Men; ○ Q1: ≤2.900; ○ Q2: 2.901–4.400; ○ Q3: 4.401–6.248; ○ Q4: ≥6.249; - Women; ○ Q1: ≤2.50; ○ Q2: 2.501–3.770; ○ Q3:3.771–5.460; ○ Q4: ≥5.461; Analysis: Cardiovascular diseases included CAD, stroke, and myocardial infarction. ORs were calculated using binary logistic regression analysis adjusted for age, current smoking, alcohol use, education level, diabetes, obesity, hypertension, hypertriglyceridemia, hypercholesterolemia, high LDL-C status, and low HDL-C status. | PbB was association with an increased risk of cardiovascular disease in women, but not men, in Q3 and Q4. Over quartiles, a positive association for prevalence of cardiovascular disease and PbB were observed for women but not men.; ORs (95% CI) for cardiovascular disease:; - Men; ○ Q1: 1 (reference); ○ Q2: 1.07 (0.61, 1.86); ○ Q3: 0.55 (0.29, 1.04); ○ Q4: 1.01 (0.58, 1.78); ○ P-trend: 0.59; - Women; ○ Q1: 1 (reference); ○ Q2: 1.04 (0.62, 1.75); ○ Q3: 1.65 (1.03, 2.66); ○ Q4: 1.93 (1.22, 3.04); ○ p-trend: <0.01; Prevalence of cardiovascular disease (%):; - Men; ○ Q1: 5.3; ○ Q2: 3.8; ○ Q3: 3.7; ○ Q4: 6.5; ○ p-trend: 0.22; - Women; ○ Q1: 3.9; ○ Q2: 4.4; ○ Q3: 6.9; ○ Q4: 10.3; ○ p-trend: <0.01
Cheng et al. 1998; Longitudinal study of 775 men (age range 48–93 years; n=277 for men <65 years of age) with no history of heart disease, hypertension, or diabetes participating in the Normative Aging Study in Boston, Massachusetts; data collection period: 1991–1995 | PbB:; Mean (SD): 5.8 (3.4); Bone Pb, µg/g, mean (SD); - Tibia: 22.2 (13.4); - Patella: 30.8 (19.2); Analysis: Standard resting 12-lead EKG was used to assess heart conduction, IVCD, AVCD, and arrhythmia. Data were analyzed by multivariable linear and logistic models, with log-transformed bone and blood Pb, adjusted for age, alcohol intake, BMI, and DBP for the QT interval and for age, fasting glucose, and DBP for the QRS interval. | In men <65 years of age (but not ≥65 years of age), associations were observed between bone Pb, but not PbB, and a longer QT interval (mseconds). β (95% CI) mseconds per 10 µg/g increase in bone Pb or 10 µg/dL increase PbB:; - Age <65 years; ○ Tibia: 5.03 (0.83, 9.22); p=0.02; ○ Patella: 3.00 (0.16, 5.84); p=0.04; ○ PbB: −0.65 (−10.40, 9.10); p=0.90; - Age ≥65 years; ○ Tibia: 1.41 (−0.67, 3.49); p=0.19; ○ Patella: 0.39 (−1.05, 1.83); p=0.60; ○ PbB: 5.63 (−3.79, 15.03); p=0.24; In men <65 years of age (but not ≥65 years of age), associations were observed between bone Pb, but not PbB, and a longer QRS interval (mseconds). β (95% CI) mseconds per 10 µg/g increase in bone Pb or 10 µg/dL PbB:; - Age <65 years; ○ Tibia: 4.83 (1.83, 7.83); p<0.01; ○ Patella: 2.23 (0.10, 4.36); p=0.04; ○ PbB: −3.49 (−10.72, 3.75); p=0.35; - Age ≥65 years; ○ Tibia: −0.83 (−2.21, 0.56); p=0.24; ○ Patella: −0.11 (−1.07, 0.85); p=0.82; ○ PbB: 2.88 (−3.45, 9.19); p=0.37; Adjusted OR for IVCD (95% CI) for a 10 µg/g increase (age <65 years) for tibia Pb: 2.23 (1.28, 3.90); p<0.01; Adjusted OR for AVCD (95% CI) for a 10 µg/g increase (age ≥65 years) for tibia Pb: 1.22 (1.02, 1.47); p=0.03
Eum et al. 2011; Prospective longitudinal study of 600 men (mean age at the first EKG: 66.7 years), with no previous EKG abnormalities, participating in the Normative Aging Study in Boston, Massachusetts | PbB:; Baseline mean (SD): 5.8 (3.6); Tertiles:; - T1: <4; - T2: 4–6; - T3: >6; Tibia Pb (µg/g); Baseline mean (SD): 21.6 (12.0); Tertiles:; - T1: <16; - T2: 16–23; - T3: >23; Patella Pb (µg/g); Baseline mean (SD): 30.3 (17.7); Tertiles:; - T1: <22; - T2: 22–23; - T3: >23; Analysis: EKG measured at baseline and 8 years later. Data were analyzed by repeated measures linear regression, adjusted for age, age^2^, education, smoking, BMI, albumin-adjusted serum calcium, diabetes status at baseline, years between EKG tests, and QT-prolongation drugs at the time of EKG measurement. | Positive trends across tertiles were observed for QT prolongation based on tibia Pb and for atrioventricular conduction defect for tibia and patella Pb. No associations were observed for PbB. No associations were found for JT (JT=QTc-QRS duration) prolongation, intraventricular conduction defect, or arrhythmia for any lead biomarker. Adjusted ORs (95% CI) for:; QT prolongation:; - Tibia; p-trend=0.003; ○ T1: 1 (reference); ○ T2: 0.86 (0.39, 1.88); ○ T3: 2.53 (1.22, 5.25); - Patella; p-trend=0.14; ○ T1: 1 (reference); ○ T2: 2.67 (1.28, 5.56); ○ T3: 2.10 (0.96, 4.60); - PbB; p-trend=0.41; ○ T1: 1 (reference); ○ T2: 1.19 (0.60, 2.37); ○ T3: 1.31 (0.69, 2.48); Atrioventricular conduction defect; - Tibia; p-trend=0.03; ○ T1: 1 (reference); ○ T2: 0.77 (0.29, 2.09); ○ T3: 0.23 (0.06, 0.87); - Patella; p-trend=0.01; ○ T1: 1 (reference); ○ T2: 0.49 (0.18, 1.31); ○ T3: 0.19 (0.05, 0.68); - PbB; p-trend=0.16; ○ T1: 1 (reference); ○ T2: 0.44 (0.13, 1.47); ○ T3: 0.52 (0.19, 1.45)
Jain et al. 2007; Longitudinal prospective study of 837 men (mean age 67 years) enrolled in Normative Aging Study in Boston, Massachusetts (1991–2001) | PbB:; Baseline mean (SD); - Non-cases 6.2 (4.3); - Cases 7.0 (3.8); Range for cases: 1.0–20.0; Patella Pb (μg/g) baseline mean (SD); - Non-cases 30.6 (19.7); - Cases 36.8 (20.8); Range for cases: 5.0–101; Tibia Pb (μg/g) baseline mean (SD); - Non-cases 21.4 (13.6); - Cases 24.2 (15.9); Range for cases: −5–75; Analysis: At the follow-up visit, ischemic heart disease was defined as myocardial infarction or angina. Log-transformed data were analyzed by multivariate Cox-proportional hazard regression models, and adjusted for age, race, and serum HDL. | A 1 SD increase in PbB increased the risk of ischemic heart disease by 1.27 (95% CI: 1.01, 1.59).; PbB and patella Pb were associated with increased risks of ischemic heart disease. Adjusted HRs (95% CI) per 1 log increase in Pb:; - log PbB: 1.45 (1.01, 2.06); p=0.05; - Patella Pb: 2.64 (1.09, 6.37); p=0.05; - Tibia Pb: 1.84 (0.57, 5.90); p=0.31
Jing et al. 2019; Cross-sectional study of 7,179 adults (2,592 men and 3,587 women) participating in NHANES III; data collection period 1988–1994 | PbB:; Gmean; - Men: 4.10; - Women: 2.93; Analysis: QRS-T angle was evaluated by 12-lead EKGs. QRS-T angles were converted to degrees and stratified by tertiles. QRS-T angle tertiles for men: T1≤70.95; T2 >70.95–≤102.1; and T3: >102.1. QRS-T angle tertiles for women: T1: ≤54.95; T2: >54.95–≤82.94; and T3: >82.94. Data were analyzed using multivariate weighted logistic regression adjusted for age, race, smoking status, poverty index, blood glucose categories, and hypertension. | An increase in log PbB was associated increased odds of an abnormal QRS-T angle in men, but not in women. OR (95% CI) per increase in unit log Pb:; - Men: 1.35 (1.05, 1.74); - Women: 1.05 (0.82, 1.36)
Park et al. 2009a; Cross-sectional study of 613 men (mean age 67 years) enrolled in Normative Aging Study (1991–1995) in Boston, Massachusetts | PbB:; Median (IQR): 5 (4–7); Bone Pb (μg/dL), median (IQR); - Patella: 26 (18–37); - Tibia: 19 (14–27); Analysis: Standard resting 12-lead EKGs were taken at the same time as subjects’ bone lead and blood lead measurements. Linear regression models were adjusted for age, BMI, serum calcium, smoking status, and diabetes status. | Bone Pb, but not PbB was associated with an increased QTc interval corrected for heart rate. β (95% CI) for msecond increase per IQR:; - PbB: 1.3 (−0.76, 3.36); - Patella: 2.64 (0.13, 5.15); - Tibia: 2.85 (0.29, 5.40)
Yang et al. 2017; Prospective study of 179 adults (50.3% women) residing in Belgium; mean age at enrollment: 39.1 years; follow-up was 11.9 years after enrollment (2005–2010) | PbB:; Gmean (at enrollment): 4.19; Analysis: Left ventricular systolic and diastolic function was assessed by Doppler imaging. Data were analyzed by multi-variable linear regression adjusted for sex, age, mean arterial pressure, heart rate, body mass index, fasting plasma glucose, total-to-HDL cholesterol ratio, serum creatinine, γ-glutamyl transferase, smoking, and antihypertensive treatment. | A negative association was observed between Pb and left ventricular systolic function. Left ventricular diastolic function was not associated with PbB (detailed results not reported). No association was observed between PbB and left ventricular mass.; Systolic left ventricular function, β, per doubling of PbB:; - Ejection fraction (%):0.150 (−1.019, 1.320); p=0.800; - Global longitudinal strain (%): −0.392 (−0.753, −0.030); p=0.034; - Regional longitudinal strain (%): −0.618 (−1.167, −0.068); p=0.028; - Regional longitudinal strain rate (per second): −0.056 (−0.097, −0.015); p=0.008; - Regional radial strain (%): −1.825 (−3.740, 0.090); p=0.062; - Regional radial strain rate (per second): −0.113 (−0.226, −0.0002); p=0.050; Left ventricular structure, β, per doubling of PbB:; - Left ventricular mass (g/m^2^): −1.399 (−4.504, 1.707); p=0.375; - End-diastolic diameter (cm): −0.064 (−0.134, 0.006); p=0.072; - Relative wall thickness: 0.0065 (−0.0031, 0.0162); p=0.185
Yang et al. 2018; Cross-sectional baseline assessment of 236 male lead-acid battery manufacturing and recycling workers (age 28.6 years ±9.4 SD) from a longitudinal cohort (Study for Promotion of Health in Recycling Lead United States); data collection period: 2015–2017 | PbB:; Gmean (IQR): 4.50 (2.60–9.15); Quartiles:; - Q1: <2.7; - Q2: 2.7–4.6; - Q3: 4.6–9.2; - Q4: ≥9.2; Analysis: Data for office and ambulatory SBP and DBP were analyzed by linear and logistic regression; adjusted for age, BMI, heart rate, smoking, mean arterial pressure, waist-to-hip ratio, total-HDL lipoprotein ratio, plasma glucose, serum γ-glutamyl transferase, and GFR_e_. | Regression (β) coefficients, expressed as change pressure (mmHg) per 2-fold increase in PbB (95% CI):; - Office; ○ Systolic: 0.79 (−0.17, 1.76) p=0.11; ○ Diastolic: 0.87 (0.03, 1.72) p=0.043; - 24-hour ambulatory; ○ Systolic: 0.29 (−0.82, 1.41) p=0.60; ○ Diastolic: −0.25 (−0.97, 0.48) p=0.50; OR (95% CI) for hypertension:; - Office: 0.89 (0.62–1.28); p=0.52; - 24-hour ambulatory: 1.21 (0.94–1.57); p=0.14
Yu et al. 2019a; Cross-sectional study of 328 newly hired male Pb workers (mean age: 28.3 years) from a longitudinal cohort (Study for Promotion of Health in Recycling Lead (United States); data collection period: May 2015–September 2017 | PbB:; Mean (IQR): 4.54 (2.60–8.90); Analysis: Heart rate variability was assessed by EKG in supine and standing positions. Data were analyzed by stepwise regression adjusted for age, heart rate (or heart rate change for orthostatic changes), mean arterial pressure, and serum insulin. | No association was observed between PbB and heart rate variability, expressed in total power (%). Regression (β) coefficients (95% CI) per 10-fold increase in PbB:; - Supine position: 3.0 (−20.4, 33.0); p=0.82; - Standing position: −6.0 (−26.2, 19.7); p=0.61; - Orthostatic change: −8.8 (−31.8, 17.5); p=0.47

AH = antihypertensive; ALAD = aminolevulinic acid dehydratase; AVCD = atrioventricular conduction defect; BMD = benchmark dose; BMDL = benchmark dose limit; BMI = body mass index; CAD = coronary artery disease; CI = confidence interval; CL = confidence limit; CRP = serum C-reactive protein; DBP = diastolic blood pressure; EKG = electrocardiogram; GFR = glomerular filtration rate; Gmean: geometric mean; HDL = high-density lipoprotein cholesterol; HOME = Home Observation for Measurement of the Environment; HR = hazard ratio; IQ = intelligence quotient; IQR = interquartile range; IVCD = intraventricular conduction defect; LDL = low density lipoprotein cholesterol; NHANES = National Health and Nutrition Examination Survey; OR = odds ratio; Pb = lead; PIH = pregnancy-induced hypertension; POR = prevalence odds ratio; RR = relative risk or rate ratio; SBP = systolic blood pressure; SD = standard deviation; SE = standard error; SES = socio-economic status

Table 4 Selected Epidemiology Studies Evaluating Hematological Effects at Mean Blood Lead Concentrations (PbB) ≤10 µg/dL

Reference and study population | PbB (µg/dL) and analysis | Outcomes
Ahamed et al. 2005; Cross-sectional study of 62 children (ages 4–12 years) from Lucknow, India | PbB:; Mean (SD); - Group 1 (n=17): 3.93 (0.61); - Group 2 (n=27): 7.11 (1.25); Analysis: Student’s t-test was used to compare group means. | No difference (p=0.4948) in blood δ-ALAD activity was observed between groups 1 and 2. Mean (SD), µmol δ-ALA/minute/L blood:; - Group 1: 4.82 (1.25); - Group 2: 4.56 (1.20)
Ahamed et al. 2006; Cross-sectional study of 39 adolescent males (ages 15–18 years) from Lucknow, India | PbB:; Mean (SD): 9.96 (3.63); Range: 4.62–18.64; Analysis: Data were analyzed by linear regression. No adjustments were reported. | A negative correlation was observed between PbB and blood δ-ALAD activity (r=-0.592; p<0.001).
Chen et al. 2019; Cross-sectional study of 158 adults (mean age: 44 years) living near an electronic waste area in China and 109 controls (mean age: 47 years); data collection period: January 2015–March 2015 | PbB:; Median (P_25_, P_75_); - Control: 5.1 (3.9, 8.4); - Exposed: 8.7 (6.2–12.2); - p=0.001; Analysis: To compare variables between groups, data were analyzed by Student’s t-tests and Chi-square. No adjustments were reported. | Hemoglobin and RBC count were significantly increased compared to controls.; Hemoglobin (g/dL), median (P_25_, P_75_):; - Control: 123.0 (107.0, 143.0); - Exposed: 137.0 (119.5, 150.0), p=0.001; RBC count (x10^3^), median (P_25_, P_75_):; - Control: 4.2 (3.5, 4.6); - Exposed: 4.5 (4.1, 4.8), p=0.001
Conterato et al. 2013; Cross-sectional of 50 painters and 36 controls from Brazil | PbB:; Mean (SE); range; - Control: 1.5 (0.1); 0.4–3.0; - Painters: 5.4 (0.4); 1.4–14.0; Analysis: Data were analyzed by one-way ANOVA. | Differences between controls and painters were observed for Hct, Hb, RBC count, and platelet count.; Mean (SE):; Hct (%); - Control: 45.3 (0.5); - Painters: 43.8 (0.4); p<0.05; Hb (g/dL); - Control: 15.4 (0.2); - Painters: 15.0 (0.1); p<0.05; RBC count (1x10^6^/µL); - Control: 5.2 (0.7); - Painters: 5.0 (0.5); p<0.05; MCV (fL); - Control: 86.9 (0.6); - Painters: 87.9 (0.5); MCH (ρg); - Control: 29.6 (0.2); - Painters: 30.0 (0.2); MCHC (g/dL); - Control: 34.1 (0.1); - Painters: 34.2 (0.1); Platelet count (1x10^3^/µL); - Control: 244.3 (8.3); - Painters: 203.7 (6.5); p<0.05
Ergurhan-Ilhan et al. 2008; Cross-sectional study of 25 male automotive repair workers (mean age 16.8 years) and 24 male controls (mean age 16.3 years) from Isparta, Turkey | PbB:; Mean (SD); - Controls: 2.6 (2.0); - Workers: 7.9 (5.2); Analysis: Data were analyzed using non-parametric Mann-Whitney U-test. | Differences between controls and workers were observed for ALAD index and ZPP:heme ratio (µmol ZPP/mol heme).; ALAD index; - Controls: 0.40 (0.34); - Workers: 0.73 (0.47); p=0.048; ZPP:heme ratio; - Controls: 26.4 (7); - Workers: 37.2 (15.9); p=0.045
Liu et al. 2015a; Cross-sectional study of 855 children (age range: 3–7 years; males: 469; females: 386) from China | PbB:; - Median: 7.33; - Quartiles:; ○ Q1: 2.20–5.16; ○ Q2: 5.16–7.33; ○ Q3: 7.33–10.62; ○ Q4: 10.62–37.78; Erythrocyte Pb (µg/dL); - Median: 19.30; ○ Q1: 5.98–13.52; ○ Q2: 13.52–19.35; ○ Q3: 19.35–28.42; ○ Q4: 28.42–101.01; Analysis: Data were analyzed by multivariate linear regression adjusted for age, sex, residence area, and SES. | Erythrocyte Pb, but not PbB, was negatively associated with blood Hb. Change in Hb in g/L (95% CI) from Q1:; PbB; - Q2: −0.63 (−2.35, 1.10); - Q3: 0.78 (−0.95, 2.51); - Q4: 1.45 (−0.28, 3.18); Erythrocyte Pb; - Q2: −0.02 (−1.89, 1.52); - Q3: −3.01 (−4.71, 1.31); p<0.05^a^; - Q4: −3.97 (−5.68, −2.27); p<0.05; A doubling of erythrocyte Pb was associated with a −2.44 g/L (−2.01, −2.86; p<0.05) decrease in Hb level.
Olivero-Verbel et al. 2007; Cross-sectional study on 189 children (ages 5–9 years; 99 boys and 90 girls) from Cartagena, Columbia | PbB:; Mean (SE): 5.49 (0.23); Range: <1.0–21.0; Analysis: Associations between PbB and hematological variables were evaluated by Spearman correlation analysis. | Negative associations were observed between PbB and MCV and MCH, but not Hb, MCHC, or erythrocyte count. Spearman correlation coefficients:; - Hb: 0.069; p=0.348; - MCV: −0.159; p=0.029; - MCH: −0.171; p=0.019; - MCHC: −0.096; p=0.188; - Erythrocyte count: 0.208; p=0.004
Queirolo et al. 2010; Cross-sectional study of 222 children (age 5–45 months) from Uruguay | PbB:; Mean (SD): 9.0 (6.0); Range: 1–35.6; Analysis: Data were analyzed by multiple linear regression. Data were adjusted for age and finger/toy mouthing behavior. | Blood Hb <10.5 g/L was a significant predictor of PbB. β (95% CI): 2.40 (0.77, 4.03); p<0.01. It was also a significant predictor of likelihood to have elevated PbB (>10 µg/dL). OR (95% CI): 1.90 (1.08, 3.35); p<0.05.
Riddell et al. 2007; Cross-sectional study of 2,861 children (age 6 months–5 years) | PbB:; Mean: 6.9; Analysis: PbB data were logarithmically transformed. Data on associations between PbB and Hb were analyzed by linear regression. | Blood Hb concentration was inversely associated with PbB. A 1 g/dL increase in PbB was associated with a 3% decrease in Hb (95% CI: 1, 5%; p=0.043).
Sakata et al. 2007; Cross-sectional studies of male tricycle taxi drivers (n=27) and age-matched non-drivers (n=9) from Kathmandu, Japan | PbB:; Mean (SD); range; - Non-drivers: 2.4 (1.1); 1.8–5.3; - Drivers: 6.4 (2.2); 1.9–11.9 (p<0.0001, compared to non-drivers); Analysis: Means between drivers and non-drivers were compared using Student’s t-test. | Serum EPO in drivers was lower than in non-drivers, serum EPO, mean (SD), mU/mL:; - Non-drivers:18.8 (4.6); - Drivers: 12.7 (3.5); p<0.01, compared to non-drivers; There was no difference in other hematologic parameters (hematocrit or blood hemoglobin parameters) between drivers and non-drivers.
Ukaejiofo et al. 2009; Cross-sectional study of male Pb workers (n=81) and controls (n=30) from Nigeria (ages 16–65 years) who were exposed between 6 months and 20 years | PbB:; Mean (SD); - Controls: 3.00 (0.19); - Workers: 7.00 (0.07); p<0.05 compared to control; Analysis: Statistical methods used to compare means between workers and controls were not reported. | Blood Hb and packed cell volume, but not MCHC, were lower in workers compared to controls. Mean (SD):; Hemoglobin (g/dL):; - Controls: 12.96 (0.089); - Workers: 12.05 (1.62); p<0.001; Packed cell volume (%):; - Controls: 39.73 (0.24); - Workers: 37.97 (5.15); p<0.05; MCHC (g/L):; - Controls: 32.94 (1.87); - Workers: 32.58 (1.32)
Wang et al. 2010; Cross-sectional study of 307 children (ages 4–13 years) and 391 adults (ages 16–77 years) from China | PbB:; - All participants; ○ Mean (SD): 6.71 (0.17); ○ Range: 1.09–51.4; - Children mean (SD): 7.86 (0.16); - Adults mean (SD): 6.43 (0.17); Analysis: PbB data was logarithmically transformed. Data on associations between PbB and blood δ-ALAD and ZPP concentration in blood were evaluated by Pearson correlation analysis. Linear regression was also used to further investigate PbB with ALAD and ZPP (both natural-log transformed). Regression analyses were adjusted for age, sex, and alcohol consumption and smoking status (for adults only). | Negative associations were observed between PbB and blood δ-ALAD activity in children and adults. Pearson correlation coefficients:; - Children: −0.256; p<0.05; - Adults: −0.213; p<0.05; Positive associations were observed between PbB and ZPP (concentration in blood) for children and adults. Pearson’s correlation coefficients:; - Children: −0.256; p<0.05; - Adults: −0.213; p<0.05
Zentner et al 2006; Cross-sectional study of 55 newborns from Brazil | PbB:; Umbilical PbB mean (SD): 3.9 (3.6); Analysis: Data were analyzed by Pearson’s correlation. No information on adjustments was reported. | No association was observed between cord PbB and blood Hb. Pearson correlation coefficient: −0.04; p=0.721.

a The discrepancy between the 95% confidence limits and the p-value appears to be caused by an error in the reporting of the upper confidence limit. (i.e., −1.31, rather than 1.31).

δ-ALA: delta-aminolevulinic acid; δ-ALAD = delta-aminolevulinic acid dehydratase; ALAD index = log(active δ-ALAD/non-activated δ-ALAD); ANOVA = analysis of variance; CI = confidence interval; EPO = serum erythropoietin; Hb = hemoglobin; Hct = hematocrit; MCH = mean corpuscular hemoglobin; MCHC = mean cell hemoglobin concentration; MCV = mean corpuscular volume; Pb = lead; RBC = red blood cell; SD = standard deviation; SE = standard error; SES = socioeconomic status; ZPP = zinc-protoporphyrin

Table 5 Epidemiology Studies Evaluating Musculoskeletal Effects at Mean Blood Lead Concentrations (PbB) ≤10 µg/dL

Reference and study population | PbB (µg/dL) and analysis | Outcomes
Effects on bone
Khalil et al. 2008; Prospective cohort study of 533 women (age range: 65–87 years) enrolled in the Study of Osteoporotic Fractures in Baltimore, Maryland and Monongahela Valley, Pennsylvania; data collection period: 1988–1994 | PbB:; Mean (SD): 5.3 (2.3); Range: 1–21; Tertiles:; - T1 (n=122): ≤3 (reference); - T2 (n=332): 4–7; - T3 (n=79): ≥8; Analysis: Baseline calcaneus BMD was measured in 1988–1990, with follow-up measurements 1993–1994. PbB was measured 1990–1991. Multivariate analysis of annualized percentage of bone loss was adjusted for age, clinic, BMI, weight change between visit 2 and visit 4, smoking, chair stands, fracture history, estrogen use, and baseline BMD. HRs for non-spine fractures were adjusted for age, clinic, education, BMI, alcohol use, baseline total hip BMD, fractures after age 50, health status, fall in past year, smoking, estrogen use, calcium and vitamin D use, grip strength, reaction time lower limb, groove pegboard score, vibration and touch, visual acuity, walk speed, chair stands, and trail making B score. | A trend for increased percentage rate of bone loss with increased PbB was observed. Annualized percentage of calcaneus bone loss (95% CI):; - T1: −1.01 (−1.27, −0.74); - T2: −1.41 (−1.57, −1.24); - T3: −1.49 (−1.86, −1.10); - p-trend: 0.03; The risk of non-spine factures was increased in T3 compared to T1. Adjusted HR (95% CI):; - T1: 1 (reference); - T2: 1.13 (0.65, 1.95); - T3: 2.50 (1.25, 5.03); - p-trend: 0.016
Lee and Park 2018; Cross-sectional study of 443 adults (223 men and 221 women; ages 39–69 years) participating in the KARE cohort; data collection period: 2001–2002 | PbB:; Gmean (GSD): 4.44 (1.80); Analysis: BMD was measured at the distal radius and midshaft tibia. Data were analyzed by linear regression adjusted for age, sex, regional area, income, and activity. | BMD was negatively associated with PbB. Regression coefficient, β (SE), for BMD: −1.27 (0.48); p<0.01
Machida et al. 2009; Cross-sectional study of 1,225 female Japanese farmers; data collection period: 2000–2001 | PbB:; Median (maximum); - Premenopausal (n=261): 1.6 (4.4); - Perimenopausal (n=319): 2.0 (7.9); - Younger postmenopausal (n=387): 1.8 (6.0); - Older postmenopausal (n=248): 1.7 (7.1); Analysis: Spearman correlations analysis to assess univariate associations for biochemical biomarkers of bone metabolism (BALP, OC, NTx, and BMD) were analyzed. | PbB was positively associated with markers of bone metabolism in all women and in peri-menopausal women. Spearman’s correlation coefficients:; - All women; ○ BALP: 0.143 (p=0.000); ○ OC: 0.191 (p=0.000); ○ NTx: 0.181 (p=0.000); ○ BMD: −0.016 (p=0.570); - Perimenopausal women; ○ BALP: 0.234 (p=0.000); ○ OC: 0.391 (p=0.000); ○ NTx: 0.261 (p=0.000); ○ BMD: −0.101 (p=0.071)
Nelson et al. 2011; Cross-sectional study of 329 males (mean age: 65 years and 342 females (mean age: 62 years) from North Carolina; data collection period 2003–2008 | PbB:; Median (range); - Males: 2.2 (0.5–25.1); - Females: 1.9 (0.5–25.4); Analysis: Biochemical biomarkers of joint tissue metabolism (uNTX-I, uCTX-II, serum C2C, serum CPII, serum HA, and serum COMP) were natural log-transformed for analyses. Data were analyzed by multiple linear regression models, adjusted for age, race, current smoking status, and BMI. | In males, correlations were observed between PbB and COMP. In females, correlations were observed between PbB and uNTX-I and uCTX-II. Results are consistent with non-mineralized cartilage turnover in men and increased bone turnover and mineralized cartilage turnover in women. β (95% CI), change in biomarker level per 5 µg/dL increase in PbB:; - Males; ○ uNTX-I: 1.06 (0.95, 1.18); ○ uCTX-II: 1.07 (0.97, 1.18); ○ C2C (65 years): 1.00 (0.94, 1.04); ○ CPII: 0.99 (0.93, 1.05); ○ HA: 1.01 (0.88, 1.05); ○ COMP: 1.08 (1.00, 1.18); - Females; ○ uNTX-I: 1.45 (1.21, 1.74); ○ uCTX-II: 1.28 (1.04, 1.58); ○ C2C (65 years): 1.00 (0.92, 1.08); ○ CPII: 1.09 (0.97, 1.22); ○ HA: 0.96 (0.71, 1.29); ○ COMP: 0.96 (0.87, 1.06)
Pollack et al. 2013; Cross-sectional study of 249 premenopausal women (ages 18–44 years) from Buffalo, New York; data collection period: 2005–2007 | PbB:; Mean (SD): 1.03 (0.64); Analysis: PbB was natural log-transformed in analyses. Data were analyzed by linear regression, adjusted for age, BMI, race, parity, average caloric intake, and age at menarche. | PbB was not associated with whole-body bone mineral density. β (95% CI), per log-unit increase in PbB: 0.004 (−0.029, 0.020).; PbB was not associated with total hip, lumbar spine, or wrist bone mineral density either.
Periodontal and dental effects
Arora et al. 2009; Cross-sectional study of 333 men (age range: 50–94 years) enrolled in the Normative Aging Study in Boston, Massachusetts; data collection period: 1992–1994 | PbB:; Mean (95% CI); - 0 tooth loss: 5.3 (4.3–6.2); - 1–8 lost teeth: 6.2 (5.5–6.9); - ≥9 lost teeth: 6.3 (5.5–7.0); Tertiles; - T1: ≤4.0 (reference); - T2: 4.2–6.4; - T3: 7.0–35.0; Bone Pb (µg/dL/g); Tertiles for tibia; - T1: ≤15.0 (reference); - T2: 16.0–23.0; - T3: 24.0–96.0; Tertiles for patella; - T1: ≤22.0 (reference); - T2: 23.0–36.0; - T3: 37.0–126.0; Analysis: Proportional odds models were used to estimate associations between PbB or bone Pb and tooth loss. Multivariate ORs were adjusted for age, smoking status, education, and diabetes. | Tooth loss was associated with bone Pb concentration, but not PbB. Adjusted ORs (95% CI) for tooth loss:; PbB:; - T1: 1; - T2: 0.86 (0.49, 1.50); - T3: 0.88 (0.52, 1.50); - p-trend: 0.57; Tibia Pb:; - T1: 1; - T2: 1.81 (1.02, 3.18); - T3: 3.03 (1.60, 5.76); - p-trend: 0.001; Patella Pb:; - T1: 1; - T2: 1.32 (0.75, 2.32); - T3: 2.41 (1.30, 4.49); - p-trend: 0.005
Dye et al. 2002; Cross-sectional study in 10,033 participant (5,255 females and 4,778 males) in NHANES III (1988–1994); age range: 20–69 years | PbB:; Mean (SE); - All participants: 2.5 (0.08); - Males: 3.3 (0.12); - Females: 1.9 (0.05); Analysis: Periodontal bone loss was analyzed by linear regression using log_10_ transformed PbB, adjusted for age, sex, race/ethnicity, education, SES, age of home, smoking, and dental furcation. | - Log PbB was associated with an increasing presence of dental furcation. β (SE): 0.13 (0.05); p=0.005
Gemmel et al. 2002; Cross-sectional study of 498 children (age range: 6–10 years) from rural (n=239) and urban (n=259) settings from Boston/Cambridge, Massachusetts (urban) and Farmington, Maine (rural); data collection period not reported | PbB:; Mean (SD); - Overall: 2.3 (1.7); - Rural: 1.7 (1.0); - Urban: 2.9 (2.0); Analysis: Natural log-transformed number for decayed and filled surfaces (lnDFS) was the primary outcome of interest. Data were analyzed by simultaneous multiple regression models using natural ln-transformed PbB, adjusted for sex, race/ethnicity, SES, maternal smoking, maternal education, and various dental hygiene variables. | PbB was positively associated with number of caries among urban children: regression coefficient (SE) ln of number per 1 ln µg/dL in blood Pb:; - Rural: −0.15 (0.09); p=0.09; - Urban: 0.22 (0.08); p=0.005
Kim and Lee 2013; Cross-sectional of 3,966 adults (≥20 years of age) participating in the Korea National Health and Nutrition Survey (2008–2009) | PbB:; Mean (SE):; - Men; ○ No periodontitis: 2.625 (0.028); ○ Periodontitis: 3.118 (0.057); p<0.001; - Women; ○ No periodontitis: 1.906 (0.025); ○ Periodontitis: 2.222 (0.052); p<0.001; Analysis: ORs for periodontitis were calculated for log-transformed PbB, adjusted for BMI, residence area, education level, household income, smoking and drinking status, hemoglobin, glucose, use of floss or interproximal toothbrush, decayed, missing, or filled permanent teeth, active caries, other blood metals, and menopausal status for women. | PbB was associated with an increased risk of having periodontitis in men but not women. OR (95% CI), per doubling of PbB:; - Men: 1.699 (1.154, 2.503); - Women: 1.242 (0.833, 1.850); In the urban subgroup, children with PbB ≥4 µg/dL had, on average, two more carious surfaces than those with PbB ≤1µg/dL.
Kim et al. 2017a; Cross-sectional study of 2,805 school-aged (age range: ≤9–≥12 years) children participating in the Children’s Health and Environment Research group in South Korea; data collection period: 2005–2010 | PbB:; Gmean (GSD): 1.53 (1.57); Range: 0.11–4.89; Analysis: PRs for teeth with dental caries, filled surfaces, and combined dental caries and filled surfaces for deciduous and permanent teeth were determined using the Poisson zero-inflated negative binomial model, adjusted for gender, age, household income, and urinary cotinine level. | PbB was associated with increased prevalence of combined dental caries and filled deciduous teeth, but not permanent teeth. PR (95% CI):; - Deciduous teeth; ○ Dental caries: 1.16 (0.91, 1.49); ○ Filled teeth: 1.11 (0.98, 1.25); ○ Combined caries and filled: 1.14 (1.02, 1.27); - Permanent teeth; ○ Dental caries: 0.69 (0.45, 1.07); ○ Filled teeth: 0.87 (0.73, 1.04); ○ Combined caries and filled: 0.83 (0.69, 0.99)
Moss et al 1999; Cross-sectional study of 24,901 participants (2–5 years: n=3,547; 6–11 years: n=2,894; ≥12 years: n=18,460) in NHANES III (1988–1994) | PbB:; Mean (SE):; - Age 2–5 years: 2.9 (0.12); - Age 6–11 years: 2.1 (0.08); - Age 12–17 years: 2.4 (0.06); Analysis: Prevalence of dental caries was analyzed by logistic regression using log-transformed PbB, adjusted for age, sex, race/ethnicity, poverty income ratio, exposure to cigarette smoke, geographic region, educational level of head of household, carbohydrate and calcium intakes, and dental visits. | There was a significant association between log-transformed PbB and caries status among all age groups. β (SE):; - DFS; ○ 2–5 years: 1.78 (0.59), p=0.004; ○ 6–11 years: 1.42 (0.51), p=0.007; - DFS; ○ 6–11 years: 0.48 (0.22), p=0.003; ○ ≥12 years: 2.50 (0.69), p<0.001; - DMFS; ○ ≥12 years: 5.48 (1.44), p<0.001; An increase in PbB of 5 μg/dL was associated with increased dental caries in children aged 5–17 years. Adjusted OR: 1.8 (95% CI 1.3, 2.5).

BALP = bone-specific alkaline phosphatase; BMD = bone mineral density; BMI = body mass index; C2C = cleavage neoepitope of type II collagen; CI = confidence interval; COMP = cartilage oligomeric matrix protein; CPII = type II procollagen synthesis C-propeptide; DFS = decayed filled surface; DMFS = decayed, missing, filled surface; Gmean: geometric mean; GSD: geometric standard deviation; HA = hyaluronic acid; HR = hazard ratio; KARE = Korean Association REsource; NHANES = National Health and Nutrition Examination Survey; NTx = N-telopeptide cross-linked collagen type I; OC = osteocalcin; OR = odds ratio; Pb = lead; PR = prevalence ratio; SD = standard deviation; SE = standard error; SES = socio-economic status; uCTX-II = C-telopeptide urine fragments of type II collagen; uNTX-I = urine cross-linked N telopeptide of type I collagen

Table 6 Epidemiology Studies Evaluating Renal Effects at Mean Blood Lead Concentrations (PbB) ≤10 µg/dL

Reference and study population | PbB (µg/dL) and analysis | Outcomes^a^
Åkesson et al. 2005; Population-based cross-sectional study of 820 adult women (ages 53–64 years) in Sweden; data collection period was June 1999 through January 2000 | PbB:; - Median: 2.2 (95% CI: 1.1, 4.6); - 10^th^–90^th^ percentile: 1.3–3.8; Analysis: GFR was calculated using cystatin C data. Markers of renal function were analyzed by linear regression analysis, adjusted for age, BMI, diabetes, hypertension, regular use of nephrotoxic drug, smoking status, and urinary cadmium. | Spearman’s rank correlation coefficients:; - GFR (mL/minute): −0.11 (p≤0.05); - SCr (µmol/L): 0.13 (p≤0.001); - UPHC (µg/L) −0.01; - UNAG (U/g creatinine): 0.02; - CCr: −0.13 (p≤0.001); Linear regression β coefficients (µg Pb/L):; - GFR: −0.20 (95% CI: −0.32, −0.09); - CCr: −0.18 (95% CI: −0.30, −0.06); - UPHC: reported as NS; - UNAG: reported as NS
Barry et al. 2019; Cross-sectional study of 211 adult men (median age: 61.9 years) residing near New York City; data collection period not specified | PbB:; Median (range): 2.5 (0–34.0); Quartiles:; - Q1: <1.6; - Q2: 1.6–2.5; - Q3: 2.6–4.2; - Q4: ≥4.3; Bone (tibia) Pb (µg Pb/g):; Median (range): 13.8 (0–127.3); Bone Pb quartiles:; - Q1: <9.6; - Q2: 9.6–13.7; - Q3: 13.8–19.5; - Q4: ≥19.6; Analysis: GFR was calculated using urine creatinine, serum creatinine, and serum cystatin C. PbB data were analyzed by linear regression continuous models, adjusted for age, smoking pack years, race, and BMI. | No associations were observed between PbB or bone Pb and GFR. Linear regression coefficients (SE):; PbB:; - Q1: reference; - Q2: 3.70 (4.02); p=0.36; - Q3: −1.93 (4.33); p=0.66; - Q4: −2.71 (4.16); p=0.52; - Continuous: −0.13 (0.28); p=0.65; Bone Pb:; - Q1: reference; - Q2: 2.60 (4.19); p=0.54; - Q3: 2.13 (4.30); p=0.62; - Q4: −5.66 (4.86); p=0.25; - Continuous: −0.15 (0.11); p=0.18
de Burbure et al. 2006; Cross-sectional study of >800 children (ages 8.5–12.3 years) from France, Poland, and the Czech Republic living near nonferrous smelters; exposed children lived near smelters for at least 8 years; control children did not live near smelters | PbB (mean±SD):; - France; ○ Control: (M) 3.42±0.19; (F) 2.81±0.19; ○ Exposed: (M) 4.21±0.20; (F) 3.64±0.17; - Poland; ○ Control: (M) 3.81±0.15; (F) 3.42±0.14; ○ Exposed: (M) 6.51±0.17; (F) 5.72±0.15; - Czech Republic; ○ Control: (M) 3.61±0.14; (F) 3.40±0.13; ○ Exposed: (M) 4.99±0.15; (F) 4.06±0.15; Analysis: Data for SCr and Sβ2M were analyzed by multiple regression analysis and ANOVA, adjusted for sex, cadmium, mercury, urinary creatinine, and interactions with cadmium and mercury. | PbBs in all exposed groups were higher than controls (p<0.05).; PbB >5.59 µg/dL (mean 7.84 µg/dL): SCr (mg/100 mL) was decreased by approximately 7% (p<0.01; data presented graphically), compared to the lowest PbB quartile (<2.85 µg/dL).; PbB >5.86 µg/dL (mean 7.84 µg/dL): Sβ2M (µg/L) was decreased by approximately 9% (p<0.001; data presented graphically), compared to the lowest quartile (<3.10 µg/dL).
Fadrowski et al. 2010; Cross-sectional study of 769 U.S. adolescents (ages 12–20 years) participating in the NHANES III study; data collection period was 1988–1994 | PbB:; - Median: 1.5; - Quartiles; ○ Q1: <1.0; ○ Q2: 1.0–1.5; ○ Q3: 1.6–2.9; ○ Q4: >2.9; Analysis: Data for GFR (estimated by serum cystatin C or SCr) were analyzed by linear regression adjusted for age, sex, race/ethnicity, urban versus rural residence, tobacco smoke exposure, obesity, annual household income, and educational level of family reference person. | GFR (mL/minute/1.73 m^2^) difference (cystatin C) β (95% CI); - Q1: 1; - Q2: −1.4 (−7.4, 4.5); - Q3: −2.6 (−7.3, 2.2); - Q4: −6.6 (−12.6, −0.7); - p-trend: 0.009; Mean difference in GFR associated with a 2-fold increase in blood lead level: −2.9 (−5.0, −0.7); GFR difference (creatinine):; - Q1: 1; - Q2: −0.5 (−6.1, 5.1); - Q3: −1.7 (−6.9, 3.5); - Q4: −1.9 (−7.4, 3.5); - p-trend: 0.31
Harari et al. 2018; Prospective cohort study of 2,567 adults (women: 60%) in Sweden; baseline data collected 1991–1994; 16-year follow-up data collected 2007–2012; mean age at baseline: 57 years; mean age at follow-up: 73 years | PbB:; Median at baseline (range): 2.5 (0.15–25.8); Quartiles (range):; - Q1: 1.5 (0.15–1.85); - Q2: 2.2 (1.85–2.47); - Q3: 2.9 (2.47–3.30); - Q4: 4.6 (3.30–25.8); Analysis: GFR was estimated by combined serum creatinine and cystatin C. Data were analyzed by multivariable-adjusted linear regression analysis, adjusted for age, sex, smoking, alcohol intake, hypertension, diabetes mellitus, waist circumference, corresponding GFR at baseline, and education level. Associations between PbB and CKD were analyzed by Cox proportional hazards regression, adjusted for age, sex, smoking, alcohol intake, hypertension, diabetes mellitus, waist circumference, education level, and baseline GFR. | At the 16-year follow-up assessment, mean GFR for Q1 was decreased from 89 to 62 mL/minute from baseline values. Additional decreases in GFR, mL/minute/1.73 m^2^, (95% CI), per quartile:; - Q1: reference; - Q2: −1.2 (−2.6, 0.16); p<0.08; - Q3: −2.6 (−4.0, −1.2); p<0.001; - Q4: −2.3 (−3.8, −0.85); p=0.002; - p-trend: <0.001; HRs (95% CI) for CKD show an association between PbB and CKD for Q4 relative to combined Q1–Q3:; [underlined: Versus Q1]; - Q1: 1 (reference); - Q2: 0.83 (0.54, 1.28); p=0.4; - Q3: 0.83 (0.53, 1.29); p=0.4; - Q4: 1.30 (0.85, 2.00); p=0.2; [underlined: Versus Q1–Q3]; - Q1–Q3: 1 (reference); - Q4: 1.49 (1.07, 2.08); p=0.02
Khan et al. 2010a; Cross-sectional study of 123 children (ages 1–6 years) of Pb-workers and 123 age- and sex-matched controls from Pakistan; data collection period not specified | PbB:; Median (range); - Control: 6.7 (1.4–13.3); - Exposed: 8.10 (1.0–20.9); p<0.01; Analysis: Comparison of serum creatinine levels between groups was conducted using Mann-Whiney test. Data also were analyzed by Spearman’s correlation. | Serum creatinine (µmol/L):; - Control: 52; - Exposed: 56; p≤0.01; Spearman’s correlation coefficient: r=0.13; p≤0.05
Kim et al. 1996a; Retrospective cohort study of 459 men participating in the Normative aging study; data collection period was 1979–1992 | PbB:; - Mean±SD: 9.9±6.1; - Range: 0.2–54.1; Analysis: Multivariate model was adjusted for age at initial visit, time elapsed since initial visit, BMI, current smoking status, daily alcohol consumption, educational level, and hypertension. The multivariate model for change In SCr (from the current to the next visit) included time elapsed from the current to the next visit and current SCr. | PbB was associated with increased concurrent SCr concentration. SCr (µmol/L) for all participants:; - Regression coefficient (SE): 0.033 per mg/dL (0.012); p=0.005; SCr (µmol/L) for participants with PbB ≤10 µg/dL:; - Regression coefficient (SE): 0.060 per mg/dL (0.019); p=0.002
Lin et al. 2001; Prospective, longitudinal study of Taiwanese patients (ages 18–70 years) 110 [n=55 in “low” body Pb burden group (<80 µg); n=55 in “high-normal” body Pb group (≥80–<600 µg)] with chronic renal insufficiency | PbB:; - Low Pb (Pb body burden <80 µg); ○ Mean±SD: 3.9±1.0; ○ Range: 1.0–7.9; - High Pb (Pb body burden ≥80–<600 µg); ○ Mean±SD: 6.6±3.5 (p<0.001, compared to Low Pb group); ○ Range 1.0–15; Analysis: Progression of renal insufficiency was evaluated at 3-month intervals for 24 months. Differences in group means evaluated with Student’s t-test. Pb body burden was estimated by EDTA mobilization. | CCr in mL/second (mean±SD); - Baseline; ○ Low Pb:0.67±0.22; ○ High Pb: 0.66±0.2 (p=0.78); - 3–18 months: no differences between groups; - 18 months; ○ Low Pb: 0.72±0.25; ○ High Pb: 0.59±0.22 (p=0.007); - 21 months; ○ Low Pb: 0.70±0.24; ○ High Pb: 0.57±0.22 (p=0.006); - 24 months; ○ Low Pb: 0.70±0.24; ○ High Pb: 0.55±0.22 (p=0.001)
Lin et al. 2003; Prospective, longitudinal study of 202 Taiwanese patients (ages 25–80 years) with chronic renal insufficiency; patients had SCr 1.5–3.9 mg/dL and body lead burden <600 μg; patients had no known history of Pb exposure | PbB:; - Baseline mean±SD: 5.3±2.9; - End of 24-month observation period (mean±SD); ○ Placebo: 5.9±3.0 (range: 1.3–14.8); ○ Chelation: 6.1±2.5 (range: 2.4–12.3); Analysis: Progression of renal insufficiency was evaluated at 3-month intervals for 24 months (SCr, CCr, GFR). At the end of the 24-month observation period, 64 patients with body Pb burdens ≥80 and <600 µg (estimated by EDTA mobilization) were randomly selected for repeated chelation or placebo treatment (n=32/group) for 27 months. Differences in group means evaluated with Student’s t-test or Mann-Whitney test. Blood pressure was controlled with diuretics and ACE inhibitors. | End of 24-month observation period (mean±SD); - GFR (mL/minute/1.73 m^2^); ○ Placebo: 31.5±9.0; ○ Chelation: 32.0±12.1; - CCr (mL/minute/1.73 m^2^); ○ Placebo: 31.6±9.9; ○ Chelation: 32.3±12.9; Chelation therapy led to improvement in renal function and the slower progression of renal insufficiency. End of 27-month treatment period; - GFR (mL/minute/1.73 m^2^); ○ Placebo: 25.5±12.3; ○ Chelation: 34.4±14.7 (p=0.01); - Change in GFR following chelation; ○ Placebo: −6.0±5.8; ○ Chelation: 2.1±5.7 (p>0.001); - CCr (mL/minute/1.73 m^2^); ○ Placebo: 26.1±11.6; ○ Chelation: 34.8±14.7 (p=0.02); - Change in CCr following chelation; ○ Placebo: −5.6±2.1; ○ Chelation: 2.1±4.9 (p>0.001)
Lin et al. 2006a; Prospective, longitudinal study of 124 Taiwanese patients (ages 18–80 years) with chronic renal insufficiency; patients had SCr 1.5–3.9 mg/dL and body lead burden <80 μg; patients had no known history of Pb exposure | PbB:; - End of 24-month observation period (mean±SD); ○ Placebo: 3.0±1.1 (range: 1.2–4.6); ○ Chelation: 2.6±1.0 (range: 1.4–4.4); Analysis: Progression of renal insufficiency was evaluated at 3-month intervals for 24 months (SCr, CCr, GFR). At the end of the 24-month observation period, 32 patients with body Pb burdens ≥80 and <600 µg (estimated by EDTA mobilization) were randomly selected for repeated chelation or placebo treatment (n=16/group) for 27 months. Student’s t-test or Mann-Whitney test was used for analysis of data. | End of 24-month observation period (mean±SD); - GFR (mL/minute/1.73 m^2^); ○ Placebo: 42.6±9.7; ○ Chelation: 41.2±11.2; - CCr (mL/minute/1.73 m^2^); ○ Placebo: 48.8±16.9; ○ Chelation: 45.0±9.0; End of 27-month treatment period; - GFR (mL/minute/1.73 m^2^); ○ Placebo:38.0±8.9; ○ Chelation: 47.9±17.0 (p=0.0493); - Change in GFR following chelation; ○ Placebo: −4.6±4.3; ○ Chelation: 6.6±10.7 (p=0.0005); - CCr (mL/minute/1.73 m^2^); ○ Placebo: 42.2±13.2; ○ Chelation: 46.6±12.8 (p=0.3537); - Change in CCr following chelation; ○ Placebo: −5.1±4.1; ○ Chelation: 5.3±6.5 (p<0.001); No difference in 24-hour urine protein (g) was observed before or after treatment. 27-Month values (mean±SD):; - Placebo: 1.11±1.63; - Chelation: 0.92±1.16 (p=0.6236)
Lin et al. 2006b; Prospective, longitudinal study of 238 Taiwanese patients with type II diabetes (ages 33–79 years) with progressive diabetic neuropathy; patients had SCr ≥1.5 and ≤3.9 mg/dL; patients had no known history of Pb exposure | PbB:; - Baseline (mean±SD): 6.5±3.4 µg/dL (range: 1.6–19.1 µg/dL); - End of 12-month observation period (mean±SD); ○ Placebo: 5.9±2.2 (range: 2.4–10.4); ○ Chelation: 7.5±4.6 (range: 1.8–17.0; p=0.2477); Analysis: Progression of renal insufficiency was evaluated at 3-month intervals for 12 months (SCr, CCr, GFR). GFR was calculated based on serum creatinine. At the end of the 12-month observation period, 30 patients with body Pb burdens ≥20 and <80 µg (estimated by EDTA mobilization) were randomly selected for repeated chelation or placebo treatment (n=15/group) for 3 months, followed by a 24-month observation period. Differences in group means evaluated with Student’s t-test or Mann-Whitney test. Blood pressure was controlled with diuretics and ACE inhibitors. | Each increase of 1 µg/dL in PbB levels resulted in a reduction in the GFR of 0.56 mL/minute/1.73 m^2^ (p=0.028).; End of 12-month observation period (mean±SD); - GFR (mL/minute/1.73 m^2^); ○ Placebo: 37.0±9.2; ○ Chelation: 35.1±7.5; - CCr (mL/minute/1.73 m^2^); ○ Placebo: 38.9±8.9; ○ Chelation: 36.4±9.1; Decrements in GFR at end of 27-month treatment/observation period; - GFR (mL/minute/1.73 m^2^); ○ Placebo: 13.1±4.5; ○ Chelation: 18.0±7.3 (p=0.0352); - Change in GFR following chelation; ○ Placebo: 13.2±7.6; ○ Chelation: 4.4±6.9 (p=0.0045); - CCr (mL/minute/1.73 m^2^); ○ Placebo: 15.3±8.4; ○ Chelation: 22.1±11.7 (p=0.0787); - Change in CCr following chelation; ○ Placebo:13.3±7.7; ○ Chelation: 1.0±9.8 (p=0.0011)
Lin-Tan et al. 2007; Placebo-controlled clinical study of 116 non-diabetic, Taiwanese patients with CKD; patients had SCr 1.5–3.9 mg/dL and body lead burden >60 and <600 µg; patients had no known history of Pb exposure | PbB:; - Baseline (mean±SD); ○ Placebo: 5.1±2.6 (range: 1.3–14.8); ○ Chelation: 5.0±2.2 (range: 1.1–12.3; p=0.8305); - After 51-month chelation (mean±SD):; ○ Placebo: 6.0±4.1; ○ Chelation: 3.5±1.5 (p=0.0306); Analysis: Patients with body lead burden ≥60 μg and <600 μg (estimated by EDTA mobilization) and serum creatinine ≤4.0 mg/dL randomly assigned to treatment with placebo or chelation therapy (n=58/group). Patients were administered treatment with placebo chelation therapy for 3 months, followed by 48 months of repeated chelation (or placebo) as needed. Differences in group means evaluated with Student’s t-test or Mann-Whitney test. Blood pressure was controlled with diuretics or ACE inhibitors. | Baseline (mean±SD); - GFR (mL/minute/1.73 m^2^); ○ Placebo: 36.0±11.2; ○ Chelation: 36.8±12.7 (p=0.6925); - CCr (mL/minute/1.73 m^2^); ○ Placebo: 40.2±10.7; ○ Chelation: 21.9±14.6; - 24-Hour urine protein (g); ○ Placebo: 0.89±0.91; ○ Chelation: 0.82±0.92 (p=0.2996); End of 51-month treatment period; - GFR (mL/minute/1.73 m^2^); ○ Placebo: 23.7±10.8; ○ Chelation: 35.4±17.0 (p<0.0001); - Change in GFR following treatment; ○ Placebo: −12.7±8.4; ○ Chelation: −1.8±8.8 (p<0.0001); - CCr (mL/minute/1.73 m^2^); ○ Placebo: 27.7±10.3; ○ Chelation:40.3±16.7 (p<0.0001); - Change in CCr following chelation; ○ Placebo: −12.6±8.1; ○ Chelation: −2.1±8.5 (p<0.0001); - 24-Hour urine protein (g); ○ Placebo: 0.96±1.04; ○ Chelation: 0.81±0.86 (p=0.3369)
Mujaj et al. 2019; Cross-sectional study of 447 newly hired male workers (mean age: 28.7 years); data collection period: May 2015–September 2017 | PbB:; Gmean (IQR): 4.34 (2.59–7.90; Analysis: GFR was measured by combined serum creatinine and cystatin C. Data for GFR and ACR were analyzed by linear regression analysis, adjusted for age, mean arterial pressure, BMI, smoking, waist-to-hip ratio, total-to-HDL cholesterol ratio, plasma glucose, γ-glutamyl transferase, and antihypertensive drug treatment. | No associations were observed between PbB and GFR or ACR. β (95% CI), per doubling of PbB:; - GFR: −0.281 (−3.07, 2.50); p=0.84; - ACR: −0.071 (−0.14, 0.59); p=0.06
Muntner et al. 2003; Cross-sectional study of 4,813 hypertensive (≥140 mmHg systolic pressure or ≥90 mmHg diastolic pressure) and 10,398 normotensive adults (≥20 years of age) participating in the NHANES III study; data collection period was 1988–1994 | PbB:; Normotensive; - Mean±SD: 3.30±0.10; - Quartiles; ○ Q1 (reference): 0.7–1.6; ○ Q2: 1.7–2.8; ○ Q3: 2.9–4.6; ○ Q4: 4.7–52.9; Hypertensive; - Mean±SD): 4.21±0.14 (p<0.001, compared to normotensive); - Quartiles:; ○ Q1 (reference): 0.7–2.4; ○ Q2: 2.5–3.8; ○ Q3: 3.9–5.9; ○ Q4: 6.0–56.0; Analysis: Data were analyzed by multivariate regression adjusted for age, race, sex, diabetes, systolic blood pressure, smoking, history of cardiovascular disease, BMI, alcohol consumption, household income, education level, marital status, and health insurance. The MDRD formula was used to calculate the estimated GFR. CKD was defined as GFR <60 mL/minute/1.73 m^2^. | Estimated GFR, mL/minute (mean±SD); - Normotensive: 115±0.7; - Hypertensive: 95±0.7 (p<0.001); Serum creatinine, mg/dL (mean±SD); - Normotensive: 1.05±0.004; - Hypertensive: 1.14±0.01 (p<0.001); Elevated serum creatinine, %; - Normotensive: 1.8; - Hypertensive: 11.5 (p<0.001); CKD, %; - Normotensive: 1.1; - Hypertensive: 10.0 (p<0.001); Normotensive: Adjusted ORs were not increased for SCr or CKD for Q2–Q4, compared to Q1. No trends were observed across quartiles.; Hypertensive, adjusted ORs (95% CI) for; - Elevated SCr; ○ Q1: 1; ○ Q2: 1.47 (1.03, 2.10); ○ Q3: 1.80 (1.34, 2.42); ○ Q4: 2.41 (1.46, 3.97); ○ p-trend: <0.001; - CKD; ○ Q1: 1; ○ Q2: 1.44 (1.00, 2.09); ○ Q3: 1.85 (1.32, 2.59); ○ Q4: 2.60 (1.52, 4.45); ○ p-trend<0.001
Navas-Acien et al. 2009; Cross-sectional study of 14,778 adults (≥20 years) participating in the NHANES (1999–2006) study | PbB; - Mean: 1.58; - Quartiles (median):; ○ Q1 (reference): ≤1.1 (0.8); ○ Q2: >1.1–1.6 (1.3); ○ Q3: >1.6–2.4 (1.9); ○ Q4: >2.4 (3.2); Analysis: Data for GFR and urine albumin were analyzed by logistic regression adjusted for survey year, age, sex, race/ethnicity, BMI, education, smoking, cotinine, alcohol intake, hypertension, diabetes, menopausal status, and blood cadmium. The MDRD formula was used to calculate the estimated GFR. | Adjusted ORs (95% CI) for albuminuria (≥30 mg/g creatinine); - Q1: 1; - Q2: 0.83 (0.66, 1.04); - Q3: 0.92 (0.76, 1.12); - Q4: 1.19 (0.96, 1.47); - p-trend: <0.001; Adjusted ORs (95% CI) for reduced GFR (<60 mL/minute/1.73 m^2^); - Q1: 1; - Q2: 1.10 (0.80, 1.51); - Q3: 1.36 (0.99, 1.85); - Q4: 1.56 (1.17, 2.08); - p-trend: <0.001
Payton et al. 1994; Cross-sectional study of 744 men (ages 43–90 years) participating in the Normative Aging Study of the Department of Veterans Affairs; data were collected July 1988 through April 1991 | PbB; Mean±SD: 8.1±3.9; Range: <4.0–26.0; Analysis: Multivariate linear regression analysis (adjusted for age, BMI, blood pressure, alcohol intake, and use of diuretic and analgesic medication) was used to evaluate CCr data. Pearson’s product-moment correlation was used to evaluate the relationship between PbB and CCr and estimated GFR. | Pearson’s product-moment correlation for PbB; - CCr (mL/minute): r = −0.082 (p=0.025); Multivariate regression coefficient, β (SE), µg/dL, for CCr (mL/minute): −0.0403 (0.0198); p=0.0426
Pollack et al. 2015; Prospective cohort study of 257 premenopausal women (ages 18–44 years) from Buffalo, New York; data were collected 2005–2007; participants were divided into two groups: (1) those with reduced GFR (<90 mL/minute/1.73 m^2^) (n=173), and (2) those without reduced GFR (≥90 mL/minute/1.73 m^2^) (n=84) | PbB; - Median: 0.88; - Tertiles; ○ T1 (reference): <0.72; ○ T2: 0.72–1.10; ○ T3: >1.10; Analysis: Linear mixed models, adjusted for age, race, BMI, smoking, average calorie intake per menstrual cycle, menstrual cycle day, and average daily alcohol, were used to evaluate changes in kidney function (BUN, creatinine, glucose, GFR, protein) relative for PbB. | PbB was associated with increased SCr (mg/dL) and decreased GFR (mL/minute/1.73 m^2^). No associations were observed for BUN, blood albumin, glucose, or protein. Regression β coefficients, expressed as percent change in outcome per 2-fold increase in PbB (95% CI):; - SCr: 3.47 (0.85, 6.16); - GFR: −3.73 (−6.55, −0.83); - BUN: −0.13 (−4.97, 4.96); - Blood albumin: −0.38 (−1.28, 0.52); - Blood glucose: 0.93 (−0.28, 2.15); - Blood protein: −0.76 (−1.61, 0.09); Evaluation of outcomes by tertile showed that PbB was associated with increased SCr and decreased GFR. Regression β coefficients by tertile, expressed as percent change in outcome per 2-fold increase in PbB (95% CI):; - SCr (mg/dL); ○ T1: reference; ○ T2: 0.05 (0.02, 0.09); p<0.05; ○ T3: 0.05 (0.0006, 0.08); p<0.05; - GFR (mL/minute/1.73 m^2^); ○ T1: reference; ○ T2: −8.28 (−14.07, −2.50); p<0.05; ○ T3: −6.79 (−13.10, −0.49); p<0.05
Spector et al. 2011; Cross-sectional study of 3,941 adults (≥20 years old; 1,332 <60 years old; 2,609 ≥60 years old) participating in the NHANES (1999–2002) study | PbB; - Mean (IQR): 1.7 (1.1, 2.5); - <60 years (IQR): 1.6 (1.0, 2.3); - ≥60 years (IQR): 2.2 (1.6, 3.1); - Tertiles:; ○ T1 (reference): ≤1.3; ○ T2: >1.3–2.2; ○ T3: >2.2; Analysis: GFR (mL/minute/1.73 m^2^) was estimated by several methods (creatinine-based MDRD, creatinine-based CKD-EPI, cystatin C single variable, multivariable and combined creatinine/cystatin C). Linear regression and logistic regression models were used to analyze data with log-transformed PbB or weighted tertiles. Models were adjusted for survey year, age, sex, race/ethnicity, BMI, education, smoking status (never, former, current), cotinine category, alcohol intake, hypertension, diabetes mellitus, and blood cadmium. | All participants: Negative trends (p-value range: 0.001–0.03) across the PbB range were observed for GFR for all except the CKD-EPI method. All methods showed associations between PbB and decreased GFR for T3. A 2-fold increase in PbB was associated with a decrease in GFR (mL/minute/1.73 m^2^) based on the following methods:; - Cystatin C single variable method: −1.9 (95% CI −3.2, −0.7); - Multivariable: −1.7 (−3.0, −0.5); - Combined creatinine/cystatin methods: −1.4 (−2.3, −0.5); - Creatinine-based MDRD method: −0.9 (−1.9, 0.02); - Creatinine-based CKD-EPI method: −0.9 (−1.8, 0.01); By tertiles for the cystatin C single variable method:; - T1: reference; - T2: −1.6 (−4.2, 1.0); - T3: −3.3 (−5.3, −1.4); - p-trend: 0.001; - ≥60 years: −4.5 (−5.6, −3.3); Participants ≥60 years old, adjusted ORs (95% CI) for reduced GFR by tertiles, based on cystatin C single variable method:; - T1: reference; - T2: 1.25 (0.86, 1.82); - T3: 1.57 (1.01, 2.46); - p-trend: 0.040; Participants <60 years old: No associations between PbB and decreased GFR or negative trends were observed for any GFR method (p-value for trends between 0.09 and 0.7).; Participants ≥60 years old: Negative trends (p-values <0.001) across the PbB range were observed for all GFR methods. All methods showed associations between PbB and decreased GFR for T2 and T3. Based on the cystatin C single variable method, a 2-fold increase in PbB was associated with a −4.5 (95% CI −5.6, −3.3) mL/minute/1.73 m2 decrease in GFR. Adjusted ORs for all GFR methods showed increased risk of decreased GFR for T3 for all GFR methods. For the combined cystatin C multivariable method, ORs were increased for both T2 and T3 [adjusted ORs (95% CI)]:; - T1: 1; - T2: 1.48 (1.04, 2.12); - T2: 2.02 (1.28, 3.17); - p-trend: 0.004; A 2-fold increase in PbB was associated with a 1.53 decreased in GFR (mL/minute/1.73 m^2^).
Staessen et al. 1992; Cross-sectional study of 1,981 adults (ages 20–88 years; 965 men; 1,016 women) in Belgium; data collection period was 1985–1989 | PbB; Mean (range); - Men: 11.4 (2.3–72.5); - Women: 7.5 (1.7–60.3); - p (difference between men and women): <0.001; Analysis: Data for CCr were analyzed by multivariate linear regression (with log-transformed PbB, adjusted for age, BMI, log γ-glutamyl transpeptidase, diabetes, and use of analgesics and diuretics. | An inverse relationship was observed between PbB and CCr (mL/L). A 10-fold increase in PbB was associated with decreases in calculated CCr (Cokcroft and Gault formula) of 13 and 30 mL/minute in men and women, respectively. Partial regression coefficients (SE) for CCr (mL/minute) per log µg /L:; - Men: −13.1 (4.0); p≤0.001; - Women: −30.1 (3.4); p≤0.001
Staessen et al. 2001; Cross-sectional study of 200 17-year-old adolescents (102 girls) from Belgium; 100 were in the exposed group and 100 were the control group; the exposed participants were from two locations (Exp1 group: Wilrijk, n=42; Exp2 group: Hoboken, n=58) | PbB; Mean (95% CI); - C (control): 1.4 (1.3, 1.6); - Exp1 (Wilrijk): 1.8 (1.6, 2.1); - Exp2 (Hoboken): 2.7 (2.4, 3.1); - p-values comparing; ○ C versus Exp1: 0.04; ○ C versus Exp2: <0.0001; ○ Exp1 versus Exp2: <0.0001; Analysis: Analysis of covariance with Bonferroni’s correction, adjusted for sex, BMI, weeks of breastfeeding, parental social class, and dietary fat intake, was used to compare serum cystatin C means across groups. | Serum cystatin C, mg/L, mean (SE); - C: 0.65 (0.08); - Exp1: 0.63 (0.08); - Exp2: 0.71 (0.08); - p-values comparing; ○ C versus Exp1: 0.13; ○ C versus Exp2: <0.0001; ○ Exp1 versus Exp2: <0.0001; A 2-fold increase in PbB was associated with a 3.6 (95% CI: 1.5, 5.7) percent increase in serum cystatin C.; Urine β2-microblobulin, µg/mmol creatinine, mean (95% CI); - C: 5.22 (4.59, 5.94); - Exp1: 5.30 (4.34, 6.48); - Exp2: 9.09 (7.67, 10.8); - p-values comparing; ○ C versus Exp1: 0.90; ○ C versus Exp2: <0.001; ○ Exp1 versus Exp2: p<0.001; A 2-fold increase in PbB was associated with a 16.0 (95% CI: 2.7, 31) percent increase in urine β2-microblobulin.
Tsaih et al. 2004; Prospective study of 448 subjects from the Normative Aging Study who had serum creatinine, blood lead, and bone lead measurements taken during the period 1991–1995 (baseline), with follow-up serum creatinine measurements made 4–8 years later; mean age of the study group was 66 years at the time of baseline evaluation and 72 years at follow-up | PbB; Mean (SD); - At baseline: 6.5 (4.2); - At follow-up: 4.5 (2.5); p<0.05; Analysis: Wilcoxon signed-rank test was used to compare of PbB at baseline and follow-up. SCr data were analyzed by log linear regression adjusted for age, age squared, BMI, hypertension, diabetes, smoking status, alcohol consumption, analgesic use, baseline serum creatinine, and serum creatinine squared. | No association was observed between PbB and longitudinal increases in SCr (mg/dL per ln µg Pb/dL):; - β=0.009 (SE 0.005); At baseline, an association was observed between ln PbB and changes in SCr in participants with diabetes (n=26), but not in participants with hypertension (n=115).; - β (diabetes): 0.076 (SE 0.023); p<0.05; - β (hypertension): 0.008 (0.010); At the follow-up assessment, an association was observed between ln PbB and changes in SCr in participants with hypertension (n=108), but not in participants with diabetes (n=24).; - β (diabetes): 0.223 (SE 0.183); - β (hypertension): 0.352 (SE 0.097); p<0.05
Yu et al. 2004; A prospective longitudinal study of 121 patients (mean age 57 years, range 2,582 years) with chronic renal insufficiency (without diabetes) and no history of occupational exposure to Pb; progression of renal insufficiency was evaluated for 48 months; patients were divided into those with high-normal body Pb burden (≥80–<600 µg, n=63) and low-normal body Pb burden (<80 µg, n=58) | PbB; At baseline, mean±SD (range); - All patients: 4.2±2.2 (1.0–13.4); - Low-normal body Pb burden <80 μg: 3.4±1.3 (1.2–6.3); - High-normal body Pb burden ≥80–<600 μg: 4.9±2.6 (1.0–13.4); p=0.0002; Analysis: Body Pb burden was estimated by EDTA mobilization. Cox proportional hazard model examined whether a predictor was associated with renal function including age, sex, BMI, hyperlipidemia, hypertension, smoking, use of ACE inhibitor, baseline serum creatinine, daily protein excretion, daily protein intake, and underlying kidney disease. | During the study period, an increased in PbB of 1 μg/dL was associated with a reduction in GFR of 4.0 mL/minute/1.73 m^2^ (p=0.0148).; Baseline mean±SE; - GFR: 36±9.8 mL/minute/1.73 m^2^; - SCr: 2.1±0.5 mg/dL; - CCr: 41.5±11.0 mL/minute/1.73 m^2^; At end of study period mean±SE; - GFR: 26.6±11.9 mL/minute/1.73 m^2^; - SCr: 3.0±1.6 mg/dL; - CCr: 31.0±13.6 mL/minute/1.73 m^2^

ACE = angiotensin-converting-enzyme; ACR = albumin-to-creatinine ratio; ANOVA = analysis of variance; BMI = body mass index; BUN = blood urea nitrogen; CCr = creatinine clearance; CI = confidence interval; CKD = chronic kidney disease; CKD-EPI = Chronic Kidney Disease Epidemiology Collaboration eGFR method; EDTA = ethylenediaminetetraacetic acid; F = female(s); GFR = glomerular filtration rate; HR = hazard ratio; IQR = interquartile range; M = male(s); MDRD = Modification of Diet in Renal Disease eGFR method; NHANES = National Health and Nutrition Examination Survey; NS = not statistically significant; OR = odds ratio; Pb = lead; Sβ2M = serum β2-microblobulin; SCr = serum creatinine concentration; SD = standard deviation; SE = standard error; UNAG = urine N-acetyl-β-D-glucosaminidase; UPHC = urine human complex-forming protein (α1-microglobulin)

a A variety of methods are used to estimate GFR (Chao et al. 2015). Each has limitations for application to both clinical evaluations and epidemiology. The preferred method is to measure the clearance of substance from plasma that is known to be eliminated solely by glomerular filtration and is not reabsorbed in the renal tubule. Typically, in the clinical setting, this is accomplished with intravenous administration of GFR markers, such as ^125^I-iothalmate for the radiocontrast agent (e.g., iohexol). These procedures are feasible in the clinical setting, but not in epidemiology studies in which invasive procedures and administration of such agents is not practical or possible. Clearance of endogenous creatinine is an alternative that has had wide use in epidemiology. However, it requires concurrent measurements of serum creatinine and the rate of urinary excretion of creatinine, which can be accurately determined only with a carefully timed urine sample that can represent the amount of glomerular filtrate formed over a given time interval. Achieving an accurately timed urine sample requires a rigidly implemented and supervised collection protocol, which is not always feasible, in particular in large scale epidemiology studies. Alternatives to clearance methods are measurement of endogenous metabolites in plasma whose clearance approximates GFR. Typically, this is achieved with endogenous creatinine or cystatin C. The serum concentration of these two metabolites strongly correlates with GFR; however, the relationship between creatinine or cystatin C concentration and GFR is also affected by other variables including age, sex, race, and for creatinine muscle mass. Several approaches have been developed to improve estimates of GFR from serum creatinine that attempt to account for these co-variables. These methods rely on multiple variable regression models that relate GFR to serum creatinine and other significant of determinants of GFR (Cockcroft and Gault 1976; Levey et al. 1999, 2009). An evaluation of two of the more commonly used methods for estimating GFR from serum creatinine, the CKD-EPI and MDRD equations, found that both achieved a median difference between calculated and measured GFR (from clearance measurements) that ranged from 2 to 6 mL/minute per 1.73 m^2^ (Levey et al. 2009). The interquartile range in the difference was approximately 18 mL/minute per 1.73 m^2^ in a validation dataset consisting of data for 3,986 study subjects. This suggests that approximately 25% of the GFR estimates from these methods are expected to be in error of true GFR by more than 18 mL/minute (or approximately 15% of the GFR in a healthy adult, 120 mL/minute).

Table 7 Epidemiology Studies Evaluating Endocrine Effects at Mean Blood Lead Concentrations (PbB) ≤10 µg/dL

Reference and study population | PbB (µg/dL) and analysis | Outcomes
Thyroid
Abdelouahab et al. 2008; Cross-sectional study of 211 adults (124 men and 87 women; ages 18–74 years) in Canada; data collection period: March–August 2003 | PbB:; Median (maximum):; - Men: 3.10 (20.9); - Women: 1.74 (12.5) (p<0.0001 compared to men); Analysis: Beta estimates were obtained from multiple regression analysis, adjusted for age, smoking and alcohol consumption, medications, and PCB congeners. PbB was log-transformed for parametric analyses. | A negative association was observed between PbB and TSH in women, but not men. No associations were observed between PbB and T3 or T4 in men or women. β per log µg/L:; - Total T3; ○ Men: 0.12; ○ Women: 0.15; - Total T4; ○ Men: −1.93; ○ Women: −0.36; - TSH; ○ Men: −0.05; ○ Women: −0.32 (p<0.05)
Chen et al. 2013; Cross-sectional study of 1,009 adolescents (ages 12–19 years) and 4,409 adults (≥20 years) participating in NHANES 2007–2008 | PbB:; Mean (range); - Adolescents: 0.93 (0.18, 9.20); - Adults: 1.75 (0.18, 33.1); Analysis: Data were analyzed by regression models with PbB and outcomes ln-transformed. Models were adjusted for age, sex, race/ethnicity, creatinine-adjusted urinary iodine, BMI z-score (adolescents only), BMI score (adults only), and serum cotinine level. | No associations between PbB and thyroid hormones were observed in adolescents or adults, Regression coefficients per 1 ln µg/dL (95% CI):; Adolescents:; - Ln-total T4: 0.01 (−0.02, 0.04); - Ln-FT4: 0.01 (−0.01, 0.04); - Ln-total T3: 0.01 (−0.01, 0.04); - Ln-FT3: 0.02 (−0.002, 0.04); - Ln-TSH: −0.05 (−0.18, 0.07); - Ln-Tg: 0.05 (−0.13, 0.24); Adults:; - Ln-total T4: −0.01 (−0.02, 0.01); - Ln-FT4: 0.01 (−0.01, 0.02); - Ln-total T3: −0.0004 (−0.02, 0.02); - Ln-FT3: 0.01 (−0.001, 0.02); - Ln-TSH: −0.01 (−0.06, 0.04); - Ln-Tg: 0.01 (−0.03, 0.06)
Dundar et al. 2006; Cohort study of 42 Pb-exposed adolescent auto repair workers (mean age 16.5 years) and 55 controls (mean age 16.2 years) from Turkey; data collection period not reported | PbB:; Mean (SD):; - Workers: 7.3 (2.92); p<0.05 compared to controls; - Controls: 2.08 (1.24); Analysis: Comparison between groups were made using Student’s t test. Data were analyzed using Spearman correlation analysis and nonlinear multivariable regression analysis. | Comparison of hormone levels between groups, mean (SD); - FT4 (ng/mL):; ○ Control: 1.12 (0.14); ○ Workers: 1.02 (0.18); p<0.05; - FT3 (ρg/mL); ○ Control: 3.70 (0.29); ○ Workers: 3.68 (0.41); - TSH (mU/L); ○ Control: 1.90 (0.73); ○ Workers: 1.97 (1.13); - Thyroid volume (mL):; ○ Control: 12.3 (5.10); ○ Workers: 11.36 (3.12); Negative correlations were found between PbB levels and FT4 levels.; - Spearman correlation analysis: r: −0.20; p=0.044; - nonlinear multivariable regression analysis: r: −0.27; p=0.048
Iijima et al. 2007; Cross-sectional study of 24 mother-infant pairs in Japan; data collection period: January–December 2005 | PbB:; Umbilical mean (SD): 6.3 (3.4); Range: 0.23–12; Analysis: Associations between PbB and FT4 and TSH were analyzed using Spearman rank correlation coefficients. No adjustments for potential confounding factors were reported. | No associations (p>0.05) were observed between PbB and FT4 or TSH levels. Spearman rank correlation coefficient:; - FT4: 0.263; - TSH: 0.174
Luo and Hendryx 2014; Cross-sectional study of 6,231 adults (≥20 years) from the NHANES 2007–2010 | PbB:; Mean: 1.82; Range: 0.18–33.10; Tertiles:; - T1: 0.18–1.09; - T2: 1.10–1.88; - T3: 1.89–33.10; *Note reporting inconsistency for T1 and T2 ranges (ranges for T1 and T2 also reported as 0.18–1.26 and 1.27–1.88, respectively).; Analysis: Data were analyzed using multiple linear regression models, adjusted for age, sex, race/ethnicity, serum cotinine, BMI, and creatinine-adjusted urinary iodine. | A positive association was observed between PbB and FT3, but not other thyroid hormones. Regression coefficient β (95% CI) per tertile, with T1 as the reference:; - FT4 (ng/dL):; ○ T2: 0.001 (−0.16, 0.14); ○ T3: −0.09 (−0.28, 0.11); - FT3 (ρg/mL):; ○ T2: 0.03 (0.001, 0.07); ○ T3: 0.04 (0.01, 0.08); p<0.01; - Ln-TSH (uIU/mL):; ○ T2: 0.01 (−0.05, 0.07); ○ T3: 0.02 (−0.06, 0.09); - Ln-Tg (ng/mL):; ○ T2: 0.04 (−0.04, 0.13); ○ T3: 0.02 (−0.07, 0.12)
Mendy et al. 2013; Cross-sectional study of 4,652 adults (≥20 years; mean 51 years) from the NHANES 2007–2008 | PbB:; Mean±SE (range): 1.52±1.20 (0.18–33.12); Analysis: Relationships between ln-PbB were analyzed by linear regression adjusted for age, sex, race/ethnicity, smoking, alcohol consumption, BMI, physical activity, medications, and bone density. | Increased ln-PbB was associated with decreased total T4, but not total T3, FT3, FT4, or TSH. Linear regression coefficient β (95% CI) for ln µg/dL:; - Total T4: −0.22 (−0.34, −0.09); p<0.01; - FT4: 0.00 (−0.01, 0.02); - Total T3: −1.05 (−3.08, 0.98); - FT3: 0.02 (−0.01, 0.05); - TSH: 0.02 (−0.12, 0.16)
Ngueta et al. 2018; Cross-sectional study of 65 adults (51% male, 49% female), aged 50–57 years from Canada | PbB:; Low PbB mean: 1.65 (all <2.48 (n=30); Higher PbB mean: 3.60 (range: >2.48–8.5) (n=35); Analysis: Relationships between PbB and basal salivary cortisol and acute cortisol stress response were evaluated by linear regression mixed models. Adjustments included sex, age, waist:hip ratio, family income levels, and current smoking status. | No differences were observed between the low and high PbB groups and cortisol levels evaluated at several time points from awakening to bedtime.; No association was observed between PbB and basal cortisol levels or cortisol levels under stress. Adjusted regression coefficient β (SE):; - Basal cortisol: −0.01 (0.02); p=0.26; - Stress cortisol: −0.01 (0.1); p=0.43
Nie et al. 2017; Cross-sectional study of 5,628 Chinese adults (2,278 men, mean age 53 years; 3,350 women, mean age 54 years; data collection period: February–June 2014 | PbB:; Men; Gmean (GSD): 4.1 (0.20); Tertiles; - T1: <3.4; - T2: 3.4–5.5; - T3: >5.5; Women:; Gmean (GSD): 3.5 (0.20); Tertiles; - T1: <2.9; - T2: 2.9–4.8; - T3: >4.8; Analysis: Relationships between PbB and TSH and thyroid antibodies were analyzed by linear and logistic regression models, adjusted for Cd, age, BMI, smoking status (men only), and alcohol consumption. | An association was observed between PbB and thyroid peroxidase antibodies and TSH for women, but not men. No association was observed for thyroglobulin antibodies for men or women.; ORs (95% CI) for lnPbB by thyroid peroxidase antibodies (TPOAb) tertile:; Men; - TPOAb T1: 1 (reference); - TPOAb T2: 1.02 (0.87, 1.29); - TPOAb T3: 1.11 (0.95, 1.29); Women; - TPOAb T1: 1 (reference); - TPOAb T2: 1.38 (1.21, 1.59); p<0.001; - TPOAb T3: 1.35 (1.20, 1.53); p<0.001; ORs (95% CI) for lnPbB by thyroglobulin antibodies (TGAb) tertile:; Men; - TGAb T1: 1 (reference); - TGAb T2: 1.07 (0.86, 1.32); - TGAb T3: 0.89 (0.77, 1.03); Women; - TGAb T1: 1 (reference); - TGAb T2: 1.09 (0.95, 1.24); - TGAb T3: 1.05 (0.93, 1.18); β (95% CI) for TSH; - Men: −0.020 (−0.059, 0.020); p=0.324; - Women: 0.047(0.012, 0.081); p=0.008
Yorita Christensen 2013; Cross-sectional study of 1,587 adults (mean 51 years) from the NHANES 2007–2008 | PbB:; Median (25^th^, 75^th^ percentiles): 1.3 (0.9, 2.1); Analysis: Multivariate linear regression was used to model the association between thyroid hormone levels and PbB, adjusted for age, sex, race/ethnicity, BMI, total serum lipids, serum cotinine, pregnancy and menopausal status, and use of medications potentially affecting thyroid function. | β (SE) for association with ln µg/dL; - Ln-Total T4: −0.028 (0.013); p<0.05; - Ln-FT4: −0.004 (0.012); - Ln-Total T3: 0.003 (0.012); - Ln-FT3: 0.011 (0.007); - Ln-TSH: 0.014 (0.043)
Cortisol
Braun et al. 2014; Cross-sectional study of 918 pregnant Women (18–44 years; mean age 27.8 years) from Mexico City; data collection period: 2007–2011 | PbB:; Mean (SD): 3.7 (2.7); Range: 0.5–23; Quintiles:; - Q1: 0–<1.8; - Q2: 1.8–<2.4; - Q3: 2.4–<3.4; - Q4: 3.4–<5.1; - Q5: ≥5.1; - Continuous: per 2.5 µg/dL; Maternal tibia Pb concentration (µg/g); mean (SD): 2.7 (8.4); Maternal patella Pb concentration (µg/g); mean (SD): 4.6 (8.6); Analysis: PbB was measured during the 2^nd^ trimester of pregnancy. Cortisol salivary levels were assessed using 10 timed collections. Cortisol awakening response was by change in the cortisol concentration between the first and second saliva samples of each day. Cortisol levels were log_10_-transformed and data were analyzed by linear mixed models, adjusted for maternal age, education, BMI, marital status, gestational age at time of cortisol collection, parity (1, 2, 3, or 4+), and maternal smoking status during pregnancy. | Salivary cortisol AUC concentrations did not vary with blood or bone Pb concentrations. Percent difference in cortisol AUC per PbB quintiles, nmol-hour (95% CI):; - Q1: 1 (reference); - Q2: 8 (−1, 18); - Q3: 9 (0, 19); - Q4: 8 (−1, 18); - Q5: 2 (−6, 12); - Continuous: −1 (−4,1); Cortisol awakening response was decreased in Q5, compared to Q1, β (SE):; - Q1: 1 (reference); - Q2: 0.00 (−0.06, 0.06); - Q3: 0.01 (−0.05, 0.07); - Q4: −0.04 (−0.11, 0.02); - Q5: −0.06 (−0.12, 0.00); - Continuous: −0.02 (−0.04, 0.00)
Gump et al. 2008; Prospective study of 169 children from Oswego, New York; data collection period not reported | PbB:; Prenatal quartiles:; - Q1: ≤1; - Q2: 1.1–1.4; - Q3: 1.5–1.9; - Q4: 2.0–6.3; Postnatal quartiles:; - Q1: 1.5–2.8; - Q2: 2.9–4.1; - Q3: 4.2–5.4; - Q4: 5.5–13.1; Analysis: Umbilical cord blood was used as the measure of prenatal PbB. Postnatal PbB was measured at 2–3 years of age. Cortisol response to stress (to cold challenge), measured by salivary cortisol levels, was assessed at 9.5 years of age. Regression analysis was conducted with adjustments for SES-related factors, HOME score, pregnancy health, and maternal substance abuse. | Associations were observed between increased salivary cortisol response to stress and PbB for prenatal PbB Q2–Q4 and postnatal PbBQ4, compared to respective Q1. No numeric data for quartiles were reported; data were presented graphically.
Vitamin D
Kemp et al. 2007; Cross-sectional study of 142 urban African-American (n=91) and Hispanic (n=51) children (ages 1–8 years) from New Jersey; data collection periods were December 2001–March 2002 for winter and July–September 2002 for summer | PbB:; Mean (SE); - 1–3 year-old children (n=78):; ○ Winter: 4.94 (0.45); ○ Summer: 6.54 (0.82); p=0.0019 compared to winter PbB; - 4–8 year-old children (n=64):; ○ Winter: 3.68 (0.31); ○ Summer: 4.16 (0.36); p<0.0001 compared to winter PbB; Analysis: This study evaluated relationships to seasonal increased PbB and vitamin D nutrition, age, and race. Data comparing groups were analyzed by paired t-tests. | An increase (approximately 45%; p<0.05; data presented graphically) in 25-OH-D in summer compared to winter was observed in African-American children ages 4–8 years, but not in African-American children ages 1–3 years or in Hispanic children of any age.; Study authors concluded that “higher summertime increase in serum 1,25-(OH)2D3 levels in children between ages 4 and 8 years is most likely due to increased sunlight-induced vitamin D synthesis and may contribute to the seasonal increase in blood lead.”
Diabetes
Moon 2013; Cross-sectional study of 1,588 men and 1596 women (age ≥30 years) participating in the Korea National Health and Nutritional Examination Surveys 2009–2010 | PbB:; Mean (SE), quartiles:; - Q1 (<25^th^ percentile): 1.43 (1.01); - Q2 (25^th^–<50^th^ percentile): 2.13 (1.00); - Q3 (50^th^–<75^th^ percentile): 2.74 (1.00); - Q4 (≥75^th^ percentile): 4.08 (1.01); Analysis: Diabetes was defined as fasting plasma glucose levels ≥126 µg/dL, currently on diabetes treatment, or reported history of physician diagnosed diabetes. Prevalence of diabetes was analyzed by logistic regression, adjusted for age, sex, region (rural or urban), smoking, alcohol consumption, and regular exercise. | Risk of diabetes was not associated with PbB. ORs (95% CI) for diabetes:; - Q1: 1 (reference); - Q2: 0.908 (0.641, 1.288); - Q3: 0.759 (0.531, 1.086); - Q4: 0.745 (0.516, 1.077); - p-trend=0.336
Insulin-like growth factor
Fleisch et al. 2013; Prospective study of 394 boys (age at initial visit: 8–9 years) from Russia; initial visit: 2003–2005 | PbB:; Median (range): 3 (0.5–31); Quartiles:; - Q1 (n=109): ≤2; - Q2 (n=176): 3–4; - Q3 (n=97): 5–9; - Q4 (n=12): ≥10; Analysis: PbB was obtained at ages 8–9 years and IGF-1 levels were measured at ages 10–11 and 12–13 years. Repeated measures analysis to estimate the association between baseline PbB and serum IGF-1 concentrations at ages 10–11 and 12–13 years. Adjusted for parental education, birth weight, nutritional intake, and baseline and follow-up age and BMI. | PbB was associated with decreased serum IGF-1 (ng/mL) levels Q3 and Q4 compared to Q1 at the age 10–11-year assessment. Mean serum IGF-1 (95% CI):; - Q1: 1 (reference); - Q2: −12.8 (−29.9, 4.4); p=0.15; - Q3: −34.5 (−53.1, −16.0); p>0.001; - Q4: −60.4 (−90.9, −29.9); p<0.001; Each unit increase in ln-PbB was associated with a 22.2 g/mL decrease in mean serum IGF-1 (95% CI: −33.9, −10.6).

AUC = area under the salivary cortisol concentration-time curve; BMI = body mass index; CI = confidence interval; Cd = cadmium; FT3 = free T3; FT4 = free T4; Gmean = geometric mean; GSD = geometric standard deviation; HOME = Home Observation for Measurement of the Environment; IGF-1 = insulin-like growth factor-1; NHANES = National Health and Nutrition Examination Survey; OR = odds ratio; Pb = lead; PCB = polychlorinated biphenyl; SD = standard deviation; SE = standard error; SES = socio-economic status; T3 = triiodothyronine; T4 = thyroxine; Tg = thyroglobulin; TSH = thyroid stimulating hormone

Table 8 Selected Epidemiology Studies Evaluating Immunological Effects at Mean Blood Lead Concentrations (PbB) ≤10 µg/dL

Reference and study population | PbB (µg/dL) and analysis | Outcomes
Susceptibility to infections
Krueger and Wade 2016; Cross-sectional study of 5,994 subjects (age ≥3 years) from NHANES, 1999–2012 | PbB:; Gmean (95% CI): 1.50 (1.43, 1.57); CdB (µg/dL):; Gmean (95% CI): 0.33 (0.31, 0.36); Analysis: Seropositivity for Heliobacter pylori, Toxoplasma gondii, and Hepatitis B virus. Multiple logistic regression. Adjustments made for age, sex, race/ethnicity, country of birth origin, family income, self-reported general health condition, tap water source, household crowding, and use of illicit/street injected drugs. | Trend (p<0.0001) for increasing OR with increasing PbB or CdB. No interaction between PbB and CdB on OR. Adjusted OR (95% CI) for a doubling of PbB:; - H. pylori: 1.22 (1.12, 1.34), p<0.05; - T. gondii: 1.19 (1.12, 1.28), p<0.05; - Hepatitis B virus: 1.19 (1.08, 1.32), p<0.05
Park et al. 2019; Cross-sectional study of 2,625 adults (mean age: 52.3 years; 1,752 men; 873 women) from South Korea; data collection period: 2014–2016 | PbB:; Mean (SD): 2.83 (1.31); Range: 0.13–9.87; Analysis: Gastrointestinal endoscopy was performed and histopathological assessments were conducted to determine the prese or absence of H. pylori. PbB data were natural log transformed. ORs were determined by multiple regression analysis adjusted for age, smoking, alcohol use, BMI, hypertension, diabetes mellitus, and exercise. | The risk of H. pylori infection increased with PbB. OR (95% CI): 1.143 (1.068, 1.223), p<0.001
Sensitization
Jedrychowski et al. 2011; Prospective study of 224 children (at 5 years of age) of women recruited in the 2^nd^ trimester of pregnancy (2001–2004, Poland) | PbB: Gmean (95% CI):; Cord: 1.16 (0.12, 1.22); Maternal: 1.60 (1.52, 1.67); Analysis: Atopic status evaluated at age 5 years for reaction to airborne allergens. Logistic regression. Adjustments made for sex, parity, maternal age, maternal education, maternal atopy, and ETS variables. | Increased risk of atopy in association with increasing cord PbB. Adjusted RR (95% CI):; - Cord PbB: 2.28 (1.12, 4.62); - Maternal PbB: 1.72 (0.98, 3.00)
Pizent et al. 2008; Cross-sectional study of 216 adults (age range 19–67 years) | PbB median (range):; - Male: 3.17 (0.99, 7.23); - Female: 2.16 (0.56, 7.35); Analysis: Skin prick test to common aeroallergens. Logistic regression with log_10_ transformed PbB. Adjustments made for age, smoking, alcohol use, log PbB, log CdB, SCu, SZn, SSe, GPx, and SOD. | Increasing PbB was associated with decreasing adjusted OR for positive skin prick test (95% CI): 0.92 (0.86, 0.98)
Humoral immunity
Karmaus et al. 2005; Cross-sectional study of 671 children (age 7–10 years) in Germany | PbB Gmean (95% CI):; - Males: 2.78 (1.48, 4.82); - Females: 2.54 (1.10, 4.38); Analysis: Serum IgA, IgE, IgG and IgM and B-cell abundance. ANOVA and multiple linear regression. Adjustments made for age, sex, ETS, number of infections during the last 12 months, lipid concentration, and breastfeeding. | Mean serum IgE levels were higher in PbB strata >2.84 and >3.41 µg/dL.; B-cell abundance was lower (p≤0.05) in PbB stratum 2.21–2.83 compared to <2.2 µg/dL. No dose-response relationship was observed between PbB and B-cell abundance.
Min and Min 2015; Cross-sectional study of 4,287 adults (age ≥22 years) from NHANES 2005–2006 | PbB Gmean (95% CI):; - 1.46 (1.44, 1.50); Analysis: Serum total IgE and antigen-specific IgEs. Multiple linear regression with log_10_ transformed PbB. Adjustments made for age, sex, race/ethnicity, family income, cigarette smoking, the presence of allergic disease, and BMI. | An association was observed between increasing serum IgE and increasing PbB. β for 1 log10 increase in IgE per 1 log_10_ increase in PbB (95% CI):; - Q2 (1.1–1.69 µg/dL): 0.20 (0.05, 0.34); - Q3 (1.7–2.6 µg/dL): 0.26 (0.10, 0.42); - Q4 (2.61–26.4 µg/dL): 0.35 (0.20, 0.51)
Pizent et al. 2008; Cross-sectional study of 216 adults (age range 19–67 years) | PbB median (range):; - Male: 3.17 (0.99, 7.23); - Female: 2.16 (0.56, 7.35); Analysis: Serum IgE. Multiple linear regression with log_10_ transformed PbB. Adjustments made for age, smoking, alcohol use, log PbB, log CdB, SCu, SZn, SSe, GPx, and SOD. | In females not taking oral contraceptives or hormone replacement therapy, increasing PbB was associated with increasing serum IgE. β log increase in IgE per log increase in PbB µg/L (SE): 0.600 (0.298), p=0.046
Sarasua et al. 2000; Cross-sectional study of 1,561 residents of communities with elevated levels of cadmium or Pb in soil and 480 residents of comparison communities (age range 6 months–75 years) (1991) | PbB mean (5^th^–95^th^ percentile range) for combined resident and comparison communities:; - Age 6–35 months: 7.0 (1.7, 16.1); - Age 36–71 months: 6.0 (1.6, 14.1); - Age 6–15 years: 4.0 (1.1, 9.2); - Age 16–75 years: 4.3 (1.0, 9.9); Analysis: B-cell abundance and serum IgA, IgG, and IgM. Multiple linear regression. Adjustments made for age (continuous), sex, study site, and smoking. | A positive association was observed between increasing PbB and serum IgA, IgG, and IgM, and B-cell abundance. β per 1 µg/dL PbB:; Age 6–35 months:; - IgA (mg/dL): 0.8, p<0.01; - IgG (mg/dL): 4.8, p<0.01; - IgM (mg/dL): 1.0, p=0.03; - B-cell count: 16.9, p<0.01; - B-cell%: 0.19, p=0.02; Age 6–15 years:; - IgG (mg/dL): 7.5, p=0.02
Wang et al. 2017a; Cross-sectional study of 930 children (mean age: 5.74 years; 469 boys and 461 girls) | PbB Gmean (GSD); - All: 1.86 (1.21); - Boys: 1.88 (1.22); - Girls: 1.83 (1.20); Analysis: IgE data were ln-transformed analyzed by linear regression, adjusted for age, maternal age, maternal history of atopy, maternal nationality, parental education and occupation, family income, number of siblings, breast feeding, environmental tobacco smoke, incensing at home, dehumidifier at home, new paintings of houses, and residence using groundwater | For all participants and boys (but not girls), a one ln-unit increase in PbB (equal to 2.72 µg/dL) was positively associated with serum IgE. Regression coefficient β (95% CI):; - All: 0.26 (0.009, 0.50); p=0.042; - Boys: 0.40 (0.03, 0.76); p=0.036; - Girls: 0.02 (−0.35, 0.40); p=0.901
Wells et al. 2014; Cross-sectional study of 1,788 children (age 2–12 years) from NHANES 2005–2006 | PbB Gmean (95% CI):; - 1.13 (1.04, 1.22); Analysis: Percent eosinophils. Multiple linear regression. Adjustments made for season, age, sex, race/ethnicity, education, passive smoke exposure, BMI, cockroaches, and avoidance/removal of pets. | An association was observed between increasing serum IgE and increasing PbB. β for percent increase per 1 µg/dL (95% CI): 10.27 (3.52, 17.47)
Xu et al. 2015; Cross-sectional study of 590 children (age 3–7 years) evaluated 2011–2012 | PbB Gmean (SD of log PbB):; - Total exposed: 6.76 (0.18); - Male: 6.61 (0.19); - Female: 6.16 (0.18); Analysis: Hepatitis B virus surface antibody titers following immunization at birth and age 6 months and 1 year. Multiple linear and mixed effects regression. Adjustments made for age and sex. | Hepatitis B virus surface antibody titers decreased with increasing PbB β signal to cutoff ratio per 1 µg/dL (SE) at two assessment dates:; - 2011: −0.4467 (0.0225), p<0.001; - 2012: 0.3661 (0.0193), p<0.001
Cell-mediated immunity
Boscolo et al. 2000; Cross-sectional study of 30 atopic women (age range 19–49 years) and 30 non-atopic women in Italy | PbB: median (25^th^–75^th^ percentile range:; - Atopic: 6.4 (4.9, 7.9); - Control: 5.5 (4.4, 6.7); Analysis: Abundances of CD4+, CD3+, CD8+, CD45+, and HLA-DR+. Spearman correlation. No adjustments. | Positive correlation between PbB and T-cell abundances in non-atopic subjects (r for cell count):; - CD4+ CD45RO-: 0.464, p<0.05; - CD3+ CD8+: 0.430 p<0.05; - CD3− HLA-DR+>: 0.435, p<0.05
Conterato et al. 2013; Cross-section study of battery manufacture workers (59), automobile painters (23), and control workers (36), age 15–61 years, in Brazil | PbB mean (SE):; - Battery workers: 49.8 (4.0); - Painters: 5.4 (0.4); - Controls: 1.5 (0.1); Analysis: Abundances of lymphocytes, neutrophils, eosinophils. ANOVA and Spearman’s rank correlation. No adjustments. | Neutrophil abundance was lower in Pb workers comparted to controls, mean (SE), 10^3^/mm^3^:; - Battery workers: 2.87 (0.27), p<0.05; - Painters: 3.07 (0.13), p<0.05); - Controls: 3.75 (2.49); Neutrophil abundance was negatively correlated with PbB.
Hsiao et al. 2011; Cross-sectional study of 214 children, enrolled in primary school grades 5–6, China | PbB Mean (SD):; - Allergic and residing near oil refinery: 8.80 (0.45); - Non-allergic and residing near oil refinery: 5.23 (0.36); - Other rural or urban groups, allergic or not: 3.16–3.83; Analysis: Serum T-helper cell cytokines: IFN-γ, interleukins IL 4, IL-5, and IL-12. Unspecified comparison of means. No adjustments. | Compared to all other groups, the allergic group residing near the refinery (mean PbB 8.80 ± 0.45 SD µg/dL) had (p<0.05) lower serum IFN-γ and IL-12 (>96% decrease) and higher serum IL-4 and IL-25 (>500% increase).
Karmaus et al. 2005; Cross-sectional study of 67 children (age 7–10 years) in Germany | PbB Gmean (95% CI):; - males: 2.78 (1.48, 4.82); - females: 2.54 (1.10, 4.38); Analysis: T-cell abundance ANOVA and multiple linear regression. Adjustments made for age, sex, ETS, number of infections during the last 12 months, lipid concentration, and breastfeeding. | Total T-cell and T_C_ abundances were lower (p≤0.05) in PbB stratum 2.21–2.83 µg/dL compared to <2.2 µg/dL.; No differences in TH or NK cell abundances were observed.; No dose-response relationship was observed between PbB and total T-cell abundances.
Sarasua et al. 2000; Cross-sectional study of 1,561 residents of communities with elevated levels of cadmium or Pb in soil and 480 residents of comparison communities (age range 6 months–75 years) (1991) | PbB mean (5^th^–95^th^ percentile range) for combined resident and comparison communities:; - age 6–35 months: 7.0 (1.7, 16.1); - age 36–71 months: 6.0 (1.6, 14.1); - age 6–15 years: 4.0 (1.1, 9.2); - age 16–72 years: 4.3 (1.0, 9.9); Analysis: T-cell and NK-cell abundances. Multiple linear regression. Adjustments made for age (continuous), sex, study site, and smoking. | An inverse association between increasing PbB and decreasing T-cell abundance β per 1 µg/dL PbB:; Age 6–35 months:; - T-cell%: −0.18, p=0.03; - T-cell count: 7.2, p=0.59; - NK-cell%: 0.00, p=0.99; - NK-cell count: 1.3, p=0.60
Wells et al. 2014; Cross-sectional study of 1,788 children (age 2–12 years) from NHANES 2005–2006 | PbB Gmean (95% CI):; - 1.13 (1.04, 1.22); Analysis: Eosinophil abundance. Multiple linear regression. Adjustments made for 6-month season, age, sex, race/ethnicity (non-Hispanic white/non-Hispanic black/other), parental educational status (<high school, high school, some college, 4-year college degree), presence of smokers in the home (IgE only) or prenatal smoke exposure (asthma only), BMI, cockroaches, and avoidance/removal of pets. | An association between increasing percent eosinophils in blood and increasing PbB was observed. β for % increase per 1 µg/dL (95% CI): 4.61 (2.44, 6.83)
Inflammation
Kim et al. 2007; Cross-sectional study of 300 adults (mean age 24±2 years) recruited in 2002 in Korea | PbB mean (range):; - Q1: 1.46 (0.337,1.885); - Q2: 2.22 (1.886, 2.511); - Q3: 2.77 (2.513, 3.103); - Q4: 3.93 (3.110, 10.470); Analysis: Serum TNFα and IL-6, GSTM1 and TNFα genotypes, and WBC. Comparison of means (Chi-square, ANOVA) and multiple linear regression. Adjustments made for age, BMI, and smoking. | In male subjects, increased PbB was associated with increasing serum TNFα and WBC in the PbB stratum >2.51 µg/dL. β % increase per µg/dL (95% CI):; - TNFα: 23 (4, 55), p=0.015; - IL-6: 26 (0, 55), p=0.082; - WBC: 15 (0, 35), p=0.004; When stratified by genotype, the effect of PbB was associated only in the TNFα GG and GSTM1-null genotypes.
Sirivarasai et al. 2013; Cross-sectional study of 924 male adults (mean age 43±25 years) enrolled in EGAT 1 study of cardiovascular disease conducted in 2009, Thailand | PbB: Mean (range):; - 5.45 (1.23, 24.63); Analysis: Human serum CRP and GST genotypes. ANOVA for CRP, logistic regression for effect of GST genotype on CRP. Adjustments made for age, BMI, smoking, alcohol use, and blood pressure. | CRP was higher in upper quartile PbB stratum compared to Q1 and Q2 (p<0.001). In Q4 stratum, adjusted OR was elevated for GSTM1 and GSTT1 null genotypes (95% CI):; - -GSTM1-/- and GSTT1-/-: 1.98 (1.47, 2.55); - -GSTM1-/-: 1.32 (1.03, 1.69); - -GSTT1-/-: 1.65 (1.17, 2.35)
Songdej et al. 2010; Cross-sectional study of 9,145 adults (age >40 years) from NHANES 1999–2004 | PbB:; Gmean: 1.89; Analysis: WBC and serum CRP and fibrinogen. Logistic regression. Adjustments made for age, BMI, smoking status, income, physical activity, ethnicity, education, and a history of inflammatory conditions, cardiovascular disease, and diabetes. | Adjusted ORs for elevated CRP were elevated in males, with no trend increasing PbB. ORs for fibrinogen or WBC were not elevated. OR (95% CI) for <1.16 versus >3.09 µg/dL:; CRP; - Males: 2.85 (1.49, 5.45); - Females: 0.57 (0.43, 0.76); Fibrinogen:; - Males: 1.15 (0.61, 2.16); - Females: 0.87 (0.57, 1.33); WBC:; - Males: 1.55 (0.96, 2.49); - Females: 0.84 (0.62, 1.13)

ANOVA = analysis of variance; BMI = body mass index; CdB = blood cadmium; CI = confidence interval; CL = confidence limit; CRP = C-reactive protein; EGAT 1 = Electric Generating Authority of Thailand study; ETS = environmental tobacco smoke; Gmean = geometric mean; GPx = glutathione peroxidase; GST = glutathione-s-transferase; GSTM1 = glutathione S-transferase mu 1; GSTT1 = glutathione S-transferase theta 1; IFN = interferon; Ig = immunoglobulin antibody; IL = interleukin; NHANES = National Health and Nutrition Examination Survey; NK = natural killer; OR = odds ratio; RR = relative risk; SCu = serum copper; SD = standard deviation; SE = standard error; SOD = superoxide dismutase; SSe = serum selenium; SZn = serum zinc; TNFα = tumor necrosis factor-alpha; WBC = white blood cell

Table 9 Selected Epidemiology Studies Evaluating Neurodevelopmental Effects in Children at Mean Blood Lead Concentrations (PbB) ≤10 µg/dL

Reference and study population | PbB (µg/dL) and analysis | Outcomes
Intellectual deficits
Baghurst et al. 1992; Prospective cohort of 494 children followed from birth (1979–1982) to age 7 years; Port Pirie, South Australia | PbB:; Quartile range:; - Birth: 4.3, 15.0; - Mean 0–2 years: 11.6, 27.1; - Mean 0–3 years: 12.2, 28.2; - Mean 0–4 years: 12.2, 27.7; - Lifetime average:10.8, 24.8; Analysis: Cognitive function (IQ) was assessed at age 7–8 years using WISC-R. Multiple linear regression with log-transformed PbB. Adjustments made for sex, birth weight, birth order, feeding method (breast, bottle, or both), duration of breastfeeding, parents’ level of education, maternal age at delivery, parents’ smoking status, SES, quality of home environment, maternal IQ, and whether the child’s natural parents were living together. | Associations between increasing PbB and decreasing FSIQ measured at age 7–8 years. Adjusted changes in IQ for each lnPbB increase. β (SE) for PbB metrics:; - Prenatal: 0.6 (1.4), p=0.68; - Mean 0–2 years: −4.6 (2.1), p=0.03; - Mean 0–3 years: −4.8 (2.3), p=0.04; - Mean 0–4 years: −4.6 (2.4), p=0.05; - Lifetime average: −3.7 (2.5), p=0.14
Bellinger et al. 1992; Bellinger and Needleman 2003; Prospective cohort 148 children followed from birth (1979–1981) to age 10 years; Boston, Massachusetts | PbB:; Mean (SE):; - 6 months: 6.7 (7.0); - 1 years: 7.7 (6.5); - 2 years: 6.5 (4.9); Analysis: Cognitive function was assessed at age 5–10 years using WISC-R. Multiple linear regression. Adjustments made for HOME57, HOME120, child stress, race, maternal IQ, SES, sex, birth order, marital status, and number of residence changes prior to age 57 months. | Associations between increasing PbB at age 2 years and decreasing FSIQ measured at age 10 years.; Adjusted changes in IQ for each 1 μg/dL increase in PbB. β (SE) for PbB metrics:; - Prenatal: −2.55 (2.56), p=0.57; - 6 months: −0.13 (0.15), p=0.39; - 2 years: −0.58 (0.21), p<0.007; - Peak <10 µg/dL: −1.56 (p=0.03); - Peak >10 µg/dL: −0.58 (p=NA)
Blackowicz et al. 2016; Retrospective study of 12,319 3^rd^ grade Hispanic children (Chicago); data collection period: 1996–2006 | PbB:; Mean (SD); 4.16 (2.03); Analysis: Educational performance was based on scores on 3^rd^ grade ISAT. Linear and log binomial regression. Adjustments were made for gender, mother’s education, low-income, small for gestational age, preterm birth, age at time of blood lead, exam type, and Hispanic subgroup (Mexican American, Puerto Rican, other Hispanic). | Increased PbB was associated with lower ISAT score in each Hispanic subgroup Adjusted β (SE) for µg/dL (All Hispanic group):; - Reading ISAT: −0.55 (0.06), p<0.001; - Math ISAT: −0.48 (0.06), p<0.001; Increased PbB was associated with increased risk of failure on ISAT in each Hispanic subgroup. Adjusted RR (95% CI) for All Hispanic group:; - Reading ISAT:; ○ 1 µg/dL increase: 1.07 (1.05, 1.10); ○ 5 µg/dL increase: 1.43 (1.25, 1.63); - Math ISAT; ○ 1 µg/dL increase: 1.09 (1.06, 1.12); ○ 5 µg/dL increase: 1.53 (1.32, 1.78)
Boucher et al. 2014; Prospective cohort of 94 infants from the Canadian Arctic (Nunavik); data collection period was 1995–2001 | PbB:; Umbilical cord PbB; - Mean (SD): 4.8 (3.5); - Range: 0.5–17.8; Analysis: Neurodevelopmental assessments (FTII, A-not-B test, BSID-II) were conducted at ages 6.5 and 11 months. Adjustments made for infant sex, infant age at testing, birth weight, maternal age, parity, social environment, maternal consumption of cigarettes, alcohol, and/or marijuana during pregnancy, cord plasma DHA, and cord blood Se. | Fixation duration (not specified if assessment time was 6.5 or 11 months) was associated with umbilical cord (ln) PbB, indicating slower information processing time. β (95% CI): 0.21 (0.07, 0.35); p≤0.01.
Braun et al. 2012; Prospective cohort of 1,035 mother-infant pairs from Mexico City; child PbB was collected from four cohorts (data collection period: 1994–2004) | PbB:; Median (5^th^, 95^th^ percentile) at age:; - 1 years: 4.2 (1.3, 10.6); - 2 years: 4.6 (1.5, 13.4); - 3 years: 5.5 (2.3, 13.8); - 4 years: 5.9 (2.5, 12.8); Analysis: PbB was collected at ages 1–4 years. Cognitive abilities (GCI) were conducted at age 4 years. Multiple linear regression. Adjustments made for maternal IQ, education, marital status, child sex, breastfeeding duration, and cohort. | Associations between increasing PbB and decreasing GCI assessed at age 4 years. Coefficient (95% CI) for change in GCI per 10 µg/dL increase in PbB for PbB measured at each year:; - PbB at 1 years: −2.5 (−5.6, 0.5); - PbB at 2 years: −3.8 (−6.3, −1.4); - PbB at 3 years: −0.7 (−3.1, 1.6); - PbB at 4 years: −2.5 (−5.1, 0.1)
Canfield et al. 2003; Prospective cohort of 172 children (born 1994–1995), followed from age 24–40 months to 5 years; from Rochester, New York | PbB:; Mean (SD):; Lifetime average at age 5 years: 7.4 (4.3); Peak: 11.1 (7.1); Concurrent with FSIQ: 5.8 (4.1); Analysis: PbB data collected at ages 6 months–5 years. Cognitive function was assessed by S-BIS at ages 3 and 5 years. Multiple linear and nonlinear regression. Adjustments made for maternal IQ, race, level of education, use of tobacco during pregnancy, household income, and HOME, and the child’s sex, birth weight, and iron status. | Associations between increasing PbB and decreasing FSIQ measured at age 3 and/or 5 years, with largest coefficients at age 5 years. Adjusted changes in IQ for each 1 μg/dL increase in PbB. β (95% CI) for PbB metrics and FSIQ age 5 years.; Full cohort (n=172); - Lifetime average: −0.57 (−0.93, −0.20); p=0.003; - Peak: −0.26 (−0.47, −0.05); p=0.02; - Concurrent: −0.61 (−0.99, −0.24); p<0.001; Peak PbB <10 (n=101); - Lifetime average: −1.52 (−2.94, −0.09); p=0.04; - Peak: −1.44 (−2.55, −0.33); p=0.01; - Concurrent: −1.79 (−3.00, −0.60); p=0.004; Relationship between PbB and IQ was nonlinear. FSIQ change for lifetime average PbB:; 1–10 µg/dL: −7.4 points; 10–20 µg/dL: −2.5 points
Chandramouli et al. 2009; Prospective study of 488 children followed from age 4 months (born 1992) to age 7 years in Avon, United Kingdom | PbB:; - Mean (SD) at age 30 months: 4.22 (3.12); - Participants with PbB >10: 6%; Analysis: PbB assessed at 30 months. Academic performance was assessed by SATs at ages 7–8 years. Adjustments made for gender, child’s IQ, maternal education, home ownership, maternal smoking, a home facilities score at 6 months, paternal SES at the time of pregnancy, Family Adversity index, and parenting attitudes at 6 months. | OR (95% CI) for standard assessment test grades for PbB categories; Reading; - PbB 2–5 μg/dL: 0.88 (0.54, 1.43); p=0.608; - PbB 5–10 μg/dL: 0.51 (0.32, 0.82); p=0.006; Writing; - PbB 2–5 μg/dL: 1.08 (0.69, 1.71); p=0.729; - PbB 5–10 μg/dL: 0.49 (0.31, 0.78); p=0.003; A 2-fold increase in PbB was associated with a 0.3 point (95% CI −0.5, −0.1) decrease in standard assessment test scores.
Chiodo et al. 2004; Prospective study of 237 children, age 7.5 years; Detroit, Michigan | PbB:; Mean (SD, range):; 5.4 (3.3, 1–25); Analysis: FSIQ measured at 7.5 years using WISC-III. Multiple nonparametric regression. Adjustments made for SES, education level, number of children <18 years old, HOME score, PPVT-R, gender, parity, FES, prenatal alcohol exposure, crowding, life stress of the child and caretaker, child’s age, prenatal exposure to cocaine and marijuana, conflict tactics, and prenatal smoking. | Association between increasing concurrent PbB and decreasing FSIQ, β (SE):; - <3 µg/dL: −0.10, p ≤0.1; - <5 µg/dL: −0.12, p ≤0.1; - <7.5 µg/dL: −0.14, p ≤0.05; - <10 µg/dL: −0.18 p ≤0.01; - Cohort: −0.20, p≤0.01
Desrochers-Couture et al. 2018; Prospective study of 609 mother-infant pairs (recruited 2008–2011) with follow-up at age 3–4 years; Canada (Maternal-infant Research on Environmental Chemicals Study) | PbB:; Gmean (SD); - 1^st^ trimester 0.62 (1.6); - 3^rd^ trimester: 0.59 (1.7); - Cord: 0.76 (1.7); - Child (3–4 years): 0.70 (1.7); Analysis: Cognitive assessments (WPPSI-III) were conducted at age 3–4 years. Adjustments made for cord blood models were child age, child sex, maternal education, evaluation site, cord mercury; and for child blood models were child age, child sex, evaluation site, marital status, family income, HOME score, parenting stress index, and cord blood lead. | FSIQ, verbal IQ, performance IQ, or general language composite were not associated with cord or child PbB, β per 1 SD PbB (95% CI); - Cord PbB; ○ FSIQ: −0.070 (−0.143, 0.003, p=0.115; - Child PbB; ○ FSIQ: 0.014 (−0.071, 0.098), p=0.791; Increasing cord PbB interacting with gender was associated with decreasing FSIQ:; - Cord PbB; ○ Male: −2.65 (−4.66, −0.48) p=0.04; ○ Female: −0.18 (−1.63, 1.21) p=0.83; - Child PbB; ○ Male: −0.07 (−2.10, 2.17), p=0.96; ○ Female: 0.52 (−1.23, 2.40) p=0.63
Dietrich et al. 1986; Prospective study of 280 mother-infant pairs from Cincinnati, Ohio (infants born 1979–1984) | PbB:; Prenatal (maternal); - Mean (SD): 8.0 (3.8); - Range: 1–27; Neonatal (age 10 days); - Mean (SD): 4.5 (2.9); - Range: 1–22; Analysis: Neurodevelopmental assessments (MDI of the BSID) were conducted at age 6 months. Multiple linear regression with ln transformed PbB. Adjustments made for birth weight, gestational age by examination, obstetrical complications, postnatal complications, tobacco and alcohol consumption during pregnancy, maternal age at birth of child, gravidity, parity, maternal total iron binding capacity, race of child, sex of child, SES, HOME, and number of children in the home. | Associations with maternal PbB (n=245), β per 1 lnPbB (SE):; - MDI: −14.978 (6.114); p<0.02; Associations with neonatal PbB (n=280), β per lnPbB (SE):; - MDI: −15.110 (5.083); p<0.003; In males (but not females, data not reported), each unit increase in lnPbB was associated with a 5.7-point decrease in MDI: F (1,122): 4.95; p=0.03
Dietrich et al. 1987; Prospective study of 185 mother-infant pairs from Cincinnati, Ohio (infants born 1979–1984) | PbB:; Mean (SD, range); - Prenatal (maternal): 8.3 (3.8, 1–27); - Neonatal (10 days): 4.9 (3.3, 1–24); - Neonatal (3 months): 6.3 (3.8, 1–22); - Neonatal (6 months): 8.1 (5.2, 1–36); Analysis: Neurodevelopmental assessments (MDI of the BSID) were conducted at age 6 months. Multiple linear regression with ln transformed PbB. Adjustments made for obstetrical complications, postnatal complications, total iron binding capacity, birth weight, gestational age at examination, composite index of tobacco and alcohol use during pregnancy (CITAC), home environment (HOME), SES, and infant race (white/nonwhite). | Associations with 3-month PbB, β per lnPbB (SE):; - MDI: −12.113 (4.727); p=0.01; - PDI: −13.248 (4.250); p=0.002; - Motor maturity: −0.570 (0.260); p=0.03; Associations with 6-month PbB, β per ln PbB (SE):; - MDI: −2.117 (0.916); p=0.02
Dietrich et al. 1989; Prospective study of 192 mother-infant pairs from Cincinnati, Ohio (infants born 1979–1984) | PbB:; Mean (SD, range); - Prenatal (maternal): 8.2 (3.6, 1–27); - Neonatal (10 days): 4.8 (3.1, 1–23); - Neonatal (3 months): 6.0 (3.5, 1–20); - Neonatal (6 months): 7.9 (4.8, 1–35); - Neonatal (9 months): 11.5 (6.9, 2–57); - Neonatal (12 months): 14.2 (7.3, 4–47); Analysis: Neurodevelopmental assessments (MDI of the BSID) were conducted at age 12 months. Multiple linear regression and SEM. Adjustments made for obstetrical complications, postnatal complications, birth weight, gestational age, child race, child sex, CITAC, maternal age, gravidity, parity, maternal total iron binding capacity, child health variables (number of infections during the last year, current illness, iron status), HOME, SES, maternal IQ, and number of children in the home. | SEM indicated associations between increasing prenatal PbB and 12-month MDI through decreasing birth weight. Standardized regression coefficients:; - Prenatal PbB --> birth weight: −0.15, p≤0.05; - Birth weight --> 12-month MDI: 0.18, p≤0.05
Dietrich et al. 1991; Prospective study of 258 4-year-old children (born 1979–1984) from Cincinnati, Ohio | PbB:; Mean (SD, range); (based on Dietrich et al. 1992); - Maternal (6–7 months): 8.2 (3.8, 1–27); - Neonatal (10 days): 4.8 (3.3, 1–26); Analysis: Neurodevelopmental assessments (K-ABC) at 4 years. Multiple linear regression. Adjustments made for birth weight, maternal cigarette and alcohol use during pregnancy, maternal marijuana use during pregnancy, child race, HOME score, maternal IQ, and preschool attendance. | Associations between increasing neonatal (but not maternal or post-natal average) PbB and decreasing K-ABC scores. Coefficients per µg/dL neonatal PbB:; Mental processing composite: −0.63 p<0.01; Sequential processing: −0.68, p<0.01; Simultaneous processing: −0.50, p<0.05; Nonverbal: −0.63, p<0.01; Achievement: −0.28, p<0.05
Dietrich et al. 1992; Prospective study of 259 5-year-old children (born 1979–1984) from Cincinnati, Ohio | PbB:; Mean (SD, range); - Maternal (6–7 months): 8.2 (3.8, 1–27); - Neonatal (10 days): 4.8 (3.3, 1–26); - Postnatal (5 years): 11.9 (6.4, 3–38); Analysis: Neurodevelopmental assessments (FWS, AFGS) at 5 years. Multiple linear regression. Adjustments made for hearing screen, social class, HOME score, birth weight, gestational age, obstetrical complications, and alcohol consumption. | Associations between increasing neo-natal and postnatal PbB and decreasing FWS scores. Coefficients per µg/dL neonatal PbB:; FWS(T): −0.26 p<0.1; FWS(L): −0.20, p<0.01; FWS(R) −0.13, p<0.1; Coefficients per µg/dL concurrent PbB:; FWS(T): −0.11 p<0.1; FWS(L): −0.06, p<0.1; FWS(R) −0.08, p<0.05
Dietrich et al. 1993a; Prospective study of 253 6–7-year-old children (born 1979–1984) from Cincinnati, Ohio | PbB:; Mean (SD); - Maternal: 8.3 (3.7); - Birth: 5 (3.4); - 4–5 years: 11.8 (6.3); Analysis: Cognitive function was assessed at age 6.5 years using WISC-R. Multiple linear regression. Adjustments made for birth weight, gestational age, obstetrical complications, postnatal complications, maternal age at birth, maternal IQ, and HOME score. | Associations between increasing PbB and decreasing FSIQ measured at age 6.5 years. Adjusted changes in IQ for each 1 μg/dL increase in PbB. β (SE) for PbB metrics:; - Prenatal: 0.15 (0.21), p>0.1; - Lifetime average: −0.13 (0.11), p≤0.01; - Concurrent: −0.33 (0.14), p≤0.05
Emory et al. 2003; Retrospective study of 79 African-American mother-infant pairs from Atlanta, Georgia; data collection period: April–May 2000 | PbB:; Mean (SD; range); - Maternal: 0.72 (0.86; 0.05–3.3); Analysis: Memory assessment using FTII at 7 months. Chi-square test of score category (low, medium, high) versus mean maternal blood lead. No adjustments. | Lower FTII scores (Scaled Novelty Risk [risk of mental retardation later in life]) associated with higher maternal PbB (p<0.05). Score: PbB (±SD):; Low risk: 0.65 µg/dL (0.80); Medium risk: 0.89 µg/dL (0.88); High risk: 1.01 µg/dL (0.126)
EPA 2014e; (re-analysis of cohorts in Lanphear et al. 2005); Prospective; pooled-analysis; 1,333 children (4.8–6 years of age) from seven prospective studies conducted in Boston, Massachusetts (Bellinger et al. 1992, n=116); Cincinnati, Ohio (Dietrich et al. 1993a, n=221); Cleveland, Ohio (Ernhart et al. 1989, n=160); Mexico City, Mexico (Schnaas et al. 2000, n=99); Port Pirie, Australia (Baghurst et al. 1992, n=324); Rochester, New York (Canfield et al. 2003; n=182); and Yugoslavia (Wasserman et al. 1997, n=231) | PbB:; Mean (95% CI):; Lifetime average: 12.4 (4.1, 34.8); Peak: 18.0 (6.2, 47.0); Concurrent with FSIQ: 9.7 (2.5, 33.2); Analysis. Cognitive function (FSIQ) was assessed at age 5–10 years using various instruments. Multiple linear regression with log-transformed PbB and spline function. Adjustments made for HOME score, birth weight, maternal IQ, and maternal education. | Regression analysis showed associations between increasing PbB and declines in FSIQ: β coefficient for FSIQ per ln PbB (μg/dL) increase in PbB (95% CI):; - 6–24 months: −2.21 (−3.38, −1304); - Lifetime average: −3.14 (−4.39, −1.88); - Peak: −2.86 (−4.10, −1.61); - Concurrent: −2.65 (−3.69, −1.61); FSIQ change for concurrent PbB range:; - 2.4–10 µg/dL: −3.8 points (−2.3, −5.3); - 10–20 µg/dL: −1.8 points (−1.1, −2.6); - 20–30 µg/dL: −1.1 (−0.7, −1.5)
Evens et al. 2015; Population-based retrospective cohort study of 47,168 3^rd^ grade children (born 1994–1998) in Chicago, Illinois; data collection period for educational performance was 2003–2006 | PbB:; Mean (SD): 4.81 (2.22); Participants with PbB <10: 100%; Analysis. Educational performance data (ISAT scores) in children in 3^rd^ grade were linked to Chicago Blood Lead Registry data (collected birth–72 months of age). Multiple linear regression with log-transformed PbB. Adjustments made for sex of child, mother’s education, low-income, very low birth weight/preterm, child’s age at time of testing, and child race. | Regression analysis showed that ISAT reading and math scores were inversely associated with PbB. Regression coefficient (SE):; - Reading: −0.60 (0.03); p<0.0001; - Math: −0.50 (0.03); p<0.0001; Adjusted RR (95% CI) for reading and math failure for increases in PbB of:; Reading:; - 1 μg/dL: 1.06 (1.05, 1.07); - 5 μg/dL: 1.32 (1.26, 1.39); Math:; - 1 μg/dL: 1.06 (1.05, 1.07); - 5 μg/dL: 1.32 (1.26, 1.39)
Geier et al. 2017; Cross-sectional study of 1,411 children (age 6–15 years) from NHANES 2003–2004 | PbB:; Mean (SD): 1.32 (0.95); Percentiles, range:; - 0–50^th^: 0.2–1.007; - 50^th^–75^th^: 1.007–1.53; - 75^th^–100^th^: 1.530–13.50; Analysis: Logistic regression of PbB and diagnosis of a learning disability, adjusted for gender and race. | Increasing PbB was associated with OR for diagnosis of a learning disability (95% CI):; OR per µg/dL: 1.19 (1.00, 1.40) p=0.044; OR for upper quartile PbB relative to <50^th^ percentile (<P50) as reference:; - P50–P75: 1.46 (1.11, 1.92), p=0.0017; - P75–P100: 1.95 (1.16, 3.29), p=0.0033
Gomaa et al. 2002; Prospective study of 197 children followed from birth to age 2 years in Mexico City (data collection period not specified) | PbB:; Umbilical cord mean (SD): 6.7 (3.4); Participants with PbB ≥10: 15.7%; Analysis: Neurodevelopment (MDI of the BSID-II) was assessed at age 24 months. Adjustments made for maternal IQ, maternal age, child sex, maternal years of education, paternal years of education, marital status, duration of breastfeeding, and child hospitalization during the first 6 month of life, and Pb biomarkers (umbilical blood lead, tibia bone Pb, and patella bone Pb). | Linear regression showed a negative association between umbilical cord PbB and MDI score. β per lnPbB (SE): −4.48 (2.04); p=0.03; A doubling of umbilical cord PbB from 5 to 10 μg/dL was associated with a 3.1-point decrement in MDI score.
Hong et al. 2015; Cross-sectional study of 1,001 children (ages 8–11 years) in South Korea; data collection period not reported | PbB:; Gmean (GSD): 1.80 (1.40); 5^th^–95^th^ percentile range: 0.53–6.16; Analysis: PbB and cognitive function (assessed by KEDI-WISC) were assessed at ages 8–11 years. Multiple linear regression with log_10_-transformed PbB. Adjustments made for age, sex, residential region, paternal education level, and yearly income, ADHD-RS and CPT scores, log_10-_transformed environmental chemical concentrations (Hg, Mn), creatinine-standardized urine concentrations of cotinine, phthalate metabolites (MnBP, MEOHP, MEHP), and bisphenol A. | PbB was associated with a decrease in IQ scores. Regression coefficients (95% CI): per 10-fold increase in PbB; - Verbal IQ: −2.64 (−4.98, −0.30); p=0.027; - Full-scale IQ: −7.23 (−13.39, −1.07); p=0.021
Hu et al. 2006; Prospective study of 146 mother-child pairs (birth dates: 1997–1999) followed prenatally to age 2 years in Mexico City | PbB:; Mean±SD (range); - Umbilical cord: 6.20±3.88 (0.9–20.0); - Child 12-month: 5.22±3.41 (0.9–20.4); - Child 24-month: 4.79±3.71 (0.8–36.8); - Maternal 1^st^ trimester: 7.07±5.10 (1.49–43.6); - Maternal 2^nd^ trimester: 6.08±3.15 (1.58–22.4); - Maternal 3^rd^ trimester: 6.86±4.23 (1.53–33.1); Analysis: Cognitive function (MDI of the BSID-II) was assessed at 24 months. Multiple linear regression with ln-transformed PbB. Adjusted for infant’s concurrent blood lead (24 months of age), sex, maternal age, current weight, height-for-age Z-score, and maternal IQ. | Regression analysis showed a negative association between 1^st^ trimester (but not 2^nd^ or 3^rd^ trimester) maternal PbB and MDI score. No association was observed for cord PbB or child PbB at 12 or 24 months. β (95% CI), per 1 SD change in lnPbB:; - Umbilical cord: −0.35 (−4.72, 4.03); p=0.88; - Child 12-month: −2.38 (−6.24, 1.49); p=0.23; - Child 24-month: −1.00 (−3.93, 1.94); p=0.50; - Maternal 1^st^ trimester: −4.13 (−8.10, −0.17); p=0.04; - Maternal 2^nd^ trimester: −4.08 (−8.29, 0.12); p=0.06; - Maternal 3^rd^ trimester: −2.42 (−6.38, 1.54); p=0.23
Jedrychowski et al. 2009; Prospective study of 444 children (born 2001–2004) followed prenatally to age 3 years in Krakow, Poland | PbB:; Umbilical cord PbB; - Gmean: 1.29; - Range: 0.44–6.90; Analysis: Cognitive function (MDI of the BSID-II) was assessed at 12, 24, and 36 months. Multiple linear regression with log_10_-transformed PbB. Adjustments made for maternal education, birth order, sex of child, and prenatal ETS exposure. | Regression analysis showed a negative association between log PbB (<5 µg/dL) and MDI scores at 24 and 36 months (but not at 12 months). β per log cord PbB±SE (95% CI):; - 12 Months: −5.419±2.935 (−11.188, 0.3495); p=0.066; - 24 Months: −7.653±3.577 (−14.684, −0.623); p=0.033; - 36 Months: −6.717±2.964 (−12.546, −0.889); p=0.024; - For participants with PbB <5 (combination of all testing times): −6.618±2.499 (−11.517, −1.719); p=0.008; A 1 log unit increase of cord PbB was associated with a 6-point reduction in MDI scores.
Jusko et al. 2008; Prospective study of 174 children (born 1994–1995) recruited at age 24–30 months and evaluated for FSIQ at 6 years in Rochester, New York | PbB:; lifetime average:; - Mean (SD): 7.2 (4.1); - Range: 1.4–27.1; - Participants <10: 77%; Analysis: Cognitive function (by WPPSI-R) was assessed at 6 years. Multiple linear and nonlinear regression. Adjustments made for child’s sex, birth weight, transferrin saturation, mother’s race, IQ, and education level; HOME-SF total score, family income, and maternal prenatal smoking. | Associations between increasing PbB and decreasing FSIQ measured at age 6 years (p=0.003).; Comparison of children with PbB of 5–9.9 (high) to those with PbB <5 (low) showed a 4.9-point decrease in FSIQ score (low: 91.3; high 86.4; p=0.04); Adjusted changes in IQ for each 1 μg/dL increase in peak lifetime PbB (p-value not reported):; 2.1–10 µg/dL: −1.2; 10–20 µg/dL: −0.32; 20–30 µg/dL: −0.15
Kim et al. 2013b; Prospective birth cohort (MOCEH study; 2006–2010); 884 mother infant pairs; South Korea | PbB:; Gmean (GSD); Early pregnancy: 1.4 (1.5); Late pregnancy: 1.3 (1.5); Analysis: Mental performance evaluated at age 6 months using MDI using the BSID-II. Multiple linear regression. Adjustments made for infant birth weight, infant sex, maternal age, maternal education level, family income, breastfeeding status, residential area, Pb, and Cd. | Association between increased PbB in late pregnancy and decreasing MDI score (β) per 1 µg/dL change in PbB (95% CI):; -1.94 (−3.60, −0.29); p=0.02
Kordas et al. 2011; Prospective study of 186 children followed prenatally (1994–1995) to age 4 years in Mexico City | PbB:; Mean (SD); - Umbilical cord: 6.6 (3.3); - 24 months: 8.1 (4.4); - 48 months: 8.1 (3.6); Analysis: Cognitive function was assessed at 24 months by BSID-II and 48 months by MSCA. Multiple linear regression. Adjustments made for birth weight, gestational age, child sex, maternal age, years of schooling, IQ, smoking status (ever), marital status at enrollment, crowding in the house, and type of floor in the house. | Associations between increasing cord PbB and concurrent PbB with decreasing scores on various assessments of cognitive function assessed at 24 and 48 months. β (SE):; - 24-Month MDI; ○ Cord PbB: −0.7 (0.3); p<0.05; ○ Concurrent PbB: −0.1 (0.2); - 24-Month PDI; ○ Cord PbB: −0.4 (0.2); p≥0.05; ○ Concurrent PbB: −0.2 (0.2); - 48-Month GCI; ○ Cord PbB: −0.2 (0.3); ○ Concurrent PbB: −0.6 (0.2); p<0.05; - Memory score; ○ Cord PbB: 0.1 (0.1); ○ Concurrent PbB: −0.3 (0.1)
Lanphear et al. 2000a; Cross-sectional study of 4,853 children (ages 6–16 years; birth year: 1972–1988) from NHANES III (1988–1994). | PbB:; Gmean: 1.9; Participants with PbB ≥5: 9.7%; Participants with PbB ≥10: 2.1%; Analysis: Cognitive function was assessed by WRAT-R and WISC-R. Adjustments made for sex, race/ethnicity, Poverty Index Ratio, educational level of reference adult, serum ferritin level, and serum cotinine level. | Inverse relationships were observed between PbB and scores for arithmetic, reading, block design (non-verbal reasoning), and digit span (short-term and working memory).; Regression coefficients (SE):; - Arithmetic:; ○ PbB <2.5: −1.28 (0.98), p=0.20; ○ PbB <5.0: −1.06 (0.48); p=0.03; ○ PbB <7.5: −1.06 (0.39); p=0.01; ○ PbB <10: −0.89 (0.32); p=0.008; - Reading:; ○ PbB <2.5: −1.71 (0.93); p=0.07; ○ PbB <5.0: −1.66 (0.36); p<0.001; ○ PbB <7.5: −1.53 (0.31); p<0.001; ○ PbB <10: −1.44 (0.30); p<0.001; - Block design:; ○ PbB <2.5: −0.08 (0.22); p=0.72; ○ PbB <5.0: −0.05 (0.07); p-0.45; ○ PbB <7.5: −0.11 (0.06); p=0.04; ○ PbB <10: −0.13 (0.06); p=0.03; - Digit span:; ○ PbB <2.5: −0.25 (0.17); p=0.17; ○ PbB <5.0: −0.09 (0.07), p=0.20; ○ PbB <7.5: −0.09 (0.05); p=0.11; ○ PbB <10: −0.08 (0.04); p=0.03; For every 1 µg/dL increase in PbB, there were decreases of approximately 1 point in mean reading score, 0.7 points in mean arithmetic score, 0.1 points in mean score of nonverbal reasoning (block design), and 0.05 points in mean digital span score.
Lanphear et al. 2005; (same cohorts used for Budtz-Jorgensen et al. 2013); Prospective; pooled-analysis; 1,333 children (4.8–6 years of age) from seven prospective studies conducted in Boston, Massachusetts (Bellinger et al. 1992, n=116); Cincinnati, Ohio (Dietrich et al. 1993a, n=221); Cleveland, Ohio (Ernhart et al. 1989, n=160); Mexico City, Mexico (Schnaas et al. 2000, n=99); Port Pirie, Australia (Baghurst et al. 1992, n=324); Rochester, New York (Canfield et al. 2003; n=182); and Yugoslavia (Wasserman et al. 1997, n=231) | PbB:; Mean (96% CL):; - Lifetime average: 12.4 (4.1, 34.8); - Peak: 18.0 (6.2, 47.0); - Concurrent with FSIQ: 9.7 (2.5, 33.2); Analysis: Cognitive function was assessed at age 5–10 years using various instruments. Multiple linear regression with log-transformed PbB and spline function. Adjustments made for HOME score, birth weight, maternal IQ, and maternal education. | Associations between increasing PbB and decreasing FSIQ measured at age 5–10 years. Adjusted changes in IQ for each ln PbB (μg/dL) increase in PbB. β (95% CI) for PbB metrics:; - 6–24 months: −2.04 (−3.27, −0.81); - Lifetime average: −3.04 (−4.33, −1.75); - Peak: −2.85 (−4.10, −1.60); - Concurrent: −2.70 (−3.74, −1.66); Relationship between PbB and IQ was nonlinear. FSIQ change for lifetime average PbB (95% CI):; 2.4–10 µg/dL: −3.9 points (−2.4, −5.3); 10–20 µg/dL: −1.9 points (−1.2, −2.6); 20–30 µg/dL: −1.1 (−0.7, −1.5)
Lanphear et al. 2019; (re-analysis of data reported in Lanphear et al. 2005; same cohorts used for Budtz-Jorgensen et al. 2013); Prospective; pooled-analysis; 1,333 children (4.8–6 years of age) from seven prospective studies conducted in Boston, Massachusetts (Bellinger et al. 1992, n=116); Cincinnati, Ohio (Dietrich et al. 1993a, n=221); Cleveland, Ohio (Ernhart et al. 1989, n=160); Mexico City, Mexico (Schnaas et al. 2000, n=99); Port Pirie, Australia (Baghurst et al. 1992, n=324); Rochester, New York (Canfield et al. 2003; n=182); and Yugoslavia (Wasserman et al. 1997, n=231) | PbB:; Median (95% CI):; - Lifetime average: 11.9 (3.6, 34.5); - Peak: 18.0 (6.0, 47.0); - Concurrent with FSIQ: 9.7 (2.5, 33.2); Analysis: Cognitive function was assessed at age 5–10 years using various instruments. Multiple linear regression with log-transformed PbB and spline function. Adjustments made for HOME score, birth weight, maternal IQ, and maternal education. | Associations between increasing PbB and decreasing FSIQ measured at age 5–10 years. Adjusted changes in IQ for each ln PbB (μg/dL) increase in PbB. β (95% CI) for PbB metrics:; - 6–24 months: −2.21 (−3.38, −1.04); - Peak: −2.86 (−4.10, −1.61); - Lifetime average: −3.25 (−4.51, −1.99); - Concurrent: −2.65 (−3.69, −1.61); Relationship between PbB and IQ was nonlinear. FSIQ change for concurrent PbB (95% CIL):; - 2.4–10 µg/dL: −3.8 points (−2.3, −5.3); - 10–20 µg/dL: −1.8 points (−1.1, −2.6); - 20–30 µg/dL: −1.1 points (−0.7, −1.5)
Lin et al. 2013; Prospective (Taiwan Birth Panel Study; birth dates: April 2004–January 2005) of 230 mother-infant pairs from Taipei, Taiwan; followed until age 2 years | PbB:; Umbilical cord; - Mean (SD): 1.30 (0.75); - Range: 0.016–4.32; Analysis: Cognitive function was assessed by CDIIT at age 2 years. Adjustments made for maternal age, maternal education, fish intake ≥2 times/week during pregnancy, infant sex, ETS during pregnancy and after delivery, and HOME. | Regression analysis comparing PbB ≥1.645 (75^th^ percentile) and PbB <1.645. Adjusted β (SE):; - Total score: −4.23 (1.82); p<0.05; - Cognitive: −5.35 (2.19); p<0.05; - Language: −2.53 (1.89)
Liu et al. 2014b; Prospective study of 243 infants followed from birth to age 3 years (birth years 2009–2010) from Pearl River Delta, Guangdong, China | PbB:; Umbilical cord mean (SD); - Low PbB group: 1.35 (0.26); - High PbB group: 5.63 (0.32); Analysis: Neurodevelopmental assessments (MDI and PDI of the BSID-II) were conducted at ages 6, 12, 24, and 36 months. Adjustments made for birth weight, sex, blood umbilical cord Pb levels, maternal age, hemoglobin, IQ, tobacco use, parents’ occupation, educational level, and yearly household income. | Increasing umbilical cord PbB (low to high group) was associated with decreasing MDI measured at 6, 12, 24, or 36 months, and decreasing PDI measured at age 36 months when adjusted for confounders. Regression coefficients (95% CI):; - MDI; ○ 6 months: −1.647 (−2.094, −1.200); p=0.016; ○ 12 months: −1.458 (−1.832, −1.084); p=0.023; ○ 24 months: −1.385 (−1.683, −1.087); p=0.033; ○ 36 months: −1.291 (−1.550, −1.032); p=0.036; - PDI at 36 months: −1.302 (−1.572, −1.031); p=0.041; Increasing PbB at age 24 and 36 months was associated with decreasing MDI scores measured at 24 and 36 months, respectively; β:; - 24 Months: −1.403; p=0.026; - 36 Months: −1.382; p=0.032
Mazumdar et al. 2011; A prospective of 43 adults followed from birth (1979–1981) to age 28–30 years; participants were from the Boston cohort (Bellinger et al. 1992) | PbB:; Mean (SD); - Cord: 6.5 (5.3); - 6 months: 8.0 (5.3); - 12 months: 10.0 (6.7); - Age 2 years: 7.7 (4.0); - Age 4 years: 6.7 (3.6); - Age 10 years: 3.0 (2.7); Analysis: FSIQ was assessed using WASI at age 28–30 years. Adjustments made for sex, race, birth weight, birth order, gestational age at delivery, mother’s marital status at delivery, highest educational level of mother at delivery, maternal IQ, maternal tobacco use during pregnancy, maternal alcohol use during pregnancy, subject’s history of concussion or head trauma, and alcohol use. | Childhood PbB was associated with a decrease in FSIQ in adults examined at age 28–30 years. Changes in FSIQ per 1 µg/dL increase in PbB. β (95%CL) for average late childhood PbB (mean of 4 and 10 years PbB):; - Unadjusted: −1.89 (−3.30, −0.47), p<0.01; - Adjusted for maternal IQ: −1.11 (−2.29, 0.06); - Other adjustments made for 95% UCLs for β <0
McLaine et al. 2013; Population-based retrospective cohort study of 3,406 children enrolled in kindergarten during 3 school years (2004–2005, 2005–2006, and 2006–2007) in Providence, Rhode Island | PbB:; Median: 4.2; Interquartile range: 2.6–6.0; Analysis: Kindergarten reading readiness scores (PALS-K test) were linked to state health department data on PbB collected at birth and PbB screening data (collected 9–72 months of age). Multiple linear regression. Adjustments made for geometric mean BLL category (0–≥10 µg/dL), sex, year, age at time of test, race, child language, and free/reduced lunch status. | PbB was associated with a decrease in PALS-K scores. Mean differences (95% CI) in PALS-K scores (85% CL), compared to PbB <5 µg/dL:; - PbB 5–9 µg/dL: −4.51 (−6.61, −2.85); p>0.182; - PbB ≥10 µg/dL: −10.13 (−13.30, −6.96); p>0.182; Prevalence ratio (95% CI) for falling below the PALS-K benchmark, compared to PbB <5 µg/dL:; - PbB 5–9 µg/dL: 1.21 (1.19, 1.23); p<0.001; - PbB ≥10 µg/dL: 1.56 (1.51, 1.60); p<0.001
Min et al. 2009; Prospective study of 267 children followed prenatally (1994–1996) to age 11 years in Cleveland, Ohio | PbB:; Mean (SD); - 4 years: 7.0 µg/dL (4.1); Analysis: Cognitive function was assessed at 4 years (WPPSI-R), 9 years (WISC-IV) and 11 years (WISC-IV). Multiple linear regression. Adjustments made for prenatal cocaine, marijuana, tobacco, and alcohol exposure, SES, maternal age, marital status at birth, mother’s education level, number of prenatal care visits, parity, child’s race, child’s sex, infant head circumference, HOME score, biological and current caregiver GSI, and iron deficiency anemia status. | Associations between increasing concurrent PbB with decreasing FSIQ score. Regression coefficient (SE):; - 4 Years: −0.50 (0.20), p<0.05; - 9 Years: −0.41 (0.19), p<0.05; - 11 Years: −0.54 (0.19) p<0.01
Miranda et al. 2009; Population-based retrospective cohort study of 57,678 4^th^ grade children from North Carolina (all counties) | PbB:; Mean: 4.8; Median: 4; Range: 1–16; Interquartile range: 3.0–6.0; Analysis: Reading EOG test scores of 4^th^ grade students were linked to PbB screening data collected at ages 6–36 months. Adjustments made for race, household income, prenatal education, and BLL. | A negative association was observed between PbB and reading EOG test scores. Regression coefficients (95% CI):; - PbB 2 µg/dL: −0.30 (−0.58, −0.01); p<0.0001; - PbB 3 µg/dL: −0.46 (−0.73, −0.19); p<0.0001; - PbB 4 µg/dL: −0.52 (−0.79, −0.24); p<0.0001; - PbB 5 µg/dL: −0.80 (−1.08, −0.51); p<0.0001; - PbB 6 µg/dL: −0.99 (−1.29, −0.68); p<0.0001; - PbB 7 µg/dL: −1.07 (−1.40, −0.74); p<0.0001; - PbB 8 µg/dL: −1.35 (−1.73, −0.97); p<0.0001; - PbB 9 µg/dL: −1.20 (−1.64, −0.75); p<0.0001; - PbB ≥10 µg/dL: −1.75 (−2.09, −1.41); p<0.0001
Polanska et al. 2018; Prospective study of 539 mother-child pairs, recruited in 2007, with follow-up of 303 children at age 2 years; Polish Mother and Child Cohort (REPRO_PL), Poland | PbB:; Gmean (SD) (range); - 2^nd^ trimester: 0.99 (0.15) (0.29, 2.63); - Cord: 0.96 (0.16) (0.24, 5.65); Analysis: Cognitive function was assessed at age 2 years using BSID III. Linear regression. Adjustments made for parental age and education, SES and marital status, child sex, pregnancy complications, delivery type, week of pregnancy, anthropomorphic measures at birth, breastfeeding, number of children at home, daycare attendance, cotinine levels in saliva, alcohol consumption during pregnancy, and environmental exposure of child to tobacco smoke. | Increasing cord PbB was associated with decreasing cognitive scores in males. β score per µg/dL (95% CI):; Cognitive score:; - Females: 0.34 (−1.30, 1.98), p=0.68; - Males: −2.07 (−4.07, −0.06), p=0.04; Language score:; - Females: −0.29 (−2.23, 1.65), p=0.77; - Males: −0.43 (−2.81, 1.95), p=0.72
Rodrigues et al. 2016; Prospective study with cross-sectional analysis of PbB and fine motor score; n=524 children, 20–30 months; Sirajdikhan and Pabna, Bangladesh | PbB:; Median (P24, P75, Maximum); - Sirajdikhan: 7.6 (5.5, 10.4); - Pabna: <LOD (<LOD, 3.8, 13.8); Analysis: Cognitive function was assessed at age 2–3 years using BSID III. General linear model regression. Adjustments made for maternal age and education, exposure to environmental tobacco smoke, child sex, HOME score, maternal Raven score, and child hematocrit. | Child PbB was associated with decreasing cognitive scores β score per lnPbB µg/dL (SE) in Pabna:; Cognitive score:; - Sirajdikhan: −0.17 (0.09), p=0.05; - Pabna: 0.02 (0.12), p=0.87
Rooney et al. 2018; Longitudinal study of 330 children age 8–12 years at recruitment (1997) with follow-up at age 12 and 17 years, Casa Pia Clinical Trial of Dental Amalgams in Children, Lisbon, Portugal | PbB:; Mean (SD) at age 8–12 years; - Females: 4.42 (2.19); - Males: 5.26 (2.73); Analysis: Cognitive function was assessed at ages 12 and 17 years using the Ray auditory Verbal Learning Test, WAdSI III, Wechsler Memory Scale for Adults III, Standard Reaction Time, finger tapping, Trailmaking A and B, Wisconsin Card Sorting Test and Stroop tests. Genetic variants of N-methyl-D-aspartate receptors (NMDAR subunits GRIN2A and GRIN2B) were evaluated at the start of the study. Bayesian mixed regression models. Adjustments made for age, race, nonverbal IQ at baseline, and urinary mercury. Other factors were considered to be sufficiently uniform to not require adjustments (e.g., SES, home environment, medical histories) | GRINA2A and GRIN2B variants were effect modifiers on associations between increasing PbB (at age 8–12 years) and decreasing performance on learning and memory and executive functions assessed at age 17 years. The associations were stronger and more consistent across tests in males.
Ruebner et al. 2019; Cross-sectional study of 412 children (median age 15.4 years) from prospective study of CKD in children; United States | PbB:; Median (P24, P75); 1.2 (0.8, 1.8); Analysis: Cognitive function was assessed at various ages ranging from 1 to 18 years using a variety of tests (MSEL, WASI, WPPSI, CPT, CPTI). Linear regression. Adjustments made for age, sex, race, poverty, maternal education, CKD stage, CKD duration, glomerular CKD diagnosis, abnormal birth history, proteinuria, hypertension, and anemia. | Increasing child PbB was associated with poorer cognitive performance. β score per µg/dL (95% CI):; FSIQ:; - PbB: −2.1 (−3.9, −0.2), p=0.029; CPT variability score:; - PbB: 1.8 (0.2, 3.5), p=0.033
Schnaas et al. 2006; Prospective study of 150 children in Mexico City, followed from birth (1987–1992) to age 10 years | PbB:; Maternal during full pregnancy; - Gmean (range): 8.0 (1–33); Maternal PbB during pregnancy weeks 28–36; - Gmean (95% CI): 7.3 (1.5–17.4); Child 1–5 years; - Gmean (range): 9.8 (2.8–36.4); Child 6–10 years; - Gmean (range): 6.2 (2.2–18.6); Analysis: Cognitive function was assessed at ages 6–10 years using WISC-II. Multiple linear regression with log-transformed PbB and mixed effects. Adjustments made for maternal IQ, SES, birth weight, and an indicator variable of first FSIQ application at 6, 7, or 8 years. | Association between increasing maternal and child PbB and decreasing FSIQ assessed at age 6–10 years. β (95% CI):; - Ln maternal PbB 28 weeks of pregnancy: −4.00 (−6.37, −1.65); p=0.001; - Ln child PbB (6–10 years): −2.45 (−4.09, −0.81); p=0.003
Shadbegian et al. 2019; Retrospective study of 560,624 children born in the period 1990–2004 with PbB measured at ages 0–5 years and cognitive assessments during school grades 3–8, North Carolina | PbB:; Mean (SD); - Full <10µg/dL: 3.66 (1.90); - Full ≤5 µg/dL: 2.89 (1.18); - CEM ≤5 µg/dL: 2.40 (1.24) (CEM is coarsened exact matching of potential co-variables to ≤1 µg/dL stratum); Analysis: Cognitive function was assessed during school grades 3–8 using standard achievement tests. General linear model of change in percentile score compared to children whose PbB was ≤1 µg/dL. Strata matched (CEM) to ≤1 µg/dL stratum for race/ethnicity, SES, mother’s marital status, enrollment in Medicaid at time of blood test, school, school grade, year of assessment, mother’s age at time of birth, and parent education. | Increasing child PbB was associated with decreasing percentile of academic performance score. Percentile score change relative to ≤1 µg/dL CEM stratum (SE) for children who had geometric mean PbB >1 and ≤5 µg/dL:; Math percentile for PbB strata:; - 2 µg/dL: −0.38 (0.19), p>0.05; - 3 µg/dL: −0.56 (0.20), p<0.01; - 4 µg/dL: −0.96 (0.23), p<0.001; - 5 µg/dL: −0.51(0.30), p>0.05; Reading percentile for PbB strata; - 2 µg/dL: −0.55 (0.19), p<0.01; - 3 µg/dL: −1.02 (0.20), p<0.001; - 4 µg/dL: −1.31 (0.23), p<0.001; - 5 µg/dL: −0.97 (0.30), p>0.001
Sobin et al. 2015; Cross-sectional; 252 children; age 5.1–11.8 years; El Paso Texas | PbB:; Mean (SD):; - Females: 2.7 (1.5); - Males: 2.4 (1.0); - 96% <5.0 µg/dL; Analysis: Memory performance assessed using CANTAB at ages 5–12 years. Multiple linear regression. Adjustments made for sex, age, mother’s level of education, and site. | Association between increasing concurrent PbB and working memory misses. β (SE): 0.11 (0.03), p<0.01
Taylor et al. 2017; Prospective study of 14,062 mother-infant pairs, followed from birth (recruited 1991–1992), with follow-up of a random subset of children at age 4 years (n=404) and 8 years (n=2,127) from 4,316 births; Avon, United Kingdom | PbB:; Mean (SD):; - Maternal (11 weeks): 3.67 (1.46); - Child (30 months): 4.22 (3.12); Analysis: Cognitive performance evaluated at age 4 years (WPPSI) and 8 years (WISC-III). Linear and logistic regression. Adjustments made for family adversity index, housing age, household crowding, first trimester tobacco smoking and alcohol consumption, maternal age at birth, parity, maternal education, residence in Avon, child sex, child age at testing, and weighted life events score. | Increasing maternal PbB was associated with increasing FSIQ of females, but not males, at age 8 years. β for score per µg/dL (95% CI):; Females:; - Verbal: 0.71 (0.11, 1.32), p=0.021; - Performance: 0.57 (−0.11, 1.24), p=0.099; - Total: 0.73 (0.13, 1.33), p=0.017; Males:; - Verbal: −0.15 (−0.90, 0.60), p=0.72; - Performance: −0.42 (−1.19, 0.35), p=0.29; - Total: −0.29 (−1.02, 0.44), p=0.44; OR for low IQ (lowest IQ quartile) at age 8 years (95% CI) for children with PbB >5 µg/dL relative to ≤5 µg/dL (reference):; - Verbal: 0.73 (0.51, 1.05), p=0.090; - Performance: 1.09 (0.78, 1.51), p=0.62; - Total: 0.86 (0.60, 1.22), p=0.39
Tellez-Rojo et al. 2006; Prospective study of 294 children followed from birth (1994–1995, 1997–1999) to age 2 years; Mexico City | PbB:; Mean (SD):; - Cord: 4.85 (3.0); - 12 months: 4.27 (2.14); - 24 months: 4.28 (2.25); Analysis: Motor performance (MDI) evaluated at ages 6 and 12 using the BSID II. Multiple linear regression with ln-transformed PbB. Adjustments made for sex, birth weight, and maternal IQ. | Association between increasing concurrent PbB and MDI score at age 24 months (β) per lnPbB:; 12 Months:; - <10 µg/dL: −0.15, p=0.57; - ≥10 µg/dL: −0.71, p=0.17; 24 Months:; - <10µg/dL: −1.04, p<0.01; - ≥10 µg/dL: 0.07, p=0.84
Vigeh et al. 2014; Prospective study of 174 mother-child pairs (mothers enrolled 2006–2011) in Tehran, Iran; followed from birth to 36 months | PbB:; Mean±SD (range); - 1^st^ Trimester: 4.15±2.43 (1.6–20.5); - 2^nd^ Trimester: 3.44±1.28 (1.1–7.5); - 3^rd^ Trimester: 3.78±1.40 (1.5–8.0); - Umbilical cord: 2.86±1.09 (1.2–6.9); Analysis: Cognitive development was assessed at children up to 36 months of age by HIECDI and ECDI tests. Adjustments made for hematocrit, child mental development, mother’s age, maternal educational level, BMI, length of pregnancy (weeks), passive tobacco exposure, mother’s education level, age of child, birth weight, sex of child, and first born. | Low cognitive development scores were “low” in 8/174 children. 1^st^ Trimester PbB was higher (p=0.01) in children with low scores (mean±SD: 6.31±1.95) than children with “normal” scores (mean±SD: 4.05±2.40).; An inverse relationship was observed between 1^st^ trimester PbB and ECDI scores. Pearson correlation coefficient: −0.173; p<0.05.; OR for low ECDI scores based on 1^st^ trimester PbB: 1.74 (95% CI 1.18, 2.57); p=0.005.
Wasserman et al. 1994, 1997, 2003; Prospective; 332 children age 4 years, 261 children age 7 years, 167 children age 10–12 years; Kosovska, Mitrovica, Kosovo, Yugoslavia; and Pristina, Kosovo, Yugoslavia | PbB:; Mean (SD); Age 4 years: 9.6, Pristina; 39.9, K. Mitrovica; 10–12 years: 6.1 (1.9), Pristina; 30.9 (9.6), K. Mitrovica; Analysis: Cognitive function was assessed at age 4, 7, and 10–12 years using McCarthy GCI, WISC-III, and WISC-III, respectively. Multiple linear regression with log-transformed PbB. Adjustments made for sex, sibship size, birthweight, language spoken in the home, HOME score, years of maternal education, maternal age, and maternal RAVEN score. | Associations between increasing PbB and decreasing FSIQ measured at age 4, 7, and 10–12 years.; Adjusted changes for each lnPbB increase in β (SE) for PbB metrics: 4 years: −9.43 (2.44), p=0.000; Lifetime AUC 7 years: −8.59 (1.89), p<0.05; Lifetime average 10–12 years: −5.31 (1.98), p<0.05
Zhang et al. 2013; Population-based retrospective cohort study of 8,831, 7,708, and 4,742 students in grades 3, 5, and 8, respectively, from Detroit, Michigan; academic achievement data was collected 2008–2010 | PbB:; Mean (SD): 7.12 (7.26); Analysis: Educational testing (MEAP tests) data from Detroit public schools for grades 3, 5, and 8 was linked to state health department data surveillance PbB collected at birth and PbB screening data (collected birth–6 years of age). Adjustments made for grade level, sex, race, language, maternal education, and SES as implied by school lunch status. | An association was observed between PbB and decreased academic achievement. ORs (95% CI) for scoring “less than proficient” on MEAP tests (reference PbB ≤1) (p<0.05 for all ORs):; - Mathematics:; ○ PbB 1–5 (µg/dL): 1.42 (1.24, 1.63); ○ PbB 6–10 (µg/dL): 2.00 (1.74, 2.30); ○ PbB >10: 2.40 (2.07, 2.77); - Science: (µg/dL); ○ PbB 1–5 (µg/dL): 1.33 (1.10, 1.62); ○ PbB 6–10 (µg/dL): 2.22 (1.82, 2.72); ○ PbB >10 (µg/dL): 2.26 (1.84, 2.78); - Reading:; ○ PbB 1–5 (µg/dL): 1.45 (1.27, 1.67); ○ PbB 6–10 (µg/dL): 2.21 (1.92, 2.55); ○ PbB >10 (µg/dL): 2.69 (2.31, 3.12)
Zhou et al. 2017; Prospective study of 139 mother-infant pairs recruited in 2010 and followed from birth to 24–36 months, Shanghai, China | PbB:; Gmean (95% CI); Mid-late pregnancy: 3.30 (3.05, 3.57); Analysis: Neurobehavioral evaluations were conducted at age 24–36 months using Gesell Development Scale. Maternal prenatal stress was evaluated using the SSCL-90-R. Linear regression. Adjustments made for maternal age at enrollment, maternal education, gestational week, child sex, birth weight, age and family economic status. | Maternal PbB was not associated with child development quotient in complete cohort. β (95% CI) for development quotient per µg/dL:; - Adaptive behavior: 3.60 (−3.64, 10.83); - Language: −6.76 (−17.29, 3.77); - Social behavior: −6.45 (−15.55, 2.65); Maternal PbB was associated with child development in subset of mothers who demonstrated high prenatal stress (Global Severity Index in upper quartile). β (95% CI) for development quotient per µg/dL:; - Adaptive behavior: −17.93 (−35.83, −0.03); - Language: −33.82 (−60.04, −7.59); - Social behavior: −41.00 (−63.11, −18.89)
Mood and behavior
Arbuckle et al. 2016; Cross-sectional study of 2,097 children (ages 6–19 years); data collection period: 2007–2009 (Cycle 1 of Canadian Health Measures Survey) | PbB:; Gmean (95% CI); age 6–11 years: 0.91 (0.81, 0.99); age 12–19 years: 0.80 (0.74, 0.85); Analysis: Behavioral problems were assessed by weighted random population survey. Adjustments made for smoking at home, gender, income, education, hours slept, and fasted. | Increased PbB was associated with increased risk of behavior problems. Adjusted ORs (95% CI) for ln(PbB):; - ADD/ADHD: 2.39 (1.32, 4.32); - Emotional symptoms: 1.08 (0.68, 1.71); - Hyperactivity/inattention: 2.33 (1.59, 3.43); - Total difficulties: 2.16 (1.33, 3.51); Pb interaction with other risk factors:; - Learning disability (higher income): 2.78 (1.40, 5.51); - Prescribed psychotropic medication (non-fasting sample): 4.20 (1.92, 9.17)
Boucher et al. 2012; Prospective study of 272 children (mean age 11.3 years) from the Canadian Arctic (Nunavik); data collection period: 2005–2010 | PbB:; Mean±SD (range); - Umbilical cord: 4.7±3.3 (0.8–20.9); - Current: 2.7±2.2 (0.4–12.8); - Tertiles:; ○ T1 (reference): 0.4–1.6; ○ T2: 1.6–2.7; ○ T3 2.7–12.8; Analysis: Behavior was assessed in children ages 8.5–14.5 years by the TRF child behavior checklist and Disruptive Behavior Disorders Rating Scale. Adjustments made for child age, child gender, SES, age of the biological mother at birth, maternal tobacco use during pregnancy, birth weight, cord Hg, and child Pb. | Child current PbB was associated with increased risk of behavior problems. Adjusted ORs (95% CI) for current PbB p<0.20 for all ORs):; - ADHD-inattentive type:; ○ T2 (n=94): 1.06 (0.42, 2.66); ○ T3 (n=91): 1.01 (0.38, 2.64); - ADHD-hyperactive-impulsive type:; ○ T2(n=94): 4.01 (1.06, 15.23); ○ T3(n=91): 5.52 (1.38, 22.12); - Oppositional defiant disorder and/or conduct disorder:; ○ T2 (n=94): 1.90 (0.88, 4.11); ○ T3 (n=91): 1.53 (0.67, 3.49); Umbilical cord PbB was not associated with behavior problem scores (data not reported).
Braun et al. 2006; Cross-sectional study of 4,704 children (ages 4–15 years) from NHANES 1999–2002 study | PbB:; Quintiles:; - Q1 (reference): ND–0.7; - Q2: 0.8–1.0; - Q3: 1.1–1.3; - Q4: 1.4–2.0; - Q5: ≥2.0; Analysis: ADHD was defined as having current stimulant medication use and parent report of ADHD diagnosed by a doctor or health professional. Adjustments made for age, sex, race, prenatal ETS exposure, postnatal ETS exposure, blood lead levels, preschool or childcare attendance, health insurance coverage, and ferritin levels. | Child PbB was associated with increased risk of ADHD. Adjusted ORs (95% CI) for ADHD:; - Q2: 1.1 (0.4, 3.4); p=0.804; - Q3: 2.1 (0.7, 6.8); p=0.195; - Q4: 2.7 (0.9, 8.4); p=0.086; - Q5: 4.1 (1.2, 14.0); p=0.026; - p-trend: 0.012
Braun et al. 2008; Cross-sectional study of 3,082 children (ages 8–15 years; born 1986–1996) from the NHANES 2001–2004 study | PbB:; Quartiles:; - Q1 (reference): 0.2–0.7; - Q2: 0.8–1.0; - Q3: 1.1–1.4; - Q4: >2.0; Analysis: Conduct disorder was assessed by DISC. Adjustments made for child’s age in years, PIR, maternal age at child’s birth, child’s sex, child’s race, prenatal tobacco smoke exposure, cotinine levels, and blood lead levels. | Child PbB was associated with increased risk of conduct disorder. Adjusted ORs (95% CI) for meeting conduct disorder criteria:; - Q2: 7.24 (1.06, 49.47); - Q3: 12.37 (2.37, 64.56); - Q4: 8.64 (1.87, 40.04)
Choi et al. 2016; Longitudinal study of 2,159 children (ages 7–9 years) from 10 South Korean cities; participants did not have symptoms of ADHD at the baseline survey; data collection period: 2006–2010 | PbB:; Gmean (GSD):; - All participants >7 years: 1.62 (1.52); - Boys: 1.65 (1.75); - Girls: 1.47 (1.76); p<0.001, compared to boys; Analysis: Time of PbB measurement was not reported. Follow-up ADHD survey was conducted 2 years after the baseline assessment. Adjustments made for age, sex, residential area, monthly income, parental marital status, family history of psychiatric disorders (anxiety disorder, ADHD, autism and schizophrenia), preterm birth, and birth weight. | RR (95% CI) for development of ADHD symptoms:; - PbB ≥2.17 (compared to PbB <2.17): 1.552 (1.002, 2.403)
Desrochers-Couture et al. 2019; Longitudinal study of 212 Inuit children followed from birth and evaluated at mean age 11.4 years (2005–2010) and 18.5 years (2013–2016); Canada (Nunavik Child Development Study) | PbB:; Gmean (GSD); - Cord: 3.80 (1.84); - Child: 2.34 (1.86); - Adolescent: 1.63 (2.00); Analysis: Behavior assessments were conducted at age 9–14 years (child) and age 16–22 years (adolescent). Behavior outcomes assessed included externalizing (Youth Self-Report), hyperactivity-impulsivity (Barkley Adult ADHD-IV Rating Scale), conduct disorder (Diagnostic Interview Schedule for Children), and substance use (Detection of alcohol and drug problems in adolescents, Version 3.2). Adjustments made for age, sex, birth weight, SES, age of biological mother, maternal tobacco use during pregnancy, and cord blood Hg. | Child PbB was not associated with adolescent externalizing behavior score, β per log_2_ µg/dL PbB (95% CI); - Externalizing: 0.61 (−0.63, 1.96); - Hyperactivity-impulsivity: 0.11 (−0.14, 0.37); - Oppositional defiant/conduct disorder: 0.02 (−0.20, 0.21); Child PbB was indirectly associated with adolescent externalizing score through child externalizing score, β per log_2_ µg/dL PbB (95% CI):; - Externalizing score: 0.32 (0.08, 0.72); Child PbB was not associated with any category of substance use; however, child PbB was indirectly associated with adolescent binge drinking and cannabis use through child externalizing score, β per log_2_ µg/dL PbB (95% CI):; - Binge drinking: 0.09 (0.02, 0.23); - Cannabis use: 0.05 (0.002, 0.14)
Dietrich et al. 2001; Prospective study of 195 subjects 15–17 years of age (born 1979–1984) from Cincinnati, Ohio | PbB:; Categories:; Lowest: <10; Low: 10–15; Medium: 16–20; High: >20; Analysis: Delinquency evaluated based on SRBDS and PRDBS. Multiple linear regression. Adjustments made for HOME scores, SES, parental IQ, and birth weight. | Associations between increasing PbB and SRDBS scores (β ± SE):; - Prenatal PbB: 0.192 (0.076); p=0.002; - 78-month PbB: 0.193 (0.061); p=0.002; - Average child PbB: 0.101 (0.047); p=0.036; When PbB was treated categorically, increasing SRSBS scores were associated with prenatal (p≥0.02) and 78 months (p≥0.0007) blood lead categories.
Froehlich et al. 2009; Cross-sectional study of (NHANES 2001–2004); 2,588 children, ages 8–15 years (born 1986–1996) | PbB:; Tertiles:; T1: 0.2–0.8; T2: 0.9–1.3; T3: >1.3; Analysis: ADHD was diagnosed based on 4^th^ Edition of DSMMD. Logistic regression. Adjustments made for child sex, household income/poverty line ratio, race/ethnicity, mother’s age at child’s birth, NICU admission, postnatal secondhand tobacco smoke exposure, and preschool attendance. | Child PbB was associated with increased risk of ADHD. Adjusted ORs (95% CI) for ADHD (T1 reference):; - T2: 1.7 (0.97, 2.9); p=0.06; - T3: 2.3 (1.5, 3.8); p=0.001; Risks associated with blood lead and exposure to tobacco smoke were greater than additive.
Fruh et al. 2019; Prospective study of 1,006 mother-child pairs (pregnancies recruited 1999–2002); children evaluated at age 8 years; Massachusetts (Project Viva) | PbB (erythrocyte Pb):; Median:1.1; 25^th^–75^th^ % range: 0.6; Analysis: Behavior was assessed using parent-rated and teacher-rated BRIEF and SDQ at mean age 7.8 (±0.8 SD) years. Adjustments for age, sex, race/ethnicity, maternal IQ, maternal smoking during pregnancy, nulliparity, parental education, prenatal Hg, prenatal Mn, child race/ethnicity, HOME score, and household income category. | Erythrocyte Pb was associated with parent-rated SDQ emotional problems score, β for change in score for an IQR increase in maternal 2^nd^ trimester erythrocyte Pb (95% CI):; Parent-rated:; - Total difficulties: 0.36 (−0.04, 0.77); - Emotional problems: 0.18 (0.03, 0.33); Teacher-rated:; - Total difficulties: 0.38 (−0.15, 0.91); - Emotional problems: 0.04 (−0.13, 0.21); Erythrocyte Pb was associated with parent-rated BRIEF plan/organize subscale, β for change in score for IQR increase in maternal 2^nd^ trimester erythrocyte Pb (95% CI):; Parent-rated:; - Behavioral Regulation Index: 0.69 (−0.13, 1.51); - General Executive Composite: 0.73 (−0.06, 1.52); - Plan Organize: 0.85 (0.12, 1.59); Teacher-rated:; - Behavioral Regulation Index: 0.46 (−0.34, 1.26); - General Executive Composite: 0.42 (−0.39, 1.23); - Plan Organize: 0.67 (−0.22, 1.57)
Geier et al. 2018; Cross-sectional study of 2,109 children (age 10–19 years) from the NHANES (2003–2004) | PbB; Mean (SD): 1.16 (1.27); Quartiles, range:; - 0–50^th^: 0.2–0.88; - 50^th^–75^th^: >0.88–<1.26; - 75^th^–100^th^: 1.26–34.8; Analysis: Logistic regression of PbB and diagnosis of ADD (mean age 14.5±1.8 SD years), adjusted for gender, race, age, and SES. | Increasing PbB was associated with OR for diagnosis of ADD (95% CI):; OR for total sample (per µg/dL): 1.292 (1.025, 1.545) p=0.0301; Prevalence ratio for upper quartile PbB relative to 0–50^th^ percentile as reference:; - 50–75^th^ %: 1.28 (0.82, 2.00), p=0.2466; - 75–100^th^ %: 1.59 (1.05, 2.39), p=0.0130
He et al. 2019; Meta-analysis of seven studies of associations between PbB and risk of ADHD diagnosis | PbB; Range of study means: 0.73, 8.77; Analysis: Pooled mean differences in risk or odds ratios. | Increasing PbB was associated with increase in risk of diagnosis of ADHD. Mean risk difference (95% CI):; - All studies (7): 0.59 (0.50, 0.68), p<0.0001; - PbB <3 µg/dL: 0.47 (0.39, 0.56), p<0.0001; - Age 5–12 years compared to age >12 years: 1.35 (0.28, 2.41), p<0.0001
Hong et al. 2015; Cross-sectional study of 1,001 children (age 8–11 years) in South Korea | PbB:; Mean (SD): 1.80 (1.40); Range: 0.53–6.16; Analysis: Behavior was assessed using the ADHD Rating Scale. Multiple linear regression with log-transformed blood lead. Adjustments made for age, sex, residential region, paternal education level, yearly income, Full-Scale IQ, and environmental chemical concentrations (Hg, Mn, Cotinine, MnBP, MEOHP, bisphenol A, Pb) | PbB (log-transformed) was associated with increases in teacher-rated hyperactivity/impulsivity and total ADHD score. Regression coefficients (95% CI):; - Hyperactivity/impulsivity: 3.66 (1.18, 6.13); p=0.004; - Inattention: 2.72 (−0.12, 5.56); p=0.060; - Total score: 6.38 (1.36, 11.40); p=0.013; PbB (log-transformed) was associated with increases in parent-rated hyperactivity/impulsivity score. Regression coefficients (95% CI):; - Hyperactivity/impulsivity: 1.99 (0.17, 3.81); p=0.032; - Inattention: 0.94 (−1.27, 3.16); p=0.402; - Total score: 2.90 (−0.86, 6.68); p=0.131
Huang et al. 2016; Prospective study of mother infant pairs recruited 1997–2001 with follow-up of 578 children at age 6–13 years; Mexico. | PbB; Mean (SD): 3.4 (3.1); Analysis: ADHD symptoms were assessed using the Connors’ Rating Scales at mean age 9.1±1.3 years. Segmented regression with adjustments for maternal marital status, age educational years, SES, maternal smoking during pregnancy; child age at testing, sex, and birth weight. | PbB was associated with hyperactivity, restless-impulsivity and hyperactivity-impulsivity scores; regression slope per 1 µg/dL (95% CI):; - Hyperactivity: 1.2 (0.3, 2.0), p=0.01; - Restless-impulsive: 1.2 (0.3, 2.0), p=0.007; - Hyperactive-impulsive: 1.1 (0.2, 2.0), p=0.02
Ji et al. 2018; Prospective study of mother-infant pairs recruited beginning 1998 with follow-up of 1,479 children at median age 9.6 years; Boston Birth Cohort | PbB; Mean (SD):; - All: 2.2 (1.6); - ADHD: 2.4 (1.9); - No neurodevelopmental disorder: 2.1 (1.5); Analysis: Early child PbB was assessed in a group of children diagnosed with ADHD (n=299) and a control group of neurotypical children (n=1,180). Logistic regression with adjustments for maternal age, race/ethnicity, education, maternal smoking during pregnancy, intrauterine infection, parity, child sex, mode of delivery, preterm birth, and birth weight. | Increased PbB was associated with increased OR for ADHD diagnosis.; Males and females:; OR per ln PbB (µg/dL): 1.25 (1.01, 1.56) p=0.045; OR relative to <2 µg/dL reference:; - 2–4 µg/dL: 1.08 (0.81, 1.44) p=0.622; - 5–10 µg/dL: 1.73 (1.09, 2.73) p=0.019; OR relative to <5 µg/dL reference:; - 5–10 µg/dL: 1.66 (1.08, 2.56) p=0.020; Association was stronger for males:; OR 5–10 µg/dL relative to <5 µg/dL reference:; - Males: 2.49 (1.46, 4.26) p=0.001; - Females: 0.68 (0.27, 1.69) p-0.401; Joint effects of sex and PbB:; OR 5–10 µg/dL relative to <5 µg/dL reference:; - Males: 7.48 (4.29, 13.02) p <0.001; - Females 0.69 (0.28, 1.71) p=0.426
Joo et al. 2017; Case-control study of 214 child ADHD cases and 214 controls (age range 6–10 years), age recruited 2008–2019; South Korea | PbB; Gmean (SD):; Cases: 1.65 (1.45); Controls: 1.49 (1.48); Analysis: Odds ratio for ADHD adjusted for maternal education, family history of ADHD, and exposure to second-hand smoke. | Increased PbB was associated with increased OR for ADHD diagnosis; OR per µg/dL:; - All AHDH: 1.28 (0.89, 1.83); - Inattention: 1.63 (1.03, 2.58), p<0.05; - Hyperactivity/impulsivity: 1.04 (0.53, 2.07)
Joo et al. 2018; Prospective study of 1,751 mother-infant pairs recruited beginning 2006 with follow-up of 575 children at age 5 years; South Korea | PbB; Gmean (SD):; Early pregnancy: 1.28 (1.48); Late pregnancy: 1.24 (1.57); Cord: 0.90 (1.57); 2 years: 1.55 (1.49); 3 years: 1.43 (1.44); 5 years: 1.29 (1.38; Analysis: Behavior assessed using the Korean version of the child behavior checklist. Linear regression with adjustments for maternal age at child’s birth, parity, maternal education, household income, residential area type, and duration of breast feeding | Increased PbB was associated with increased total score for behavioral problems in females; β for score per µg/dL (95% CI):; PbB at age 2 years:; - Females: 3.82 (1.25, 3.69); - Males: 0.22 (−1.87, 2.32); PbB at age 3 years:; - Females: 2.43 (−1.00, 5.87); - Males: 0.48 (−2.17, 3.12); PbB at age 5 years:; - Females: 5.72 (0.44, 10.99); - Males: 1.37 (−2.06, 4.80)
Kim et al. 2016; Prospective study of 2,473 children (enrolled at age 7–8 years) with no history of development disorders, in South Korea (10 cities) | PbB:; Mean (95% CI); - Age 7–8 years: 1.64 (1.60, 1.68); - Age 9–10 years: 1.58 (1.55, 1.61); - Age 11–12 years: 1.58 (1.55, 1.61); Analysis: Autistic behavior was assessed in children at ages 11–12 years by ASSQ and SRS. Multiple binomial regression. Adjustments made for sex, fetal and environmental tobacco smoke exposure, paternal and maternal education levels, family income, low birth weight, breastfeeding, gestational week at delivery, children’s fish intake, and blood Hg concentration. | PbB (log transformed) at ages 7–8 years, but not ages 9–10 and 11–12 years, was associated with increased autistic behaviors. β (SE):; ASSQ; ○ PbB at 7–8 years: 0.151 (0.061, 0.242); ○ PbB at 9–10 years: −0.023 (−0.143, 0.097; ○ PbB at 11–12 years: 0.054 (−0.061, 0.170); SRS; - PbB at 7–8 years: 2.489 (1.378, 3.600); - PbB at 9–10 years: 1.295 (−0.235, 2.825); - PbB at 11–12 years: 0.724 (−0.727, 2.176)
Liu et al. 2014a; Prospective study of 332 mother-infant pairs from Shenzhen, Guangdong, China | PbB:; Mean (SD); - Low PbB group; ○ 1^st^ Trimester: 1.22 (0.28); ○ 2^nd^ Trimester: 1.01 (0.19); ○ 3^rd^ Trimester: 1.19 (0.23); ○ Delivery: 1.26 (0.25); - High PbB group; ○ 1^st^ Trimester: 6.49 (0.62); ○ 2^nd^ Trimester: 5.63 (0.43); ○ 3^rd^ Trimester: 6.31 (0.51); ○ Delivery: 6.65 (0.55); Analysis: Infant behavior was assessed at 3 days of age by NBNA. Multiple and multivariate linear regression. Adjustments made for maternal IQ, hemoglobin, tobacco use, educational level, and parent’s occupation. | A negative association was observed between 1^st^ trimester PbB and NBNA scores but not 2^nd^ trimester, 3^rd^ trimester, and delivery PbB. β (95% CI):; - 1^st^ Trimester: −4.86 (−8.831, −0.889); p=0.03; - 2^nd^ Trimester: −3.98 (−8.180, 0.220); p=0.07; - 3^rd^ Trimester: −3.65 (−6.609, 1.309); p=0.21; - Delivery: −3.39 (−7.531, 0.751); p=0.11
Liu et al. 2015b; Prospective study of 665 children (enrolled at ages 3–13 years) in Jintan City, China | PbB:; Mean (SD): 6.26 (2.54); Analysis: PbB was measured at ages 3–5 years. Sleep was assessed at ages 9–13 years by parents using the CSHQ and by children using an adolescent sleep questionnaire. Multiple logistic regression. Adjustments made for age, sex, parental education, and school district. | Positive associations were observed between PbB and sleep onset delay. β (95% CI): 0.033 (0.009, 0.056); p=0.006
Park et al. 2016; Case-control study of child (mean age 9 years) ADHD cases (n=114) and controls (n=114) identified in 2013 in Busan, Korea | PbB:; Gmean ± SD (range):; Cases: 1.90±0.86 (0.37, 5.35); Controls: 1.59±0.68 (0.18, 3.41); Q1: 0.18, 1.12; Q2: 1.13, 1.71; Q2: 1.72, 2.29; Q4: 2.30, 5.35; Analysis: ADHD assessed with CPT and parental ADHD-RS at age 9 years. Multiple logistic regression and linear regression. Adjustments made for age, sex, gestational age, birth weight, economic status, parental education, and parent smoking behavior. | Increasing PbB was associated with diagnosis of ADHD. OR (95% CI): All subjects: 1.60 (1.04, 2.25), p=0.03; Relative to Q1:; Q2: 1.26 (0.56, 2.84), p=0.39; Q3: 1.26 (0.55, 2.87), p=0.61; Q4: 2.54 (1.09, 5.94), p=0.03; No association between scores on ADHD-RS or CPT. β (SE) for score per log-transformed PbB:; ADHD-RS score: 1.74 (1.29), p=0.18; CPT score:; - Omission errors: 0.05 (2.29), p=0.99; - Commission errors: −0.72 (2.08), p=0.72; - Response time: 2.48 (2.60), p=0.12; - Response time variability: 2.26 (2.23), p=0.31
Sioen et al. 2013; Prospective study of 270 children enrolled in the birth cohort from the Flemish Environment and Health Study (2002–2006); followed birth to 8 years | PbB:; Umbilical cord mean (25^th^–75^th^ percentiles): 1.43 (0.73–2.53); Analysis: Child behavior was assessed at ages 7–8 years by SDQ. Multiple logistic regression. Adjustments made for BMI of the parents, age of the mother at pregnancy, weight increase of the mother during pregnancy, smoking during pregnancy, current smoking habits of parents, smoking behavior of the maternal grandmother before the birth of the mother, highest education level of both parents, sex of the child, and serious infections of the child since birth. | Umbilical cord PbB was associated with an increased risk of hyperactivity. OR (95% CI): 2.940 (1.172, 7.380); p=0.022
Stroustrup et al. 2016; Prospective study of 948 mother-infant pairs, followed from birth (recruited 2007–2011), with follow-up of 500 children at age 24 months; Mexico City | PbB:; Median (IQR):; 2^nd^ trimester: 2.8 (2.7); Bone Pb; Median (SD); - postpartum tibia: 2.6 (8.6); - postpartum patella: 4.9 (8.9); Analysis: Child temperament was evaluated at age 24 months using the TTS. Logistic regression. Adjustments made for postnatal depression (EPDS) | Increasing PbB and tibial Pb were associated with increasing probability of child demonstrating more difficult temperament score. OR (95% CI) for TTS score (easy, intermediate or difficult), easy score as reference:; EPDS:; Intermediate: 1.23 (0.78, 1.93); Difficult: 2.53 (1.69, 3.77); OR corresponding to 1 unit change of ln(maternal PbB µg/dL):; Intermediate: 0.88 (0.59, 1.3); Difficult: 1.52 (1.03, 2.26); Tibia Pb OR corresponding to 1 unit change per 10 μg/g change in tibia Pb:; Intermediate: 1.25 (0.95, 1.65); Difficult: 1.32 (1.01, 1.73); Probability of demonstrating difficult TTS score was approximately doubled if EPDS score was high.
Wang et al. 2008; Case-control study of 630 children with ADHD and 630 matched controls without ADHD in China; children were assessed at ages 4–12 years; data collection period: 2003–2007 | PbB:; Means (SE); - ADHD cases: 8.77 (3.89); - Controls: 5.76 (3.36); - Cases versus control: p<0.05; Tertiles:; - T1 (reference): ≤5; - T2: 5–10; - T3: ≥10; Analysis: ADHD was diagnosed based on 4^th^ Edition of DSMMD Multiple logistic regression. Adjustments made for BLLs, household composition, birth weight, twin, family history of ADHD, labor complications, cesarean, premature labor, NICU, mother’s age, father’s age, parents’ education, prenatal tobacco exposure, and prenatal alcohol exposure. | PbB was associated with an increased risk of ADHD. OR (95% CI):; - T2: 4.92 (3.47, 6.98); p<0.01; - T3: 6.00 (4.11, 8.77); p<0.01
Winter and Sampson 2017; Prospective study of birth cohort (n=1,255) recruited in 1995–1997, with follow-up from birth to age 18 years (n=208), Chicago | PbB:; Means (SD) at age <6 years: 6.14 (4.58); Analysis: Impulsivity and anxiety or depression was evaluated using the Child Behavior Checklist. Linear regression with and without CEM. Adjustments made for child age at testing, gender, race/ethnicity; and primary caregiver immigrant generational status, marital status, education, Temporary Assistance for Needy Families receipt; proportion of child’s residential neighborhood that is non-Hispanic Black, Hispanic and below poverty line; and proportion of child’s residential neighborhood that was tested for Pb exposure. | Increasing PbB was associated with increasing impulsivity and anxiety or depression scores. β for score per µg/dL (95% CI):; Ordinary least squares:; - Impulsivity: 0.06 (0.01, 0.12); - Anxiety or depression: 0.09 (0.03, 0.16); Course exact matching:; - Impulsivity: 0.08 (0.01, 0.16); - Anxiety or depression: 0.11 (0.01, 0.21)
Neuromotor neurosensory function
Chiodo et al. 2004; Prospective study of 237 children, age 7.5 years; Detroit, Michigan | PbB:; Mean (SD, range):; 5.4 (3.3, 1–25); Analysis: Neurobehavioral test battery administered at 7.5 years. Multiple nonparametric regression. Adjustments made for SES, education level, number of children <18 years, HOME score, PPVT-R, sex, parity, FES, prenatal alcohol exposure, crowding, life stress of the child and caretaker, child’s age, prenatal exposure to cocaine and marijuana, conflict tactics, and prenatal smoking. | Association between increasing child PbB and decreasing performance on tests battery:; Tests with declines (p≤0.05), β at <3, <5, <7.5, or <10 µg/dL:; - Block design: <10, <5; - Digit span backwards: <7.5; - Beery visual-motor integration: <10, <5; - Matching familiar figures (number correct): <5; - Attention-TRF: <3; - Barkley-inattention: <5 <3; - Withdrawn-TRF: <7.5, <3; - Barkley off-task: <10, <5; - Sternberg reaction time “Yes”: <5, <3; - Color naming: <5; - CPT visual (number correct): none; - Seashore rhythm: <3; - Mental rotation RT “forward”: <10, <5
Dietrich et al. 1987; Prospective study of 185 mother-infant pairs from Cincinnati, Ohio (infants born 1979–1984) | PbB:; Mean (SD, range); - Prenatal (maternal): 8.3 (3.8, 1–27); - Neonatal (10 days): 4.9 (3.3, 1–24); - Neonatal (3 months): 6.3 (3.8, 1–22); - Neonatal (6 months): 8.1 (5.2, 1–36); Analysis: Neurodevelopmental assessments (PDI of the BSID) were conducted at age 6 months. Adjustments made for obstetrical complications, postnatal complications, mother’s iron status during pregnancy, gestational age by examination, birth weight, CITAC, HOME score, SES, and race of infant. | Associations with 3-month ln PbB, β (SE):; - PDI: −13.248 (4.250); p=0.002; - Motor maturity: −0.570 (0.260); p=0.03; Associations with 6-month ln PbB, β (SE):; - PDI: −2.117 (0.916); p=0.02; - Motor maturity: −0.092 (0.056); p=0.11
Dietrich et al. 1989; Prospective study of 192 mother-infant pairs from Cincinnati, Ohio (infants born 1979–1984) | PbB:; Mean (SD, range); - Prenatal (maternal): 8.2 (3.6, 1–27); - Neonatal (10 days): 4.8 (3.1, 1–23); - Neonatal (3 months): 6.0 (3.5, 1–20); - Neonatal (6 months): 7.9 (4.8, 1–35); - Neonatal (9 months): 11.5 (6.9, 2–57); - Neonatal (12 months): 14.2 (7.3, 4–47); Analysis: Neurodevelopmental assessments (PDI of the BSID) were conducted at age 12 months. Multiple linear regression and SEM. Adjustments made for obstetrical complications, postnatal complications, birth weight, gestational age, child race, child sex, CITAC, maternal age, gravidity, parity, maternal total iron binding capacity, child health variables (number of infections during the last year, current illness, iron status), HOME, SES, maternal IQ, and number of children in the home. | Associations between increasing prenatal PbB and decreasing 12-month PDI score β (SE):; - PDI: −14.09 (7.26); p=0.054; SEM indicated significant associations between increasing prenatal PbB and race and 12-month PDI.; - Prenatal PbB --> 12-month PDI: −0.47, p≤0.05; - Prenatal PbB × race --> birth weight: 0.97, p≤0.05; - Race --> 12-month MDI: −0.72, p≤0.05
Dietrich et al. 1993b; Prospective study of 245 children (age 6 years, born 1979–1984) from Cincinnati, Ohio | PbB:; Mean (SD); - Prenatal (maternal): 8.4 (3.8); - Neonatal: 4.8 (3.1); - Life average; - 6 years: 10.1 (5.6); - Lifetime average quartile range: 7–22; Analysis: Motor function assessed with test battery at age 6.5 years using BOTMP. Multiple linear regression. Adjustments made for maternal age at birth, birth weight, gestational age, 5-minute Apgar, race, SES, HOME score, maternal IQ, marital status, and parents’ education level. | Associations between increasing PbB and decreasing motor performance measured at age 6 years. Tests with significant (p≤0.05) declines (β) associated with neonatal (N), mean lifetime (L) or concurrent (C) PbB:; - Bilateral coordination: N, M; - Visual motor control: C; - Upper limb speed and dexterity: C, M, N; - Fine motor composite: C, M, N; Bilateral coordination score exhibited trend for decreasing score with increasing PbB.
Ethier et al. 2012; Prospective longitudinal; 149 children; age 10–13 years; Canadian Arctic (Nunavik) | PbB:; Mean (SD, range); - Cord: 4.6 (3.1, 0.8–19.5); - 11 years: 2.6 (2.3, 0.4–12.8); Analysis: VEPs were assessed at age 10 and 13 years. Multiple linear regression. Adjustments made for smoking during pregnancy, marijuana and alcohol use during pregnancy, sex, cord DHA, current DHA, and cord and current child blood levels of Se, Hg, and PCB-153. | Association between increasing cord PbB and delay of N150 latency of VEP at multiple contrast levels. Mean latency (estimated from reported bar plot):; - ≥4.15 µg/dL: ~160 ms, p<0.05; - <4.15 µg/dL: ~153 ms (reference)
Fraser et al. 2006; Prospective study; 101 children (2000–2002); age 5 years; Canadian Arctic (Nunavik) | PbB:; Mean (SD):; Cord: 4.9 (3.7); Child: 5.3 (4.9); Analysis: Motor function was assessed at age 5 years (tremor, sway, reaction time). Multiple linear regression with log-transformed PbB. Adjustments made for binge drinking during pregnancy, child’s weight at testing time, and blood PCB153 concentration at testing time. | Associations between increasing concurrent PbB and fine motor function (β):; - Hand movements: 0.30, p≤0.01; - Sway velocity: 0.28, p≤0.01; - Transversal sway: 0.24, p≤0.05
Kim et al. 2013b; Prospective birth cohort (MOCEH study; 2006–2010); 884 mother-infant pairs; South Korea | PbB:; Gmean (GSD); Early pregnancy: 1.4 (1.5); Late pregnancy: 1.3 (1.5); Analysis: Motor performance (PDI) evaluated at age 6 months using the BSID II. Multiple linear regression. Adjustments made for infant birth weight, infant sex, maternal age, maternal education level, family income, breastfeeding status, residential area, and Pb and Cd concentrations. | Maternal PbB was not associated with PDI score (β) per 1 µg/dL change in PbB (95% CI):; -1.69 (−3.65, −0.27); p=0.09
Liu et al. 2018b; Cross-sectional study of 234 children (age 3–7 years) in evaluated in 2014; China. | PbB:; Median (SE); e-waste location: 4.94 (0.20); reference location: 3.85 (1.81); Analysis: Hearing was evaluated (pure-tone air conduction) in 146 children who resided near an e-waste site and 88 children from a reference location. Logistic regression of hearing loss and PbB. Adjustments made for age, sex, body weight and height, BMI, parent education, family member smoking, family income, distance to road, noise (from various sources), and earphone use. | Increasing PbB (but not urinary cadmium) was associated with hearing loss (pure-tone air conduction score >25 dB); OR per µg/dL (95% CI):; - Hearing loss 1.24 (1.029, 1.486) p<0.05; - Low frequency loss: 1.02 (0.869, 1.190); - High frequency: 1.08 (0.839, 1.379)
Osman et al. 1999; Retrospective study of longitudinal cohort of 155 children, age 4–14 years; Katowice region of Poland | PbB: Median (range); - 7.2 (1.9–28.1); Analysis: Hearing thresholds and BAEP evaluated at age 4–14 years. Multiple linear regression. Adjustments made for age, sex, BLL, Apgar score, ears without pathologies at inspection, nasopharynx without pathologies at inspection, ear diseases, frequent colds, mumps, gentamycin, environmental noise, and maternal smoking during pregnancy. | β per 1 change in PbB for right ear (95% CI) for full cohort:; - 0.5 kHz: 0.054 (0.035, 0.074); - 1 kHz: 0.044 90.026, 0.062); - 2 kHz: 0.048 (0.029, 0.066); - 4 kHz: 0.060 (0.039, 0.081); - 6 kHz: 0.068 (0.044, 0.092); - 8kHz: 0.072 (0.050, 0.094); β per 1 change in PbB for left ear (95% CI):; - 0.5 kHz: 0.051 (0.026, 0.075)*; - 1 kHz: 0.032 (0.014, 0.050)*; - 2 kHz: 0.036 (0.019, 0.053)*; - 4 kHz: 0.039 (0.020, 0.059)*; - 6 kHz: 0.004 (0.044, 0.049)*; - 8 kHz: 0.047 (0.024, 0.080)*; Association (p<0.05) between increasing PbB and increasing hearing threshold in stratum <10 µg/dL (thresholds not reported).; No association between PbB and BAEPs.
Polanska et al. 2018; Prospective study of 539 mother-child pairs, recruited in 2007, with follow-up of children at age 2 years; 280 blood and 303 cord blood samples were randomly chosen for analysis; Polish Mother and Child Cohort (REPRO_PL), Poland | PbB:; Gmean (SD) (range); - 2^nd^ trimester: 0.99 (0.15) (0.29, 2.63); - Cord: 0.96 (0.16) (0.24, 5.65); Analysis: Cognitive function was assessed at age 2 years using BSID III. Linear regression. Adjustments made for person who conducted child examination, mother’s age, mother’s education, sex of the child, age of the child, and mother’s cotinine levels. | Increasing cord PbB was associated with decreasing cognitive scores in males. β score per µg/dL (95% CI): Motor score:; - Females: 0.48 (−1.55, 2.52), p=0.64; - Males: −0.70 (−2.90, 1.51), p=0.53
Rodrigues et al. 2016; Prospective study with cross-sectional analysis of PbB and fine motor score; n=524 children, 20–30 months; Sirajdikhan and Pabna Bangladesh | PbB:; Median (P25, P75, Maximum); - Sirajdikhan: 7.6 (5.5, 10.4); - Pabna: <LOD (<LOD, 3.8, 13.8); Analysis: Cognitive function was assessed at age 2–3 years using BSID. General linear model regression. Adjustments made for maternal age and education, exposure to environmental tobacco smoke, child sex, HOME score, maternal Raven score, and child hematocrit. | Child PbB was associated with decreasing cognitive scores β score per lnPbB µg/dL (SE):; Fine motor score:; - Sirajdikhan: 0.07 (0.11), p=0.50; - Pabna: −0.07 (0.11), p=0.50
Silver et al. 2016; Prospective study; infants assessed for hearing at 2 days and vision at 6 weeks. Maternal blood Pb collected at mid pregnancy and late pregnancy and in cord blood; Hebei Province, China | [underlined: Exposure for infants with hearing data:]; Gmean (SD); Mid-pregnancy: 2.4 (2.5) (n=343); Late-pregnancy: 2.7 (2.3) (n=362); Cord: <LOQ (n=321); [underlined: Exposure for infants with vision data:]; Gmean (SD); Mid-pregnancy: 2.4 (2.6) (n=1,038); Late-pregnancy: 2.9 (2.2) (n=1,058); Cord: <LOQ (n=949); Analysis: Data were analyzed by general linear model. Adjustments made for age at testing, sex, cord blood iron status, gestational age, birth weight, and head circumference. | Increasing late-pregnancy PbB was associated with decreasing visual acuity score and increasing ABR central-peripheral response time ratios (ABR-C-P ratio); percent change in score relative to <2 µg/dL reference group (95% CI):; Visual acuity score for PbB strata:; - >3.8 µg/dL: −8.5 (−14.7, −2.4); - 2–3.8 µg/dL: −7.2 (−13.3, −1.1)*; ABR C-P ratio for PbB strata:; - >3.8 µg/dL: 4.6 (1.8, 7.4); - 2–3.8 µg/dL: 3.2 (0, 5.9)*
Taylor et al. 2018; Prospective study of 14,541 mother-infant pairs, followed from birth (recruited 1991–1992) with follow-up of 1,558 children at age 7 years; Avon, United Kingdom | PbB:; Mean (SD) at gestation week 11; Mean (SD) 3.66 (1.55); Range: 0.20, 19.14; Analysis: Motor skills were evaluated using the Movement Assessment Battery at age 7 years. Logistic regression. Adjustments made for maternal education, smoking in pregnancy, alcohol in pregnancy, age, parity, and sex of child. | PbB was not associated with scores on motor skill tests. OR for scores per µg/dL prenatal PbB (95% CI):; Heal to toe: 0.99 (0.74, 1.33), p=0.93; Beanbag: 0.88 (0.58, 1.32), p=0.54; Threading lace: 1.12 (0.83, 1.50), p=0.47; Peg board (preferred hand): 1.19 (0.88, 1.60), p=0.26; Peg board (non-preferred hand): 1.14 (0.85, 1.54), p=0.37
Tellez-Rojo et al. 2006; Prospective study of 294 children followed from birth (1994–1995, 1997–1999) to age 2 years; Mexico City | PbB:; Mean (SD):; - Cord: 4.85 (3.0); - 12 months: 4.27 (2.14); - 24 months: 4.28 (2.25); Analysis: Motor performance (PDI) evaluated at ages 6 and 12 years using the BSID II. Multiple linear regression with ln-transformed PbB. Adjustments made for sex, birth weight, and maternal IQ. | Association between increasing concurrent PbB and PDI score at age 24 months (β) per 1 ln change in PbB:; 12 Months:; - <10 µg/dL: −0.01, p=0.98; - ≥10 µg/dL: −1.19, p=0.01; 24 Months:; - <10µg/dL: −1.18. p<0.01; - ≥10 µg/dL: 0.04, p=0.89
Zhou et al. 2017; Prospective study of 139 mother-infant pairs recruited in 2010 and followed from birth to 24–36 months, Shanghai, China | PbB:; Gmean (95% CI); Mid-late pregnancy: 3.30 (3.05, 3.57); Analysis: Neurobehavioral evaluations were conducted at age 24–36 months using Gesell Development Scale. Maternal prenatal stress was evaluated using the Symptom Checklist-90-Revised scale (SCL-90-R). Linear regression. Adjustments made for maternal age at enrollment, maternal education, family monthly income, gestational week, child sex, birth weight, age, and family economic status. | Maternal PbB was not associated with child development quotient in complete cohort. β (95% CI) for development quotient per µg/dL:; - Gross motor: 3.31 (−6.11, 12.73); - Fine motor: 0.49 (−11.27, 12.24)
Altered brain structure and chemistry
Cecil et al. 2008 (Brubaker et al. 2010); Prospective study of 157 adults, age 19–24 years from a birth cohort born 1979–1984 from Cincinnati, Ohio | PbB: Mean (SD, range):; - 6 months–6.5 years: 13.3 (5.9, 4.6–37.2); Analysis: Brain volume evaluated at ages 19–24 years using MRI. Multiple linear regression with ln-transformed PbB. Adjustments made for age at time of scanning, and birth weight. | Association (p≤0.001) between increasing childhood mean PbB and decreasing brain volume affecting 1.2% of the total gray matter. Effects were greater in males than females. Largest effects were in the anterior cingulate cortex. The association was strongest for PbB measured at age 5–6 years.
Cecil et al. 2011; Prospective study of 159 adults, age 19–24 years from a birth cohort born 1979–1984 from Cincinnati, Ohio | PbB: Mean (SD, range):; - 6 months–6.5 years: 13.3 (6.1, 4.7–37.2); Analysis: Brain metabolites were imaged at ages 19–24 years using proton magnetic resonance spectroscopy. Multiple linear regression with ln-transformed PbB. Adjustments made for age at time of imaging, FSIQ. | Association (p<0.05) between increasing childhood mean PbB and decreasing regional levels of gray matter N-acetyl aspartate, glutamate-glutamine, creatine, and phosphocreatine, and white matter cholines. Areas affected include the basal ganglia, cerebellum vermis, parietal white matter, and frontal white matter.

ABR = Brainstem Auditory Response; ADD = attention deficit disorder; ADHD = attention deficit/hyperactivity disorder; ADHD-RS = ADHD-rating scale; AFGS = Auditory Figure-Ground Subtest; ASSQ = Autism Spectrum Screening Development Questionnaire; AUC = area under the curve; BAEP = Brainstem Auditory Evoked Potentials; BLL = blood lead level; BOTMP = Bruininks-Oseretsky Test of Motor Proficiency; BRIEF = Behavior Rating Inventory of Executive Function; BSID = Bayley Scales of Infant Development; CANTAB = Computer-based Tests of Working Memory; Cd = cadmium; CDIIT = Comprehensive Developmental Inventory for Infants and Toddlers; CEM = Coarsened Exact Matching; CI = confidence interval; CITAC = Composite Index of Tobacco and Alcohol Consumption; CKD = chronic kidney disease; CL = confidence limit; CPT = Continuous Performance Test; CSHQ = Children’s Sleep Habits Questionnaire; DHA = docosahexaenoic acid; DISC = Diagnostic Interview Schedule for Children-Caregiver Module; DSMMD = Diagnostic and Statistical Manual of Mental Disorders; ECDI = Early Child Development Inventory; EOG = End of Grade; EPDS = Edinburgh Postnatal Depression Scale; ETS = Environmental Tobacco Smoke; FES = Family Environmental Scale; FSIQ = full-scale IQ; FTII = Fagan Test of Infant Intelligence; FWS = filtered word subtest; GCI = General Cognitive Index; Gmean = geometric mean; GSD = geometric standard deviation; GSI = Global Severity Index; Hg = mercury; HIECDI = Harold Ireton Early Child Development Inventory; HOME = The Home Observation for Measurement of the Environment Inventory; HOME57 = HOME at age 57 months; HOME120 = HOME at 10 years; HOME-SF = HOME Short Form; IQ = intelligence quotient; IQR = interquartile range; ISAT = Illinois Standard Achievement Tests; K-ABC = Kaufman Assessment Battery for Children; KEDI-WISC = Korean Educational Development Institute’s WISC; LOD = limit of detection; MDI = Mental Development Index; MEAP = Michigan Educational Assessment Program; MEHP = mono-2-ethylhexyl phthalate; MEOHP = mono-2-ethyl-5-oxohexyl phthalate; Mn = manganese; MnBP = mono-n-butyl phthalate; MOCEH = Mothers and Children’s Environmental Health; MRI = magnetic resonance imaging; MSCA = McCarthy Scales of Children’s Abilities; MSEL = Mullen Scales of Early Learning; NA = not available; NBNA = Neonatal Behavioral Neurological Assessment; ND= not detected; NHANES = National Health and Nutrition Examination Survey; NICU = neonatal intensive care unit; OR = odds ratio; PALS-K = Phonological Awareness Literacy Screening-Kindergarten; Pb = lead; PCB-153 = 2,2’,4,4’,5,5’-hexachlorobiphenyl; PDI = Psychomotor Development Index; PIR = poverty-to-income ratio; PPVT-R = Peabody Picture Vocabulary Test Revised; PRDBS = Parental Report of Predelinquent and Delinquent Behavior Survey; RAVEN = standard progressive matrices; a nonverbal group test typically used in educational settings; RR = relative risk; SAT = Standardized Assessment Test; S-BIS = Stanford-Binet Intelligence Scale; SCL-90-R = Symptom Checklist-90-Revised scale; SD = standard deviation; SDQ = Strengths and Difficulties Questionnaire; Se = selenium; SE = standard error; SEM = structural equation modeling; SES = socioeconomic status; SRBDS = Self-Reported Delinquent Behavior Survey; SRS = Social Responsiveness Scale; TRF = Teacher Report Form from the Child Behavior Checklist; TTS = Toddler Temperament Scales; UCL = upper confidence limit; VEP = visual evoked potential; WAdSI = Wechsler Adult Scale of Intelligence; WASI = Wechsler Abbreviated Scale of Intelligence; WISC = Wechsler Intelligence Scale for Children; WISC-R = WISC-Revised; WPPSI-R = Wechsler Preschool and Primary Scale of Intelligence, Revised; WRAT-R = Wide Range Achievement Test-Revised

Table 10 Selected Epidemiology Studies Evaluating Neurodevelopmental Effects in Adults at Mean Blood Lead Concentrations (PbB) ≤10 µg/dL

Reference and study population | PbB (µg/dL) and analysis | Outcomes
Cognitive abilities
Krieg et al. 2005; Cross-sectional study of 5,662 adults, age 20–59 years (from NHANES III, 1988–1994). | PbB:; - Gmean (range): 2.51 (0.7, 41.8); - Percent <10: 96%; Analysis: Cognitive function was assessed at age 20–59 years using the NBES. Multiple linear regression with log-transformed PbB. Adjustments made for sex, age, education, family income, race/ethnicity, computer or video game familiarity, alcohol use, test language, and survey phase. | No associations between PbB and performance scores for:; - Simple visual reaction time:; ○ Mean reaction time: p=0.24; - Symbol-digit substitution; ○ Mean total latency: p=0.27; ○ Number of errors: p=0.82; - Serial digit learning; ○ Trials to criterion: p=0.26; ○ Total score: p=0.24
Muldoon et al. 1996; Cross-sectional, mean age 70±4 (SD) years study of 530 adult women recruited from the Study of Osteoporotic Fractures (1990) | PbB: Mean (SD):; - All: 4.8 (0.4); - Rural: 4.5 (0.4); - Urban: 5.4 (0.4); - Low: <4; - Medium: 4–7; - High: >7; Analysis: Cognitive function was assessed at age ≥65 years using a modification of the MMSE, WASI-R, and IMT. Analysis of variance and covariance. Adjustments made for age, education, smoking, and alcohol consumption. | Difference in mean test scores between PbB categories (ANOVA). OR (95% CI) for poor performance (low PbB reference):; Rural; - Trailmaking B: ANOVA, p=0.03:; ○ Medium PbB: 2.05 (1.05, 4.02); ○ High PbB: 2.60 (1.04, 6.49); - Digit symbol (correct): ANOVA, p=0.03; ○ Medium PbB: 2.03 (1.06, 3.88); ○ High PbB: 3.73 (1.57, 8.84); - Incidental memory: ANOVA, p=0.70; ○ Medium PbB: 1.37 (0.77, 2.41); ○ High PbB: 1.89 (0.83, 3.41); Urban; - Trailmaking B: ANOVA, p=0.70; ○ Medium PbB OR: 0.97 (0.40, 2.40); ○ High PbB OR: 0.79 (0.20, 3.04); - Digit symbol (correct): ANOVA, p=0.20; ○ Medium PbB OR: 0.61 (0.25, 1.50); ○ High PbB OR: 0.64 (0.16, 2.47); - Incidental memory: ANOVA, p=0.25; ○ Medium PbB OR: 0.50 (0.22, 1.16); ○ High PbB OR:0.99 (0.28, 1.16)
Payton et al. 1998; Longitudinal study 141 males, mean age 67±6.8 (SD) years (from Normative Aging Study, 1988–1994) | PbB: Mean (SD):; - 5.5 (3.5); - Q1: 1.4; - Q2: 3.5; - Q3: 5.4; - Q4: 9.8; Analysis: Cognitive function was assessed at age 67 years using NBES, WASI-R, and CERAD. Multivariate linear regression. Adjustments made for age and education. | Association between increasing PbB and performance on various cognitive tests; coefficient (SE):; - Pattern recognition: 0.074 (0.032), p=0.02; - Vocabulary: −0.841 (0.20), p=0.0001; - Word list memory: −0.182 (0.086), p=0.036; - Boston naming test: −0.036 (0.016), p=0.028; - Verbal fluency: −0.230 (0.120), p=0.09
Power et al. 2014; Longitudinal study 584 adult females, mean age 61±6 (SD) years (from Nurses’ Health Study 2002–2008) | PbB: Mean (SD):; - 2.9 (1.9); Tibia Pb (µg/g): Mean (SD):; - 10.5 (9.7); Patella Pb (µg/g): Mean (SD):; - 12.6 (11.7); Analysis: Cognitive function was assessed using a telephone interview (TICS). Linear mixed model regression. Adjustments made for variables for time, data source (cognitive and lead), alcohol consumption, smoking status, education, husband’s education, menopausal status/hormone replacement therapy use, aspirin use, physical activity, ibuprofen use, aspirin use, vitamin E supplementation, percent of residential census tract of white race/ethnicity, and median income of residential census track, including both main effects and interactions with change in age from baseline cognitive test and a marker for second or subsequent interview. | No associations between PbB (or bone Pb) and performance on various cognitive tests; β for 1-age year change in score per 1 SD PbB (95% CI):; - Overall cognition: −0.013 (−0.044, 0.017); - Verbal memory: 0.006 (−0.037, 0.050)
Przybyla et al. 2017; Cross-sectional study 498 adults (age 60–84 years) from NHANES 1999–2002, United States | PbB:; Gmean (range): 2.17 (0.4, 16.4); Analysis: Cognitive function was assessed using the DST of the WAdSI. Path analysis. Adjustments made for sex, age, race/ethnicity, education, smoking, and lipids. | Increasing PbB was associated with lower DST scores. β for DST score per lnPbB µg/dL (95% CI):; - -0.10 (−0.20, −0.006), p=0.04
Seo et al. 2014; Cross-sectional study of 31 retired female Pb workers, mean age 60.4±5.5 (SD) years, and 34 sex and age-matched controls in South Korea (date not reported) | PbB: Mean (SD):; PbB: Gmean (range):; - Exposed: 4.07 (0.88–13.5); - Controls: 2.00 (1.24–6.47); Analysis: Verbal working memory was assessed using the N-back test with concurrent brain MRI. T-test for means of memory test scores; multiple linear regression with log-transformed PbB for MRI. Adjustment made for educational level. | Lower mean score on verbal working memory test in retired workers compared to controls:; Accuracy % (SD), exposed versus control:; - 1-Back test: 55.9 (19.8) versus 65.4 (19.4), p=0.056; - 2-Back test: 61.4 (20.1) versus 77.2 (15.6), p=0.001; Decreased activation of DLPFC, IPC, and IFC; β per log-PbB (95% CI):; - Left DLPFC: −0.125 (−0.232, −0.018), p<0.05; - Right DLPFC: −0.120 (−0.241, 0.0001) p≥0.05; - Right IPC: −0.094 (−0.172, −0.015), p<0.05; - Right IFC: −0.087 (−0.152, −0.022), p<0.05
Shih et al. 2006; Cross-sectional study of 985 adults, mean age 59.4±6.0 (SD) years (from Baltimore Memory Study) | PbB: Mean (SD):; - 3.46 (2.23); Tibia Pb (µg/g): Mean (SD):; - 18.72 (11.24); Analysis: Cognitive performance evaluated with various (20) tests of language, eye-hand coordination, processing speed, executive function, verbal memory and learning, visual memory, and visuoconstruction. Multiple linear regression. Adjustments made for age, sex, technician (categorical), and presence of APOE-ε4 allele (ε2ε4, ε3ε4, ε4ε4 versus noε4 allele). | Performance on cognitive tests declined (p<0.05) with increasing tibia Pb, but not PbB; β per 1 µg/g tibia Pb (SE):; - Language: −0.0083 (0.0023), p≤0.01; - Processing speed: −0.0042 (0.0021), p<0.01; - Eye-hand: −0.0079 (0.0020), p≤0.01; - Executive function: −0.0075 (0.0019), p≤0.01; - Verbal memory and learning: −0.0078 (0.0024), p≤0.01; - Visual memory: −0.0067 (0.0023), p≤0.01; - Visuoconstruction: −0.0122 (0.0027), p≤0.01; The above associations were attenuated (p≥0.05) in models that included race/ethnicity and years of education.
Weisskopf et al. 2007; Longitudinal study cohort 1089 males, mean age 68.7±7.4 (SD) years (from Normative Aging Study, 1991–2001) | PbB: Median (IQ range):; - 5 (3–6); Tibia Pb (µg/g): Median (IQ range):; - 20 (13–28); Patella Pb (µg/g): Median (IQ range):; - 25 (17–37); Analysis: Cognitive performance (attention/working memory/executive function, short-term memory, visuospatial, verbal, language) evaluated using NES2, WASI-R, CERAD, MMSE, and VMI. Linear regression and nonlinear spline regression. Adjustments made for age, age squared, education, smoking, alcohol intake, years between bone Pb measurement and first cognitive test, and years between the cognitive tests. | Cross-sectional analysis: association between lower score on vocabulary test with increasing PbB; β per 3 µg/dL increase in PbB (95% CI):; - Vocabulary: −1.26 (−2.08, −0.44), p=0.003; No associations between PbB or bone Pb on other performance domains.; Longitudinal analysis (two tests): Association between change in test scores and increasing bone Pb; β per IQR (95% CI): Patella Pb:; - Visuoconstruction: −0.067 (−0.11, −0.02), p=0.0041; Tibia Pb:; - Pattern comparison latency (ms): 0.079 (0.04, 0.12), p=0.0004
Weuve et al. 2006; Longitudinal study cohort of 915 males, mean age 68.7±7.4 (SD) years (from Normative Aging Study, 1991–1997) | PbB: Median (IQ range):; - 5.2 (2.9); - 94% <10; Tibia Pb (µg/g): Median (IQ range):; - 19 (13–28); Patella Pb (µg/g): Median (IQ range):; - 27 (18–39); Analysis: Cognitive performance using MMSE. Nonlinear spline regression. Adjustments made for age, age squared, education, experience with computers, time between Pb assessment and cognitive assessment and for the blood analyses, and time between cognitive measures. | Association between increasing PbB and decreasing scores of cognitive function tests among ALAD-2 carriers (but not wild-type). Change in MMSE score per IQR in PbB, 3 µg/dL (95% CI):; - ALAD-2: −0.29 (−0.56, −0.02); - ALAD wildtype: −0.05 (−0.16, 0.06); No association with bone Pb.
Weuve et al. 2009; Longitudinal study cohort 587 females, mean age 61 (range 47–74) years (from Nurses’ Health Study, 2000–2005) | PbB: Mean (SD):; - 2.9 (1.9); Tibia Pb (µg/g): Median (SD):; - 10.5 (9.7); Patella Pb (µg/g): Median (SD):; - 12.6 (11.6); Analysis: Cognitive function was assessed using a telephone interview (TICS). Multiple linear regression. Adjustments made for education, husband’s education, Pb substudy source, and cognitive substudy source. | Association between increasing PbB and decreasing scores of cognitive function tests (excluding test of letter fluency). Change in score per 1 SD in PbB or bone Pb (95% CI):; - Tibia Pb: −0.051 (−0.099, −0.003), p=0.04; - Patella Pb: −0.033 (−0.080, 0.014), p=0.17; - PbB: −0.016 (−0.071, 0.039), p=0.57; The Pb effect was greater than for age (years between repeated tests):; - -0.017 (−0.028, −0.007), p=0.002.
Wright et al. 2003b; Longitudinal study cohort of 736 males, mean age 68.2±6.9 (SD) years (from Normative Aging Study, 1991–1997) | PbB: Mean (SD):; - All: 4.5 (2.5); - Q1: 2.5; - Q2: 4.0; - Q3: 5.9; - Q4: 8.9; Tibia Pb (µg/g): Median (SD):; - 22.4 (15.3); Patella Pb (µg/g): Median (SD):; - 29.5 (21.2); Analysis: Cognitive performance using MMSE. Logistic regression. Adjustments made for age, education, and alcohol intake. | Adjusted OR for low MMSE score (<24) associated with 1 µg/dL increase in PbB or 1 µg/g increase in bone Pb (95% CI):; - PbB: 1.21 (1.07, 1.36); - Patella Pb: 1.02 (1.00, 1.03); - Tibia Pb: 1.02 (1.00, 1.04); Interaction between age and PbB and bone Pb with increasing β for age with increasing Pb, age β for PbB quartile (95% CI):; - Q1: −0.04 (−0.07, −0.02); - Q2: −0.04 (−0.08, −0.01); - Q3: −0.09 (−0.13, −0.06); - Q4: −0.12 (−0.17, −0.02)
Yu et al. 2019b; Cross-sectional study of 339 males, mean age 28.6 years, newly hired lead workers recruited in 2015–2017 (SPHERL longitudinal study), United States | PbB:; Gmean (IQR): 2.47 (2.00, 3.00); Analysis: Cognitive performance assessed using Stroop test MRT, DST, and MTL. Linear and logistic regression. Adjustments made for age, ethnicity, waist-to-hip ratio, heart rate, smoking, alcohol consumption, education, serum insulin levels, and total-to-HDL cholesterol ratio. | PbB was not associated with cognitive performance. β per log_10_ PbB (95%CI):; - Stroop MRT incongruent trials (%): 5.1 (−4.5, 15.6), p=0.30; - Stroop MRT congruent trials (%): - 1.2 (−10.4, 9.0), p=0.81; - Stroop interference effect (%): 23.0 (−15.4, 78.9), p=0.28; - DST MTL (%): 5.4 (−0.4, 11.5), p=0.066; OR for cognitive performance scores not significant (95% CI):; - Stroop error score incongruent trials: 1.48 (0.63, 3.47), p=0.37; - Stroop interference score: 0.79 (0.33, 1.89). p=0.59; - Digit symbol error score: 0.58 (0.31, 1.10), p=0.096
Mood and behavior
Bouchard et al. 2009; Cross-sectional study of 1987 adults (age 20–39) years from the NHANES (1999–2004) | PbB:; Gmean (range); - 1.24 (1.96); - 99% ≤10; - Q1: 0.6; - Q2: 0.9; - Q3: 1.2; - Q4: 1.3; - Q5: 3.0; Analysis: Psychiatric disorders (major depressive, panic, generalized anxiety) were assessed based on the WHO CIDI and the DSM-IV. Logistic regression. Adjustments made for age, sex, race/ethnicity, education, and poverty to income ratio. | Adjusted ORs (95% CI) for PbB relative to Q1:; - Major depressive disorder; ○ Q5: 2.32 (1.13, 4.75); p=0.05, trend; - Panic disorder; ○ Q5: 4.94 (1.32, 18.48); p=0.02, trend; - Generalized anxiety disorder; ○ Q5: 1.53 (0.39, 5.96); p=0.78, trend; Eliminating current smokers from the analysis strengthened the effect size (smoking was correlated with higher PbB):; - Major depressive disorder; ○ Q5: 2.93 (1.24, 6.92); p=0.03, trend; - Panic disorder; ○ Q5: 9.57 (1.28, 71.43); p=0.01, trend; - Generalized anxiety disorder; ○ Q5: 1.59 (0.19, 13.31); p=0.44, trend
Buser and Scinicariello 2017; Cross-sectional study of 3,905 adults (age ≥20 years) from NHANES 2011–2012 | PbB:; Gmean (GSD); - Males: 1.29 (0.04); - Females: 0.93 (0.03); - All: 1.09 (0.03); - Q1: <0.7; - Q2: 0.70–1.06; - Q3: 1.07–1.67; - Q4: >1.67; Analysis: Depression symptoms scored from self-administered version of Prime MD (NHANES PHQ-9). Logistic regression. Adjustments made for sex, age, race/ethnicity, obesity, serum cotinine, poverty income ratio, smoking status, alcohol consumption, and education level. | Adjusted OR for depression symptoms associated with increasing PbB quartile in females age 20–47 years (95% CI):; Q2: 1.23 (0.71, 2.13); Q3: 1.86 (1.01, 3.41); p<0.05; Q4: 2.97 (1.01, 8.74); p<0.05
Fan et al. 2020; Cross-sectional study of 994 adults (544 females), age >60 years, recruited in 2016; Anhui Province, China | PbB:; Mean (SD): 3.229 (2.357); Q1: <2.027; Q2: 2.027, 2.677; Q3: 2.677, 3.058; Q4: ≥3.058; Analysis: Depression symptoms were assessed using a GDS. Logistic regression adjusted for age, gender, residence region, marital status, income, education, alcohol consumption, smoking, and BMI. | Increasing PbB was associated with higher depression scores on GDS. OR for depression for PbB quartiles relative to Q1 (95% CI):; Q2: 1.28 (0.79, 2.08), p=0.315; Q3: 1.36 (0.84, 2.22), p=0.216; Q4: 2.03 (1.23, 3.35), p=0.006; p-trend =0.007
Golub et al. 2010; Cross-sectional study of 4,195 adults (age ≥20 years) from NHANES 2005–2006 | PbB:; Mean (SE); - 1.75 (0.05); - Q1: ≤0.88; - Q2: 0.89–1.40; - Q3: 1.41–2.17; - Q4: 2.18–26.4; Analysis: Depression symptoms scored from self-administered version of Prime MD (NHANES PHQ-9). Logistic regression. Adjustments made for sex, age, ethnicity, poverty income ratio, and education level. | Adjusted OR for depression symptoms was elevated in PbB quartile 3 (95% CI):; Q2: 1.22 (0.98, 1.51); Q3: 1.25 (1.07, 1.47); Q4: 1.18 (0.83, 1.68)
Li et al. 2017a; Cross-sectional study of 1,931 pregnancies (age 13–42 years), recruited in 2010; Shanghai, China | PbB:; Gmean (range): 3.99 (0.80, 14.84); Analysis: Depression, anxiety, and psychological stress symptoms were scored at gestation weeks 28–36 using LESPW, SCL-90-R, and GSI. Linear regression. Adjustments made for age, ethnicity, education, income, and residence time in Shanghai. | Increasing PbB was associated with depression or anxiety symptoms in PbB stratum ≤2.57 µg/dL. β per log_10_ PbB:; Full cohort:; - GSI: 0.01 (−0.05, 0.07), p=0.815; - Depression: 0.03 (−0.05, 0.10), p=0.466; - Anxiety: 0.01 (−0.06, 0.08), p=0.770; PbB ≤2.57:; - GSI: 0.22 (0.05, 0.40), p=0.013; - Depression: 0.34 (0.12, 0.56), p=0.002; - Anxiety: 0.25 (0.04, 0.46), p=0.019; PbB >2.57:; - GSI: −0.07 (−0.16, 0.01), p=0.100; - Depression: −0.09 (−0.19, 0.02), p=0.113; - Anxiety: −0.08 (−0.18, 0.02), p=0.136
Opler et al. 2004; Case-control study of 44 schizophrenia cases and 75 matched controls from birth cohorts (1959–1966) from California | PbB:; Cohort stratified into <15 or ≥15 µg/dL based on 2^nd^ trimester ALA measurements; Analysis: Mantel-Haenszel OR and logistic regression. Adjustments made for mother’s age at delivery. | Adjusted OR for schizophrenia associated with high (≥15 µg/dL) prenatal PbB. OR (95% CI):; - 2.43 (0.99, 5.96), p=0.051
Opler et al. 2008; Case-control study of 71 schizophrenia cases and 129 matched controls from birth cohorts (1959–1966) from California and New England | PbB:; Cohort stratified into <15 µg/dL or ≥15 µg/dL based on 2^nd^ trimester ALA measurements; Analysis: Logistic regression. Adjustments made for maternal age and maternal education. | Adjusted OR for schizophrenia associated with high (≥15 µg/dL) prenatal PbB. OR (95% CI):; - 1.92 (1.05, 3.87), p=0.03
Rajan et al. 2007; Longitudinal study cohort of 1,075 males, mean age 67.1±7.2 (SD) years (from Normative Aging Study, 1991–2002) | PbB: Mean (SD):; - All: 6.2 (4.1); Tibia Pb (µg/g): Median (SD):; - 22.1 (13.8); Patella Pb (µg/g): Median (SD):; - 31.4 (19.6); Analysis: Psychiatric symptoms scored using Brief Symptom Inventory. Logistic regression. Adjustments made for age at bone scan, alcohol consumption (categorical), education (categorical), time between BSI assessments, and cumulative smoking (pack-years). | Association between increasing bone Pb and psychiatric symptoms (abnormal, responses to BSI). Adjusted OR (95% CI) for inter quartile increases in tibia Pb (14 µg/g) or patella Pb (20 µg/g):; - Somatization, tibia Pb: 1.21 (1.01, 1.46); - Global severity index, patella Pb: 1.23 (1.02, 1.47); OR 95% CIs encompassed 1 for anxiety, depression, hostility, phobic anxiety, or total symptoms.
Rhodes et al. 2003; Longitudinal study cohort of 526 males, mean age 67.1±7.2 (SD) years (from Normative Aging Study, 1991–1995) | PbB: Mean (SD):; - 6.3 (4.2); Tibia Pb (µg/g): Median (SD):; - 21.9 (13.5); Patella Pb (µg/g): Median (SD):; - 32.1 (19.8); Analysis: Psychiatric symptoms scored using Brief Symptom Inventory. Logistic regression. Adjustments made for age, age squared, alcohol ingestions (g/day), education (four levels), and employment status (three levels). | Association between increasing bone Pb and psychiatric symptoms (abnormal, responses to BSI). Adjusted OR (95% CI) for inter-quintile increases in blood (8.9 µg/dL), tibia Pb (27 µg/g), or patella Pb (45 µg/g):; - Phobic anxiety, patella Pb: 1.91 (1.01, 3.61); - Combined symptoms, PbB: 2.91 (1.39, 6.09); - Combined symptoms, tibia Pb: 2.08 (1.06, 4.07); - Combined symptoms, patella Pb: 3.62 (1.62, 8.08)
Scinicariello and Buser 2015; Cross-sectional study of 2,892 adults (age 20–39 years) from NHANES 2007–2010 | PbB:; Gmean (GSD); - 0.96 (0.02); Analysis: Depression symptoms scored from self-administered version of Prime MD (NHANES PHQ-9). Logistic regression. Adjustments made for sex, age, race/ethnicity, obesity, blood cadmium, serum cotinine, poverty income ratio, smoking status, alcohol consumption, and education level. | Adjusted OR for depression symptoms was not associated with increasing PbB (ORs were not reported).
Neuromotor neurosensory function
Casjens et al. 2018; Longitudinal study of 1,188 males, age 55–86 years at follow-up (median age at baseline of 58 years), recruited in 2000–2003 with follow-up 2011–2014, Germany | PbB:; Median (% >9); - Baseline: 3.29 (2.27%); - Follow-up: 2.59 (0.84%); Analysis: Olfaction and fine motor skills were assessed using an odor identification test and a Motor Performance Series (finger tapping, aiming, line tracing, steadiness). Logistic regression adjusted for age, occupation, smoking, alcohol consumption, and test time. | PbB was not associated with odor detection error. POR (95% CI) for impaired odor identification relative <5.0 µg/dL:; Baseline:; - 5.0–<9.0 µg/dL: 0.91 (0.65, 1.28); - ≥9.0 µg/dL: 1.96 (0.94, 4.11); Follow-up:; - 5.0–<9.0 µg/dL: 1.04 (0.55, 1.94); - ≥9.0 µg/dL: 1.57 (0.47, 5.19); PbB was associated with fine motor skills assessed by tapping test at 5.0–<9.0 µg/dL, but not other tests. OR (95% CI) for impaired performance compared to <5.0 µg/dL:; Finger tapping hits:; Baseline; - 5.0–<9.0 µg/dL: 0.87 (0.53, 1.44); - ≥9.0 µg/dL: 1.35 (0.49, 3.70); Follow-up:; - 5.0–<9.0 µg/dL: 2.63 (1.26, 5.94); - ≥9.0 µg/dL: 0.80 (0.14, 4.59); Aiming errors; Baseline:; - 5.0–<9.0 µg/dL: 1.07 (0.75, 1.53); - ≥9.0 µg/dL: 0.56 (0.22, 1.42); Follow-up:; - 5.0–<9.0 µg/dL: 1.35 (0.73, 2.51); - ≥9.0 µg/dL: 0.42 (0.09, 2.08); Line tracing errors:; Baseline:; - 5.0–<9.0 µg/dL: 1.09 (0.68, 1.76); - ≥9.0 µg/dL: 0.93 (0.32, 2.74); Follow-up; - 5.0–<9.0 µg/dL: 1.01 (0.41, 2.48); - ≥9.0 µg/dL: 0.59 (0.08, 4.11); Steadiness errors:; Follow-up:; - 5.0–<9.0 µg/dL: 0.99 (0.62, 1.59); - ≥9.0 µg/dL: 1.36 (0.50, 3.66); Follow-up:; - 5.0–<9.0 µg/dL: 1.16 (0.50, 2.69); - ≥9.0 µg/dL: 1.75 (0.41, 7.58)
Hwang et al. 2009; Cross-sectional study of 259 male steel workers, mean age 36.0±6.5 years; Taiwan, China | PbB:; Mean (SD): 5.43 (3.46); Analysis: Hearing loss assessed. Logistic regression. Adjustments made for age and noise level. | Association between increasing PbB and hearing loss. Adjusted OR (95% CI) for hearing loss (>25 dB) in PbB categories relative to ≤4 µg/dL:; Loss at 3,000 Hz:; - 4–7 µg/dL: 0.75 (0.17, 3.29); - ≥7 µg/dL: 4.49 (1.28, 15.8); p<0.005; Loss at 4,000 Hz:; - 4–7 µg/dL: 3.54 (1.40, 8.97); p-value not reported; - ≥7 µg/dL: 6.26 (2.35, 16.6); p<0.005; Loss at 6,000 Hz:; - 4–7 µg/dL: 2.11 (0.94, 4.47); - ≥7 µg/dL: 3.06 (1.27, 7.39); p<0.05; Loss at 8,000 Hz:; - 4–7 µg/dL: 3.0 (0.78, 11.5); - ≥7 µg/dL: 6.16 (1.59, 23.9); p<0.05
Huh et al. 2018; Cross-sectional study of 2,387 adults, age 19–85 years; KNHANES 2010–2012, Korea | PbB:; Gmean (95% CI): 2.46 (2.41, 2.52); Q1: 0.515, 1.780; Q2: 1.780, 2.248; Q3: 2.248, 2.723; Q4: 2.273, 3.396; Q5: 3.396, 26.507; Analysis: Hearing loss assessed (pure tone average). Logistic regression. Adjustments made for age, sex, income, education, smoking, BMI, occupational noise exposure, loud noise exposure, firearm noise exposure, hypertension, and diabetes. | Increasing PbB was associated with high frequency hearing loss. OR per doubling of PbB (95% CI):; - Low frequency: 0.91 (0.52, 1.61); - Speech frequency: 1.21 (0.72, 2.04); - High frequency: 1.88 (1.11, 3.17); Joint interaction blood cadmium on high frequency loss was in the negative direction.; OR ratio (95% CI):; - Joint (multiplicative) 0.55 (0.33, 0.92), p=0.023; OR for high frequency hearing loss for PbB quintile relative to Q1:; - Q2: 1.07 (0.68, 1.68); - Q3: 1.16 (0.75, 1.82); - Q4: 1.51 (0.97, 2.36); - Q5: 1.44 (0.90, 2.31); - p-trend =0.035
Ji et al. 2013; Cross-sectional study of 1,795 males and 1,798 females, age >50 years (median 61.2 years) from NHANES (1999–2002) | PbB:; Mean (SD):; - Females: 2.17 (0.06); - Males: 3.18 (0.12); Analysis: Walking speed assessed. Multiple linear regression. Adjustments made for age, education, ethnicity, alcohol use, smoking status, height, and waist circumference. | Association between increasing PbB and walking speed in women. Mean change in walking speed (feet/second) for PbB quintile relative to Q1 (≤1.2 µg/dL):; - 1.3–≤1.6: −0.024 (−0.112, 0.064), p=0.58; - 1.7–≤2.1: −0.027, (−0.118, 0.063), p=0.54; - 2.2–≤2.9: −0.104 (−0.187, −0.021), p=0.02; - 3.3–≤53.0: −0.114 (−0.191, −0.038), p=0.01; Trend, p=0.005
Ji et al. 2015; Longitudinal study cohort of 807 males, mean age 69±7 years (from Normative Aging Study, 1991–ND) | PbB: Mean (SD):; - 5.0 (2.7); - % <10: 96%; Tibia Pb (µg/g): Median (SD):; - 21.2 (13.3); Patella Pb (µg/g): Median (SD):; - 28.0 (18.4); Analysis: Hand tremor assessed. Linear and logistic regression. Adjustments made for age, age squared, alcohol intake, cigarette pack-years, and education level. | No association between PbB or bone Pb and tremor. Adjusted OR (95% CI) for bone Pb or PbB quintiles relative to Q1 (3 µg/dL):; - Q5 (8–28), PbB: 0.84 (0.38, 1.86), p=0.72; - Q5 (40–165), patella Pb: 0.83 (0.31, 2.19), p=0.41; - Q5 (30–126), tibia Pb: 1.08 (0.46, 2.53), p=0.60
Kang et al. 2018; Cross-sectional study of 6,409 adults (50.4% female), age 20–87 years (mean age 57 years); KNHANES 2010–2013, Korea | PbB:; Mean (SE); Females, weighted mean (SE); - Q1: 1.12 (0.01); - Q2: 1.61 (0.01); - Q3: 2.11 (0.01); - Q4: 3.03 (0.03); Males, weighted mean (SE); - Q1: 1.56 (0.01); - Q2: 2.22 (0.01); - Q3: 2.82 (0.01); - Q4: 4.22 (0.08); Analysis: Hearing loss assessed (pure tone average). Logistic regression. Adjustments made for age, BMI, education, smoking alcohol consumption, exercise, diabetes mellitus, hypertension, occupational noise exposure, loud noise exposure, and firearm noise exposure. | Increasing PbB was associated with high frequency hearing loss. OR for high frequency hearing loss for PbB quartile relative to Q1:; Males:; - Q2: 1.368 (1.006, 1.859); - Q3: 1.402 (1.005, 1.955); - Q4: 1.629 (1.161, 2.287); Females:; - Q2: 0.947 (0.606 1.477); - Q3: 1.013 (0.698, 1.471); - Q4: 1.502 (1.027, 2.196)
Krieg et al. 2005; Cross-sectional study of 5,662 adults, age 20–59 years (from NHANES III, 1988–1994 | PbB:; - Gmean (range): 2.51 (0.7, 41.8); - Percent <0: 96%; Analysis: Cognitive function was assessed at age 20–59 years using the NBES. Multiple linear regression with log-transformed PbB. Adjustments made for sex, age, education, family income, race/ethnicity, computer or video game familiarity, alcohol use, test language, and survey phase. | No associations between PbB and performance scores for:; - Simple visual reaction time:; ○ Mean reaction time: p=0.24
Muldoon et al. 1996; Cross-sectional, mean age 70±4 (SD) years study of 530 adult women recruited from the Study of Osteoporotic Fractures (1990) | PbB: Mean (SD):; - All: 4.8 (0.4); - Rural: 4.5 (0.4); - Urban: 5.4 (0.4); - Low: <4; - Medium: 4–7; - High: >7; Analysis: Sensorimotor function was assessed at age ≥65 years using grooved pegboard and reaction time. Analysis of variance and covariance. Adjustments made for age, education, smoking, and alcohol consumption. | Difference in mean reaction time test scores between PbB categories (ANOVA). OR (95% CI) for poor performance (low PbB reference) in the rural cohort:; - Pegboard: ANOVA, p=0.98; ○ Medium PbB: 1.37 (0.71, 2.65); ○ High PbB: 1.16 (0.45, 3.01); - Upper extremity: ANOVA, p<0.01:; ○ Medium PbB: 1.39 (0.73, 2.65); ○ High PbB: 2.43 (1.01, 5.83); - Lower extremity: ANOVA, p<0.01; ○ Medium PbB: 1.29 (0.68, 2.47); ○ High PbB: 2.84 (1.19, 6.74); No difference in mean reaction time test scores between PbB categories (ANOVA) for poor performance (low PbB reference) were observed in the urban cohort.
Neurological disease
Fang et al. 2010; Case-control study of 184 male ALS cases and 194 matched controls, mean age 63 years (range 34–84 years) from the National registry of U.S. veterans with ALS (2003–2006) | PbB: Mean (range):; - Controls 1.76 (0.32–6.90); - Cases: 2.41 (0.72–7.58); Analysis: Logistical regression. Adjustments made for age (continuous; age at diagnosis for cases and age at interview for controls) and log_2_-transformed CTX level. | Association between increasing PbB and ALS. Adjusted OR for ALS (95% CI) for doubling of PbB:; - All cases (n=184): 1.9 (1.3, 2.7); - Excluding progressive muscular atrophy and primary lateral sclerosis (n=151): 1.8 (1.2, 2.5)
Kamel et al. 2002; Case-control study of 109 ALS cases and 256 matched controls, age 30–80 years from New England hospitals (1993–1996) | PbB: Mean (range):; - Cases: 3 of 194 had PbB >10; - Controls: <10 µg/dL; Analysis: Logistical regression. Adjustments made for age, sex, region, education, and inactivity, | Association between increasing PbB and ALS.; Adjusted OR for ALS (95% CI) for a 1 µg/dL increase in PbB:; - 1.9 (1.4, 2.6); Adjusted OR for ALS (95% CI) relative to <2 µg/dL:; - 3–4 µg/dL: 14.3 (3.0, 69.3); - 5–14 µg/dL: 24.5 (4.3, 139.3)

ALA = aminolevulinic acid; ALAD-2 = delta-aminolevulinic acid dehydratase allele; ALS = amyotrophic lateral sclerosis; ANOVA = analysis of variance; BMI = body mass index; BSI = Brief Symptom Inventory; CERAD = Consortium to Establish Registry for Alzheimer’s Disease; CI = confidence interval; CIDI = Composite International Diagnostic Interview; CL = confidence limit; CTX = C-terminal telopeptides of type 1 collagen; DLPFC = dorsolateral prefrontal cortex; DSM = Diagnostic and Statistical Manual; DST = Digit-Symbol Test; GDS = Geriatric Depression Scale; Gmean = geometric mean; GSD = geometric standard deviation; GSI = Global Severity Index; HDL = high-density lipoprotein; IFC = inferior frontal cortex; IMT = Incidental Memory Test; IPC = inferior parietal cortex; IQ = intelligence quotient; IQR = interquartile range; KNHANES = Korean National Health and Nutrition Examination Survey; LESPW = Life Event Stress Scale for Pregnant Women; MMSE = Mini-Mental Status Examination; MRI = Magnetic Resonance Imaging; MRT = mean reaction time; MTL = mean total latency; NBES = Neurobehavioral Evaluation System; NES2 = Neurobehavioral Evaluation System 2; NHANES = National Health and Nutrition Examination Survey; OR = odds ratio; Pb = lead; PHQ = Public Health Questionnaire; POR = proportional odds ratio; SCL-90-R = Symptom Checklist 90 Revised; SD = standard deviation; SE = standard error; SPHERL = Study for Promotion of Health in Recycling Lead; TICS = Telephone Interview for Cognitive Status; VMI = Visual Motor Integration; WAdSI = Wechsler Adult Scale of Intelligence; WASI = Wechsler Abbreviated Scale of Intelligence; WHO = World Health Organization

Table 11 Epidemiology Studies Evaluating Effects on the Male Reproductive System at Mean Blood Lead Concentrations (PbB) ≤10 µg/dL

Reference and study population | PbB (µg/dL) and analysis | Outcomes
Chen et al. 2016; Cross-sectional study of 2,286 men (mean age: 54 years) in China | PbB:; - Median (IQR): 4.40 (2.90–6.23); - Quartiles:; ○ Q1: <2.9 (n=558); ○ Q2: 2.9–4.39 (n=572); ○ Q3: 4.4–6.2 (n=585); ○ Q4: >6.2 (n=571); Analysis: Data for blood levels of reproductive hormones (SHBG, T, FSH, LH, E) were log-transformed and analyzed by linear regression analysis, adjusted for age, current smoking status, BMI, systolic blood pressure, diabetes, and blood Cd concentration. | SHBG, T, FHS, and LH were positively associated with PbB in the Q4 group; no association was observed between PbB and E. β coefficients (SE):; - SHBG: p-trend: <0.001; ○ Q1: 1 (reference); ○ Q2: < 0.001 (0.011); ○ Q3: 0.021 (0.011); ○ Q4: 0.038 (0.012); p<0.01; - T: p-trend=0.001.; ○ Q1: 1 (reference); ○ Q2: 0.001 (0.010); ○ Q3: 0.010 (0.010); ○ Q4: 0.033 (0.010); p<0.01; - E: p-trend=0.794; ○ Q1: 1 (reference); ○ Q2: −0.008 (0.016); ○ Q3: 0.014 (0.017); ○ Q4: −0.003 (0.017); - FSH: p-trend=0.067; ○ Q1: 1 (reference); ○ Q2: 0.010 (0.014); ○ Q3: 0.004 (0.014); ○ Q4: 0.030 (0.015); p<0.05; - LH: p-trend=0.065; ○ Q1: 1 (reference); ○ Q2: 0.018 (0.013); ○ Q3: 0.015 (0.013); ○ Q4: 0.028 (0.013); p<0.05
Famurewa and Ugwuja 2017; Cross-sectional study of 75 men (age range: 20–45 years) with infertility from Nigeria | PbB:; Mean (SD); - Normospermic, n=36: 1.49 (0.59); - Azoospermic, n=15: 1.71 (0.98); - Oligospermic, n=22: 2.05 (0.97); Analysis: ANOVA was used to compare means for PbB. Semen parameters were evaluated using Pearson correlation analysis. No information on adjustments was reported. | PbBs were higher (p<0.05) in azoospermic and oligospermic groups compared to the normospermic group.; A negative association between PbB and sperm count, but not for other parameters, in infertile men. Pearson correlation R value:; - Semen volume (mL): −0.132; p=0.27; - Sperm count (x10^6^ cells/mL): −0.280; p=0.02; - Total motility (%): −0.092; p=0.44; - Morphology (%): −0.081; p=0.50
Hernandez-Ochoa et al. 2005; Cross-sectional study of 68 men (21–54 years of age) who resided in the Region Lagunera, Mexico (site of large smelter complex) for at least 3 years | PbB:; Mean (SD): 9.31; - Range: 1.9–24.4; - Participants with PbB >10: 48%; Other Pb measurements:; - Seminal fluid: 2.02 µg/L (range 1.14–12.4 µg/L); - Spermatozoa: 0.047 ng/10^6^ cells (range: 0.032–0.245 ng/10^6^ cells); - No correlation was observed between PbB and Pb levels in seminal fluid or in spermatozoa; Analysis: Semen parameters (volume, sperm concentration, motility, morphology, viability and viscosity) were analyzed by linear and multi-linear regression adjusted for age, BMI, days of sexual abstinence, smoking intensity, and consumption of alcohol and drugs. | No associations (p>0.05) were observed between PbB and sperm or semen quality. β coefficients per µg/dL:; - Sperm motility: −0.006; - Sperm morphology: −0.001; - Sperm viability: −0.095; - Semen volume: −0.043; Sperm quality: concentration, motility, morphology, and viability were negatively associated with Pb in spermatozoa (β coefficients per ng/10^6^ cells):; - Log sperm concentration (10^6^ cells/mL): −17.17 (p<0.05); - Motility (%): −2.12 (p<0.05); - Morphology (%): −1.42 (p<0.05); - Viability (%): −0.130 (p<0.05); Semen volume: negatively associated with Pb in seminal fluid (β coefficient mL per µg/L:; - -0.183 mL; p<0.05).
Li et al. 2015; Cross-sectional study of 154 male participants from a reproductive medical center; recruited May 2012–February 2013 | PbB:; Mean (SD):; - All participants: 2.78 (1.85); - Low-quality semen group: 3.43 (2.47); n=59; - High-quality semen group: 2.38 (1.17); n=95; High-quality semen was defined as a sperm concentration ≥15x10^6^/mL, semen volume ≥1.5 mL, number of sperm ≥39x10^6^, total motility sperm ≥40% or progressive motility sperm ≥32%, and sperm with normal morphology ≥4%.; Analysis: Semen parameters (volume, sperm concentration, sperm number, motility, and morphology) were analyzed by multiple logistic regression analysis and adjusted for age, BMI, education, smoking intensity, alcohol consumption, betel nut chewing, coffee intake, nutritional supplement consumption, chronic disease, and Pb-related occupation. | Mean PbB in the low-quality semen group was significantly higher (p=0.0391) than in the high-quality semen group.; Adjusted ORs (95% CI) with PbB as a variable for:; - Low-quality sperm: 1.040 (1.011, 1.069); p=0.0061; - Decreased sperm concentration: 1.046 (1.015, 1.078); p=0.0032; - Decreased sperm number: 1.041 (1.012, 1.071); p=0.0048; - Decreased motile sperm: 1.057 (1.026, 1.089; p=0.0003; - Decreased progressive motile sperm: 1.047 (1.014, 1.080); p=0.00043; - Decreased morphologically normal sperm: 1.071 (1.025, 1.118; p=0.0021
Kresovich et al. 2015; Cross-sectional study of 869 men (aged >20 years) participating in three consecutive NHANES (1990–2000, 2001–2002, and 2003–2004) studies | PbB:; - Median: 2.0; - Quartiles; ○ Q1: ≤1.4 (reference); ○ Q2: 1.4–2.1; ○ Q3: 2.10–3.20; ○ Q4: >3.20; Analysis: Reproductive hormones (testosterone, free testosterone, estradiol, free estradiol, androstenedione, glucuronide, and SHBG) were analyzed by multiple linear regression adjusted for age, race, BMI, smoking, diabetes status, and alcohol consumption. | PbB was associated with an increase in serum testosterone (ng/mL) in Q3 and Q4. β coefficient per µg/dL (SE):; - Q1: reference; - Q2: 0.38 (0.23); - Q3: 0.54 (0.21); p<0.05; - Q4: 0.79 (0.22); p<0.05; - p-trend=0.0026; PbB was associated with an increase in serum free testosterone (ng/mL) in Q4. β coefficient per µg/dL (SE):; - Q1: reference; - Q2: 0.95 (0.50); - Q3: 0.70 (0.51); - Q4: 1.06 (0.51); p<0.05; - p-trend=0.1388
Lewis and Meeker 2015; Cross sectional study of 484 men (aged 18–55 years) participating in an NHANES (2011–2012) study | PbB:; - Gmean: 1.06; - Quartiles:; ○ Q1 (<25^th^ percentile): <0.71; ○ Q2 (25^th^–50^th^ percentile): 0.71–1.00; ○ Q3 (50^th^–75^th^ percentile): 1.00–1.59; ○ Q4 (>75^th^ percentile): 1.59–33.67; Analysis: Serum testosterone was analyzed by multiple linear regression adjusted for age, BMI, economic status, and serum cotinine. | Adjusted models showed that a doubling of PbB was associated with a 6.65% (95% CI: 2.09, 11.41; p<0.004) increase in serum testosterone. A positive trend (p=0.003) was observed across quartiles.
Meeker et al. 2008; Cross-sectional study of 219 men (aged 18–55 years) recruited from two Michigan infertility clinics | PbB:; - Median: 1.50; - Quartiles (Q):; ○ Q1: <1.10; ○ Q2: 1.10–1.50; ○ Q3: 1.50–2.00; ○ Q4: 2.00–16.2; Analysis: Semen parameters (volume, sperm count, sperm concentration, percent motile, and sperm morphology) and semen quality were analyzed by multiple linear regression and adjusted for age, BMI, race, income, smoking status, and blood levels of Cd, Cu, Se, and Zn. | No association was observed for PbB and sperm concentration, sperm motility, morphologically abnormal sperm, or semen volume for Q2, Q3, or Q4, compared to Q1 (reference).; Adjusted regression coefficients per µg/dL (95% CI):; - ln-sperm concentration (10^6^/mL); ○ Q2: −0.15 (−0.55, 0.25); ○ Q3: −0.25 (−0.67, 0.18); ○ Q4: 0.02 (−0.39, 0.43); ○ p-trend: 0.97; - Sperm motility: (% mobile); ○ Q2: 0.96 (−4.52, 6.45); ○ Q3: 2.00 (−3.87, 7.88); ○ Q4: 1.10 (−4.56, 6.75); ○ p-trend: 0.64; - Sperm morphology (% normal):; ○ Q2: 0.71 (−0.69, 2.11); ○ Q3: −0.83 (−2.34, 0.67); ○ Q4: −0.16 (−1.58, 1.26); ○ p-trend: 0.64; - Semen volume (mL); ○ Q2: −0.43 (−0.99, 0.13); ○ Q3: −0.28 (−0.87, 0.31); ○ Q4: 0.17 (−0.41, 0.74); ○ p-trend: 0.92
Meeker et al. 2010; Cross-sectional study of 219 men (aged 18–55 years) recruited from two Michigan infertility clinics | PbB:; - Median: 1.5; - Quartiles; ○ Q1: <1.1 (reference); ○ Q2: 1.1–1.5; ○ Q3: 1.5–2.0; ○ Q4: >2.0–16.2; Analysis: Reproductive hormones (serum FSH, LH, inhibin B, T, and SHBG levels) was analyzed by bivariate analysis using SAS (version 9.1) and adjusted for age, BMI, and smoking status. | Elevated serum testosterone (ng/dL) was associated with PbB for Q4. Regression coefficient Q4: 39.9 (3.32, 76.4). Trend analysis across quartiles was not statistically significant (p<0.07).; No associations between PbB and serum levels of other hormone were observed (FSH, LH, inhibin B, SHBG, FAI) for Q2–Q4, compared to Q1. Adjusted regression coefficients per µg/dL (95% CI) for Q4 versus Q1, and p-trend:; - FSH (IU/L): 0.07 (−0.18, 0.31); p-trend=0.65; - ln-LH (IU/L): 0.08 (−0.14, 0.29); p-trend=0.32; - Inhibit B (pg/mL): −7.79 (−29.0, 13.4); p-trend=0.52; - ln-SHBG (nmol/L): 0.07 (−0.10, 0.23); p-trend=0.34; - ln-FAI: 0.08 (−0.05, 0.21); p-trend=0.35
Mendiola et al. 2011; Case-control study of 61 men (30 case subjects and 31 controls; average age 33.5 years) attending three infertility clinics in Southeastern Spain between 2005 and 2007 | PbB:; - Mean: 2.8; - Median: 2.9; - 95^th^ percentile: 3.3; Analysis: Reproductive hormones (FSH, LH, and T) and serum samples (seminal plasma) were analyzed using multiple linear regression and adjusted for age, BMI, and smoking. | A significant association between Pb in seminal plasma and the % of immotile sperm was observed (β=1.5; 95% CI: 0.37, 1.9; p≤0.05).; No association was observed between PbB and sperm concentration (10^6^/mL), immotile sperm (%), and morphologically normal sperm (%), or serum levels of FSH, LH, or T. β per µg/L (95% CI):; - ln-sperm concentration (10^6^/mL): 0.08 (−4.1, 5.2); - % Immotile sperm: −0.49 (−1.8, 0.62); - % Morphologically normal sperm: −0.08 (−3.5, 3.4); - FSH (IU/L): −0.20 (−0.64, 0.25); - LH (IU/L): −0.07 (−0.49, 0.31); - T (ng/mL): −0.12 (−0.40, 0.14)
Telisman et al. 2007; Cross-sectional study of 240 Croatian men (aged 19–55 years) with no previous occupational exposure to metals; data collection period was October 2002–May 2005 | PbB:; - Median: 4.92; - 10^th^–90^th^ percentile: 2.10–9.44; - Range: 1.13–14.91; Analysis: Reproductive parameters (semen volume, pH, percentage of leukocytes/erythrocytes, number of immature sperm cells, sperm concentration, sperm count, motility, viability, morphology, FSH, LH, prolactin, testosterone, and estradiol) were analyzed using linear multiple regression and adjusted for age, smoking and alcohol consumption, and body burden of cadmium, copper, zinc, and selenium. | Standardized regression coefficients for log PbB µg/L (β coefficients) for:; - Effects on sperm; ○ Immature sperm (x10^6^/mL): 0.13 (p<0.07); ○ Pathologic sperm (%): 0.31 (p<0.0002); ○ Wide sperm (%): 0.32 (p<0.0001); ○ Round sperm (%): 0.16 (p<0.03); - Effects on hormone levels; ○ Prolactin (IU/L): −0.18 (p<0.007); ○ T (nmol/L): 0.21 (p<0.003); ○ Estradiol (nmol/L): 0.22 (p<0.0008)

ANOVA = analysis of variance; BMI = body mass index; Cd = cadmium; CI = confidence interval; Cu = copper; E = estradiol; FAI = free androgen index; FSH = follicle-stimulating hormone (http://www.webmd.com/women/follicle-stimulating-hormone); Gmean = geometric mean; Inhibin B = gonadal dimeric polypeptide hormone; IQR = interquartile range; LH = luteinizing hormone; NHANES = National Health and Nutrition Examination Survey; OR = odds ratio; Pb = lead; SD = standard deviation; Se = selenium; SE = standard error; SHBG = sex hormone-binding globulin; T = testosterone; Zn = zinc

Table 12 Epidemiology Studies Evaluating Effects on the Female Reproductive System at Mean Blood Lead Concentrations (PbB) ≤10 µg/dL

Reference and study population | PbB (µg/dL) and analysis | Outcomes
Hormone levels
Chang et al. 2006; Case control study of 147 women (64 cases and 83 controls aged 23–44 years) who attended a fertility clinic in Kaohsiung City, Taiwan August 2000–July 2001; controls consisted of women who delivered normal babies January–June 1999 | PbB:; - Control group mean (SD): 2.78 (2.05); - Infertile group mean (SD): 3.55 (1.39); p=0.007 compared to control; Analysis: Hormone levels (FSH, LH) were analyzed using multivariate linear regression and adjusted for age, BMI, and smoking (active and passive). | No differences between control and infertile groups were observed for serum levels of LH (mIU/mL), FSH (mIU/mL), estradiol (ρg/mL), or progesterone (ng/mL). Means (SD); - LH: control: 4.38 (2.00); infertile: 4.47 (2.75); p=0.813; - LH: control: 7.13 (2.05); infertile: 6.64 (1.88); p=0.135; - Estradiol: control: 27.5 (12.65); infertile: 30.4 (13.74); p=0.181; - Progesterone: control: 0.44 (0.19); infertile: 0.44 (0.19); p=0.692; For women with PbB >2.5, an association was observed between PbB (per 1 µg/dL and estradiol (ρg/mL). β coefficient (SE): 1.18 (0.60); p=0.049
Chen et al. 2016; Cross-sectional study of 1,571 postmenopausal women (mean age: 63 years) in Chirimina | PbB:; - Median (IQR): 4.1 (2.7–6.0); - Quartiles:; ○ Q1: <2.7 (n=382); ○ Q2: 2.7–4.09 (n=395); ○ Q3: 4.1–5.98 (n=401); ○ Q4: >5.98 (n=393); Analysis: Data for blood levels of reproductive hormones (SHBG, T, E, FSH, LH) were log-transformed and analyzed by linear regression analysis, adjusted for age, current smoking status, BMI, systolic blood pressure, diabetes, and blood cadmium concentration. | FSH was positively associated with PbB in the Q3 and Q4 groups; SHBG, LH were positively associated with PbB in the Q4 group; no association was observed between PbB and T or E. β coefficients (SE):; - SHBG: p-trend: <0.002; ○ Q1: 1 (reference); ○ Q2: 0.010 (0.015); ○ Q3: 0.018 (0.015); ○ Q4: 0.048 (0.016); p<0.01; - T: p-trend=0.612; ○ Q1: 1 (reference); ○ Q2: −0.033 (0.019); ○ Q3: −0.017 (0.019); ○ Q4: −0.016 (0.020); - E: p-trend=0.201; ○ Q1: 1 (reference); ○ Q2: −0.001 (0.019); ○ Q3: −0.020 (0.019); ○ Q4: −0.021 (0.020); - FSH: p-trend=0.001; ○ Q1: 1 (reference); ○ Q2: 0.013 (0.015); ○ Q3: 0.047 (0.015); p<0.01; ○ Q4: 0.046 (0.016); p<0.01; - LH: p-trend=0.026; ○ Q1: 1 (reference); ○ Q2: 0.022 (0.015); ○ Q3: 0.027 (0.016); ○ Q4: 0.037 (0.016); p<0.05
Jackson et al. 2011; Longitudinal Cohort of 252 healthy, pre-menopausal women (aged 18–44 years) with self-reported menstrual cycle length between 21 and 35 days, BMI >18 or <35 mg/m^3^, no recent birth control use, and who were not planning on becoming pregnant and were not breastfeeding; the study was carried out at the University of Buffalo 2005–2007 | PbB:; - Mean: 0.87; Analysis: The correlation between Pb and reproductive hormone levels (FSH, LH, E, and progesterone) was analyzed using linear and logistic regression and adjusted for age, race, ethnicity, Pb, and Cd. Models were not adjusted for smoking status; however, subanalysis was restricted to nonsmokers. | No associations were observed between PbB and menstrual cycle length (days) or serum levels of FSH (mIU/mL), LH (mg/mL), E (ρg/mL), or progesterone (ng/mL). Percentage difference per unit change in PbB (µg/dL):; - Cycle length: 0.2 (−2.8, 3.3); - FSH: −2.5 (−11.2, 7.0); - LH: 2.5 (−12.3, 19.9); - E: 4.9 (−5.0, 15.9); - Progesterone: 4.6 (−12.2, 24.6)
Krieg 2007; Cross sectional study of 3,375 women (aged 35–60 years) participating in an NHANES III study 1998–1994 | PbB:; - Gmean: 2.2; - Range: 0.7–31.1; Analysis: Hormone levels (FSH and LH) were analyzed using linear regression and adjusted for age, total bone mineral density, log_10_ serum cotinine, alcohol use, current breastfeeding, hysterectomy, one ovary removed, Norplant use, radiation/chemotherapy, hormone pill use, vaginal cream use, and hormone patch use. | Slopes (SE) for serum FSH (IU/L) and log_10_ PbB (µg/dL) by status:; - Pre-menopausal: 8.3 (2.2); 95% CI: 3.8, 12.7; p=0.0006; - Post-menopausal: 22.2 (4.3); 95% CI: 13.5, 30.8; p=0.0000; - Both ovaries removed: 32.6 (11.2); 95% CI: 10.1, 55.1; p=0.0054; Slopes (SE) for serum LH (IU/L) and log_10_ PbB by status:; - Pre-menopausal: 1.7 (1.2); 95% CI: −0.6, 4.1; p=0.1486; - Post-menopausal: 6.2 (1.6); 95% CI: 3.0, 9.5; p=0.0003; - Both ovaries removed: 10.0 (4.4); 95% CI: 1.1, 18.9; p=0.0279; Lowest PbB for at which a relationship for FSH was detected by status:; - Pre-menopausal: 4.1; slope (SE): 5.5 (2.7); 95% CI: 0.1, 11.0; p=0.0475; - Post-menopausal: 2.4; slope (SE): 28.0 (13.0); 95% CI: 2.0, 54.1; p=0.0354; - Both ovaries removed: 1.7; slope (SE): 71.6 (32.1); 95% CI: 7.1, 136.2; p=0.0304; Lowest PbB for at which a relationship for LH was detected by status:; - Pre-menopausal: NR; - Post-menopausal: 2.8; slope (SE): 8.6 (3.3); 95% CI: 2.1, 15.2; p=0.0109; - Both ovaries removed: 4.2; slope (SE): 9.7 (4.5); 95% CI: 0.6, 18.8; p=0.0380
Pollack et al. 2011; Longitudinal Cohort of 252 healthy, pre-menopausal women (aged 18–44 years) with self-reported menstrual cycle length between 21 and 35 days, BMI >18 or <35 mg/m^3^, no recent birth control use, and who were not planning on becoming pregnant and were not breastfeeding; the study was carried out at the University of Buffalo 2005–2007 | PbB:; - Gmean: 0.93; - Tertiles (T):; ○ T1: 0.30–0.72 (reference); ○ T2: 0.73–1.10; ○ T3: 1.11–6.20; Analysis: Hormone levels (FSH, E, LH, progesterone, and cycle length) were analyzed using nonlinear mixed models with harmonic terms and weighted linear mixed models and adjusted for age, BMI, race, Cd, and Hg. | No associations were observed between PbB (µg/dL) and mean serum levels of E (ρg/mL), FSH (mIU/mL), LH (ng/mL), or progesterone (ng/mL). β-coefficient (95% CI):; - E: 0.03 (−0.05, 0.11); - FSH: −0.01 (−0.07, 0.06); - LH: 0.02 (−0.06, 0.10); - Progesterone: 0.06 (−0.04, 0.17); OR for anovulation per 1 µg/dL increase in PbB: 1.20 (95% CI, 0.62–2.34).; When examined by tertiles, an association was observed between PbB for mean progesterone (%) and progesterone amplitude for T2, but not for T3:; - Mean (95% CI):; ○ T2: 7.5 (0.1,15.4); ○ T3: 6.8 (−0.8, 14.9); - Amplitude (95% CI); ○ T2: 0.07 (0.01, 0.15); ○ T3: −0.06 (−0.13, 0.01)
Fertility
Bloom et al. 2010; Longitudinal cohort of 15 women who previously took part in a SMART study at the Center for Reproductive Health of the University of California at San Francisco September 2007–August 2008; women were referred to the center for infertility treatment and their first IVF procedure | PbB:; - Mean (SD): 0.82 (0.32); - Range: 0.34–1.50; Analysis: Oocyte maturity was analyzed using multivariate log-binomial regression and adjusted for smoking status, race, and ethnicity. Adjustment was also made for cadmium in urine of male partners. | No association was observed between PbB and oocyte fertilization. RR (95% CI): 1.09 (0.72, 1.65).
Bloom et al. 2011; Longitudinal cohort of 80 women (aged 18–34 years) who previously participated in a fish consumption study in New York, 1991–1992; eligible women from this study (not currently pregnant) were re-contacted 1996–1997 and were followed for 12 menstrual cycles or until they became pregnant | PbB:; - No positive pregnancy test group:; ○ Mean (SD): 1.55 (0.16); ○ Range: 0.60–4.30; - Positive pregnancy test group:; ○ Mean (SD): 1.54; ○ Range: 0.80–3.00; ○ p>0.05 (between group means); Analysis: Fecundity was analyzed using Cox proportional hazards and adjusted for baseline arsenic, cadmium, magnesium, nickel, selenium, and zinc, total serum lipids, age, parity, frequency of intercourse during fertility, alcohol consumption, and smoking habits. | No association was observed between PbB and achieving pregnancy over a 12-month observation period. Regression coefficient β probability of pregnancy per µg/L: −0.031 (95% CI: −1.066, 1.004); p=0.954
Chang et al. 2006; Case control study of 147 women (64 cases and 83 controls aged 23–44 years) who attended a fertility clinic in Kaohsiung City, Taiwan August 2000–July 2001; controls consisted of women who delivered normal babies, January–June 1999 | PbB:; - Control group mean (SD): 2.78 (2.05); - Infertile group mean (SD): 3.55 (1.39); p=0.007 compared to control; - Combined control and infertile groups; ○ mean (SD): 3.12 (0.19); ○ range: 0.068–9.85; Analysis: Infertility was analyzed using multivariate linear regression and adjusted for age, BMI, and smoking (active and passive). | Adjusted OR for infertility for all participants for PbB >2.5 versus ≤2.5 µg/dL: 2.94 (95% CI: 1.18, 7.34); p=0.021
Pregnancy outcome
Bloom et al. 2015; Case control study of 235 women (aged 18–40 years) from 16 counties in Michigan and Texas, 2005–2009, who had no use of injectable contraceptive within 12 months, and with self-reported menstrual cycle of 21–42 days | PbB:; Mean (SD): 0.71 (0.30); Median: 0.55; Range: <0.25–2.23; Tertiles (mean):; - T1: not reported; - T2: 0.66; - T3: 0.73; Analysis: Pregnancy outcome was analyzed using multivariate linear regression and adjusted for maternal age, difference between maternal and parental ages, smoking habits, income, and race. | No association was observed between maternal PbB and duration of gestation. Linear regression coefficient, gestational age (weeks) per µg/L (95% CI):; - T1: reference; - T2: 0.43 (−0.48, 1.35); - T3: 0.14 (−0.81, 1.09); - p-trend: 0.671
Garcia-Esquinas et al. 2014; Birth cohort study of infants born in the Madrid Autonomous region, October 2003–May 2004; participants included 100 pregnant women (mean age of 31.1 years) who had resided in the study area for >1 year and had attended childbirth classes in the public health care system | PbB:; Gmean (95% CI): 1.83 (1.67, 2.01); Analysis: Pregnancy outcome (duration of gestation) was analyzed using multivariate linear regression and adjusted for district of residence (metropolitan or urban), maternal age, smoking habits, and newborn sex. | No associations were observed between PbB and duration of gestation. Adjusted mean difference per 2-fold increase in PbB: gestational age (weeks) per µg/L: 0.02 (95% CI: −0.44, 0.47)
Gundacker et al. 2010; Cross-sectional study of 30 women (8 with previous miscarriage; 22 with no previous miscarriage) recruited during their second trimester, May–November 2005 in Vienna, Austria | PbB:; Maternal PbB:; - Median: 2.5; - Range: 1.04–8.40; Placental Pb (µg/kg); - Median: 25.8; - Range: 10.7–75.4; Analysis: Pregnancy outcome (miscarriage) was analyzed using categorical regression (no confounders were applied). | The placental level of Pb (PbPl) in women with a history of miscarriage was higher (p=0.039) than in women with no history of miscarriage.; - PbPl with history of miscarriage: 39 μg/kg, n=8; - PbPl with no history of miscarriage: 27 μg/kg, n=22
Lamadrid-Figueroa et al. 2007; Cross-sectional study of 207 women (71 with previous miscarriage; 136 with no previous miscarriage) from Mexico City originally recruited for two cohorts, 1997–2004 | PbB:; Mean (SD); - All participants: 6.24 (4.48); - Controls (no miscarriages): 6.47 (4.95); - Cases (≥1 miscarriage): 5.79 (3.41); Plasma Pb (µg/dL); - All participants: 0.014 (0.013); - Controls: 0.013 (0.013); - Cases: 0.014 (0.013); Plasma/blood Pb ratio (%): mean (SD); - All participants: 0.22 (0.14); - Controls: 0.21 (0.13); - Cases: 0.25 (0.17); Analysis: Pregnancy outcome (miscarriage) was analyzed using Poisson regression and adjusted for age and education. | Adjusted IRR of miscarriage per 1 SD increase in:; - PbB: 0.93; p=0.56; - Plasma Pb: 1.12; p=0.22; - Plasma/blood Pb ratio: 1.18; p=0.02; Adjusted IRRs for miscarriage for plasma/blood Pb ratio (values for tertiles were not reported):; - T1: reference; - T2: 1.161; p=0.612; - T3: 1.903; p=0.015
Li et al. 2017b; Population-based birth cohort of 3,125 mother-infant pairs in China, enrolled in 2009 | PbB:; Mean (range): 1.5 (0.02–5.46); Stratified:; - Low: <1.18; - Medium: 1.18–1.70; - High: ≥1.71; Analysis: Pre-term birth was defined as a live birth at less than 37 weeks of gestation. Data were analyzed using multiple logistic regression models, with data adjusted for maternal age, pre-pregnancy BMI, monthly income, gravidity, and parity. | Maternal serum Pb was positively associated with risk of preterm birth in the medium and high PbB groups. ORs (95% CI):; - Low PbB: 1 (reference); - Medium PbB: 2.33 (1.49, 3.65); p<0.001; - High PbB: 3.09 (2.01, 4.76); p<0.001
Perkins et al. 2014; Birth cohort of 949 mother-infant pairs recruited at their first prenatal visit in Massachusetts 1999–2002 | PbB:; RBC Pb concentration (µg/dL); - Mean (SD): 1.22 (0.59); - Quartiles (SD):; ○ Q1: 0.65 (0.15); ○ Q2: 0.96 (0.09); ○ Q3: 1.27 (0.12); ○ Q4: 2.02 (0.60); PbB (estimated based on the assumption that the RBC Pb concentration is approximately 3-fold higher than PbB); - Mean: 0.4; Analysis: Pregnancy outcome was analyzed using multiple linear regression and logistic regression and adjusted for maternal age, race, pre-pregnancy BMI, and smoking habits. | No association was observed between RBC Pb concentration and gestational age (weeks). Adjusted linear regression, β estimates per µg/dL (95% CI):; - Q1: reference; - Q2: 0.04 (−0.28, 0.36); - Q3: −0.14 (−0.4, 0.18); - Q4: −0.17 (−0.51, 0.16); - p-trend=0.20
Rabito et al. 2014; Birth cohort study of 98 women in their 16^th^ and 28^th^ week of gestation and (aged 16–40 years) participating in the CANDLE study in Shelby County, Tennessee study 2008–2011 | PbB:; Second trimester; - Mean (SD): 0.42 (0.20); - Median: 0.43; - Range: 0.19–1.22; Third trimester; - Mean (SD): 0.45 (0.28); - Median: 0.43; - Range: 0.19–2.10; Delivery; - Mean (SD): 0.50 (0.35); - Median: 0.50; - Range: 0.21–2.47; Analysis: The association between maternal blood Pb and gestational age was analyzed using multiple linear regression. Models were adjusted for maternal age, smoking, calcium intake during pregnancy, race, gravidity (primigravida versus multigravida), insurance (Medicaid versus other insurance), marital status, education, and income. | OR (95% CI) for preterm birth:; - Second trimester PbB: 1.66 (1.23, 2.23); p<0.01; - Third trimester PbB: 1.24 (1.01, 1.52); p=0.04
Taylor et al. 2013, 2015; Longitudinal cohort of 3,870 women enrolled in the ALSPAC in the Avon area of Bristol, United Kingdom, April 1991–December 1992 | PbB:; Mean (SD): 3.67 (1.47); Median: 3.42; Range: 0.41–19.14; Analysis: Pregnancy outcome (preterm birth) was analyzed using linear regression (continuous outcomes) and logistic regression (categorical outcomes) and adjusted for maternal height, smoking, parity, sex of infant, and gestational age. | Preterm birth (number observed/number examined) comparing PbB <5.0 and PbB ≥5.0.; - <5.0: 186/3,330 (5.3%) (n=3,330); - ≥5.0: 52/540 (8.8%); p=0.001 (n=540); Adjusted OR (95% CI) for preterm birth:; - <5.0: 1 (reference); - ≥5.0: 2.0 (1.35, 3.00); p=0.001
Vigeh et al. 2010; Longitudinal cohort of 351 singleton pregnant women (15 with spontaneous abortion; 336 with no spontaneous abortion; aged 16–35 years) in Tehran, Iran 2006–2008 | PbB:; Mean (SD); - All participants: 3.8 (2.0); range: 1.0–20.5; - No spontaneous abortion: 3.83 (1.99); - Spontaneous abortion 3.51 (1.42); Analysis: Pregnancy outcome was analyzed using the t-test and logistic regression and adjusted for age, parity, hematocrit, and passive smoking exposure. | Mean PbB between the spontaneous abortion and no spontaneous abortion groups were not different (p=0.41).; No association was observed between PbB and spontaneous abortion during gestational weeks 13–19. Adjusted OR (95% CI) for log PbB: 0.331 (0.011, 10.096); p=0.53.
Vigeh et al. 2011; Longitudinal cohort of 348 singleton pregnant women (44 with preterm birth; 304 with term birth; aged 16–35 years) referred for prenatal care during the first trimester of pregnancy in Tehran, Iran, 2006 | PbB:; Mean (SD); - All participants: 3.8 (2.0); range: 1.0–20.5; - Term birth: 3.72 (2.03); - Preterm birth: 4.52 (1.63); Analysis: Preterm birth was analyzed using logistic regression and adjusted for age, infant sex, education, passive smoking exposure, pregnancy weight gain, parity, hematocrit, and delivery type. | PbB for women with preterm birth were higher (p<0.05) than for women having full-term births.; An association was observed between PbB and the risk of preterm birth.; - Adjusted OR for preterm birth: 1.41 (95% CI: 1.08, 1.84)
Yin et al. 2008; Case control study in 80 women (40 cases of anembryonic pregnancies; 40 normal pregnancies; aged 25–35 years) enrolled at 8–12 weeks of gestation in the Shanxi Province, China, August 2004–December 2006 | PbB:; Mean (95% CI); - Controls (term birth): 4.5 (3.7, 5.0); - Cases of anembryonic pregnancy: 5.3 (5.3, 5.9); Analysis: Anembryonic pregnancy was analyzed using the t-test with no adjustment for confounding factors. | PbB was higher in cases of anembryonic pregnancy (with miscarriage or resorption during gestational weeks 8–13) compared to controls with term births (p=0.03).
Zhu et al. 2010; Retrospective cohort of 43,288 mother-infant pairs (3,519 preterm birth; 39,769 term birth; aged 15–49 years) with blood Pb <10 μg/dL registered in the New York State Heavy Metal Registry 2003–2005 | PbB; Mean: 2.1; Median: 2.0; Range: 0–9.9; Quartiles:; - Q1: ≤1.0; - Q2: 1.1–2.0; - Q3: 2.1–3.0; - Q4: 3.1–9.9; Analysis: Birth outcome (birth weight, preterm delivery, and SGA) was analyzed using multiple linear regression with fractional polynomials and logistic regression and adjusted for timing of Pb test, maternal age, race, Hispanic ethnicity, smoking status, drug abuse, marital status, participation in special financial programs, parity, and infant sex. | Adjusted ORs did not show an increased risk of preterm birth for any quartile:; - Q1 (n=1,069): reference; - Q2 (n=1,036): 1.03 (0.93, 1.13); - Q3 (n=1,171): 1.01 (0.92, 1.10); - Q4 (n=243): 1.04 (0.89, 1.22)

ALSPAC = Avon Longitudinal Study of Parents and Children; BMI = body mass index; CANDLE = Conditions Affecting Neurocognitive Development and Learning in Early Childhood; Cd = cadmium; CI = confidence interval; E = estradiol; FSH = follicle-stimulating hormone; Gmean = geometric mean; Hg = mercury; IRR = incidence rate ratio; IVF = in vitro fertilization; LH = luteinizing hormone; NHANES = National Health and Nutrition Examination Survey; NR = not reported; OR = odds ratio; Pb = lead; RBC = red blood cell; RR = relative risk; SD = standard deviation; SE = standard error; SGA = small for gestational age; SHBG = sex hormone binding globulin; SMART = Study of Metals and Assisted Reproductive Technologies; T = testosterone

Table 13 Epidemiology Studies Evaluating Developmental Effects at Mean Blood Lead Concentrations (PbB) ≤10 µg/dL

Reference and study population | PbB (µg/dL) and analysis | Outcomes
Birth outcome
Al-Saleh et al. 2014; Cross-sectional study of 1,578 mother-infant pairs who delivered in Al-Kharj hospital, Saudi Arabia 2005–2006 | PbB:; Mean (SD): 2.897 (1.851); Median: 2.540; 75^th^ percentile: 3.314; Range: 0.073–25.955; Analysis: Univariate logistic regression analysis was performed to determine the odds of fetal growth outcomes in the >10^th^ percentile per log unit change in metal level compared <10^th^ percentile. | No associations were observed between maternal PbB (µg/dL) and neonatal head circumference, crown-heel length or birth weight, comparing PbB in the >10^th^ percentile to the <10^th^ PbB percentile. Unadjusted ORs (95% CI):; - Birth weight: 1.107 (0.797, 1.538); p=0.545; - Birth height: 1.299 (0.945, 1.786); p=0.107; - SGA: 1.168 (0.837, 1.631); p=0.362; - Head circumference: 1.007 (0.724,1.400); p=0.968; - Crown-heel length: 1.061 (0.795, 1.415); p=0.689; - Apgar 5-minute score: 1.027 (0.787, 1.341); p=0.842
Bloom et al. 2015; Case control study of 235 mother-infant pairs from 16 counties in Michigan and Texas, 2005–2009 | PbB:; Mean (SD): 0.71 (0.30); Median: 0.66; Range: <0.25–2.23; Tertiles:; - T1: <0.55 (reference); - T2: 0.55–<0.73; - T3: 0.73–2.23; Analysis: Birth outcome (birth weight, birth length, head circumference) was analyzed using multivariate linear regression and adjusted for maternal age, difference between maternal and parental ages, smoking habits, income, and race. | No associations were observed between maternal PbB and birth weight, birth length or head circumference. Linear regression coefficients per µg/dL (95% CI):; - Birth weight (g); ○ T2: 81.80 (−74.94, 238.55); ○ T3: −34.85 (−197.76, 128.06); ○ p-trend: 0.202; - Birth length (cm):; ○ T2: 0.43 (−0.48, 1.35); ○ T3: 0.14 (−0.81, 1.09); ○ p-trend: 0.671; - Head circumference (cm); ○ T2: 0.03 (−0.68, 0.74); ○ T3: −0.33 (−1.07, 0.41); ○ p-trend: 0.132
Bornschein et al. 1989; Prospective study of 202 mother-infant pairs for a birth cohort of 861 pairs in Cincinnati Ohio, recruited between January 1980 and May 1985 | PbB:; Mean (SD): 7.5 (1.6); Range: 1–27; Analysis: Multiple linear regression with natural log of PbB (ln PbB) adjusted for gestational age, alcohol and tobacco consumption, maternal age, maternal height, and number of prenatal visits. | A significant association between ln PbB and birth weight (with significant interaction with maternal age; p=0.0073) and length, but not head circumference. Decrease in birth weight (g) per lnPbB (µg/dL):; - Maternal age 18 years: −58; - Maternal age 30 years: −601; In the complete birth cohort (n=861) the decrease was −114 g per ln PbB (p<0.001).; Decreased birth length was associated with PbB. Regression coefficient (cm per ln PbB µg/dL): 2.5; p<0.019; No association between PbB and head circumference. Regression coefficient (cm per ln PbB µg/dL): 0.0; p=0.97
Garcia-Esquinas et al. 2014; Birth cohort with 100 mother-infant pairs in the Madrid Autonomous region from October 2003 to May 2004. Participants (mean age of 31.1 years) had resided in the study area for >1 year and had attended childbirth classes in the public health care system | PbB:; Gmean (95% CI): 1.83 (1.67, 2.01); Analysis: Birth outcome (birth weight, birth length, abdominal diameter, and cephalic diameter) was analyzed using multivariate linear regression and adjusted for district of residence (metropolitan or urban), maternal age, smoking habits, and newborn sex. | No associations were observed between maternal PbB and neonatal birth weight, birth length, abdominal diameter or cephalic diameter. Adjusted mean difference (95% CI) for a 2-fold increase in PbB (µg/L):; - Birth weight (g): 62.4 (−73.1, 197.8); - Birth length (cm): 0.17 (−0.56, 0.91); - Abdominal diameter (cm): 0.31 (−0.52, 1.15); - Cephalic diameter (cm): 0.15 (−0.21, 0.51)
Gonzalez-Cossio et al. 1997; Birth cohort study of 272 mother-infant pairs from Mexico City, Mexico; examinations were conducted at delivery | PbB:; - Maternal; ○ Mean (SD): 8.9 (4.1); ○ Quartiles:; ■ Q1: ≤5.8; ■ Q2: 5.9–8.0; ■ Q3: 8.1–11.0; ■ Q4: ≥11.1; - Umbilical cord; ○ Mean (SD): 7.1 (3.5); ○ Quartiles; ■ Q1: ≤4.6; ■ Q2: 4.7–6.1; ■ Q3: 6.2–8.5; ■ Q4: ≥8.6; Bone Pb (mg Pb/g bone):; - Tibia Pb; ○ Mean (SD): 9.8 (8.9); ○ Quartiles:; ■ Q1: ≤4.50; ■ Q2: 4.51–9.59; ■ Q3: 9.60–15.14; ■ Q4: ≥15.15; - Patella Pb; ○ Mean (SD): 14.2 (13.2); ○ Quartiles:; ■ Q1: ≤4.84; ■ Q2: 4.85–13.75; ■ Q3: 13.76–23.34; ■ Q4: ≥23.35 | Tibia Pb was negatively associated with birth weight. No association was observed between maternal or umbilical PbB and birthweight. Regression coefficient (SE):; - Maternal PbB for Q4: −98.30 (59.55); p=0.100; - Umbilical cord PbB for Q4: −41.74 (64.04); p=0.514; - Tibia Pb for Q4: −155.55 (61.18); p=0.012; - Patella Pb for Q4: −57.37 (63.22); p=0.356; For tibia, an increase of 10 mg Pb/g bone was associated with a decrease in birth weight of 73 g.
Kim et al. 2017b; Longitudinal study of 280 mother-infant pairs (maternal age range: 23–46 years) enrolled in the Children’s Health and Environmental Chemicals in Korea for the period January 2011–December 2012 | PbB:; Umbilical cord, mean (SE); - All: 1.31 (0.06); - Infant boys: 1.39 (0.09); - Infant girls: 1.21 (0.07); Analysis: Birth outcome parameters were assessed at birth. Log-transformed data were analyzed by linear regression, adjusted for maternal age, maternal BMI, gestational period, cesarean section, and smoking status. | PbB was positively associated with birth length and negatively associated with ponderal index in boys. No associations were observed for birth weight or head circumference in boys or any birth outcome measure in girls. Regression coefficient β (95% CI) for log-transformed PbB:; - Boys; ○ Birth weight: 0.010 (−0.014, 0.034); p=0.403; ○ Birth length: 0.017 (0.003, 0.031); p=0.019; ○ Head circumference: 0.010 (−0.001, 0.022); p=0.083; ○ Ponderal index: −0.055 (−0.103, −0.006); p=0.027; - Girls; ○ Birth weight: 0.001 (−0.025, 0.027); p=0.950; ○ Birth length: 0.007 (−0.010, 0.025); p=0.410; ○ Head circumference: −0.007 (−0.016, 0.002); p=0.148; ○ Ponderal index: −0.009 (−0.062, 0.045); p=0.748
Nishioka et al. 2014; Cohort study of 386 mother-infant pairs (maternal age ≥20 years) who visited Juntendo University Hospital in Tokyo, Japan December 2010–October 2012 during early gestational week 12 | PbB:; Mean (SD; range) at gestational week; - 12 weeks: 0.98 (0.55; 0.10–3.99); - 25 weeks: 0.92 (0.63; >0.09–3.96); - 36 weeks: 0.99 (0.66; <0.09–3.96); Analysis: Birth weight was analyzed using multiple regression and adjusted for hematocrit, maternal age, maternal BMI, gestational age, and alcohol consumption. | A significant correlation was observed between log maternal PbB (µg/dL) at gestational week 12 and decreased birth weight (g) in male newborns (Spearman’ coefficient=-0.145, p<0.05), but not female newborns. Regression coefficient for gestational week 12 and log PbB:; - Males: −0.151 (p<0.05); - Females: −0.098 (p>0.05); No significant correlation was observed between maternal PbB at gestational weeks 25 and 36 in both male and females.
Odland et al. 1999; Cohort study of 262 mother-infant pairs from 3 Russian (n=148; mean age 25.0) and 3 Norwegian (n=144; mean age 28.2) hospital delivery departments April 1993–June 1994 | PbB:; Maternal, mean (range); p-values compare Russian and Norwegian cohorts; - Russian cohort: 2.9 (0.83–13.5); - Norwegian cohort: 2.3 (0.41–3.9); p<0.001; - Combined cohort: not reported; Cord PbB, mean (range); - Russian cohort: 2.1 (0.62–11.0); - Norwegian cohort: 1.0 (0.41–3.7); p<0.001; Analysis: Birth weight was analyzed using multivariate and univariate linear regression and adjusted for maternal age, BMI, height, serum zinc, urinary creatinine and MBPb, parity, pre-eclamptic condition, local food consumption, smoking, and gestational age. | A significant correlation was observed between maternal PbB and decreased birth weight for combined Russian and Norwegian cohorts. Regression coefficients (g per PbB µmol/L): −1,068 (95% CI: −2,134, −2); p<0.05)
Perkins et al. 2014; Birth cohort of 829 mother-infant pairs recruited at their first prenatal visit in eastern Massachusetts 1999–2002 | PbB:; Mean: 0.4 (estimated based on the assumption that the maternal RBC Pb concentration is approximately 3-fold higher than PbB); RBC Pb concentration (µg/dL):; mean (SD): 1.22 (0.59); - Quartiles for maternal RBC Pb; mean (SD):; ○ Q1: 0.65 (0.15); ○ Q2: 0.96 (0.09); ○ Q3: 1.27 (0.12); ○ Q4: 2.02 (0.60); Analysis: Birth outcome (birth weight, birth weight for gestational age, birth length, and head circumference) was analyzed using multiple linear regression and logistic regression and adjusted for gestational weight gain, pre-pregnancy BMI, race, country of birth, 2^nd^ trimester calcium intake, parity, smoking in pregnancy, maternal age, and child sex. | No associations were observed between maternal RBC Pb concentration (µg/dL) and birth weight, birth length or head circumference. Linear regression β coefficient (95% CI) across RBC quartiles:; - Birth weight (g):; ○ Q1: reference; ○ Q2: −17 (−98, 63); ○ Q3: −15 (−95, 64); ○ Q4: −47 (−128, 35); ○ p-trend: 0.27; - Head circumference (cm):; ○ Q1: reference; ○ Q2: −0.06 (−0.29, 0.17); ○ Q3: −0.08 (−0.31, 0.15); ○ Q4: −0.08 (−0.33, 0.16); ○ p-trend: 0.56; - Birth length (cm):; ○ Q1: reference; ○ Q2: 0.03 (−0.33, 0.40); ○ Q3: 0.02 (−0.36, 0.39); ○ Q4: −0.15 (−0.54, 0.23); ○ p-trend: 0.37
Rabito et al. 2014; Birth cohort of 98 mother-infant pairs (maternal age: 16–40 years) participating in the CANDLE study in Shelby County, Tennessee, 2008–2011 | PbB:; Second trimester; - Mean (SD): 0.42 (0.20); - Median: 0.43; - Range: 0.19–1.22; Third trimester; - Mean (SD): 0.45 (0.28); - Median: 0.43; - Range: 0.19–2.10; Delivery; - Mean (SD): 0.50 (0.35); - Median: 0.50; - Range: 0.21–2.47; Analysis: Birth weight was analyzed using linear regression adjusted for maternal age, smoking, calcium intake during pregnancy, race, gravidity (Primigravida versus Multigravida), insurance (Medicaid versus other insurance), marital status, education, and income. | No association was observed (g) between maternal PbB and birth weight. Linear regression β coefficient (95% CI) µg/dL maternal PbB:; - Second trimester: −43.21 (−88.6, 2.18); p=0.06; - Third trimester: β not reported; p=0.68; - Delivery: β not reported; p=0.83
Rodosthenous et al. 2017; Prospective cohort study of 944 mother-infant pairs (mean maternal age: 27.2 years) in Mexico City; data collection period: 2007–2011 | PbB:; Maternal 2^nd^ trimester; - mean (SD): 3.7 (2.7); - range: 0.5–22.9; - Quartiles:; ○ Q1: <1.93; ○ Q2: 1.93–2.79; ○ Q3: 2.80–4.53; ○ Q4: >4.53; Analysis: Evaluation for associations between PbB and birthweight-for-gestational age z-score were conducted using multivariable linear regression, adjusted for maternal age, BMI, SES, hemoglobin levels, and infant sex. ORs were determined using logistic regression. | No association was observed between maternal PbB and birthweight-for-gestational age z-score. β (95% CI) for a doubling of PbB: −0.06 (−0.13, 0.003); p=0.06.; No trend for small-for gestational age infants was observed across PbB quartiles. OR (95% CI):; - Q1: 1 (reference); - Q2: 1.30 (0.79–2.15); - Q3: 1.37 (0.83–2.25); - Q4: 1.62 (0.99–2.65); - p-trend: 0.06
Taylor et al. 2013, 2015; Longitudinal cohort study of 4,285 mother-infant pairs enrolled in the ALSPAC in the Avon area of Bristol, United Kingdom April 1991–December 1992 | PbB:; Mean (SD): 3.67 (1.47); Median: 3.42; Range: 0.41–19.14; Analysis: Birth outcome (birth weights, head circumference, crown-heel length, and low birth weight) was analyzed using linear regression (continuous outcomes) and logistic regression (categorical outcomes) and adjusted for maternal height, smoking, parity, sex of infant, and gestational age. | Birth outcomes comparing PbB <5.0 and PbB ≥5.0 µg/dL.; - Birth weight (g), mean (SD); ○ <5.0: 3,424 (567) (n=3,469); ○ ≥5.0: 3,334 (595); p=0.001 (n=583); - Head circumference (cm), mean (SD); ○ <5.0: 34.8 (1.5) (n=3010); ○ ≥5.0: 34.6 (1.8); p=0.031 (n=504); - Crown-heel length (cm); ○ <5.0: 50.7 (2.3) (n=2,970); ○ ≥5.0: 50.4 (2.6); p=0.011 (n=497); - Low birth weight (<2,500 g), n (%); ○ <5.0: 346/3,654 (9.5%); ○ ≥5.0: 74/615 (12.0%); p=0.048; Maternal PbB was associated with significant reductions in birth weight (g), head circumference (sc), and crown-heel length (cm). β coefficients per µg/dL (SE); 95% CI; - Birth weight: −13.23 (5.37); −23.75, −2.70; p=0.014; - Head circumference: −0.04 (0.16); −0.07, −0.06 (as reported; β coefficient is outside of the 95% CI); p=0.021; - Crown-heel length: −0.05 (0.03); −0.10, −0.00; p=0.034
Thomas et al. 2015; Prospective cohort of 1,835 mother-infant pairs (maternal age ≥18 years), recruited 2008–2011 and evaluated from their first trimester from 10 study sites across Canada | PbB:; Median: 0.59; Range: 0.17–4.04; Tertiles:; - T1: <0.52; - T2: 0.52–1.04; - T3: >1.04; Analysis: Birth outcome (length, weight at birth, gestational age) was analyzed using log binomial regression and adjusted for age, parity, ethnicity, country of origin, household income, education, smoking status, pre-pregnancy BMI, and marital status. | No association was observed between maternal PbB and SGA. Adjusted RR (95% CI):; - T1: reference; - T2: 1.33 (0.88,1.99); - T3: 1.19 (0.65, 2.18)
Wang et al. 2017b; Prospective cohort study of 3,125 mother-infant pairs (mean age of mothers: 27.5 years) participating in the China-Anhui Birth Cohort Study; data collection period not specified | Serum Pb (maternal):; Mean: 1.50; Median: 1.43; Range: 0.02–5.46; Tertiles (for serum Pb measured in 1^st^ and 2^nd^ trimesters):; - T1: <1.18; - T2: 1.18–1.70; - T3: ≥1.71; Analysis: Associations between serum Pb and birth outcome measures were analyzed by linear regression models. ORs for correlation of maternal Pb level with risk of SGA infants were analyzed by multivariate logistic regression. All models were adjusted for pre-pregnancy BMI, maternal age, gravidity, parity, time for collection serum, and monthly income. | A negative association was observed between serum Pb and SGA for all infants in T2 and T3, and for girl infants and boy infants in T3. OR (95% CI):; - All infants:; ○ T1: 1 (reference); ○ T2: 1.45 (1.04,2.02); p=0.03; ○ T3: 1.69 (1.22,2.34); p=0.002; - Boys:; ○ T1: 1 (reference); ○ T2: 1.44 (0.83, 2.50); ○ T3: 1.75 (1.03, 2.99); - Girls:; ○ T1: 1 (reference); ○ T2: 1.51 (0.99, 2.31); ○ T3: 1.68 (1.12, 2.54); A negative association was observed between serum Pb and birth weight, but not birth length, head circumference or chest circumference. Regression coefficient β (95% CI):; - Birth weight: −2.74 (−5.17, −0.31); p=0.03; - Birth length: −0.013 (−0.026, 0.001); p=0.06; - Head circumference: −0.008 (−0.019, 0.004); p=0.18; - Chest circumference: −0.008 (−0.018, 0.002); p=0.13
Wang et al. 2017c; Cross-sectional study of 1,009 mother-infant pairs (537 boys and 472 girls) in Shanghai; data collection period: September 2008–October 2009 | PbB:; Cord PbB, Gmean (95% CI); All: 4.07 (3.98, 4.17); Infant boys: 4.07 (3.89, 4.17); Infant girls: 4.17 (3.98, 4.36); Analysis: PbB data were log-transformed. Data on birth outcome variables (birth weight, birth length, head circumference, and ponderal index) were analyzed by multiple linear regression adjusted for maternal age, gestational age, maternal BMI before delivery, parity, sex of baby, monthly household income per capita, mode of delivery, and diet. | A positive association was observed between cord PbB and birth weight in boys and negative association for ponderal index in girls. Regression coefficient β (95%), per 1-unit increase in log_10_-transformed PbB:; - Birth weight (g); ○ All: 60.78 (−66.30, 187.85); p=0.35; ○ Boys: 182.32 (15.24. 349.39); p=0.03; ○ Girls: −96.06 (−289.23, 97.10); p=0.33; - Birth length (cm); ○ All: 0.32 (−0.18, 0.82); p=0.21; ○ Boys: not reported; ○ Girls: 0.30 (−0.46, 1.05); p=0.44; - Head circumference (cm); ○ All: −0.36 (−0.78, 0.06); p=0.09; ○ Boys: −0.50 (−1.09, 0.09); p=0.10; ○ Girls: −0.32 (−0.91, 0.27); p=0.29; - Ponderal index [(g/cm^3^) × 100]; ○ All: −0.01(−0.10, 0.09); p=0.94; ○ Boys: 0.10 (−0.03, 0.23); p=0.12; ○ Girls: −0.17 (−0.31, −0.02); p=0.02
Xie et al. 2013; Birth cohort of 252 mother-infant pairs recruited from a rural area near the south coast of Laizhou Bay, China, 2010–2011 | PbB:; Mean (SD): 3.53 (1.51); Median: 3.20; Range: 1.00–11.91; Analysis: Birth outcome (birth weight, birth length, and head circumference) was analyzed using multiple linear regression and adjusted for infant sex, gestational age, maternal education, parity, maternal age, pre-pregnancy BMI, and weight gain during pregnancy. | A negative association was observed for maternal PbB for a square root unit increase and birth weight (g), but no association was found for birth length (cm) or head circumference (cm). β coefficients per square root increase in PbB µg/dL (95% CI):; - Birth weight: −148.99 (−286.33, −11.66); p=0.03; - Birth length: −0.46 (−1.25, 0.34); p=0.26; - Head circumference: −0.37 (−0.78, 0.19); p=0.24; A 1-µg/dL increase in maternal PbB was associated with a decrease in birth weight of 39.10 g (95% C: −72.79, −5.41); p=0.02.
Zhu et al. 2010; Retrospective cohort of 43,288 mother-infant pairs (3,519 preterm birth; 39,769 term birth; aged 15–49 years) with blood Pb <10 μg/dL registered in the New York State Heavy Metal Registry 2003–2005 | PbB; Mean: 2.1; Median: 2.0; Range: 0–9.9; Quartiles:; - Q1: ≤1.0; - Q2: 1.1–2.0; - Q3: 2.1–3.0; - Q4: 3.1–9.9; Analysis: Birth outcome (birth weight, preterm delivery, and SGA) was analyzed using multiple linear regression with fractional polynomials and logistic regression and adjusted for timing of Pb test, maternal age, race, Hispanic ethnicity, smoking status, drug abuse, marital status, participation in special financial programs, parity, and infant sex. | A negative association was observed for maternal PbB (per 1 µg/dL increased in PbB) and birth weight (g). β coefficients (95% CI) for PbB of:; 0: reference; 1: −27.4 (−17.1, −37.8); 2: −38.8 (−24.1, −53.4); 3: −47.5 (−29.6, −65.4); 4: −54.8 (−34.2, −75.5); 5: −61.3 (−38.2, −84.4); 6: −67.2 (−41.8, −92.5); 7: −72.5 (−45.2, −99.9); 8: −77.6 (−48.3, −106.8); 9: −82.3 (−51.2, −113.3); 10: −86.7 (−54.0, −119.4); Adjusted ORs did not show an increased risk of small-for-gestational age for any quartile:; - Q1 (n=1168): reference; - Q2 (n=1268): 1.07 (0.98, 1.17); - Q3 (n=1353): 1.06 (0.98, 1.16; - Q4 (n=303): 1.07 (0.93, 1.23)
Birth defects
Brender et al. 2006; Case-control study of 184 Mexican-American women (age range not specified) with neural tube defect-affected pregnancies living in Texas counties boarding Mexico 1995–2000; controls (n=225) had normal live births | PbB:; Control; - Mean (SD): 2.5 (1.6); - Range: 0–8; Cases; - Mean (SD): 2.4 (1.9); - Range: 0–8; Analysis: Birth defects (neural tube defect) was analyzed using logistical regression and adjusted for household income, proximity to industrial sites, and breastfeeding. | No difference was observed between maternal PbB in controls versus cases (p>0.05).; The risk of neural tube defect was not increased in cases versus controls: OR (95% CI) for PbB ≥6 µg/dL: 1.5 (0.6, 4.3). Further adjustment for breastfeeding increased the OR (95% CI): 3.8 (0.8, 19.5).
Liu et al. 2018a; Case-control study for congenital heart disease for gestational ages 14–40 weeks in 97 cases and 201 controls in China; data collection period: February 2010–October 2011 | PbB:; - Umbilical cord Pb median (median); ○ Controls: 0.740; ○ Cases: 0.791; - Tertiles; ○ T1: <0.696; ○ T2: 0.696–<0.826; ○ T3: ≥0.826; Analysis: ORs for congenital heart defects were calculated by logistic regression adjusted for maternal age, maternal BMI, maternal education level, use of folic acid supplement, and parental smoking status. | The risk of all congenital heart disease (including septal defects, conotruncal defects, right- or left-sided outflow tract deformity, anomalous pulmonary venous return, and any other structural abnormalities) ORs (95% CI):; - T1: 1.00 (reference); - T2: 1.46 (0.77, 2.77); - T3: 1.67 (0.88, 3.17)
Needleman et al. 1984; Case-control study of 4,354 mother-infant pairs (maternal age 16–35 years) delivering at least 20 weeks gestation age at the Boston Hospital for Woman, April 1979–March 1980 | Cord blood Pb; Quartiles: mean (percentage of neonates with cord blood Pb >mean); - Q1: 0.7 (98.7); - Q2: 6.3 (50.0); - Q3: 15 (1.7); - Q4: 24 (0.2); Analysis: Birth defects (hemangiomas, lymphangiomas, hydrocele, minor skin irritations, and undescended testicles) were analyzed using logistic regression and adjusted for gestational age, birth weight, history of spontaneous or induced abortion, maternal parity, and age. | The following minor congenital anomalies were observed: hemangiomas, lymphangiomas, hydrocele, minor skin irritations (e.g., skin tags, papillae), and undescended testicles. No association with Pb was observed for any single malformation (summary statistics not reported).; RR (95% CI) of all anomalies:; - Q1: 1 (reference); - Q2: 1.87 (1.44, 2.42); - Q3: 2.38 (1.66, 3.43); - Q4: 2.73 (1.80, 4.16)
Anthropometric measures in children
Afeiche et al. 2011; Cross-sectional study of 999 children (522 boys; 477 girls; aged 0–5 years) previously enrolled in one of three birth cohorts for other longitudinal studies in Mexico City 1994–2005 | PbB:; - Child PbB, mean (SD): 3.8 (2.9); - Maternal PbB not reported; Maternal bone Pb, mean (SD), µg/g; - Patella: 10.4 (11.8); - Tibia: 8.7 (9.7); Analysis: Birth weight was analyzed using Univariate and bivariate regression and adjusted for birth cohort, maternal age, maternal calf circumference, maternal height, education, parity, breast feeding, gestational age, height at birth, and repeated concurrent child blood Pb measures. | A lower weight (g) trajectory was observed in females at 1–5 years of age, but not males, in association with maternal patella Pb. β coefficients (95% CI) for a 1-SD increase in maternal patella Pb (µg/g):; Females; - 12 months: −70.9 (−147.9, 6.0); - 24 months: −96.1 (−170.4, −21.8); - 36 months: −121.3 (−200.0, −42.6); - 48 months: −146.4 (−235.5, −57.4); - 60 months: −171.6 (−275.2, −68.0); Males; - 12 months: 29.4 (−42.1, 100.8); - 24 months: 27.8 (−43.5, 99.1); - 36 months: 7.9 (−67.3, 83.1); - 48 months: −13.6 (−97.9, 70.8); - 60 months: −35.0 (−132.4, 62.3)
Alvarez-Ortega et al. 2019; Cross-sectional study of 554 children (ages 5–16 years; 53.1% female) from Columbia; data collection period: January–August 2015 | PbB:; Mean (SE): 3.5 (0.2); Median: 1.9; Range: 0.1–50.1; Analysis: The relationship between PbB and anthropometric measures were analyzed by Spearman correlation analysis. No information on adjustments was reported. | Negative correlations were observed between PbB and weight, height, and BMI for all participants, females, and children ages 12–16 years: Spearman correlations:; - Weight; ○ All participants: −0.152; p<0.001; ○ Females: −0.226; p<0.001; ○ Males: −0.056; p=0.380; ○ Age 5–11 years: −0.069; p=0.010; ○ Age 12–16 years: −0.385; p<0.001; - Height; ○ All participants: −0.101; p=0.019; ○ Females: −0.153; p=0.009; ○ Males: −0.037; p=0.567; ○ Age 5–11 years: −0.137; p=0.418; ○ Age 12–16 years: −0.206; p=0.009; - BMI; ○ All participants: −0.172; p<0.001; ○ Females: −0.273; p<0.001; ○ Males: −0.040; p=0.536; ○ Age 5–11 years: −0.056; p=0.295; ○ Age 12–16 years: −0.384; p<0.001
Dallaire et al. 2014; Prospective cohort study of 290 children (aged 8–14 years) born from Inuit mothers (n=233) who were recruited at their first prenatal visit, Arctic Québec 1993–1998 | Cord blood Pb:; - Mean (SD): 4.8 (3.3); - Range: 0.8–20.9; Child blood Pb:; - Mean (SD): 2.7 (2.1); - Range: 0.4–12.8; Analysis: Pubertal state (head circumference, height, weight) was analyzed using multiple regression and adjusted for: (1) child characteristics (sex of child, duration of gestation, duration of breastfeeding, child age at testing, concentrations of mercury, vitamin, and hemoglobin in child blood), (2) maternal parameters (pre-pregnancy weight, height, age at delivery, parity, education, marital status, SES, food insecurity of the family, cord plasma levels of the omega-3 fatty acid docosahexaenoic acid, and (3) other prenatal exposures (cord mercury, maternal smoking, alcohol use, and illicit drug use). | Cord blood Pb: significant associations were observed between cord blood Pb and child head circumference (cm) and height (cm), but not child weight (kg) or BMI (kg/m^2^), in children 8–14 years of age. β coefficients per µg/dL; 95% CI not reported:; - Height: −1.57 (p=0.004); - Head circumference: −0.005; p=0.04; - Weight: β not reported; p=0.70; - BMI: −0.07; p=0.23
Deierlein et al. 2019; Prospective longitudinal study of 683 girls (enrolled at ages 6–8 years) from three locations (New York, Cincinnati, and San Francisco); data collection period: 2004–2007 | PbB:; - All participants (n=683); ○ Mean (SD): 1.16 (0.67); ○ Range: 0.18–5.40; - New York (n=30); ○ Mean (SD): 1.29 (0.63); ○ Range: 0.44–3.20; ○ <1 µg/dL: n=12; ○ ≥1 µg/dL: n=18; - Cincinnati (n=326); ○ Mean (SD): 1.28 (0.79); ○ Range: 0.34–5.40; ○ <1 µg/dL: n=153; ○ ≥1 µg/dL: n=173; - San Francisco (n=327); ○ Mean (SD): 1.04 (0.51); ○ Range: 0.18–3.73; ○ <1 µg/dL: n=177; ○ ≥1 µg/dL: n=150; Analysis: PbB was measured at enrollment and anthropometry measurements (height, BMI, waist circumference, and percent body fat) were measured at ≥3 biannual or annual follow-up visits. Participants were stratified into two groups: <1 and ≥1 µg/dL. Linear mixed effects regression analysis was used to estimate associations between PbB and anthropometric measures from ages 7 to 14 years, adjusting for age, age squared, race, interaction between age and PbB, interaction between age squared and PbB, and interaction between race and age. | Regression analysis predicted lower anthropometric measures were lower in girls with PbB ≥1 µg/dL compared to <1 µg/dL at all ages. Predicted mean differences (95% CI) for PbB ≥1 µg/dL compared to <1 µg/dL at ages 7–14 years:; - Height (cm) at ages; ○ 7: −2.0 (−3.0, −1.0); p<0.001; ○ 8: −1.9 (−2.8, −0.9): p<0.001; ○ 9: −1.7 (−2.7, −0.8); p<0.001; ○ 10: −1.6 (−2.6, −0.7): p=0.001; ○ 11: −1.6 (−2.5, −0.6): p=0.002; ○ 12: −1.5 (−2.5, −0.5): p=0.004; ○ 13: −1.5 (−2.5, −0.5): p=0.004; ○ 14: −1.5 (−2.5, −0.4): p=0.01; - BMI (kg/m^2^) at ages; ○ 7: −0.7 (−1.2, −0.2); p=0.005; ○ 8: −0.8 (−1.3, −0.3); p=0.001; ○ 9: −0.9 (−1.4, −0.4) p=0.001; ○ 10: −0.9 (−1.4, −0.4); p=0.001; ○ 11: −0.9 (−1.5, −0.3); p=0.002; ○ 12: −0.9 (−1.5, 0.3); p=0.005; ○ 13: −0.8 (−1.5, −0.2); p-0.02; ○ 14: −0.8 (−1.5, −0.02); p=0.05; - Waist circumference (cm) at ages; ○ 7: −2.2 (−3.8, −0.6); p=0.01; ○ 8: −2.5 (−3.8, −1.1); p<0.001; ○ 9: −2.7 (−4.0, −1.4); p<0.001; ○ 10: −2.9 (−4.3, −1.4) p<0.001; ○ 11: −3.0 (−4.5, −1.4); p<0.001; ○ 12: −3.0 (−4.7, −1.3); p=0.001; ○ 13: −3.0 (−4.8, −1.1); p=0.002; ○ 14: −2.9 (−4.8, −0.9); p=0.005; - Body fat (%) at ages; ○ 7: −1.8 (−3.2, −0.4); p=0.01; ○ 8: −2.0 (−3.3, −0.7); p=0.003; ○ 9: −2.1 (−3.4, −0.8); p=0.001; ○ 10: −2.2 (−3.4, −0.9); p=0.001; ○ 11: −2.1 (−3.4, −0.9); p=0.001; ○ 12: −2.1 (−3.4, −0.8); p=0.002; ○ 13: −1.9 (−3.2, −0.6); p=0.003; ○ 14: −1.7 (−3.1, −0.4); p=0.01
Hauser et al. 2008; Cross-sectional study of 489 healthy boys (aged 8–9 years) residing in Chapaevsk Russia, May 2003–May 2005 | Child PbB:; Mean (25^th^–75^th^ percentile): 3 (2–5); Number of children with PbB >10: 3; Analysis: Pubertal state (height and weight) was analyzed using multivariate logistic regression and adjusted for gestational age, height, BMI, and age at exam. | Associations were observed for PbB (natural log transformation, µg/dL) and height (cm), but not weight (kg) or BMI (kg/m^2^), in 8–9-year-old boys. Adjusted regression coefficient (95% CI):; - Height: −1.439 (−2.25, −0.63); p<0.001; - Weight: −0.761 (−1.54, 0.02); p=0.067; - BMI: −0.107 (−0.44, 0.23); p=0.53
Hong et al. 2014; Cross-sectional study of 1,150 mother-infant pairs (546 girls; 604 boys; aged 6–24 months) previously enrolled in a prospective birth cohort, South Korea May 2006–December 2010 | Maternal PbB:; Early pregnancy,; - Mean (SD): 1.25 (1.46); - Range: 0.25–2.63; Late pregnancy; - Mean (SD): 1.25 (1.52); - Range: 0.26–2.52; Cord blood Pb:; Mean (SD): 0.91 (1.57); Range: 0.11–1.90; Analysis: Pubertal state (weight and height) was analyzed using multivariate linear regression and adjusted for child sex, maternal age, maternal education, pre-pregnancy maternal BMI, and gestational age. | Associations between maternal PbB (log transformed, µg/dL) in late pregnancy, but not for maternal PbB in early pregnancy or cord blood Pb, and z scores for weight (g) and height (cm) were observed in children at 24 months of age. β coefficients (95% CI):; - Late pregnancy PbB:; ○ Weight z score: −0.28 (−0.48, −0.09); p<0.05; ○ Height z score: −0.28 (−0.49, −0.06); p<0.05; - Early pregnancy PbB:; ○ Weight z score: −0.05 (−0.22, 0.11); ○ Height z score: −0.15 (−0.34, 0.04); - Cord blood PbB:; ○ Weight z score: −0.1 (−0.21, 0.17); ○ Height z score: 0.02 (−0.19, 0.24)
Ignasiak et al. 2006; Cross-sectional study of 899 school children (463 boys, 436 girls; aged 7–15 years) residing near copper smelters and refineries, South-Western Poland, 1995 | PbB:; Mean: 7.7; Range: 2.0–33.9; Analysis: Pubertal state (weight and height, BMI, trunk length, leg length, arm length, and trunk-length ratio) was analyzed using stepwise multiple regression analysis and adjusted for mother’s education and two age terms (age, age^2^). | Associations were observed between PbB and several anthropometric measures. Slope per log_10_ µg/dL (SE):; - Weight (kg); ○ Boys: −4.00 (2.45); p=0.10; ○ Girls: −6.59 (2.09); p=0.001; - Height (cm); ○ Boys: −6.26 (1.40); p=0.002; ○ Girls: −5.54 (2.05); p=0.007; - BMI (kg/m^2^); ○ Boys: −0.39 (0.82); p=NS; ○ Girls: −1.86 (0.75); p=0.01); - Trunk length (cm); ○ Boys: −2.21 (0.97); p=0.02; ○ Girls: −1.47 (1.00); p=NS; - Leg length (cm); ○ Boys: −4.05 (1.27); p=0.002; ○ Girls: −4.08 (1.27) p=0.0001; - Arm length (cm); ○ Boys: −3.20 (0.97); p=0.0001; ○ Girls: −2.61 (0.98); p=0.008; - Trunk-length ratio; ○ Boys: 0.71 (0.34): p=0.04; ○ Girls: 1.03 (0.34); p=0.003
Kim et al. 2017b; Prospective longitudinal study of 280 children enrolled in the Children’s Health and Environmental Chemicals in Korea recruited during January 2011–December 2012 | PbB:; Umbilical cord, mean (SE): 1.31 (0.06); - All: 1.31 (0.06); - Boys: 1.39 (0.09); - Girls: 1.21 (0.07); Analysis: Anthropogenic measures were assessed during a 27-month period. All data were log-transformed data associations between PbB and outcome measures were analyzed by linear regression, adjusted for child gender, maternal age, maternal BMI, gestational period, cesarean section, and smoking status. | Positive associations were observed between PbB and body weight and BMI at 24 months, no associations were observed at 18 or 27 months. Regression coefficient β (95% CI):; - Weight:; ○ 18 months: 0.897 (−0.171, 1.965); p=0.092; ○ 24 months: 0.717 (0.195, 1.239); p=0.009; ○ 27 months: 0.316 (−0.345, 0.977); p=0.333; - Height:; ○ 18 months: 0.909 (−0.222, 2.040); p=0.101; ○ 24 months: 0.138 (−0.530, 0.806); p=0.675; ○ 27 months: 0.354 (−0.497, 1.205); p=0.394; - BMI:; ○ 18 months: 0.157 (−1.266, 1.580) p=0.806; ○ 24 months: 0.695 (0.077, 1.313); p=0.029; ○ 27 months: 0.409 (−0.398, 1.216); p=0.300
Lamb et al. 2008; Population-based prospective cohort study of 309 mother-child pairs (children aged 1–10 years) who previously participated in the Yugoslavia Study of Environmental Lead Exposure, Pregnancy Outcomes, and Childhood Development, Mitrovica and Pristina, Yugoslavia 1985–1986 | Maternal PbB:; Mid-pregnancy, mean (SD), for town of:; - Pristina: 5.60 (1.99); - Mitrovica: 20.56 (7.38); Analysis: Pubertal state (height and BMI at birth) was analyzed using linear regression and adjusted for infant sex, ethnicity, parity, maternal height or BMI, maternal education, gestational age at blood sample, gestational age at birth, and quality of home environment. | No associations were observed between maternal PbB and child height (cm) or BMI (kg/m^2^) at 1, 4, 6.5, or 10 years of age. β coefficients per log µg/dL (95% CI) for ages 1 and 10 years for attained height/BMI:; - Pristina:; ○ 1 years: −0.61 (−2.24, 1.03); ○ 10 years: −0.09 (−3.69, 3.52); - Mitrovica:; ○ 1 years: −0.30 (−2.55, 1.96); ○ 10 years: −2.87 (−6.21, 0.47)
Little et al. 2009; Cross-sectional study of 360 children (aged 2–12 years), from two cohorts studied in 1980–1989 (n=191) and 2002 (n=169), Dallas, Texas | Child PbB:; Mean (SE); - 1980 cohort: 23.6 (1.3); - 2002 cohort: 1.6 (0.2); - Pooled cohort PbB not reported; Analysis: Pubertal state (height, weight, and BMI) was analyzed using MANOVA/MANCOVA and regression models and adjusted for child’s sex, cohort effect, and two age terms (age, age^2^). | Study authors concluded that “male and female children ages one to 12 years old in 2002 were significantly (p<0.0001) taller and heavier with higher BMI and lower blood lead than children measured in the 1980s.”; For the pooled cohort, a decrease in PbB of 10 µg/dL was associated with increased height (cm), weight (kg), and BMI (kg/m^2^).; - Height: 2.1 (95% CI: 1.9, 2.3); p<0.0001; - Weight: 1.9 (95% CI: 1.7, 2.1); p<0.0001; - BMI: 0.5 (0.4, 0.7); p<0.0001.
Min et al. 2008b; Cross-sectional study of 108 children (62 boys, 46 girls; aged 5–13 years), Seoul South Korea (study dates not reported) | Child PbB:; Mean (SD): 2.4 (0.7); Range: 0.8–5.2; Number of children with PbB >10: 14; Analysis: Pubertal state (height, weight, BMI, and total arm length) was analyzed using multiple linear regression and adjusted for child’s age, child’s sex, and father’s education. | PbB was negatively associated with height (cm) and total arm length (cm), but not weight (kg) or BMI (kg/m^2^). Regression coefficient per µg/dL (SE); - Height: −1.449 (0.639); p=0.026; - Weight: −0.646 (0.718); p=0.370; - BMI: −0.006 (0.272); p=0.982; - Total arm length: −1.804 (0.702); p=0.012
Olivero-Verbel et al. 2007; Cross-sectional study of 189 children (99 boys, 90 girls; aged 5–9 years) from 10 primary schools, Cartagena Columbia, June–August 2004 | Child PbB:; Mean (SE): 5.53 (0.23); Range: <1.0–21.0; Analysis: Pubertal state (height and weight) was analyzed using univariate and bivariate statistics and Spearman correlation without adjustment for confounding factors. | An association was observed between PbB and height (cm), but not weight (kg). Correlation coefficients:; - Height: −0.224;p=0.002; - Weight: −0.126; p=0.087
Raihan et al. 2018; Cross-sectional study of 729 children (<2 years of age; mean age: 12.6 months; 50.3% males) in Bangladesh; data collection period: November 2009–December 2012 | Child PbB:; Mean (SD): 8.25 (3.64); 95% CI: 7.98, 8.51; “Normal” PbB: <5; “Elevated” PbB: ≥5; Analysis: ORs for “elevated” PbB (relative to “normal” PbB) and stunting (defined as length-for-age z score <-2), wasting (defined as weight-for-length z-score <-2), and underweight (defined as weight-for-age z-score <-2) were analyzed by multiple logistic regression. Adjustment variables included gender, age, weight, maternal education, BMI, average household income, and Household Food Insecurity Access Scale categories. | For PbB ≥5 µg/dL (compared to PbB <5 µg/dL) increased risks were observed for stunting and underweight, but not wasting. Adjusted ORs (95% CI):; - Stunting: 1.78 (1.07, 2.99); p=0.028; - Wasting: 1.18 (0.64, 2.19); p=0.581; - Underweight: 1.63 (1.02, 2.61); p=0.043
Renzetti et al. 2017; Prospective study of 513 mothers and their children who returned for assessments at ages 4–6 years in Mexico City; data collection period: 2007–2011; PROGRESS cohort | PbB:; Gmean (range); - Maternal; ○ 2^nd^ trimester: 3.0 (0.8–17.8); ○ 3^rd^ trimester: 3.1 (0.3–28.3); ○ At delivery: 3.5 (0.7–21.9); - Umbilical cord: 2.8 (0.4–18.5); Analysis: Maternal PbB was collected during the 2^nd^ and 3^rd^ trimesters of pregnancy and within 12 hours of delivery; umbilical cord PbB was also measured. Anthropometric measures in children were assessed at ages 4–6 years. PbB data were log2-transformed and associations between PbB and anthropometric measures were analyzed by linear regression, adjusted for mother’s age, BMI, education, gestational age, primiparity, cigarette smoke exposure, delivery mode, breastfeeding, sex of the child, parity, total dietary intake, childhood blood lead, and child’s age. | Negative associations between PbB and weight-for-age z-score and height-for-age z-score in the 3^rd^ trimester. No associations were observed for any other PbB measurements. β coefficient (95% CI) for:; BMI z-score; - 2^nd^ trimester: 0.04 (−0.07, 0.15); p=0.51; - 3^rd^ trimester: −0.01 (−0.12, 0.10); p=0.81; - At delivery: −0.03 (−0.08, 0.14); p=0.58; - Cord PbB: 0.05 (−0.08, 0.17); p=0.46; Percentage body fat; - 2^nd^ trimester: −0.13 (−0.75, 0.49); p=0.68; - 3^rd^ trimester: −0.21 (−0.82, 0.41); p=0.52; - At delivery: −0.12 (−0.74, 0.50); p=0.70; - Cord PbB: 0.31 (−0.37, 0.99); p=0.37; Weight-for-age z-score; - 2^nd^ trimester: −0.02 (−0.13, 0.09); p=0.68; - 3^rd^ trimester: −0.11 (−0.22, −0.003); p=0.04; - At delivery: −0.03 (−0.13, 0.08); p=0.58; - Cord PbB: −0.03 (−0.15, 0.09); p=0.64; Height-for-age z-score; - 2^nd^ trimester: −0.04 (−0.13, 0.04); p=0.32; - 3^rd^ trimester: −0.10 (−0.19, −0.01); p=0.03; - At delivery: −0.04 (−0.13, 0.05); p=0.39; - Cord PbB: −0.04 (−0.14, 0.06); p=0.39
Schell et al. 2009; Longitudinal cohort study of 244 mother-child pairs (mean maternal age 22.7 years; children aged 3–12 months) receiving first-time prenatal care in Albany New York, 1986–1992 and 1992–1998 (study was conducted in two phases) | Maternal PbB:; (measured in the 2^nd^ trimester); - Mean (SD): 2.8 (2.63); - Range: 0.4–13; Analysis: Pubertal state (length, weight for age, weight for length, head circumference, and upper arm circumference) was analyzed using multiple linear regression and adjusted for infant sex, infant birth weight, infant nutrition, maternal age, marital status, employment, race, height, parity, 2^nd^ trimester smoking, and education. | Associations were observed between maternal PbB and length (positive) and head circumference (negative), but not for weight, weight for length, or upper arm circumference. Regression coefficients per log µg/dL (SE):; - Length (cm); ○ 6 months: 0.149 (0.076); p=0.05; ○ 12 months: 0.073 (0.083); p=0.38; - Weight-for-age (kg); ○ 6 months: 0.013 (0.098); p=0.89; ○ 12 months: 0.124 (0.107); p=0.25; - Weight for length (kg):; ○ 6 months: −0.158 (0.111); p=0.16; ○ 12 months: 0.084 (0.111); p=0.45; - Head circumference (cm); ○ 6 months: −0.242 (0.094); p=0.01; ○ 12 months: −0.220 (0.109); p=0.05; - Upper arm circumference (cm); ○ 12 months: −0.132 (0.114); p=0.25; When stratified by maternal PbB <3 and ≥3 µg/dL, no associations were observed at PbB <3 µg/dL. For PbB ≥3 µg/dL, significant associations were observed for weight for length at 6 months and head circumference at 6 and 12 months. Regression coefficients (SE):; - Weight (kg); ○ 6 months: −0.771 (0.344); p=0.03; - Weight for length (kg):; ○ 6 months: −1.461 (0.404); p<0.01; - Head circumference (cm); ○ 6 months: −0.846 (0.338); p=0.01; ○ 12 months: −1.163 (0.376); p<0.01; - Upper arm circumference (cm); ○ 12 months: −1.063 (0.436); p=0.02
Yang et al. 2013a; Cross sectional study of 246 children (aged 3–8 years) attending kindergarten near an electronic waste processing area, Guiyu China (dates are not reported) | Child PbB; Mean: 7.30; 5^th^–95^th^ percentile: 4.33–15.43; Analysis: Pubertal state (height, weight, BMI, and biochemical markers related to bone metabolism) was analyzed using multiple linear regression and Spearman correlation coefficients and adjusted for child age and sex. | Linear regression analysis showed negative associations between PbB and height (cm) and weight (kg), but not BMI (kg/m^2^). β coefficients per µg/dL:; - Height: −0.10; p=0.02; - Weight: −0.14; p=0.01; - BMI: −0.08; p=0.24; Spearman correlation coefficients:; - Height: −0.119; 0.05<p<0.01; - Weight: −0.128; 0.05<p<0.01; - Osteocalcin: 0.020; p>0.05; - bALP: 0.087; p>0.05; - uDPD: 0.239; p<0.01
Onset of puberty in females
Den Hond et al. 2011; Cross-sectional study of 792 girls (aged 14–15 years) attending their 3^rd^ year of secondary education and living in the study area for at least 5 years, Flanders Belgium 2003–2004 | PbB:; Median: 1.81; 10^th^–90^th^ percentile: 0.88–3.81; Analysis: Puberty onset (pubic hair growth and breast development) was analyzed using logistic regression and adjusted for age, BMI, smoking, and oral contraception use. | A 2-fold increase in PbB was associated with 35% lower odds of reaching stage P4 for pubic hair development. Adjusted OR (95% CI): 0.65 (0.45, 0.93); p=0.020.; No association was observed between PbB and breast development (data not reported).
Denham et al. 2005; Cross-sectional study of 138 Akwesasne Mohawk Nation girls (aged 10–16.9 years), territory spanning New York, Ontario and Quebec, Canada (dates are not reported) | PbB:; Mean (SD): 0.49 (0.905); Range: 0.07–4.40; Median: 1.2; 75^th^ percentile: 1.66; Analysis: Puberty onset (attainment of menarche) was analyzed using probit and logistic regression and adjusted for age, SES, and BMI. | PbB was associated with a decreased likelihood of attaining menarche. β coefficient (SE) predicting menarcheal status based on PbB (ln µg/dL):; - Mean PbB: −1.29 (0.494); p=0.01; - 75^th^ percentile PbB: −3.75 (1.822); p=0.04; For PbB ≥1.2, the predicted age at menarche for girls was 10.6 months later than for girls with PbB <1.2. Predicted age of menarche (95% CI):; - PbB <1.2: 11.8 years (9.9. 12.8); - PbB ≥1.2: 12.7 years (12.2, 13.1); A doubling of PbB was associated with decreased odds of reaching menarche (data presented graphically):; - PbB increase from 0.49 to 0.98: 72% decrease; - PbB increase from 1.66 to 3.32: 98% decrease
Gollenberg et al. 2010; Cross-sectional study of 705 girls (aged 6–11 years) who previously participated in the NHANES III study 1988–1994 | PbB:; Median: 2.5; Range: 0.07–29.4; Participants with PbB >10: n=32 (5%); Tertiles; - T1: <1.0; - T2: 1–4.99; - T3: ≥5.00; Analysis: Reproductive hormones (luteinizing hormone and inhibin B) were analyzed using survey logistic regression and adjusted for age, race/ethnicity, BMI, census region, and poverty income ratio. | Decrease in the likelihood of exceeding the inhibin B (a marker of follicular development) pubertal cutoff value (35 ρg/mL) was observed for a 1 unit increase in PbB (log-transformed). Adjusted OR (95% CI):0.51 (0.34, 0.78).; Adjusted ORs (95% CI) for exceeding the inhibin B pubertal cutoff value by tertile:; - T1: reference; - T2: 0.38 (0.12, 1.15); - T3: 0.26 (0.11, 0.60); No association was observed between PbB and serum LH levels (data not shown).
Naicker et al. 2010; Cross-sectional and longitudinal study of 682 girls (aged 13 years) of black or mixed ancestry who were previously enrolled in the Birth to Twenty cohort and living in the study area for at least 6 months after birth, South Africa | PbB:; Mean (SD): 4.9 (1.9); Range: 1.0–16.3; Participants with PbB >10: n=5 (1%); Analysis: Puberty onset (breast development and attainment of menarche) was analyzed using logistic regression and adjusted for BMI. | Higher PbB was associated with delays in the onset of puberty.; Trend analysis for Tanner breast development associated and mean PbB (SD):; - Stage 1 (n=9): 7.3 (2.47); - Stage 2 n=82: 5.6 (1.74); - Stage 3 (n=283): 5.0 (1.83); - Stage 4 (n=262): 4.8 (1.92); - Stage 5 (n=46): 4.5 (1.69); - p-trend=<0.001; Trend analysis for pubic hair and mean PbB (SD):; - Stage 1 (n=16): 5.5 (1.67); - Stage 2 n=86: 5.4 (1.87); - Stage 3 (n=322): 5.0 (2.04); - Stage 4 (n=230): 4.7 (1.59); - Stage 5 (n=28): 4.6 (2.18); - p-trend=<0.001; Trend analysis for attainment of menarche associated and mean PbB (SD) for age:; - 9 (n=5): 3.8 (0.87); - 10 (n=15): 4.2 (1.31); - 11 (n=91): 4.9 (2.04); - 12 (n=186): 4.8 (2.01); - 13 (n=220): 4.8 (1.75); - 14 (n=115): 5.5 (1.66); - 15 (n=33): 5.6 (2.04); - 16 (n=9): 5.9 (2.73); - p-trend=<0.001
Selevan et al. 2003; Cross-sectional study of 2,186 girls (aged 8–18 years) who had previously participated in the NHANES III study, 1988–1994 | PbB:; Gmean (95% CI); - Non-Hispanic White (NHW): 1.4 (1.2, 1.5); - Non-Hispanic African-American (NHAA): 2.1 (1.9, 2.3); - Mexican-American (MA): 1.7 (1.6, 12.4); Analysis: Puberty onset (breast development, pubic hair development, and age of menarche) was analyzed using ordinal logistic regression and Cox proportional hazards and adjusted for age, age^2^, smoking, dietary Ca2+, dietary iron, dietary vitamin C, dietary total fat, anemia, urban residence, and family income. | Adjusted ORs (95% CI) for the likelihood of reaching a successive stage of pubertal development for girls for PbB (log-transformed) of 3 µg/dL compared to 1 µg/dL:; - Breast development; ○ NHW: 0.82 (0.47, 1.42); ○ NHAA: 0.64 (0.42, 0.97); p<0.05; ○ MA: 0.76 (0.63, 0.91); p<0.05; - Pubic hair development:; ○ NHW: 0.75 (0.37, 1.51); ○ NHAA: 0.62 (0.41, 0.96); p<0.05; ○ MA: 0.70 (0.54, 0.91); p<0.05; - Age of menarche 8–16-year-old girls (hazard ratio [95% CI]); ○ NHW: 0.74 (0.55, 1.002); ○ NHAA: 0.78 (0.63, 0.98); p<0.05 (age at menarche delayed 3.6 months); ○ MA: 0.90 (0.73, 1.11)
Wolff et al. 2008; Cross-sectional study of a multiethnic group of 192 girls (aged 9 years) residing in New York City, New York 1996–1997 | PbB:; Median: 2.4; Analysis: Puberty onset (breast development, pubic hair stage, attainment of menarche) was analyzed using Poisson multivariate regression with robust error variance. Adjustments for breast development included age, BMI, and race and adjustments for hair stage included height, private clinic, and race. | No association was observed between ln PbB and delay of sexual maturation as measured by Breast development stage and public hair development stage. Prevalence ratios (95% CI):; - Breast stage ≥2 versus stage 1: 1.01 (0.79,1.30); - Pubic hair stage ≥2 versus stage 1: 1.25 (0.83, 1.88)
Wu et al. 2003b; Cross-sectional study of 1,706 girls (aged 8–16 years) who had previously participated in the NHANES III study, 1988–1994 | PbB:; Mean (SD): 2.5 (2.2); Range: 0.7–21.7; Tertiles:; - T1: 0.7–2.0 (reference); - T2: 2.1–4.9; - T3: 5.0–21.7; Analysis: Puberty onset (breast development, pubic hair stage, attainment of menarche) was analyzed using logistic regression with weighted and adjusted for race/ethnicity, age, family size, residence, poverty income, ratio, and BMI. | PbB was associated with delayed pubic hair development and attainment of menarche and, but not with breast development. Adjusted ORs (95% CI):; - Breast development:; ○ T2: 1.51 (0.90, 2.53); ○ T3: 1.20 (0.51, 2.85); - Pubic hair development:; ○ T2: 0.48 (0.25, 0.92); ○ T3: 0.27 (0.08, 0.93); - Attainment of menarche:; ○ T2: 0.42 (0.18, 0.97); ○ T3: 0.19 (0.08, 0.43)
Onset of puberty in males
Den Hond et al. 2011; Cross-sectional study of 887 boys (aged 14–15 years) attending their 3^rd^ year of secondary education and living in the study area for at least 5 years, Flanders, Belgium 2003–2004 | PbB:; Median: 2.50; 10^th^–90^th^ percentile: 1.20–5.12; Analysis: Puberty onset (risk of gynecomastia, sexual maturation) was analyzed using logistic regression and adjusted for age, parental education, age, BMI, and smoking status. | A 2-fold increase in PbB was associated with increased risk of gynecomastia. Adjusted OR (95% CI): 1.84 (1.11–3.05); p=0.018; No association was observed between PbB and sexual maturation (data not reported).
Hauser et al. 2008; Cross-sectional study of 489 peripubertal boys (aged 8–9 years) residing in Chapaevsk, Russia 2003–2005 | PbB:; Median: 3; 5^th^ –95^th^ percentile: 2–5; Participants with PbB ≥5: n=137 (28%); Participants with PbB >10: 3%; Analysis: Puberty onset (odds of having entered genitalia stage G2) was analyzed using multivariate logistic regression and adjusted for gestational age, height, BMI, and age at exam. | Reduced OR of having entered genitalia stage G2 were reduced at PbB ≥5 compared to PbB <5. OR (95% CI): 0.57 (0.34, 0.95); p=0.03
Williams et al. 2010; Longitudinal cohort of 489 peripubertal boys (aged 8–9 years) who had two follow-up evaluations residing in Chapaevsk, Russia 2003–2008 | PbB:; Median: 3; Participants with PbB ≥5: 28%; Participants with PbB >10: 3%; Analysis: Puberty onset was analyzed using Cox proportional hazards and adjusted for birth weight, gestational age, energy intake, proportion of fat consumption, proportion of protein consumption, maternal alcohol consumption during pregnancy, height at study entry, BMI at study entry, household income, and parental education. | Onset of puberty occurred 6–8 months later for boys with PbB ≥5 µg/dL compared to boys with PbB <5 µg/dL.; A reduced risk of pubertal onset was observed in boys with PbB ≥5 µg/dL compared to those with PbB <5 µg/dL, based on testicular volume and genitalia stage. HRs (95% CI):; - Testicular volume <3 mL: 0.73 (0.55, 0.97); p=0.03; - Genitalia stage ≥2: 0.76 (0.59, 0.98); p=0.04; - Pubic hair stage ≥2: 0.69 (0.44, 1.07); p=0.10
Williams et al. 2019; Longitudinal cohort study of 481 boys (enrolled at ages 8–9 years) residing in Chapaevsk, Russia; enrollment period: 2003–2005; assessment period: through 2017 | PbB:; Median: 3; Range: 0.5–31; <5: n=347; ≥5: n=134 (28%); Analysis: PbB measurements were made at enrollment; PbB was stratified as <5 and ≥5 µg/dL. Puberty and sexual maturity were assessed at 12-month intervals and measured by genitalia and pubic hair development and testicular volume. To determine difference between the <5 and ≥5 µg/dL groups for ages of onset of puberty and sexual maturity, data were analyzed by interval-censored regression models. Adjustments for puberty onset were high caloric intake for genitalia, pubic hair, and testicular volume; low maternal education for genitalia; no biological father residing in household for genitalia, pubic hair, and testicular volume; and birth weight for genitalia and testicular volume. Adjustments for sexual maturity were high caloric intake for genitalia; mother <20 years old at birth for genitalia, no biological father residing in household for public hair and testicular weight; low income level for public hair; and low maternal education level for testicular volume. | Age at pubertal onset (shift in mean age in months) (95% CI) based on:; - Genitalia: 8.40 (3.70,13.10); p<0.001; - Pubic hair: 8.12 (3.46,12.78); p<0.001; - Testicular volume: 7.68 (3.46,11.90); p<0.001; Age at sexual maturity (shift in mean age in months) (95% CI) based on:; - Genitalia: 4.20 (0.56, 7.84); p=0.024; - Pubic hair: 4.23 (−0.31, 8.77); p=0.068; - Testicular volume: 5.14 (1.70, 8.58); p=0.003

ALSPAC = Avon Longitudinal Study of Parents and Children; bALP = bone alkaline phosphatase; BMI = body mass index; CANDLE = Conditions Affecting Neurocognitive Development and Learning in Early Childhood; CI = confidence interval; Gmean = geometric mean; HR = hazard ratio; LH = luteinizing hormone; MA = Mexican Americans; MANCOVA = multivariate analysis of covariance; MANOVA = multivariate analysis of variance; MBPb = maternal whole blood lead; NHW = non-Hispanic whites; NHAA = non-Hispanic African Americans; NHANES = National Health and Nutrition Examination Survey; NS = not statistically significant; OR = odds ratio; Pb = lead; PROGRESS = Programming Research in Obesity, Growth, Environment and Social Stressors; RBC = red blood cell; RR = relative risk; SD = standard deviation; SE = standard error; SES = socioeconomic status; SGA = small for gestational age; uDPD = urine deoxypyridinoline

Table 14 Epidemiological Studies Assessing Genotoxicity

Reference and study population | PbB (µg/dL) | Cell type | Test type | Result
PbB ≤10 µg/dL
Van Larebeke et al. 2004; Flemish women with no previous occupational exposure (n=99; age 50–65 years) in Antwerp and Antwerp peer | Mean; - Antwerp: 3.3; - Peer: 2.9 | Peripheral blood lymphocytes | Gene mutation (HPRT) | +; Higher PbB level (10^th^–90^th^ percentile: 1.6–5.2 μg/dL; p=0.033) was associated with greater HPRT mutation frequency than found in the total population.
Akram et al. 2019; 100 construction workers and 100 matched controls | Mean:; - Workers: 8; - Controls: 3.5; (estimates; data displayed graphically) | Peripheral blood lymphocytes | DNA damage | +
Al Bakheet et al. 2013; Heavy metal exposed male workers (n=40, age 20–42 years; n=20 age-matched controls) in Saudi Arabia | Mean (SE):; - Workers: 2.1 (0.251); - Controls: 1.1 (0.062) | Peripheral blood lymphocytes | DNA damage/repair | −
Hengstler et al. 2003; Occupational exposure (n=78 workers and n=22 controls); co-exposure to cadmium, cobalt, and lead | Mean: 4.41 | Mononuclear blood | DNA damage/repair | −
Jasso-Pineda et al. 2012; Children (4–11 years) in three Mexican communities (n=A: 48; B: 12; C: 25) co-exposed to arsenic and lead | Mean, community:; A: 11.4; B: 7.3; C: 5.3 | Peripheral blood mononuclear cells | DNA damage/repair | +; Compared to Community C, Communities A and B had increased (p<0.05) DNA damage.
Zota et al. 2015; Adults (n=6,796) participating in NHANES (1999–2002) | Mean (95% CI):1.67 (1.63, 1.70) | Leukocytes | Telomere length | −
Pawlas et al. 2015; Children (n=99); 8 years of age, from Poland | Gmean (range): 3.28 (0.90–14.2) | Whole blood | Telomere length | +; PbB was associated with decreased telomere length (β: −0.13, p=0.029)
Hanna et al. 2012; Women (n=43, mean age 36 years) undergoing IVF | Low: <0.73; High: >0.73 | Whole blood | DNA methylation | +; Reduced methylation was detected in the COL1A2 promoter in women with higher exposure to lead (p=0.004), and an inverse correlation was observed (r:-0.45, p=0.03).
Li et al. 2016b; Adults (n=105; 64 females, 41 males) with PbB obtained from birth to 78 months from the Cincinnati Lead Study | Mean: 1.36 | Peripheral blood lymphocytes | DNA methylation | +; Mean PbB from birth to 78 months was associated with decreased DNA methylation (p=0.002) at some differentially methylated regions, and increased DNA methylation (p=0.01) at other regions in adults.
Pilsner et al. 2009; Umbilical cord blood samples (n=103) (Mexico) | Mean (SD): 6.6 (2.7) | Umbilical cord leukocytes | DNA methylation | +; Prenatal Pb exposure was inversely associated with genomic DNA methylation in cord blood (p=0.01).
Wu et al. 2017; Mother-infant pairs (n=268) in Massachusetts | Mean (SD) maternal erythrocyte Pb, 2^nd^ trimester: 1.22 | Umbilical cord blood (all cell types) | DNA methylation | +; Prenatal Pb exposure was associated with decreased epigenome-wide DNA methylation in cord blood (−1:4% per doubling of PbB; p=2:3x10^−7^)
Mielzyńska et al. 2006; Children (n=74; age 5–14 years) in Silesia, Poland | Mean (SD): 7.69 (4.29); Range: 2.7–23.0 | Peripheral blood lymphocytes | SCE | −
Wu et al. 2002; Occupational exposure in 57 storage battery workers (high exposure n=23; low exposure n=34) and 30 controls in Taiwan | Mean (SD):; - High exposure: 32.5 (14.5); - Low exposure: 9.3 (2.9); - Control: 4.2 (1.4) | Peripheral blood lymphocytes | SCE | −; No increase in SCE for the low exposure group.
Mielzyńska et al. 2006; Children (n=74; age 5–14 years) in Silesia, Poland | Mean (SD): 7.69 (4.29); Range: 2.7–23.0 | Peripheral blood lymphocytes | MN | −; No increase in MN in children below the threshold value of 10 µg/dL.
PbB >10 µg/dL
Chinde et al. 2014; Occupational exposure (n=200 storage battery workers; n=200 controls) | Mean (SD); - Workers: 30.1 (4.13); - Controls: 6.71 (0.97) | Peripheral blood lymphocytes | DNA damage (Comet assay) | +; Increased (p<0.01) mean percent tail DNA compared to controls.
Danadevi et al 2003; Occupational exposure (n=45 Pb recovery unit workers; 36 controls) in India | Mean (SD); - Workers: 25 (14.7); - Controls: 2.7 (1.5) | Peripheral blood lymphocytes | DNA damage (Comet assay) | +; - Percentage of cells with DNA damage (44.58%) in exposed works was increased compared to controls (21.14%).; - A positive correlation was observed between PbB and DNA damage (p<0.01).
de Restrepo et al. 2000; Occupational exposure (n=43 electric battery factory workers; n=13 controls) in Bogotá, Colombia | Mean:; - Workers: 98.5; - Controls: 5.4 | Peripheral blood lymphocytes | DNA damage/repair (comet assay) | +; Increased DNA damage (p=0.05) in workers with PbB >120 µg/dL compared to workers with PbB >40 µg/dL.
Fracasso et al. 2002; Occupational exposure (n=37 battery plant workers; n=29 controls) | Workers:; - Mean (SE): 39.63 (7.56); - Control mean (SE): 4.4 (1.7) | Peripheral blood lymphocytes | DNA damage (comet assay) | +; Elevated levels of DNA breaks in workers compared to controls (p<0.00001).
Grover et al. 2010; Occupational exposure (n=90 male Pb recovery unit workers; n=90 controls) in India | Mean (SD); - Workers: 30.33 (2.085); - Controls: 3.21 (0.26) | Peripheral blood lymphocytes | DNA damage (comet assay) | +; Increased comet tail length in workers compared to controls (p<0.05).
Jannuzzi and Alpertunga 2016; Occupational exposure (n=25 male storage battery workers; n=25 controls) in Turkey | Mean (SE); - Workers: 28.58 (3.78); - Controls: 3.58 (0.08) | Peripheral blood lymphocytes | DNA damage/repair (comet assay) | +; - Increased percentage of DNA in tail than controls (p<0.05).; - In challenge assay, mean DNA% repair capacity was reduced (p<0.01).
Kasuba et al. 2012; Occupational exposure (n=30 pottery-glaze workers; n=30 controls; age 18–57 years) | Workers; - Mean (SE): 22.04 (1.775); Range: 4.168–40.477; Controls:; - Mean (SE): 3.04 (0.24); Range: 1.2–5.2 | Peripheral blood lymphocytes | DNA damage (Comet assay and DNA diffusion assay) | +; - Increased tail intensity in workers compared to controls (p<0.0001).; - Poisson regression analysis showed a correlation between PbB and increased primary DNA damage (p<0.0001).
Kayaalti et al. 2015a; Pb workers (n=61, mean age 38.27 years) in Turkey | Mean (SD); - Workers: 12.56 (12.17); - Controls: not reported | Peripheral blood lymphocytes | DNA damage (Comet assay) | +; Statistically significant positive correlation (p<0.01) between PbB and including tail intensity, tail moment, and DNA tail.
Méndez-Gómez et al. 2008; Cross-sectional study in children from schools in three locations in Mexico based on distance from a smelter: distant (n=21); intermediate (n=22); and near (n=22) | Mean; - Distant: 4.6; - Intermediate: 19.5; - Near: 28.6 | Peripheral blood lymphocytes | DNA damage/repair (Comet assay) | +; Tail length and cells with long tails were increased (p<0.05) in the nearest location group, compared to the intermediate and distant groups.
Shaik and Jamil 2009; Pb battery workers (n=113) and controls (n=102) in India | Range:; - Workers: 21.8–88.0; - Controls: 0.6–3.4 | Peripheral blood lymphocytes | DNA damage (Comet assay) | +; Workers had increased DNA damage, compared to controls, for mean comet tail length (p<0.05) and basal DNA damage (p<0.01).
Al-Hakkak et al. 1986; Occupational exposure (n=19 storage battery workers; n=9 controls) in Baghdad city | Workers; - Mean: 64; - Range: 38–96; Controls:; - Mean: 24; - Range: 6–30 | Peripheral blood lymphocytes | CAs | +; Higher frequencies of chromatid and chromosome aberrations were observed in workers compared to controls (p<0.05).
Anwar and Kamal 1988; Occupational exposure (n=28 traffic policemen with exposure to automobile exhaust for over 10 years; n=15 controls) in Cairo | Mean (SD):; - Workers: 30.1 (8.7); - Controls: 18.2 (1.2) | Peripheral blood lymphocytes | CAs | +; CAs were increased in workers compared to controls (p<0.05).
Bauchinger et al. 1977; Study of children (n=30) living in a town with a lead plant | Range: 12–33 | Peripheral blood lymphocytes | CAs | −
Chinde et al. 2014; Occupational exposure (n=200 storage battery workers; n=200 controls) | Mean (SD):; - Workers: 30.1 (4.13); - Controls: 6.71 (0.97) | Peripheral blood lymphocytes | CAs | +; CAs were increased (p<0.01) in workers compared to controls.
Forni et al. 1976; Occupational exposure (n=10 storage battery plant workers; n=11 controls) | Range:; - Workers: 45–64; - Controls: 34 | Peripheral blood lymphocytes | CAs | +; Rate of abnormal metaphase approximately doubled after 1 month of work (p<0.05).
Grover et al. 2010; Occupational exposure (n=90 male Pb recovery unit workers; n=90 controls) in India | Mean (SD); - Workers: 30.33 (2.085); - Controls: 3.21 (0.26) | Peripheral blood lymphocytes | CAs | +; Aberrant metaphase in workers was elevated compared to controls (p<0.05).
Huang et al. 1988; Occupational exposure (n=21 battery plant workers; n=7 controls | Mean (SD):; - Low Pb group: 33.7 (5.9); - Medium Pb group: 52.1 (7.3); - High Pb group: 86.9 (16.5); - Controls: 7.8 (2.3) | Peripheral blood lymphocytes | CAs | +; - Significant increase in CA percentage in medium and high exposure groups compared to controls (p<0.01).; - CA percentage increased with PbB (p<0.01).
Maki-Paakkanen et al. 1981; Occupational exposure (n=18 male Finnish smelter workers; n=12 controls) | Mean:; - Workers: 49; - Controls: <10 | Peripheral blood lymphocytes | CAs | −
Nordenson et al. 1978; Occupational exposure (n=6 for high exposure; n=16 for medium exposure; n=4 for low exposure) in Northern Sweden | Mean:; - High exposure: 64.7; - Medium exposure group: 39.2; - Low exposure group: 22.9; - Controls: not reported | Peripheral blood lymphocytes | CAs | +; - CA frequency was increased in Pb-exposed workers compared to controls (p<0.001).; - Frequency of aberrations correlated with PbB.
Pinto et al. 2000; Occupational exposure (n=25 male outdoor painters; n=25 controls) in Mexico | Mean (SE); - Workers: 10.48 (3.13); - Controls: 7.10 (2.79) | Peripheral blood lymphocytes | CAs | +; Elevated CAs in workers compared to controls (p<0.05).
Schwanitz et al. 1970; Occupational exposure (n=8 Pb oxide factory workers) | Range; - Workers: 60–90 | Peripheral blood lymphocytes | CAs | +; Increased proportion of mitoses with secondary CAs in workers compared to controls (p-value not reported).
Schwanitz et al 1975; Occupational exposure (n=105 workers) | Mean:; - Workers: 38 | Peripheral blood lymphocytes | CAs | −
Shaik and Jamil 2009; Pb battery workers (n=113) and controls (n=102) in India | Range:; - Workers: 21.8–88.0; - Controls: 0.6–3.4 | Peripheral blood lymphocytes | CAs | +; Increased number of aberrant cells, satellite associations, and CAs in workers compared to controls (Chi-square test; p<0.01).
Anwar and Kamal 1988; Occupational exposure (n=28 traffic policemen with exposure to automobile exhaust for over 10 years; n=15 controls) in Cairo | Mean (SD):; - Workers: 30.1 (8.7); - Controls: 18.2 (1.2) | Peripheral blood lymphocytes | SCEs | −; Increased SCEs on workers compared to controls (p<0.05); however, increase in SCEs was not correlated with PbB.
Dalpra et al. 1983; Children (n=19 exposed; n=12 controls, age 3–14 years) living in a contaminated area near a smelting plant | Mean: 29.3–62.7 | Peripheral blood lymphocytes | SCEs | −
Duydu et al. 2001; Occupational exposure (n=31 battery plant workers; n=20 controls) in Turkey | Mean (SD); - Workers: 36.31 (8.28); - Controls: 11.1 (2.13) | Peripheral blood lymphocytes | SCEs | +; SCEs were increased in workers compared to controls (p<0.05).
Duydu et al. 2005; Occupational exposure (n=50 storage battery plant workers; n=50 controls) in Turkey | Workers; - Mean (SE): 40.14 (9.99); - Range: 22.24–63.11; Controls:; - Mean: 9.77 (1.67); - 7.92–13.51 | Peripheral blood lymphocytes | SCEs | +; Increased SCE in exposed workers compared to controls (p<0.001).
Grandjean et al. 1983; Occupational exposure study (n=10 long-term Pb exposed men at a battery plant; n=18 newly employed workers; each subject served as his own control) | Range:; - Workers: 29–75 | Peripheral blood lymphocytes | SCEs | −
Huang et al. 1988; Occupational exposure: n=21 battery plant workers; n=7 controls | Mean (SD):; - Low exposure group: 33.7 (5.9); - Medium exposure group: 52.1 (7.3); - High exposure group: 86.9 (16.5); - Controls: 7.8 (2.3) | Peripheral blood lymphocytes | SCEs | +; - SCEs were increased in the high-exposure group compared to controls (p<0.001).; - No correlation between PbB and SCEs was observed.
Maki-Paakkanen et al. 1981; Occupational exposure (n=18 male Finnish smelter workers; n=12 controls) | Mean:; - Workers: 49; - Controls: <10 | Peripheral blood lymphocytes | SCEs | −
Pinto et al. 2000; Occupational exposure (n=25 male outdoor painters; n=25 controls) in Mexico | Mean (SE); - Workers: 10.48 (3.13); - Controls: 7.10 (2.79) | Peripheral blood lymphocytes | SCEs | +; Elevated SCEs in workers compared to controls (p<0.05).
Wiwanitkit et al. 2008; Occupational exposure (n=32 volunteer male Thai police officers, 24 in high-exposure group, and 6 in low-exposure group); no controls were included | Mean:; - Total for all subjects: 43.5; - High exposure group: 68.3; - Low exposure group: 31.1 | Peripheral blood lymphocytes | SCEs | +; The average SCE was increased (p<0.05) in the high-exposure group compared to those with low-metal exposure.
Wu et al. 2002; Occupational exposure (n=57 storage battery workers; n=30 controls) in Taiwan | Mean (SD):; - High exposure group (n=23): 32.5 (14.5); - Low exposure (n=34): 9.3 (2.9); - Controls: 4.2 (1.4) | Peripheral blood lymphocytes | SCEs | +; Significant increase in SCEs in high Pb group (p<0.01).
Chinde et al. 2014; Occupational exposure (n=200 storage battery workers; n=200 controls) | Mean (SD):; - Workers: 30.1 (4.13); - Controls: 6.71 (0.97) | Peripheral blood lymphocytes | MN | +; MN increased in workers compared to controls (p<0.01).
Grover et al. 2010; Occupational exposure (n=90 male Pb recovery unit workers; n=90 controls) in India | Mean (SD); - Workers: 30.33 (2.085); - Controls: 3.21 (0.26) | Peripheral blood lymphocytes and buccal mucosa cells | MN | +; Significant increase in frequency of MN in workers compared to controls (p<0.05).
Hamurcu et al. 2001; Occupational exposure (n=31 male workers at a metal powder-producing plants; n=20 controls) | Mean (SD); - Workers: 40 (18); - Controls: 12 (4) | Peripheral blood lymphocytes | MN | +; Exposed workers had higher MN mean values than controls (p<0.01).
Khan et al. 2010b; Occupational exposure (n=30 male painters; n=30 controls) in India | Mean (SD); - Workers: 21.56 (6.43); - Controls: 2.84 (0.96) | Buccal epithelial cells | MN | +; - Elevation in MN frequencies and nuclear changes (karyorrhexis, karyolysis, broken egg, and binucleate) in buccal epithelial cells in workers compared to controls (p<0.01).; - Association of PbB observed between MN frequency and PbB.
Kasuba et al. 2012; Occupational exposure (n=30 pottery-glaze workers; n=30 controls; age 18–57 years) | Workers; - Mean (SE): 22.04 (1.775); - Range: 4.168–40.477; Controls:; - Mean: 3.04 (0.24); - Range: 1.2–5.2 | Peripheral blood lymphocytes | MN | +; Frequency of MN was increased in workers compared to controls (p<0.03).
Mielzyńska et al 2006; Genotoxic effects in children (n=74, age 5–14 years), living in two cities in Upper Silesia Poland | Mean: 7.69; Range 2.7–23.0 | Peripheral blood lymphocytes | MN | +; MN was increased in children with PbB >10 µg/dl compared to children with PbB <10 µg/dL.
Minozzo et al. 2004; Occupational exposure (n=26 male workers of a recycling automotive battery industry; n=29 controls) in Brazil | Mean; - Workers: 35.40; - Controls: 1.95 | Peripheral blood lymphocytes | MN | +; MN frequency was higher in workers compared to controls (p<0.0001).
Pinto et al. 2000; Occupational exposure (n=25 male outdoor painters; n=25 controls) in Mexico | Mean (SE); - Workers: 10.48 (3.13); - Controls: 7.10 (2.79) | Peripheral blood lymphocytes | MN | +; Elevated MN was observed in workers compared to controls (p<0.05).
Shaik and Jamil 2009; Occupational exposure (n=113 battery workers; n=102 controls) in India | Range; - Workers: 21.8–88.0; - Controls: 0.6–3.4 | Buccal epithelial cells | MN | +; MN formation was increased in workers compared to controls (p<0.01).
Singh et al. 2013; Occupational exposure (n=30 battery workers; n=30 controls) | Workers; - Mean (SD): 57.17 (18.4); - Range: 22.45–95.45; Controls; - Means: 5.43 (1.94); - Range: 2.45–8.77 | Buccal mucosal cells | MN | +; - Increased MN frequency was observed in workers compared to controls (p<0.001).; - A positive association was observed between PbB and MN frequency (p<0.001).
Vaglenov et al. 1998; Occupational exposure (n=22 exposed workers; n=19 unexposed workers from the same plant; n=19 external unexposed workers) | Mean (SE):; - Workers: 60.9 (3.1); - External controls: 18.2 (0.62); - Internal controls: 27.5 (1.66) | Peripheral blood lymphocytes | MN | +; An increased incidence of MN was observed in workers compared to controls (p<0.001).
Vaglenov et al. 2001; Occupational exposure (n=103 exposed workers; n=78 controls) (follow-up study to Vaglenov et al. 1998) | Mean (SE):; - Workers: 55.9 (2.1); - Controls: 18.8 (0.83) | Peripheral blood lymphocytes | MN | +; PbB >25 μg/dL was associated with increased MN frequency (p<0.001).

− = negative test result; + = positive test result; ± = equivocal result; CA = chromosomal aberration; CI = confidence interval; DNA = deoxyribonucleic acid; Gmean = geometric mean; IVF = in vitro fertilization; MN = micronuclei; NHANES = National Health and Nutrition Examination Survey; Pb = lead; PbB = blood lead concentration; SCE = sister chromatid exchange; SD = standard deviation; SE = standard error

## REFERENCES

Abdelouahab N, Mergler D, Takser L, . 2008. Gender differences in the effects of organochlorines, mercury, and lead on thyroid hormone levels in lakeside communities of Quebec (Canada). Environ Res 107(3):380–392. 10.1016/j.envres.2008.01.006.18313043
Afeiche M, Peterson KE, Sánchez BN, . 2011. Prenatal lead exposure and weight of 0- to 5 year-old children in Mexico City. Environ Health Perspect 119(10):1436–1441. 10.1289/ehp.1003184.21715242
Ahamed M, Verma S, Kumar A, . 2005. Environmental exposure to lead and its correlation with biochemical indices in children. Sci Total Environ 346(1–3):48–55. 10.1016/j.scitotenv.2004.12.019.15993681
Ahamed M, Verma S, Kumar A, . 2006. Delta-aminolevulinic acid dehydratase inhibition and oxidative stress in relation to blood lead among urban adolescents. Hum Exp Toxicol 25(9):547–553. 10.1191/0960327106het657oa.17017008
Ahn J, Kim NS, Lee BK, . 2018. Association of blood pressure with blood lead and cadmium levels in Korean adolescents: Analysis of data from the 2010-2016 Korean National Health and Nutrition Examination Survey. J Korean Med Sci 33(44):e278. 10.3346/jkms.2018.33.e278.30369859
Åkesson A, Lundh T, Vahter M, . 2005. Tubular and glomerular kidney effects in Swedish women with low environmental cadmium exposure. Environ Health Perspect 113(11):1627–1631. 10.1289/ehp.8033.16263522
Akram Z, Riaz S, Kayani MA, . 2019. Lead induces DNA damage and alteration of ALAD and antioxidant genes mRNA expression in construction site workers. Arch Environ Occup Health 74(4):171–178. 10.1080/19338244.2018.1428523.29336731
Al Bakheet SA, Attafi IM, Maayah ZH, . 2013. Effect of long-term human exposure to environmental heavy metals on the expression of detoxification and DNA repair genes. Environ Pollut 181:226–232.23872045
Al-Hakkak ZS, Hamamy HA, Murad AM, . 1986. Chromosome aberrations in workers at a storage battery plant in Iraq. Mutat Res Genet Toxicol 171(1):53–60.
Almeida Lopes ACB, Silbergeld EK, Navas-Acien A, . 2017. Association between blood lead and blood pressure: A population-based study in Brazilian adults. Environ Health 16(1):27. 10.1186/s12940-017-0233-5.28292314
Al-Saleh I, Shinwari N, Mashhour A, . 2005. Is lead considered as a risk factor for high blood pressure during menopause period among Saudi women? Int J Hyg Environ Health 208(5):341–356.16217919
Al-Saleh I, Shinwari N, Mashhour A, . 2014. Birth outcome measures and maternal exposure to heavy metals (lead, cadmium and mercury) in Saudi Arabian population. Int J Hyg Environ Health 217(2–3):205–218. 10.1016/j.ijheh.2013.04.009.23735463
Alvarez-Ortega N, Caballero-Gallardo K, Olivero-Verbel J. 2019. Toxicological effects in children exposed to lead: A cross-sectional study at the Colombian Caribbean coast. Environ Int 130:104809. 10.1016/j.envint.2019.05.003.31302530
An HC, Sung JH, Lee J, . 2017. The association between cadmium and lead exposure and blood pressure among workers of a smelting industry: A cross-sectional study. Ann Occup Environ Med 29:47. 10.1186/s40557-017-0202-z.29034097
Anwar WA, Kamal AA. 1988. Cytogenetic effects in a group of traffic policemen in Cairo. Mutat Res 208(3–4):225–231.2456461
Aoki Y, Brody DJ, Flegal KM, . 2016. Blood lead and other metal biomarkers as risk factors for cardiovascular disease mortality. Medicine 95(1):e2223. 10.1097/md.0000000000002223.26735529
Arbuckle TE, Davis K, Boylan K, . 2016. Processed data for CHMS 2007-2009: Bisphenol A, phthalates and lead and learning and behavioral problems in Canadian children 6-19 years of age. Data Brief 8:784–802. 10.1016/j.dib.2016.06.017.27500191
Ari E, Kaya Y, Demir H, . 2011. The correlation of serum trace elements and heavy metals with carotid artery atherosclerosis in maintenance hemodialysis patients. Biol Trace Elem Res 144(1–3):351–359. 10.1007/s12011-011-9103-0.21647752
Arora M, Weuve J, Weisskopf MG, . 2009. Cumulative lead exposure and tooth loss in men: The normative aging study. Environ Health Perspect 117(10):1531–1534.20019902
Baghurst PA, McMichael AJ, Wigg NR, . 1992. Environmental exposure to lead and children’s intelligence at the age of seven years. N Engl J Med 327(18):1279–1284.1383818
Barry V, Todd AC, Steenland K. 2019. Bone lead associations with blood lead, kidney function and blood pressure among US, lead-exposed workers in a surveillance programme. Occup Environ Med 76(5):349–354. 10.1136/oemed-2018-105505.30661026
Bauchinger M, Dresp J, Schmid E, . 1977. Chromosome analyses of children after ecological lead exposure. Mutat Res 56:75–80.593297
Bellinger D, Needleman HL. 2003. Intellectual impairment and blood lead levels. N Engl J Med 349(5):500. 10.1056/NEJM200307313490515.
Bellinger DC, Stiles KM, Needleman HL. 1992. Low-level lead exposure, intelligence and academic achievement: A long-term follow-up study. Pediatrics 90(6):855–861.1437425
Blackowicz MJ, Hryhorczuk DO, Rankin KM, . 2016. The impact of low-level lead toxicity on school performance among Hispanic subgroups in the Chicago public schools. Int J Environ Res Public Health 13(8):774. 10.3390/ijerph13080774.27490560
Bloom MS, Parsons PJ, Steuerwald AJ, . 2010. Toxic trace metals and human oocytes during in vitro fertilization (IVF). Reprod Toxicol 29(3):298–305.10.1016/j.reprotox.2010.01.003.20096775
Bloom MS, Louis GMB, Sundaram R, . 2011. Associations between blood metals and fecundity among women residing in New York State. Reprod Toxicol 31(2):158–163. 10.1016/j.reprotox.2010.09.013.20933593
Bloom MS, Buck Louis GM, Sundaram R, . 2015. Birth outcomes and background exposures to select elements, the Longitudinal Investigation of Fertility and the Environment (LIFE). Environ Res 138:118–129. 10.1016/j.envres.2015.01.008.25707016
Bornschein RL, Grote J, Mitchell T, . 1989. Effects of prenatal lead exposure on infant size at birth. In: Smith MA, Grant LD, Sors AI, eds. Lead Exposure and Child Development. Dordrecht: Springer, 307–319. 10.1007/978-94-009-0847-5_18.
Boscolo P, Di Gioacchino M, Sabbioni E, . 2000. Lymphocyte subpopulations, cytokines and trace elements in asymptomatic atopic women exposed to an urban environment. Life Sci 67(10):1119–1126. 10.1016/S0024-3205(00)00712-8.10954046
Bost L, Primatesta P, Dong W, . 1999. Blood lead and blood pressure: Evidence from the health survey for England 1995. J Hum Hypertens 13(2; 2):123–128.10100061
Bouchard MF, Bellinger DC, Weuve J, . 2009. Blood lead levels and major depressive disorder, panic disorder, and generalized anxiety disorder in US young adults. Arch Gen Psychiatry 66(12):1313–1319. 10.1001/archgenpsychiatry.2009.164.19996036
Boucher O, Jacobson SW, Plusquellec P, . 2012. Prenatal methylmercury, postnatal lead exposure, and evidence of attention deficit/hyperactivity disorder among Inuit children in Arctic Quebec. Environ Health Perspect 120(10):1456–1461. 10.1289/ehp.1204976.23008274
Boucher O, Muckle G, Jacobson JL, . 2014. Domain-specific effects of prenatal exposure to PCBs, mercury, and lead on infant cognition: Results from the Environmental Contaminants and Child Development Study in Nunavik. Environ Health Perspect 122(3):310–316. 10.1289/ehp.1206323.24441767
Braun JM, Kahn RS, Froehlich T, . 2006. Exposures to environmental toxicants and attention deficit hyperactivity disorder in U.S. children. Environ Health Perspect 114(12):1904–1909. 10.1289/ehp.9478.17185283
Braun JM, Froehlich TE, Daniels JL, . 2008. Association of environmental toxicants and conduct disorder in U.S. children: NHANES 2001-2004. Environ Health Perspect 116(7):956–962. 10.1289/ehp.11177.18629321
Braun JM, Hoffman E, Schwartz J, . 2012. Assessing windows of susceptibility to lead-induced cognitive deficits in Mexican children. Neurotoxicology 33(5):1040–1047. 10.1016/j.neuro.2012.04.022.22579785
Braun JM, Wright RJ, Just AC, . 2014. Relationships between lead biomarkers and diurnal salivary cortisol indices in pregnant women from Mexico City: A cross-sectional study. Environ Health 13(1):50. 10.1186/1476-069x-13-50.24916609
Brender JD, Suarez L, Felkner M, . 2006. Maternal exposure to arsenic, cadmium, lead, and mercury and neural tube defects in offspring. Environ Res 101(1):132–139. 10.1016/j.envres.2005.08.003.16171797
Brubaker CJ, Dietrich KN, Lanphear BP, . 2010. The influence of age of lead exposure on adult gray matter volume. Neurotoxicology 31(3):259–266. 10.1016/j.neuro.2010.03.004.20226811
Budtz-Jorgensen E, Bellinger D, Lanphear B, . 2013. An international pooled analysis for obtaining a benchmark dose for environmental lead exposure in children. Risk Anal 33(3):450–461. 10.1111/j.1539-6924.2012.01882.x.22924487
Burns JS, Williams PL, Lee ML, . 2017. Peripubertal blood lead levels and growth among Russian boys. Environ Int 106:53–59. 10.1016/j.envint.2017.05.023.28599171
Buser MC, Scinicariello F. 2017. Cadmium, lead, and depressive symptoms: Analysis of National Health and Nutrition Examination Survey 2011-2012. J Clin Psychiatry 78(5):e515–e521. 10.4088/JCP.15m10383.27929609
Bushnik T, Levallois P, D’Amour M, . 2014. Association between blood lead and blood pressure: Results from the Canadian Health Measures Survey (2007 to 2011). Health Rep 25(7):12–22.
Canfield RL, Henderson CR, Cory-Slechta DA, . 2003. Intellectual impairment in children with blood lead concentrations below 10 micrograms per deciliter. N Engl J Med 348(16):1517–1526. 10.1056/NEJMoa022848.12700371
Casjens S, Pesch B, van Thriel C, . 2018. Associations between blood lead, olfaction and fine-motor skills in elderly men: Results from the Heinz Nixdorf Recall Study. Neurotoxicology 68:66–72. 10.1016/j.neuro.2018.06.013.30009858
Cassidy-Bushrow AE, Havstad S, Basu N, . 2016. Detectable blood lead level and body size in early childhood. Biol Trace Elem Res 171(1):41–47. 10.1007/s12011-015-0500-7.26358768
Cecil KM, Brubaker CJ, Adler CM, . 2008. Decreased brain volume in adults with childhood lead exposure. PLoS Med 5(5):e112. 10.1371/journal.pmed.0050112.18507499
Cecil KM, Dietrich KN, Altaye M, . 2011. Proton magnetic resonance spectroscopy in adults with childhood lead exposure. Environ Health Perspect 119(3):403–408. 10.1289/ehp.1002176.20947467
Chandramouli K, Steer CD, Ellis M, . 2009. Effects of early childhood lead exposure on academic performance and behaviour of school age children. Arch Dis Child 94(11):844–848. 10.1136/adc.2008.149955.19770197
Chang SH, Cheng BH, Lee SL, . 2006. Low blood lead concentration in association with infertility in women. Environ Res 101(3):380–386. 10.1016/j.envres.2005.10.004.16360143
Chao K, Hutton H, Levin A. 2015. Laboratory assessment of kidney disease. Glomerular filtration rate, urinalysis and proteinuria. In: Shorecki K, Chertow GM, Mardsen PA, ., eds. Brenner and Rector’s the kidney. Elsevier, 780–803.
Chen CC, Yen HW, Lo YH, . 2013. The association of prolonged QT interval on electrocardiography and chronic lead exposure. J Occup Environ Med 55(6):614–619.10.1097/JOM.0b013e318291787a.23722940
Chen C, Wang N, Zhai H, . 2016. Associations of blood lead levels with reproductive hormone levels in men and postmenopausal women: Results from the SPECT-China Study. Sci Rep 6:37809. 10.1038/srep37809.27898110
Chen C, Li Q, Nie X, . 2017. Association of lead exposure with cardiovascular risk factors and diseases in Chinese adults. Environ Sci Pollut Res Int 24(28):22275–22283. 10.1007/s11356-017-9884-6.28799038
Chen Y, Xu X, Zeng Z, . 2019. Blood lead and cadmium levels associated with hematological and hepatic functions in patients from an e-waste-polluted area. Chemosphere 220:531–538. 10.1016/j.chemosphere.2018.12.129.30594806
Cheng Y, Schwartz J, Vokonas PS, . 1998. Electrocardiographic conduction disturbances in association with low-level lead exposure (the Normative Aging Study). Am J Cardiol 82:594–599.9732886
Cheng Y, Schwartz J, Sparrow D, . 2001. Bone lead and blood lead levels in relation to baseline blood pressure and the prospective development of hypertension: The Normative Aging Study. Am J Epidemiol 153(2):164–171. 10.1093/aje/153.2.164.11159162
Chinde S, Kumari M, Devi KR, . 2014. Assessment of genotoxic effects of lead in occupationally exposed workers. Environ Sci Pollut Res Int 21(19):11469–11480. 10.1007/s11356-014-3128-9.24906834
Chiodo LM, Jacobson SW, Jacobson JL. 2004. Neurodevelopmental effects of postnatal lead exposure at very low levels. Neurotoxicol Teratol 26(3):359–371. 10.1016/j.ntt.2004.01.010.15113598
Choi WJ, Kwon HJ, Lim MH, . 2016. Blood lead, parental marital status and the risk of attention-deficit/hyperactivity disorder in elementary school children: A longitudinal study. Psychiatry Res 236:42–46. 10.1016/j.psychres.2016.01.002.26774190
Chu NF, Liou SH, Wu TN, . 1999. Reappraisal of the relation between blood lead concentration and blood pressure among the general population in Taiwan. Occup Environ Med 56:30–33.10341743
Chung HK, Chang YS, Ahn CW. 2015. Effects of blood lead levels on airflow limitations in Korean adults: Findings from the 5th KNHNES 2011. Environ Res 136:274–279. 10.1016/j.envres.2014.10.027.25460646
Cockcroft DW, Gault MH. 1976. Prediction of creatinine clearance from serum creatinine. Nephron 16:31–41.1244564
Conterato GM, Bulcao RP, Sobieski R, . 2013. Blood thioredoxin reductase activity, oxidative stress and hematological parameters in painters and battery workers: Relationship with lead and cadmium levels in blood. J Appl Toxicol 33(2):142–150. 10.1002/jat.1731.21910133
Dallaire R, Dewailly E, Ayotte P, . 2014. Growth in Inuit children exposed to polychlorinated biphenyls and lead during fetal development and childhood. Environ Res 134:17–23. 10.1016/j.envres.2014.06.023.25042032
Dalpra L, Tibiletti MG, Nocera G, . 1983. SCE analysis in children exposed to lead emission from a smelting plant. Mutat Res 120:249–256.6855793
Danadevi K, Rozati R, Banu BS, . 2003. DNA damage in workers exposed to lead using comet assay. Toxicology 187(2):183–193.12699907
de Burbure C, Buchet JP, Leroyer A, . 2006. Renal and neurologic effects of cadmium, lead, mercury, and arsenic in children: Evidence of early effects and multiple interactions at environmental exposure levels. Environ Health Perspect 114(4):584–590. 10.1289/ehp.8202.16581550
de Restrepo HG, Sicard D, Torres MM. 2000. DNA damage and repair in cells of lead exposed people. Am J Ind Med 38(3):330–334.10940972
Deierlein AL, Teitelbaum SL, Windham GC, . 2019. Lead exposure during childhood and subsequent anthropometry through adolescence in girls. Environ Int 122:310–315. 10.1016/j.envint.2018.11.031.30503317
Den Hond E, Nawrot T, Staessen JA. 2002. The relationship between blood pressure and blood lead in NHANES III. J Hum Hypertens 16:563–568.12149662
Den Hond E, Dhooge W, Bruckers L, . 2011. Internal exposure to pollutants and sexual maturation in Flemish adolescents. J Expo Sci Environ Epidemiol 21(3):224–233. 10.1038/jes.2010.2.20197795
Denham M, Schell LM, Deane G, . 2005. Relationship of lead, mercury, mirex, dichlorodiphenyldichloroethylene, hexachlorobenzene, and polychlorinated biphenyls to timing of menarche among Akwesasne Mohawk girls. Pediatrics 115(2):e127–e134. 10.1542/peds.2004-1161.15653789
Desrochers-Couture M, Oulhote Y, Arbuckle TE, . 2018. Prenatal, concurrent, and sex-specific associations between blood lead concentrations and IQ in preschool Canadian children. Environ Int 121(Pt 2):1235–1242. 10.1016/j.envint.2018.10.043.30392942
Desrochers-Couture M, Courtemanche Y, Forget-Dubois N, . 2019. Association between early lead exposure and externalizing behaviors in adolescence: A developmental cascade. Environ Res 178:108679. 10.1016/j.envres.2019.108679.31454729
Dietrich KN, Berger OG, Succop PA. 1993b. Lead exposure and the motor developmental status of urban six-year-old children in the Cincinnati prospective study. Pediatrics 91(2):301–307.7678702
Dietrich KN, Krafft KM, Bier M, . 1986. Early effects of fetal lead exposure: Neurobehavioral findings at 6 months. Int J Biosoc Res 8(2):151–168.
Dietrich KN, Krafft KM, Shukla R, . 1987. The neurobehavioral effects of early lead exposure. In: Schroeder SR, ed. Toxic substances and mental retardation: Neurobehavioral toxicology and teratology. Washington, DC: American Association on Mental Deficiency, 71–95.
Dietrich KN, Krafft KM, Bier M, . 1989. Neurobehavioral effects of foetal lead exposure: The first year of life. In: Lead exposure and child development. Dordrecht: Springer, 320–331. 10.1007/978-94-009-0847-5_19.
Dietrich KN, Succop PA, Berger OG, . 1991. Lead exposure and the cognitive development of urban preschool children: The Cincinnati Lead Study cohort at age 4 years. Neurotoxicol Teratol 13(2):203–211.1710765
Dietrich KN, Succop PA, Berger OG, . 1992. Lead exposure and the central auditory processing abilities and cognitive development of urban children: The Cincinnati Lead Study cohort at age 5 years. Neurotoxicol Teratol 14(1):51–56.1593979
Dietrich KN, Berger OG, Succop PA, . 1993a. The developmental consequences of low to moderate prenatal and postnatal lead exposure: Intellectual attainment in the Cincinnati Lead Study Cohort following school entry. Neurotoxicol Teratol 15(1):37–44.8459787
Dietrich KN, Douglas RM, Succop PA, . 2001. Early exposure to lead and juvenile delinquency. Neurotoxicol Teratol 23(6):511–518.11792521
Disha, Sharma S, Goyal M, . 2019. Association of raised blood lead levels in pregnant women with preeclampsia: A study at tertiary centre. Taiwan J Obstet Gynecol 58(1):60–63. 10.1016/j.tjog.2018.11.011.30638482
Dundar B, Öktem F, Arslan MK, . 2006. The effect of long-term low-dose lead exposure on thyroid function in adolescents. Environ Res 101(1):140–145. 10.1016/j.envres.2005.10.002.16360141
Duydu Y, Dur A, Süzen HS. 2005. Evaluation of increased proportion of cells with unusually high sister chromatid exchange counts as a cytogenetic biomarker for lead exposure. Biol Trace Elem Res 104(2):121–129. 10.1385/BTER:104:2:121.15894812
Duydu Y, Süzen H, Aydin A, . 2001. Correlation between lead exposure indicators and sister chromatid exchange (SCE) frequencies in lymphocytes from inorganic lead exposed workers. Arch Environ Contam Toxicol 41(2):241–246.11462150
Dye BA, Hirsch R, Brody DJ. 2002. The relationship between blood lead levels and periodontal bone loss in the United States, 1988-1994. Environ Health Perspect 110(10):997–1002.12361924
Elmarsafawy SF, Jain NB, Schwartz J, . 2006. Dietary calcium as a potential modifier of the relationship of lead burden to blood pressure. Epidemiology 17(5):531–537.16878040
Emory E, Ansari Z, Pattillo R, . 2003. Maternal blood lead effects on infant intelligence at age 7 months. Am J Obstet Gynecol 188(4):S26–S32.12712133
EPA. 2014e. Identification and consideration of errors in Lanphear et al. (2005), “Low-level environmental lead exposure and children’s intellectual function: An international pooled analysis”. Memorandum to Integrated Science Assessment for lead docket (EPA-HQ-ORD-2011-0051). Research Triangle Park, NC: U.S. Environmental Protection Agency. https://ofmpub.epa.gov/eims/eimscomm.getfile?p_download_id=518543. February 5, 2019.
Ergurhan-Ilhan I, Cadir B, Koyuncu-Arslan M, . 2008. Level of oxidative stress and damage in erythrocytes in apprentices indirectly exposed to lead. Pediatr Int 50(1):45–50. 10.1111/j.1442-200X.2007.02442.x.18279204
Ernhart CB, Morrow-Tlucak M, Wolf AW, . 1989. Low level lead exposure in the prenatal and early preschool periods: Intelligence prior to school entry. Neurotoxicol Teratol 11(2):161–170.2733654
Ethier AA, Muckle G, Bastien C, . 2012. Effects of environmental contaminant exposure on visual brain development: A prospective electrophysiological study in school-aged children. Neurotoxicology 33(5):1075–1085. 10.1016/j.neuro.2012.05.010.22683800
Eum KD, Nie LH, Schwartz J, . 2011. Prospective cohort study of lead exposure and electrocardiographic conduction disturbances in the Department of Veterans Affairs Normative Aging Study. Environ Health Perspect 119(7):490–494. 10.1289/ehp.1003279.
Evens A, Hryhorczuk D, Lanphear BP, . 2015. The impact of low-level lead toxicity on school performance among children in the Chicago public schools: A population-based retrospective cohort study. Environ Health 14:21. 10.1186/s12940-015-0008-9.25889033
Fadrowski JJ, Navas-Acien A, Tellez-Plaza M, . 2010. Blood lead level and kidney function in US adolescents: The Third National Health and Nutrition Examination Survey. Arch Intern Med 170(1):75–82. 10.1001/archinternmed.2009.417.20065202
Famurewa AC, Ugwuja EI. 2017. Association of blood and seminal plasma cadmium and lead levels with semen quality in non-occupationally exposed infertile men in Abakaliki, South East Nigeria. J Family Reprod Health 11(2):97–103.29282417
Fan Y, Sheng J, Liang C, . 2020. Association of blood lead levels with the risk of depressive symptoms in the elderly Chinese population: Baseline data of a cohort study. Biol Trace Elem Res 194(1):76–83. 10.1007/s12011-019-01755-x.31147977
Fang F, Kwee LC, Allen KD, . 2010. Association between blood lead and the risk of amyotrophic lateral sclerosis. Am J Epidemiol 171(10):1126–1133. 10.1093/aje/kwq063.20406759
Faramawi MF, Delongchamp R, Lin YS, . 2015. Environmental lead exposure is associated with visit-to-visit systolic blood pressure variability in the US adults. Int Arch Occup Environ Health 88(3):381–388. 10.1007/s00420-014-0970-5.25086568
Fleisch AF, Burns JS, Williams PL, . 2013. Blood lead levels and serum insulin-like growth factor 1 concentrations in peripubertal boys. Environ Health Perspect 121(7):854–858. 10.1289/ehp.1206105.23632160
Forni A, Cambiaghi G, Secchi GC. 1976. Initial occupational exposure to lead. Chromosome and biochemical findings. Arch Environ Health 31:73–78.1259473
Fracasso ME, Perbellini L, Soldà S, . 2002. Lead induced DNA strand breaks in lymphocytes of exposed workers: Role of reactive oxygen species and protein kinase C. Mutat Res Genet Toxicol Environ Mutagen 515(1):159–169.
Fraser S, Muckle G, Despres C. 2006. The relationship between lead exposure, motor function and behaviour in Inuit preschool children. Neurotoxicol Teratol 28(1):18–27. 10.1016/j.ntt.2005.10.008.16337107
Froehlich TE, Lanphear BP, Auinger P, . 2009. Association of tobacco and lead exposures with attention-deficit/hyperactivity disorder. Pediatrics 124(6):E1054–E1063.10.1542/peds.2009-0738.19933729
Fruh V, Rifas-Shiman SL, Amarasiriwardena C, . 2019. Prenatal lead exposure and childhood executive function and behavioral difficulties in project viva. Neurotoxicology 75:105–115. 10.1016/j.neuro.2019.09.006.31513824
Gambelunghe A, Sallsten G, Borne Y, . 2016. Low-level exposure to lead, blood pressure, and hypertension in a population-based cohort. Environ Res 149:157–163. 10.1016/j.envres.2016.05.015.27208466
Garcia-Esquinas E, Aragones N, Fernandez MA, . 2014. Newborns and low to moderate prenatal environmental lead exposure: Might fathers be the key? Environ Sci Pollut Res Int 21(13):7886–7898. 10.1007/s11356-014-2738-6.24647583
Geier DA, Kern JK, Geier MR. 2017. Blood lead levels and learning disabilities: A cross-sectional study of the 2003-2004 National Health and Nutrition Examination Survey (NHANES). Int J Environ Res Public Health 14(10):1202. 10.3390/ijerph14101202.28994742
Geier DA, Kern JK, Geier MR. 2018. A cross-sectional study of the relationship between blood lead levels and reported attention deficit disorder: An assessment of the economic impact on the United States. Metab Brain Dis 33(1):201–208. 10.1007/s11011-017-0146-6.29134344
Gemmel A, Tavares M, Alperin S, . 2002. Blood lead level and dental caries in school-age children. Environ Health Perspect 110(10):A625–A630.12361944
Gerr F, Letz R, Stokes L, . 2002. Association between bone lead concentration and blood pressure among young adults. Am J Ind Med 42:98–106.12125085
Glenn BS, Stewart WF, Links JM, . 2003. The longitudinal association of lead with blood pressure. Epidemiology 14(1):30–36.12500043
Gollenberg AL, Hediger ML, Lee PA, . 2010. Association between lead and cadmium and reproductive hormones in peripubertal U.S. girls. Environ Health Perspect 118(12):1782–1787. 10.1289/ehp.1001943.20675266
Golub NI, Winters PC, van Wijngaarden E. 2010. A population-based study of blood lead levels in relation to depression in the United States. Int Arch Occup Environ Health 83(7):771–777.19967393
Gomaa A, Howard H, Bellinger D, . 2002. Maternal bone lead as an independent risk factor for fetal neurotoxicity: A prospective study. Pediatrics 110(1):110–118.12093955
González-Cossío T, Peterson KE, Sanin L, . 1997. Decrease in birth weight in relation to maternal bone-lead burden. Pediatrics 100(5):856–862.9346987
Grandjean P, Wulf HC, Niebuhr E. 1983. Sister chromatid exchange in response to variations in occupational lead exposure. Environ Res 32(1):199–204.6617612
Grover P, Rekhadevi PV, Danadevi K, . 2010. Genotoxicity evaluation in workers occupationally exposed to lead. Int J Hyg Environ Health 213(2):99–106. 10.1016/j.ijheh.2010.01.005.20153251
Gump BB, Stewart P, Reihman J, . 2005. Prenatal and early childhood blood lead levels and cardiovascular functioning in 9 1/2 year old children. Neurotoxicol Teratol 27(4):655–665. 10.1016/j.ntt.2005.04.002.15919179
Gump BB, Stewart P, Reihman J, . 2008. Low-level prenatal and postnatal blood lead exposure and adrenocortical responses to acute stress in children. Environ Health Perspect 116(2):249–255.10.1289/ehp.10391.18288326
Gump BB, Mackenzie JA, Bendinskas K, . 2011. Low-level Pb and cardiovascular responses to acute stress in children: The role of cardiac autonomic regulation. Neurotoxicol Teratol 33(2):212–219. 10.1016/j.ntt.2010.10.001.20934510
Gundacker C, Fröhlich S, Graf-Rohrmeister K, . 2010. Perinatal lead and mercury exposure in Austria. Sci Total Environ 408(23):5744–5749. 10.1016/j.scitotenv.2010.07.079.20825977
Hamurcu Z, Donmez H, Saraymen R, . 2001. Micronucleus frequency in human lymphocyte exposed to occupational lead, zinc, and cadmium. Biol Trace Elem Res 83(2):97–102.11762535
Hanna CW, Bloom MS, Robinson WP, . 2012. DNA methylation changes in whole blood is associated with exposure to the environmental contaminants, mercury, lead, cadmium and bisphenol A, in women undergoing ovarian stimulation for IVF. Hum Reprod 27(5):1401–1410. 10.1093/humrep/des038.22381621
Harari F, Sallsten G, Christensson A, . 2018. Blood lead levels and decreased kidney function in a population-based cohort. Am J Kidney Dis 72(3):381–389. 10.1053/j.ajkd.2018.02.358.29699886
Hauser R, Sergeyev O, Korrick S, . 2008. Association of blood lead levels with onset of puberty in Russian boys. Environ Health Perspect 116(7):976–980. 10.1289/ehp.10516.18629324
He J, Ning H, Huang R. 2019. Low blood lead levels and attention-deficit hyperactivity disorder in children: A systematic review and meta-analysis. Environ Sci Pollut Res Int 26(18):17875–17884. 10.1007/s11356-017-9799-2.28780688
Hengstler JG, Bolm-Audorff U, Faldum A, . 2003. Occupational exposure to heavy metals: DNA damage induction and DNA repair inhibition prove co-exposures to cadmium, cobalt and lead as more dangerous than hitherto expected. Carcinogenesis 24(1):63–73.12538350
Hense HW, Filipiak B, Keil U. 1993. The association of blood lead and blood pressure in population surveys. Epidemiology 4:173–179.8452907
Hernández-Ochoa I, García-Vargas G, López-Carrillo L, . 2005. Low lead environmental exposure alters semen quality and sperm chromatin condensation in northern Mexico. Reprod Toxicol 20(2):221–228. 10.1016/j.reprotox.2005.01.007.15907657
Hong YC, Kulkarni SS, Lim YH, . 2014. Postnatal growth following prenatal lead exposure and calcium intake. Pediatrics 134(6):1151–1159. 10.1542/peds.2014-1658.25422017
Hong SB, Im MH, Kim JW, . 2015. Environmental lead exposure and attention deficit/hyperactivity disorder symptom domains in a community sample of South Korean school-age children. Environ Health Perspect 123(3):271–276. 10.1289/ehp.1307420.25280233
Hsiao CL, Wu KH, Wan KS. 2011. Effects of environmental lead exposure on T-helper cell-specific cytokines in children. J Immunotoxicol 8(4):284–287. 10.3109/1547691X.2011.592162.21726182
Hu H, Aro A, Payton M, . 1996a. The relationship of bone and blood lead to hypertension. The normative aging study. J Am Med Assoc 275(15):1171–1176.
Hu H, Tellez-Rojo MM, Bellinger D, . 2006. Fetal lead exposure at each stage of pregnancy as a predictor of infant mental development. Environ Health Perspect 114(11):1730–1735. 10.1289/ehp.9067.17107860
Huang XP, Feng ZY, Zhai WL, . 1988. Chromosomal aberrations and sister chromatid exchanges in workers exposed to lead. Biomed Environ Sci 1:382–387.3268122
Huang S, Hu H, Sanchez BN, . 2016. Childhood blood lead levels and symptoms of Attention Deficit Hyperactivity Disorder (ADHD): A cross-sectional study of Mexican children. Environ Health Perspect 124(6):868–874. 10.1289/ehp.1510067.26645203
Huh DA, Choi YH, Ji MS, . 2018. Comparison of pure-tone average methods for estimation of hearing loss caused by environmental exposure to lead and cadmium: Does the pure-tone average method which uses low-frequency ranges underestimate the actual hearing loss caused by environmental lead and cadmium exposure? Audiol Neurotol 23(5):259–269. 10.1159/000494049.
Hwang YH, Chiang HY, Yen-Jean MC, . 2009. The association between low levels of lead in blood and occupational noise-induced hearing loss in steel workers. Sci Total Environ 408(1):43–49. 10.1016/j.scitotenv.2009.09.016.19818992
Ignasiak Z, Slawinska T, Rozek K, . 2006. Lead and growth status of schoolchildren living in the copper basin of south-western Poland: Differential effects on bone growth. Ann Hum Biol 33(4):401–414. 10.1080/03014460600730752.17060065
Iijima K, Otake T, Yoshinaga J, . 2007. Cadmium, lead, and selenium in cord blood and thyroid hormone status of newborns. Biol Trace Elem Res 119(1):10–18. 10.1007/s12011-007-0057-1.17914214
Jackson LW, Howards PP, Wactawski-Wende J, . 2011. The association between cadmium, lead and mercury blood levels and reproductive hormones among healthy, premenopausal women. Hum Reprod 26(10):2887–2895. 10.1093/humrep/der250.21778284
Jain NB, Potula V, Schwartz J, . 2007. Lead levels and ischemic heart disease in a prospective study of middle-aged and elderly men: The VA Normative Aging Study. Environ Health Perspect 115(6):871–875. 10.1289/ehp.9629.17589593
Jannuzzi AT, Alpertunga B. 2016. Evaluation of DNA damage and DNA repair capacity in occupationally lead-exposed workers. Toxicol Ind Health 32(11):1859–1865. 10.1177/0748233715590919.26149192
Jasso-Pineda Y, Diaz-Barriga F, Calderon J, . 2012. DNA damage and decreased DNA repair in individuals exposed to arsenic and lead in a mining site. Biol Trace Elem Res 146(2):141–149.22016027
Jedrychowski W, Perera FP, Jankowski J, . 2009. Very low prenatal exposure to lead and mental development of children in infancy and early childhood: Krakow prospective cohort study. Neuroepidemiology 32(4):270–278. 10.1159/000203075.19223686
Jedrychowski W, Perera F, Maugeri U, . 2011. Intrauterine exposure to lead may enhance sensitization to common inhalant allergens in early childhood: A prospective prebirth cohort study. Environ Res 111(1):119–124. 10.1016/j.envres.2010.11.002.21094490
Ji JS, Elbaz A, Weisskopf MG. 2013. Association between blood lead and walking speed in the National Health and Nutrition Examination Survey (NHANES 1999-2002). Environ Health Perspect 121(6):711–716. 10.1289/ehp.1205918.23603014
Ji JS, Power MC, Sparrow D, . 2015. Lead exposure and tremor among older men: The VA normative aging study. Environ Health Perspect 123(5):445–450. 10.1289/ehp.1408535.25633720
Ji Y, Hong X, Wang G, . 2018. A prospective birth cohort study on early childhood lead levels and attention deficit hyperactivity disorder: New insight on sex differences. J Pediatr 199:124–131.e128. 10.1016/j.jpeds.2018.03.076.29752174
Jing J, Thapa S, Delhey L, . 2019. The relation of blood lead and QRS-T angle in American adults. Arch Environ Occup Health 74(5):287–291. 10.1080/19338244.2018.1488674.29920162
Joo H, Lim MH, Ha M, . 2017. Secondhand smoke exposure and low blood lead levels in association with attention-deficit hyperactivity disorder and its symptom domain in children: A community-based case-control study. Nicotine Tob Res 19(1):94–101. 10.1093/ntr/ntw152.27613950
Joseph CLM, Havstad S, Ownby DR, . 2005. Blood lead level and risk of asthma. Environ Health Perspect 113(7):900–904. 10.1289/ehp.7453.16002380
Jusko TA, Henderson CR, Lanphear BP, . 2008. Blood lead concentrations <10 µg/dL and child intelligence at 6 years of age. Environ Health Perspect 116(2):243–248. 10.1289/ehp.10424.18288325
Kamel F, Umbach DM, Munsat TL, . 2002. Lead exposure and amyotrophic lateral sclerosis. Epidemiology 13:311–319.11964933
Kang GH, Uhm JY, Choi YG, . 2018. Environmental exposure of heavy metal (lead and cadmium) and hearing loss: Data from the Korea National Health and Nutrition Examination Survey (KNHANES 2010-2013). Ann Occup Environ Med 30:22. 10.1186/s40557-018-0237-9.29692915
Karmaus W, Brooks KR, Nebe T, . 2005. Immune function biomarkers in children exposed to lead and organochlorine compounds: A cross-sectional study. Environ Health 4(1):5. 10.1186/1476-069X-4-5.15831097
Kasuba V, Rozgaj R, Milic M, . 2012. Evaluation of genotoxic effects of lead in pottery-glaze workers using micronucleus assay, alkaline comet assay and DNA diffusion assay. Int Arch Occup Environ Health 85(7):807–818. 10.1007/s00420-011-0726-4.22160131
Kayaalti Z, Yavuz I, Soylemez E, . 2015a. Evaluation of DNA damage using 3 comet assay parameters in workers occupationally exposed to lead. Arch Environ Occup Health 70(3):120–125. 10.1080/19338244.2013.787964.24965324
Kemp FW, Neti PVSV, Howell RW, . 2007. Elevated blood lead concentrations and vitamin D deficiency in winter and summer in young urban children. Environ Health Perspect 115(4):630–635. 10.1289/ehp.9389.17450235
Khalil N, Cauley JA, Wilson JW, . 2008. Relationship of blood lead levels to incident nonspine fractures and falls in older women: The Study of Osteoporotic Fractures. J Bone Miner Res 23(9):1417–1425. 10.1359/jbmr.080404.18410230
Khalil N, Wilson JW, Talbott EO, . 2009. Association of blood lead concentrations with mortality in older women: A prospective cohort study. Environmental Health: A Global Access Science Source 8:15. 10.1186/1476-069x-8-15.19344498
Khan D, Qayyum S, Saleem S, . 2010a. Lead exposure and its adverse health effects among occupational worker’s children. Toxicol Ind Health 26(8):497. 10.1177/0748233710373085.20538706
Khan MI, Ahmad I, Mahdi AA, . 2010b. Elevated blood lead levels and cytogenetic markers in buccal epithelial cells of painters in India: Genotoxicity in painters exposed to lead containing paints. Environ Sci Pollut Res Int 17(7):1347–1354. 10.1007/s11356-010-0319-x.20300868
Kim KN, Kwon HJ, Hong YC. 2016. Low-level lead exposure and autistic behaviors in school-age children. Neurotoxicology 53:193–200. 10.1016/j.neuro.2016.02.004.26877220
Kim R, Rotnitzky A, Sparrow D, . 1996a. A longitudinal study of low-level lead exposure and impairment of renal function: The normative aging study. J Am Med Assoc 275(15):1177–1181.
Kim JH, Lee KH, Yoo DH, . 2007. GSTM1 and TNF-alpha gene polymorphisms and relations between blood lead and inflammatory markers in a non-occupational population. Mutat Res 629(1):32–39. 10.1016/j.mrgentox.2007.01.004.17298885
Kim Y, Ha EH, Park H, . 2013b. Prenatal lead and cadmium co-exposure and infant neurodevelopment at 6 months of age: The Mothers and Children’s Environmental Health (MOCEH) study. Neurotoxicology 35:15–22. 10.1016/j.neuro.2012.11.006.23220728
Kim YS, Ha M, Kwon HJ, . 2017a. Association between low blood lead levels and increased risk of dental caries in children: A cross-sectional study. BMC Oral Health 17(1):42. 10.1186/s12903-017-0335-z.28086936
Kim JH, Park Y, Kim SK, . 2017b. Timing of an accelerated body mass increase in children exposed to lead in early life: A longitudinal study. Sci Total Environ 584–585:72–77. 10.1016/j.scitotenv.2017.01.122.
Kordas K, Ettinger AS, Bellinger DC, . 2011. A dopamine receptor (DRD2) but not dopamine transporter (DAT1) gene polymorphism is associated with neurocognitive development of Mexican preschool children with lead exposure. J Pediatr 159(4):638–643. 10.1016/j.jpeds.2011.03.043.21592505
Korrick SA, Hunter DJ, Rotnitzky A, . 1999. Lead and hypertension in a sample of middle-aged women. Am J Public Health 89(3):330–335.10076481
Kresovich JK, Argos M, Turyk ME. 2015. Associations of lead and cadmium with sex hormones in adult males. Environ Res 142:25–33. 10.1016/j.envres.2015.05.026.26093239
Krieg EF. 2007. The relationships between blood lead levels and serum follicle stimulating hormone and luteinizing hormone in the third national health and nutrition examination survey. Environ Res 104(3):374–382. 10.1016/j.envres.2006.09.009.17084837
Krieg EF, Chrislip DW, Crespo CJ, . 2005. The relationship between blood lead levels and neurobehavioral test performance in NHANES III and related occupational studies. Public Health Rep 120(3):240–251.16134563
Krueger WS, Wade TJ. 2016. Elevated blood lead and cadmium levels associated with chronic infections among non-smokers in a cross-sectional analysis of NHANES data. Environ Health 15(1):16. 10.1186/s12940-016-0113-4.26864738
Lamadrid-Figueroa H, Téllez-Rojo MM, Hernández-Avila M, . 2007. Association between the plasma/whole blood lead ratio and history of spontaneous abortion: A nested cross-sectional study. BMC Pregnancy Childbirth 7:22. 10.1186/1471-2393-7-22.17900368
Lamb MR, Janevic T, Liu X, . 2008. Environmental lead exposure, maternal thyroid function, and childhood growth. Environ Res 106(2):195–202. 10.1016/j.envres.2007.09.012.17988663
Lanphear BP, Dietrich K, Auinger P, . 2000a. Cognitive deficits associated with blood lead concentrations< 10 microg/dL in US children and adolescents. Public Health Rep 115(6):521–529.11354334
Lanphear BP, Hornung R, Khoury J, . 2005. Low-level environmental lead exposure and children’s intellectual function: An international pooled analysis. Environ Health Perspect 113(7):894–899.16002379
Lanphear BP, Rauch S, Auinger P, . 2018. Low-level lead exposure and mortality in US adults: A population-based cohort study. Lancet Public Health 3(4):e177–e184. 10.1016/S2468-2667(18)30025-2.29544878
Lanphear BP, Hornung R, Khoury J, . 2019. Erratum: “Low-level environmental lead exposure and children’s intellectual function: An international pooled analysis”. Environ Health Perspect 127(9):99001. 10.1289/ehp5685.31526192
Lee HS, Park T. 2018. Nuclear receptor and VEGF pathways for gene-blood lead interactions, on bone mineral density, in Korean smokers. PLoS ONE 13(3):e0193323.10.1371/journal.pone.0193323.29518117
Lee BK, Ahn J, Kim NS, . 2016a. Association of blood pressure with exposure to lead and cadmium: Analysis of data from the 2008-2013 Korean National Health and Nutrition Examination Survey. Biol Trace Elem Res 174(1):40–51. 10.1007/s12011-016-0699-y.27087554
Lee W, Yoon JH, Roh J, . 2016b. The association between low blood lead levels and the prevalence of prehypertension among nonhypertensive adults in Korea. Am J Hum Biol 28(5):729–735. 10.1002/ajhb.22857.27121332
Leem AY, Kim SK, Chang J, . 2015. Relationship between blood levels of heavy metals and lung function based on the Korean National Health and Nutrition Examination Survey IV-V. Int J Chron Obstruct Pulmon Dis 10:1559–1570. 10.2147/copd.s86182.26345298
Levey AS, Bosch JP, Lewis JB, . 1999. A more accurate method to estimate glomerular filtration rate from serum creatinine: A new prediction equation. Ann Intern Med 130(6):461–479.10075613
Levey AS, Stevens LA, Schmid CH, . 2009. A new equation to estimate glomerular filtration rate. Ann Intern Med 150:604–612.19414839
Lewis RC, Meeker JD. 2015. Biomarkers of exposure to molybdenum and other metals in relations to testosterone among men from the United States National Health and Nutrition Examination Survey 2011-2012. Fertil Steril 103:172–178.25439796
Li CJ, Yeh CY, Chen RY, . 2015. Biomonitoring of blood heavy metals and reproductive hormone level related to low semen quality. J Hazard Mater 300:815–822. 10.1016/j.jhazmat.2015.08.027.26340548
Li Y, Xie C, Murphy SK, . 2016b. Lead exposure during early human development and DNA methylation of imprinted gene regulatory elements in adulthood. Environ Health Perspect 124(5):666–673. 10.1289/ehp.1408577.26115033
Lin JL, Tan DT, Hsu KH, . 2001. Environmental lead exposure and progressive renal insufficiency. Arch Intern Med 161:264–271.11176742
Lin J, Lin-Tan D, Hsu K, . 2003. Environmental lead exposure and progression of chronic renal diseases in patients without diabetes. N Engl J Med 348(4):277–286.12540640
Lin JL, Lin-Tan DT, Li YJ, . 2006a. Low-level environmental exposure to lead and progressive chronic kidney diseases. Am J Med 119(8):1–9. 10.1016/j.amjmed.2006.01.005.
Lin JL, Lin-Tan DT, Yu CC, . 2006b. Environmental exposure to lead and progressive diabetic nephropathy in patients with type II diabetes. Kidney Int 69(11):2049–2056.16641918
Lin CC, Chen YC, Su FC, . 2013. In utero exposure to environmental lead and manganese and neurodevelopment at 2 years of age. Environ Res 123:52–57. 10.1016/j.envres.2013.03.003.23578827
Lin-Tan DT, Lin JL, Yen TH, . 2007. Long-term outcome of repeated lead chelation therapy in progressive non-diabetic chronic kidney diseases. Nephrol Dial Transplant 22(10):2924–2931. 10.1093/ndt/gfm342.17556414
Little BB, Spalding S, Walsh B, . 2009. Blood lead levels and growth status among African-American and Hispanic children in Dallas, Texas-1980 and 2002: Dallas Lead Project II. Ann Hum Biol 36(3):331–341. 10.1080/03014460902806615.19381987
Little BB, Ignasiak Z, Slawinska T, . 2017. Blood lead levels, pulmonary function and agility in Polish schoolchildren. Ann Hum Biol 44(8):723–728. 10.1080/03014460.2017.1387284.29082756
Liu J, Gao D, Chen Y, . 2014a. Lead exposure at each stage of pregnancy and neurobehavioral development of neonates. Neurotoxicology 44:1–7. 10.1016/j.neuro.2014.03.003.24704588
Liu J, Chen Y, Gao D, . 2014b. Prenatal and postnatal lead exposure and cognitive development of infants followed over the first three years of life: A prospective birth study in the Pearl River Delta region, China. Neurotoxicology 44:326–334. 10.1016/j.neuro.2014.07.001.25124739
Liu C, Huo X, Lin P, . 2015a. Association between blood erythrocyte lead concentrations and hemoglobin levels in preschool children. Environ Sci Pollut Res Int 22(12):9233–9240. 10.1007/s11356-014-3992-3.25588596
Liu J, Liu X, Pak V, . 2015b. Early blood lead levels and sleep disturbance in preadolescence. Sleep 38(12):1869–1874. 10.5665/sleep.5230.26194570
Liu Z, He C, Chen M, . 2018a. The effects of lead and aluminum exposure on congenital heart disease and the mechanism of oxidative stress. Reprod Toxicol 81:93–98. 10.1016/j.reprotox.2018.07.081.30031113
Liu Y, Huo X, Xu L, . 2018b. Hearing loss in children with e-waste lead and cadmium exposure. Sci Total Environ 624:621–627. 10.1016/j.scitotenv.2017.12.091.29272831
Luo J, Hendryx M. 2014. Relationship between blood cadmium, lead, and serum thyroid measures in US adults - The National Health and Nutrition Examination Survey (NHANES) 2007-2010. Int J Environ Health Res 24(2):125–136. 10.1080/09603123.2013.800962.23782348
Machida M, Sun SJ, Oguma E, . 2009. High bone matrix turnover predicts blood levels of lead among perimenopausal women. Environ Res 109(7):880–886. 10.1016/j.envres.2009.06.005.19595303
Maki-Paakkanen J, Sorsa M, Vainio H. 1981. Chromosome aberrations and sister chromatid exchanges in lead-exposed workers. Hereditas 94:269–275.7298357
Martin D, Glass TA, Bandeen-Roche K, . 2006. Association of blood lead and tibia lead with blood pressure and hypertension in a community sample of older adults. Am J Epidemiol 163(5):467–478. 10.1093/aje/kwj060.16421242
Mazumdar M, Bellinger DC, Gregas M, . 2011. Low-level environmental lead exposure in childhood and adult intellectual function: A follow-up study. Environ Health 10(1):24. 10.1186/1476-069X-10-24.21450073
McLaine P, Navas-Acien A, Lee R, . 2013. Elevated blood lead levels and reading readiness at the start of kindergarten. Pediatrics 131(6):1081–1089. 10.1542/peds.2012-2277.23669514
Meeker JD, Rossano MG, Protas B, . 2008. Cadmium, lead, and other metals in relation to semen quality: Human evidence for molybdenum as a male reproductive toxicant. Environ Health Perspect 116(11):1473–1479. 10.1289/ehp.11490.19057699
Meeker JD, Rossano MG, Protas B, . 2010. Environmental exposure to metals and male reproductive hormones: Circulating testosterone is inversely associated with blood molybdenum. Fertil Steril 93(1):130–140. 10.1016/j.fertnstert.2008.09.044.18990371
Méndez-Gómez J, García-Vargas GG, López-Carrillo L, . 2008. Genotoxic effects of environmental exposure to arsenic and lead on children in region Lagunera, Mexico. Ann N Y Acad Sci 1140:358–367. 10.1196/annals.1454.027.18991935
Mendiola J, Moreno JM, Roca M, . 2011. Relationships between heavy metal concentrations in three different body fluids and male reproductive parameters: A pilot study. Environ Health 10(1):6. 10.1186/1476-069X-10-6.21247448
Mendy A, Gasana J, Vieira ER. 2013. Low blood lead concentrations and thyroid function of American adults. Int J Environ Health Res 23(6):461–473. 10.1080/09603123.2012.755155.23323812
Menke A, Muntner P, Batuman V, . 2006. Blood lead below 0.48 micromol/L (10 microg/dL) and mortality among US adults. Circulation 114(13):1388–1394. 10.1161/circulationaha.106.628321.16982939
Mielzyńska D, Siwińska E, Kapka L, . 2006. The influence of environmental exposure to complex mixtures including PAHs and lead on genotoxic effects in children living in Upper Silesia, Poland. Mutagenesis 21(5):295–304. 10.1093/mutage/gel037.16891332
Min KB, Min JY. 2015. Environmental lead exposure and increased risk for total and allergen-specific IgE in US adults. J Allergy Clin Immunol 135(1):275–277. 10.1016/j.jaci.2014.08.052.25441290
Min JY, Min KB, Kim R, . 2008a. Blood lead levels and increased bronchial responsiveness. Biol Trace Elem Res 123(1–3):41–46. 10.1007/s12011-008-8099-6.18286239
Min KB, Min JY, Cho SI, . 2008b. Relationship between low blood lead levels and growth in children of white-collar civil servants in Korea. Int J Hyg Environ Health 211(1–2):82–87. 10.1016/j.ijheh.2007.03.003.17588495
Min MYO, Singer LT, Kirchner HL, . 2009. Cognitive development and low-level lead exposure in poly-drug exposed children. Neurotoxicol Teratol 31(4):225–231. 10.1016/j.ntt.2009.03.002.19345261
Minozzo R, Deimling LI, Gigante LP, . 2004. Micronuclei in peripheral blood lymphocytes of workers exposed to lead. Mutat Res 565(1):53–60. 10.1016/j.mrgentox.2004.09.003.15576239
Miranda ML, Kim D, Reiter J, . 2009. Environmental contributors to the achievement gap. Neurotoxicology 30(6):1019–1024. 10.1016/j.neuro.2009.07.012.19643133
Moon SS. 2013. Association of lead, mercury and cadmium with diabetes in the Korean population: The Korea National Health and Nutrition Examination Survey (KNHANES) 2009-2010. Diabet Med 30(4):e143–148. 10.1111/dme.12103.23278294
Moss ME, Lanphear BP, Auinger P. 1999. Association of dental caries and blood lead levels. JAMA 281(24):2294–2298.10386553
Mujaj B, Yang WY, Zhang ZY, . 2019. Renal function in relation to low-level environmental lead exposure. Nephrol Dial Transplant 34(6):941–946. 10.1093/ndt/gfy279.30165570
Muldoon SB, Cauley JA, Kuller LH, . 1996. Effects of blood lead levels on cognitive function of older women. Neuroepidemiology 15:62–72.8684585
Muntner P, He J, Vupputuri S, . 2003. Blood lead and chronic kidney disease in the general United States population: Results from NHANES III. Kidney Int 63(3):1044–1050.12631086
Muntner P, Menke A, DeSalvo KB, . 2005. Continued decline in blood lead levels among adults in the United States - The National Health and Nutrition Examination Surveys. Arch Intern Med 165(18):2155–2161. 10.1001/archinte.165.18.2155.16217007
Naicker N, Norris SA, Mathee A, . 2010. Lead exposure is associated with a delay in the onset of puberty in South African adolescent females: Findings from the birth to twenty cohort. Sci Total Environ 408(21):4949–4954. 10.1016/j.scitotenv.2010.07.037.20692685
Nash D, Magder L, Lustberg M, . 2003. Blood lead, blood pressure, and hypertension in perimenopausal and postmenopausal women. JAMA 289(12):1523–1532.12672769
Navas-Acien A, Selvin E, Sharrett AR, . 2004. Lead, cadmium, smoking, and increased risk of peripheral arterial disease. Circulation 109:3196–3201.15184277
Navas-Acien A, Tellez-Plaza M, Guallar E, . 2009. Blood cadmium and lead and chronic kidney disease in US adults: A joint analysis. Am J Epidemiol 170(9):1156–1164. 10.1093/aje/kwp248.19700501
Needleman HL, Rabinowitz M, Leviton A, . 1984. The relationship between prenatal exposure to lead and congenital anomalies. J Am Med Assoc 251(22):2956–2959.
Nelson AE, Chaudhary S, Kraus VB, . 2011. Whole blood lead levels are associated with biomarkers of joint tissue metabolism in African American and white men and women: The Johnston County Osteoarthritis Project. Environ Res 111(8):1208–1214. 10.1016/j.envres.2011.08.002.21839992
Ngueta G, Verner MA, Fiocco AJ, . 2018. Blood lead levels and hypothalamic-pituitary-adrenal function in middle-aged individuals. Environ Res 160:554–561. 10.1016/j.envres.2017.10.032.29102031
Nie X, Chen Y, Chen Y, . 2017. Lead and cadmium exposure, higher thyroid antibodies and thyroid dysfunction in Chinese women. Environ Pollut 230:320–328. 10.1016/j.envpol.2017.06.052.28667913
Nishioka E, Yokoyama K, Matsukawa T, . 2014. Evidence that birth weight is decreased by maternal lead levels below 5 ug/dl in male newborns. Reprod Toxicol 47:21–26.10.1016/j.reprotox.2014.05.007.24878230
Nordenson I, Beckman G, Beckman L, . 1978. Occupational and environmental risks in and around a smelter in northern Sweden. IV. Chromosomal aberrations in workers exposed to lead. Hereditas 88:263–267.689896
Obeng-Gyasi E, Obeng-Gyasi B. 2018. Blood pressure and oxidative stress among U.S. adults exposed to lead in military environments - A preliminary study. Diseases 6(4):97. 10.3390/diseases6040097.30373250
Odland JO, Nieboer E, Romanova N, . 1999. Blood lead and cadmium and birth weight among sub-arctic and arctic populations of Norway and Russia. Acta Obstet Gynecol Scand 78:852–860.10577613
Olivero-Verbel J, Duarte D, Echenique M, . 2007. Blood lead levels in children aged 5-9 years living in Cartagena, Colombia. Sci Total Environ 372(2–3):707–716. 10.1016/j.scitotenv.2006.10.025.17157895
Opler MGA, Brown AS, Graziano J, . 2004. Prenatal lead exposure, delta-aminolevulinic acid, and schizophrenia. Environ Health Perspect 112(5):548–552. 10.1289/ehp.10464.15064159
Opler MGA, Buka SL, Groeger J, . 2008. Prenatal exposure to lead, delta-aminolevulinic acid, and schizophrenia: Further evidence. Environ Health Perspect 116(11):1586–1590. 10.1289/ehp.10464.19057716
Osman K, Pawlas K, Schutz A, . 1999. Lead exposure and hearing effects in children in Katowice, Poland. Environ Res 80 Section A:1–8.9931221
Park SK, Hu H, Wright RO, . 2009a. Iron metabolism genes, low-level lead exposure, and QT interval. Environ Health Perspect 117(1):80–85.19165391
Park SK, Mukherjee B, Xia X, . 2009b. Bone lead level prediction models and their application to examine the relationship of lead exposure and hypertension in the third National Health and Nutrition Examination Survey. J Occup Environ Med 51(12):1422–1436. 10.1097/JOM.0b013e3181bf6c8d.19952788
Park JH, Seo JH, Hong YS, . 2016. Blood lead concentrations and attention deficit hyperactivity disorder in Korean children: A hospital-based case control study. BMC pediatrics 16(1):156. 10.1186/s12887-016-0696-5.27659349
Park WJ, Kim SH, Kang W, . 2019. Blood lead level and Helicobacter pylori infection in a healthy population: A cross-sectional study. Arch Environ Occup Health 74:1–6.10.1080/19338244.2019.1654969.30932794
Pawlas N, Broberg K, Olewinska E, . 2015. Genetic modification of ALAD and VDR on lead-induced impairment of hearing in children. Environ Toxicol Pharmacol 39(3):1091–1098. 10.1016/j.etap.2015.03.008.25899472
Payton M, Hu H, Sparrow D, . 1994. Low-level lead exposure and renal function in the normative aging study. Am J Epidemiol 140(9):821–829.7977292
Payton M, Riggs KM, Sprio A, . 1998. Relations of bone and blood lead to cognitive function: The VA normative aging study. Neurotoxicol Teratol 20(1):19–27.9511166
Perkins M, Wright RO, Amarasiriwardena CJ, . 2014. Very low maternal lead level in pregnancy and birth outcomes in an eastern Massachusetts population. Ann Epidemiol 24(12):915–919. 10.1016/j.annepidem.2014.09.007.25444892
Perlstein T, Weuve J, Schwartz J, . 2007. Cumulative community-level lead exposure and pulse pressure: The Normative Aging Study. Environ Health Perspect 115(12):1696–1700. 10.1289/ehp.10350.18087585
Pilsner JR, Hu H, Ettinger A, . 2009. Influence of prenatal lead exposure on genomic methylation of cord blood DNA. Environ Health Perspect 117(9):1466–1471. 10.1289/ehp.0800497.19750115
Pinto D, Ceballos JM, García G, . 2000. Increased cytogenetic damage in outdoor painters. Mutat Res Genet Toxicol Environ Mutagen 467(2):105–111. 10.1016/S1383-5718(00)00024-3.
Pizent A, Macan J, Jurasović J, . 2008. Association of toxic and essential metals with atopy markers and ventilatory lung function in women and men. Sci Total Environ 390(2–3):369–376. 10.1016/j.scitotenv.2007.10.049.18045657
Polanska K, Hanke W, Pawlas N, . 2018. Sex-dependent impact of low-level lead exposure during prenatal period on child psychomotor functions. Int J Environ Res Public Health 15(10):2263. 10.3390/ijerph15102263.30332762
Pollack AZ, Schisterman EF, Goldman LR, . 2011. Cadmium, lead, and mercury in relation to reproductive hormones and anovulation in premenopausal women. Environ Health Perspect 119(8):1156–1161. 10.1289/ehp.1003284.21543284
Pollack AZ, Mumford SL, Wactawski-Wende J, . 2013. Bone mineral density and blood metals in premenopausal women. Environ Res 120:76–81.23122770
Pollack AZ, Mumford SL, Mendola P, . 2015. Kidney biomarkers associated with blood lead, mercury, and cadmium in premenopausal women: A prospective cohort study. J Toxicol Environ Health A 78(2):119–131. 10.1080/15287394.2014.944680.25424620
Power MC, Korrick S, Tchetgen Tchetgen EJ, . 2014. Lead exposure and rate of change in cognitive function in older women. Environ Res 129:69–75. 10.1016/j.envres.2013.12.010.24529005
Proctor SP, Rotnitzky A, Sparrow D, . 1996. The relationship of blood lead and dietary calcium to blood pressure in the normative aging study. Int J Epidemiol 25(3):528–536.8671553
Przybyla J, Houseman EA, Smit E, . 2017. A path analysis of multiple neurotoxic chemicals and cognitive functioning in older US adults (NHANES 1999-2002). Environ Health 16(1):19. 10.1186/s12940-017-0227-3.28270159
Queirolo EI, Ettinger AS, Stoltzfus RJ, . 2010. Association of anemia, child and family characteristics with elevated blood lead concentrations in preschool children from Montevideo, Uruguay. Arch Environ Occup Health 65(2):94–100. 10.1080/19338240903390313.20439228
Rabito FA, Kocak M, Werthmann DW, . 2014. Changes in low levels of lead over the course of pregnancy and the association with birth outcomes. Reprod Toxicol 50:138–144. 10.1016/j.reprotox.2014.10.006.25461912
Raihan MJ, Briskin E, Mahfuz M, . 2018. Examining the relationship between blood lead level and stunting, wasting and underweight - A cross-sectional study of children under 2 years-of-age in a Bangladeshi slum. PLoS ONE 13(5):e0197856. 10.1371/journal.pone.0197856.29795643
Rajan P, Kelsey KT, Schwartz JD, . 2007. Lead burden and psychiatric symptoms and the modifying influence of the delta-aminolevulinic acid dehydratase (ALAD) polymorphism: The VA Normative Aging Study. Am J Epidemiol 166(12):1400–1408. 10.1093/aje/kwm220.17823382
Renzetti S, Just AC, Burris HH, . 2017. The association of lead exposure during pregnancy and childhood anthropometry in the Mexican PROGRESS cohort. Environ Res 152:226–232. 10.1016/j.envres.2016.10.014.27810680
Rhodes D, Spiro III A, Aro A, . 2003. Relationship of bone and blood lead levels to psychiatric symptoms: The normative aging study. J Occup Environ Med 45(11):1144–1151.14610395
Riddell TJ, Solon O, Quimbo SA, . 2007. Elevated blood-lead levels among children living in the rural Philippines. Bull World Health Organ 85(9):674–680.18026623
Rodosthenous RS, Burris HH, Svensson K, . 2017. Prenatal lead exposure and fetal growth: Smaller infants have heightened susceptibility. Environ Int 99:228–233. 10.1016/j.envint.2016.11.023.27923585
Rodrigues EG, Bellinger DC, Valeri L, . 2016. Neurodevelopmental outcomes among 2- to 3-year-old children in Bangladesh with elevated blood lead and exposure to arsenic and manganese in drinking water. Environ Health 15:44. 10.1186/s12940-016-0127-y.26968381
Rokadia H, Agarwal S. 2013. Serum heavy metals and obstructive lung disease: Results from the National Health and Nutrition Examination Survey. Chest 143(2):388–397.10.1378/chest.12-0595.22911427
Ronco AM, Gutierrez Y, Gras N, . 2010. Lead and arsenic levels in women with different body mass composition. Biol Trace Elem Res 136:269–278. 10.1007/s12011-009-8546-z.19851721
Rooney JPK, Woods NF, Martin MD, . 2018. Genetic polymorphisms of GRIN2A and GRIN2B modify the neurobehavioral effects of low-level lead exposure in children. Environ Res 165:1–10. 10.1016/j.envres.2018.04.001.29655037
Rothenberg SJ, Kondrashov V, Manalo M, . 2002. Increases in hypertension and blood pressure during pregnancy with increased bone lead levels. Am J Epidemiol 156(12):1079–1087.12480651
Ruebner RL, Hooper SR, Parrish C, . 2019. Environmental lead exposure is associated with neurocognitive dysfunction in children with chronic kidney disease. Pediatr Nephrol 34(11):2371–2379. 10.1007/s00467-019-04306-7. (Retrieval in progress)31327061
Sakata S, Shimizu S, Ogoshi K, . 2007. Inverse relationship between serum erythropoietin and blood lead concentrations in Kathmandu tricycle taxi drivers. Int Arch Occup Environ Health 80(4):342–345. 10.1007/s00420-006-0125-4.16838166
Sarasua SM, Vogt RF, Henderson LO, . 2000. Serum immunoglobulins and lymphocyte subset distributions in children and adults living in communities assessed for lead and cadmium exposure. J Toxicol Environ Health A 60(1):1–15. 10.1080/009841000156556.10832614
Schell LM, Denham M, Stark AD, . 2009. Growth of infants’ length, weight, head and arm circumferences in relation to low levels of blood lead measured serially. Am J Hum Biol 21(2):180–187. 10.1002/ajhb.20842.18991336
Schnaas L, Rothenberg SJ, Perroni E, . 2000. Temporal pattern in the effect of postnatal blood lead level on intellectual development of young children. Neurotoxicol Teratol 22:805–810.11120385
Schnaas L, Rothenberg SJ, Flores MF, . 2006. Reduced intellectual development in children with prenatal lead exposure. Environ Health Perspect 114(5):791–797. 10.1289/ehp.8552.16675439
Schober SE, Mirel LB, Graubard BI, . 2006. Blood lead levels and death from all causes, cardiovascular disease, and cancer: Results from the NHANES III Mortality Study. Environ Health Perspect 114(10):1538–1541.17035139
Schwanitz G, Lehnert G, Gebhart E. 1970. Chromosome damage after occupational exposure to lead. Dtsch Med Wochenschr 95(32):1636–1641.5433400
Schwanitz G, Gebhart E, Rott H-D, . 1975. [Chromosomenuntersuchungen bei Personen mit beruflicher Bleiexposition]. Dtsch Med Wochenschr 100(18):1007–1011. (German)
Schwartz J. 1995. Lead, blood pressure, and cardiovascular disease in men. Arch Environ Health 50(1):31–37.7717767
Scinicariello F, Buser MC. 2015. Blood cadmium and depressive symptoms in young adults (aged 20-39 years). Psychol Med 45(4):807–815.25115444
Scinicariello F, Abadin HG, Murray HE. 2011. Association of blood lead and blood pressure in the NHANES 1999-2006. Environ Res 111(8):1249–1257.21907978
Scinicariello F, Yesupriya A, Chang MH, . 2010. Modification by ALAD of the association between blood lead and blood pressure in the U.S. population: Results from the Third National Health and Nutrition Examination Survey. Environ Health Perspect 118(2):259–264. 10.1289/ehp.0900866.20123609
Scinicariello F, Buser MC, Mevissen M, . 2013. Blood lead level association with lower body weight in NHANES 1999-2006. Toxicol Appl Pharmacol 273(3):516–523. 10.1016/j.taap.2013.09.022.24099784
Selevan SG, Rice DC, Hogan KA, . 2003. Blood lead concentration and delayed puberty in girls. N Engl J Med 348(16):1527–1536. 10.1056/NEJMoa020880.12700372
Seo J, Lee BK, Jin SU, . 2014. Lead-induced impairments in the neural processes related to working memory function. PLoS ONE 9(8):e105308. 10.1371/journal.pone.0105308.25141213
Shadbegian R, Guignet D, Klemick H, . 2019. Early childhood lead exposure and the persistence of educational consequences into adolescence. Environ Res 178:108643.10.1016/j.envres.2019.108643.31473504
Shaik AP, Jamil K. 2009. Individual susceptibility and genotoxicity in workers exposed to hazardous materials like lead. J Hazard Mater 168(2–3):918–924. 10.1016/j.jhazmat.2009.02.129.19327888
Shih RA, Glass TA, Bandeen-Roche K, . 2006. Environmental lead exposure and cognitive function in community-dwelling older adults. Neurology 67(9):1556–1562. 10.1212/01.wnl.0000239836.26142.c5.16971698
Silver MK, Li X, Liu Y, . 2016. Low-level prenatal lead exposure and infant sensory function. Environ Health 15(1):65. 10.1186/s12940-016-0148-6.27266277
Singh Z, Chadha P, Sharma S. 2013. Evaluation of oxidative stress and genotoxicity in battery manufacturing workers occupationally exposed to lead. Toxicol Int 20(1):95–100. 10.4103/0971-6580.111550.23833444
Sioen I, Den Hond E, Nelen V, . 2013. Prenatal exposure to environmental contaminants and behavioural problems at age 7-8 years. Environ Int 59:225–231. 10.1016/j.envint.2013.06.014.23845936
Sirivarasai J, Wananukul W, Kaojarern S, . 2013. Association between inflammatory marker, environmental lead exposure, and glutathione S-transferase gene. Biomed Res Int 2013:474963.10.1155/2013/474963.23484121
Sobin C, Flores-Montoya MG, Gutierrez M, . 2015. delta-Aminolevulinic acid dehydratase single nucleotide polymorphism 2 (ALAD2) and peptide transporter 2*2 haplotype (hPEPT2*2) differently influence neurobehavior in low-level lead exposed children. Neurotoxicol Teratol 47:137–145. 10.1016/j.ntt.2014.12.001.25514583
Songdej N, Winters PC, McCabe MJ, . 2010. A population-based assessment of blood lead levels in relation to inflammation. Environ Res 110(3):272–277. 10.1016/j.envres.2009.12.008.20116055
Spector JT, Navas-Acien A, Fadrowski J, . 2011. Associations of blood lead with estimated glomerular filtration rate using MDRD, CKD-EPI and serum cystatin C-based equations. Nephrol Dial Transplant 26(9):2786–2792. 10.1093/ndt/gfq773.21248295
Staessen JA, Lauwerys RR, Buchet JP, . 1992. Impairment of renal function with increasing blood lead concentrations in the general population. N Engl J Med 327:151–156.1608406
Staessen JA, Nawrot T, Den Hond E, . 2001. Renal function, cytogenetic measurements, and sexual development in adolescents in relation to environmental pollutants: A feasibility study of biomarkers. Lancet 357(9269):1660–1669.11425371
Stroustrup A, Hsu HH, Svensson K, . 2016. Toddler temperament and prenatal exposure to lead and maternal depression. Environ Health 15(1):71. 10.1186/s12940-016-0147-7.27312840
Taylor CM, Golding J, Emond AM. 2015. Adverse effects of maternal lead levels on birth outcomes in the ALSPAC study: A prospective birth cohort study. BJOG 122(3):322–328. 10.1111/1471-0528.12756.24824048
Taylor CM, Golding J, Hibbeln J, . 2013. Environmental factors predicting blood lead levels in pregnant women in the UK: The ALSPAC study. PLoS ONE 8(9):e72371. 10.1371/journal.pone.0072371.24039753
Taylor CM, Kordas K, Golding J, . 2017. Effects of low-level prenatal lead exposure on child IQ at 4 and 8 years in a UK birth cohort study. Neurotoxicology 62:162–169. 10.1016/j.neuro.2017.07.003.28687448
Taylor CM, Emond AM, Lingam R, . 2018. Prenatal lead, cadmium and mercury exposure and associations with motor skills at age 7 years in a UK observational birth cohort. Environ Int 117:40–47.29723752
Telisman S, Colak B, Pizent A, . 2007. Reproductive toxicity of low-level lead exposure in men. Environ Res 105(2):256–266. 10.1016/j.envres.2007.05.011.17632096
Téllez-Rojo MM, Bellinger DC, Arroyo-Quiroz C, . 2006. Longitudinal associations between blood lead concentrations lower than 10 microg/dL and neurobehavioral development in environmentally exposed children in Mexico City. Pediatrics 118(2):e323–e330. 10.1542/peds.2005-3123.16882776
Thomas S, Arbuckle TE, Fisher M, . 2015. Metals exposure and risk of small-for-gestational age birth in a Canadian birth cohort: The MIREC study. Environ Res 140:430–439. 10.1016/j.envres.2015.04.018.25967284
Tsaih SW, Korrick S, Schwartz J, . 2004. Lead, diabetes, hypertension, and renal function: The normative aging study. Environ Health Perspect 112(11):1178–1182. 10.1289/ehp.7024.15289163
Ukaejiofo EO, Thomas N, Ike SO. 2009. Haematological assessment of occupational exposure to lead handlers in Enugu urban, Enugu State, Nigeria. Niger J Clin Pract 12(1):58–64.19562924
Vaglenov A, Carbonell E, Marcos R. 1998. Biomonitoring of workers exposed to lead. Genotoxic effects, its modulation by polyvitamin treatment and evaluation of induced radioresistance. Mutat Res 418:79–92.9757002
Vaglenov A, Creus A, Laltchev S, . 2001. Occupational exposure to lead and induction of genetic damage. Environ Health Perspect 109(3):295–298.11333192
Van Larebeke N, Koppen G, Nelen V, . 2004. Differences in HPRT mutant frequency among middle-aged Flemish women in association with area of residence and blood lead levels. Biomarkers 9(1):71–84. 10.1080/13547500310001652160.15204312
Vigeh M, Yokoyama K, Kitamura F, . 2010. Early pregnancy blood lead and spontaneous abortion. Women Health 50(8):756–766.21170817
Vigeh M, Yokoyama K, Seyedaghamiri Z, . 2011. Blood lead at currently acceptable levels may cause preterm labour. Occup Environ Med 68(3):231–234. 10.1136/oem.2009.050419.20798002
Vigeh M, Yokoyama K, Matsukawa T, . 2014. Low level prenatal blood lead adversely affects early childhood mental development. J Child Neurol 29(10):1305–1311. 10.1177/0883073813516999.24532811
Vupputuri S, He J, Muntner P, . 2003. Blood lead level is associated with elevated blood pressure in blacks. Hypertension 41(3):463–468.12623944
Wang IJ, Karmaus WJJ, Yang CC. 2017a. Lead exposure, IgE, and the risk of asthma in children. J Expo Sci Environ Epidemiol 27(5):478–483. 10.1038/jes.2017.5.28401896
Wang HL, Chen XT, Yang B, . 2008. Case-control study of blood lead levels and attention deficit hyperactivity disorder in Chinese children. Environ Health Perspect 116(10):1401–1406. 10.1289/ehp.11400.18941585
Wang Q, Zhao HH, Chen JW, . 2010. delta-Aminolevulinic acid dehydratase activity, urinary delta-aminolevulinic acid concentration and zinc protoporphyrin level among people with low level of lead exposure. Int J Hyg Environ Health 213(1):52–58. 10.1016/j.ijheh.2009.08.003.19733117
Wang N, Chen C, Nie X, . 2015. Blood lead level and its association with body mass index and obesity in China - Results from SPECT-China study. Scientific reports 5:18299. 10.1038/srep18299.26658662
Wang H, Li J, Hao JH, . 2017b. High serum lead concentration in the first trimester is associated with an elevated risk of small-for-gestational-age infants. Toxicol Appl Pharmacol 332:75–80. 10.1016/j.taap.2017.07.020.28755861
Wang J, Gao ZY, Yan J, . 2017c. Sex differences in the effects of prenatal lead exposure on birth outcomes. Environ Pollut 225:193–200. 10.1016/j.envpol.2017.03.031.28371734
Wasserman GA, Graziano JH, Factor-Litvak P, . 1994. Consequences of lead exposure and iron supplementation on childhood development at age 4 years. Neurotoxicol Teratol 16(3):233–240.7523846
Wasserman GA, Liu X, Lolacono NJ, . 1997. Lead exposure and intelligence in 7-year-old children: The Yugoslavia Prospective Study. Environ Health Perspect 105(9):956–962.9410739
Wasserman GA, Factor-Litvak P, Liu X, . 2003. The relationship between blood lead, bone lead and child intelligence. Child Neuropsychol 9(1):22–34.12815520
Weisskopf MG, Proctor SP, Wright RO, . 2007. Cumulative lead exposure and cognitive performance among elderly men. Epidemiology 18(1):59–66. 10.1097/01.ede.0000248237.35363.29.17130688
Weisskopf MG, Nitin J, Nie H, . 2009. A prospective study of bone lead concentration and death from all causes, cardiovascular diseases, and cancer in the department of veterans affairs normative aging study. Circulation 120(12):1056–1064. 10.1161/circulationaha.108.827121.19738141
Wells EM, Navas-Acien A, Herbstman JB, . 2011. Low-level lead exposure and elevations in blood pressure during pregnancy. Environ Health Perspect 119:664–669.21292600
Wells EM, Bonfield TL, Dearborn DG, . 2014. The relationship of blood lead with immunoglobulin E, eosinophils, and asthma among children: NHANES 2005-2006. Int J Hyg Environ Health 217(2–3):196–204. 10.1016/j.ijheh.2013.04.010.23726529
Weuve J, Kelsey KT, Schwartz J, . 2006. delta-Aminolevulinic acid dehydratase polymorphism and the relation between low level lead exposure and the Mini-Mental Status Examination in older men: The Normative Aging Study. Occup Environ Med 63(11):746–753. 10.1136/oem.2006.027417.16757504
Weuve J, Korrick SA, Weisskopf MA, . 2009. Cumulative exposure to lead in relation to cognitive function in older women. Environ Health Perspect 117(4):574–580. 10.1289/ehp.11846.19440496
Williams PL, Sergeyev O, Lee MM, . 2010. Blood lead levels and delayed onset of puberty in a longitudinal study of Russian boys. Pediatrics 125(5):1088–1096. 10.1542/peds.2009-2575.20421257
Williams PL, Bellavia A, Korrick SA, . 2019. Blood lead levels and timing of male sexual maturity: A longitudinal study of Russian boys. Environ Int 125:470–477. 10.1016/j.envint.2019.01.070.30769180
Winter AS, Sampson RJ. 2017. From lead exposure in early childhood to adolescent health: A Chicago birth cohort. Am J Public Health 107(9):1496–1501. 10.2105/ajph.2017.303903.28727523
Wiwanitkit V, Suwansaksri J, Soogarun S. 2008. White blood cell sister chromatid exchange among a sample of Thai subjects exposed to lead: Lead-induced genotoxicity. Toxicol Environ Chem 90(4):765–768. 10.1080/02772240701712758.
Wolff MS, Britton JA, Boguski L, . 2008. Environmental exposures and puberty in inner-city girls. Environ Res 107(3):393–400. 10.1016/j.envres.2008.03.006.18479682
Wright RO, Tsaih SW, Schwartz J, . 2003b. Lead exposure biomarkers and mini-mental status exam scores in older men. Epidemiology 14(6):713–718.14569188
Wu T, Buck GM, Mendola P. 2003b. Blood lead levels and sexual maturation in U.S. girls: The Third National Health and Nutrition Examination Survey, 1988-1994. Environ Health Perspect 111(5):737–741. 10.1289/ehp.6008.12727603
Wu F, Chang P, Wu C, . 2002. Correlations of blood lead with DNA-protein cross-links and sister chromatid exchanges in lead workers. Cancer Epidemiol Biomarkers Prev 11(3):287–290.11895879
Wu S, Hivert MF, Cardenas A, . 2017. Exposure to low levels of lead in utero and umbilical cord blood DNA methylation in project viva: An epigenome-wide association study. Environ Health Perspect 125(8):087019. 10.1289/ehp1246.28858830
Xie X, Ding G, Cui C, . 2013. The effects of low-level prenatal lead exposure on birth outcomes. Environ Pollut 175:30–34. 10.1016/j.envpol.2012.12.013.23321271
Xu X, Chen X, Zhang J, . 2015. Decreased blood hepatitis B surface antibody levels linked to e-waste lead exposure in preschool children. J Hazard Mater 298:122–128. 10.1016/j.jhazmat.2015.05.020.26022852
Yang H, Huo X, Yekeen TA, . 2013a. Effects of lead and cadmium exposure from electronic waste on child physical growth. Environ Sci Pollut Res Int 20(7):4441–4447. 10.1007/s11356-012-1366-2.23247522
Yang WY, Zhang ZY, Thijs L, . 2017. Left ventricular structure and function in relation to environmental exposure to lead and cadmium. Journal of the American Heart Association 6(2):e004692. 10.1161/jaha.116.004692.28151401
Yang WY, Efremov L, Mujaj B, . 2018. Association of office and ambulatory blood pressure with blood lead in workers before occupational exposure. J Am Soc Hypertens 12(1):14–24. 10.1016/j.jash.2017.10.010.29195913
Yazbeck C, Thiebaugeorges O, Moreau T, . 2009. Maternal blood lead levels and the risk of pregnancy-induced hypertension: The EDEN cohort study. Environ Health Perspect 117(10):1526–1530. 10.1289/ehp.0800488.20019901
Yin Y, Zhang T, Dai Y, . 2008. The effect of plasma lead on anembryonic pregnancy. Ann N Y Acad Sci 1140:184–189. 10.1196/annals.1454.042.18991916
Yorita Christensen KL. 2013. Metals in blood and urine, and thyroid function among adults in the United States 2007-2008. Int J Hyg Environ Health 216(6):624–632.23044211
Yu C, Lin J, Lin-Tan D. 2004. Environmental exposure to lead and progression of chronic renal diseases: A four-year prospective longitudinal study. J Am Soc Nephrol 15(4):1016–1022.15034104
Yu CG, Wei FF, Yang WY, . 2019a. Heart rate variability and peripheral nerve conduction velocity in relation to blood lead in newly hired lead workers. Occup Environ Med 76(6):382–388.10.1136/oemed-2018-105379.30928907
Yu CG, Yang WY, Saenen N, . 2019b. Neurocognitive function in relation to blood lead among young men prior to chronic occupational exposure. Scand J Work Environ Health 45(3):298–307. 10.5271/sjweh.3798. (Retrieval in progress)30631878
Zeng X, Xu X, Zheng X, . 2016. Heavy metals in PM2.5 and in blood, and children’s respiratory symptoms and asthma from an e-waste recycling area. Environ Pollut 210:346–353. 10.1016/j.envpol.2016.01.025.26803791
Zeng X, Xu X, Boezen HM, . 2017. Decreased lung function with mediation of blood parameters linked to e-waste lead and cadmium exposure in preschool children. Environ Pollut 230:838–848. 10.1016/j.envpol.2017.07.014.28734265
Zentner LE, Rondó PH, Mastroeni SS. 2006. Lead contamination and anthropometry of the newborn baby. J Trop Pediatr 52(5):369–371. 10.1093/tropej/fml009.16554339
Zhang N, Baker HW, Tufts M, . 2013. Early childhood lead exposure and academic achievement: Evidence from Detroit public schools, 2008-2010. Am J Public Health 103(3):e72–77. 10.2105/ajph.2012.301164.23327265
Zhang A, Hu H, Sánchez BN, . 2011. Association between prenatal lead exposure and blood pressure in female offspring. Environ Health Perspect 120(3):445–450. 10.1289/ehp.1103736.21947582
Zhou L, Xu J, Zhang J, . 2017. Prenatal maternal stress in relation to the effects of prenatal lead exposure on toddler cognitive development. Neurotoxicology 59:71–78. 10.1016/j.neuro.2017.01.008.28159619
Zhu M, Fitzgerald EF, Gelberg KH, . 2010. Maternal low-level lead exposure and fetal growth. Environ Health Perspect 118(10):1471–1475. 10.1289/ehp.0901561.20562053
Zota AR, Shenassa ED, Morello-Frosch R. 2013. Allostatic load amplifies the effect of blood lead levels on elevated blood pressure among middle-aged U.S. adults: A cross-sectional study. Environ Health 12(1):64. 10.1186/1476-069x-12-64.23953669
Zota AR, Needham BL, Blackburn EH, . 2015. Associations of cadmium and lead exposure with leukocyte telomere length: Findings from National Health and Nutrition Examination Survey, 1999-2002. Am J Epidemiol 181(2):127–136. 10.1093/aje/kwu293.25504027